# Bibliography

Aabakken L, Karesen R, Serck-Hanssen A, et al Transpapillary biopsies and brush cytology from the common bile duct Endoscopy 1986 Mar 18(2):49 51 3956437
Abdul Ghani AK Selective pre-operative cholangiography and scoring method for selection Bangladesh Med Res Counc Bull 1989 Dec 15(2):81 9 2698160
Acosta JM, Ronzano GD, Pellegrini CA Ampullary obstruction monitoring in acute gallstone pancreatitis: a safe, accurate, and reliable method to detect pancreatic ductal obstruction Am J Gastroenterol 2000 Jan 95(1):122 7 10638569
Acosta JM, Rubio Galli OM, Rossi R, et al Effect of duration of ampullary gallstone obstruction on severity of lesions of acute pancreatitis J Am Coll Surg 1997 May 184(5):499 505 9145071
Adamek HE, Albert J, Breer H, et al Pancreatic cancer detection with magnetic resonance cholangiopancreatography and endoscopic retrograde cholangiopancreatography: a prospective controlled study Lancet 2000 Jul 15 356(9225):190 3
Adamek HE, Albert J, Weitz M, et al A prospective evaluation of magnetic resonance cholangiopancreatography in patients with suspected bile duct obstruction Gut 1998 Nov 43(5):680 3 9824351 1727306
Adamek HE, Breer H, Karschkes T, et al Magnetic resonance imaging in gastroenterology: time to say good-bye to all that endoscopy? Endoscopy 2000 May 32(5):406 10 10817182
Adamek HE, Maier M, Jakobs R, et al Management of retained bile duct stones: a prospective open trial comparing extracorporeal and intracorporeal lithotripsy Gastrointest Endosc 1996 Jul 44(1):40 7 8836715
Adams DB, Anderson MC Changing concepts in the surgical management of pancreatic pseudocysts Am Surg 1992 Mar 58(3):173 80 1558335
Adams DB, Srinivasan A Failure of percutaneous catheter drainage of pancreatic pseudocyst Am Surg 2000 Mar 66(3):256 61 10759195
Adams DB, Tarnasky PR, Hawes RH, et al Outcome after laparoscopic cholecystectomy for chronic acalculous cholecystitis Am Surg 1998 Jan 64(1):1 5 9457029
Adzick NS, Shamberger RC, Winter HS, et al Surgical treatment of pancreas divisum causing pancreatitis in children J Pediatr Surg 1989 Jan 24(1):54 8 2723997
Agenant DM, Bartelsman JF, Tijtgat GN Endoscopic retrograde cholangiopancreaticographic aspects of choledocholithiasis and its sequelae Radiol Clin (Basel) 1978 47(6):397 411 740890
Ahearne PM, Baillie JM, Cotton PB, et al An endoscopic retrograde cholangiopancreatography (ERCP)-based algorithm for the management of pancreatic pseudocysts Am J Surg 1992 Jan 163(1):111 5 1733357
Aiyer MK, Burdick JS, Sonnenberg A Outcome of surgical and endoscopic management of biliary pancreatitis Dig Dis Sci 1999 Aug 44(8):1684 90 10492153
al Karawi MA, el Shiekh Mohamed AR, al Shahri MG, et al Endoscopic sphincterotomy in acute gallstone pancreatitis and cholangitis: a Saudi hospital experience Hepatogastroenterology 1993 Aug 40(4):396 401 8406313
al Shahri AM, Mohamed ARES, Bushnak MA, et al Acute biliary pancreatitis six-and-a-half years' experience Saudi Med J 1992 13(1):46 48
Alam MK Assessment of indicators for predicting choledocholithiasis before laparoscopic cholecystectomy Ann Saudi Med 1998 18(6):511 513 17344723
Alcaraz MJ, De la Morena EJ, Polo A, et al A comparative study of magnetic resonance cholangiography and direct cholangiography Rev Esp Enferm Dig 2000 Jul 92(7):427 38 11026760
al-Hadeedi S, Leaper DJ Falls in hemoglobin saturation during ERCP and upper gastrointestinal endoscopy World J Surg 1991 Jan-Feb 15(1):88 94 1994612
Alhalel R, Haber GB Endoscopic therapy of pancreatic stones Gastrointest Endosc Clin N Am 1995 Jan 5(1):195 215 7728344
Aliperti G Complications related to diagnostic and therapeutic endoscopic retrograde cholangiopancreatography Gastrointest Endosc Clin N Am 1996 Apr 6(2):379 407 8673333
al-Mofarreh MA, Laajam MA Periampullary cysts: endoscopic management Am J Gastroenterol 1992 Feb 87(2):211 3 1734700
Alonso Casado O, Hernandez Gallardo D, Moreno Gonzalez E, et al Intraductal papillary-mucinous tumors: an entity which is infrequent and difficult to diagnose Hepatogastroenterology 2000 Jan-Feb 47(31):275 84 10690621
Alponat A, Kum CK, Rajnakova A, et al Predictive factors for synchronous common bile duct stones in patients with cholelithiasis Surg Endosc 1997 Sep 11(9):928 32 9294275
AlQasabi Q, Mofti AB, Suleiman SI, et al Operative cholangiography in laparoscopic cholecystectomy: Is it essential? Ann Saudi Med 1997 17(2):167 169 17377423
Alsumait AR, Jabbari M, Goresky CA Pancreaticocolonic fistula: a complication of pancreatitis Can Med Assoc J 1978 Oct 7 119(7):715 9
Alvarez C, Livingston EH, Ashley SW, et al Cost-benefit analysis of the work-up for pancreatic cancer Am J Surg 1993 Jan 165(1):53 8 8418703
Alveyn CG, Robertson DA, Wright R, et al Prevention of sepsis following endoscopic retrograde cholangiopancreatography J Hosp Infect 1991 Sep 19Suppl C:65 70
Gastroenterology. 1998;115:763-4. [pmid: 9721174].
Amman RW, Akovbiantz A, Larglader F, et al. Course and outcome of chronic pancreatitis: Longitudinal study of a mixed medical-surgical series of 245 patients. Gastroenterology. 1984;86:820-828. [pmid: 6706066].
Ammann RW, Buellhaupt B. The natural history of pain in alcoholic chronic pancreatitis. Gastroenterology. 1999;116:1132-40. [pmid: 10220505].
Ammori BJ, Birbas K, Davides D, et al Routine vs "on demand" postoperative ERCP for small bile duct calculi detected at intraoperative cholangiography. Clinical evaluation and cost analysis Surg Endosc 2000 Dec 14(12):1123 6 11148780
Amouyal P, Amouyal G, Levy P, et al Diagnosis of choledocholithiasis by endoscopic ultrasonography Gastroenterology 1994 Apr 106(4):1062 7 8143973
Anacker H, Lamarque JL, Pistolesi GF Efficiency of different radiodiagnostic techniques in pancreatic disorders Eur J Radiol 1981 Mar 1(1):79 84 6279400
Anacker H, Rupp N, Reiser M Magnetic resonance (MR) in the diagnosis of pancreatic disease Eur J Radiol 1984 Nov 4(4):265 9 6519059
Anacker H, Weiss HD, Kramann B Endoscopic retrograde pancreaticocholangiography in chronic diseases of the pancreas and in papillary stenoses Gastrointest Radiol 1978 Aug 31 3(3):325 34
Andersen JR, Sorensen SM, Kruse A, et al Randomised trial of endoscopic endoprosthesis versus operative bypass in malignant obstructive jaundice Gut 1989 Aug 30(8):1132 5 2475392 1434171
Anderson SD, Holley HC, Berland LL, et al Causes of jaundice during hepatic artery infusion chemotherapy Radiology 1986 Nov 161(2):439 42 2945226
Andonov V, Tcholakova E, Ananoshtev N, et al Diagnostic strategies for evaluation and prognosticating the outcome of jaundice among patients with cholestasis caused by neoplastic diseases of the hepatobiliary system and the pancreas Folia Med (Plovdiv) 1999 41(1):72 4 226275 10462927
Andriulli A, Leandro G, Niro G, et al Pharmacologic treatment can prevent pancreatic injury after ERCP: a meta-analysis Gastrointest Endosc 2000 Jan 51(1):1 7 10625786
Andrus CH, Dean PA, Ponsky JL Evaluation of safe, effective intravenous sedation for utilization in endoscopic procedures Surg Endosc 1990 4(3):179 83 2267652
Apel D, Riemann JF Emergency endoscopy Can J Gastroenterol 2000 Mar 14(3):199 203 10758417
Appelros S, Borgstrom A Incidence, aetiology and mortality rate of acute pancreatitis over 10 years in a defined urban population in Sweden Br J Surg 1999 Apr 86(4):465 70 10215815
Aranha GV, Prinz RA, Freeark RJ, et al The spectrum of biliary tract obstruction from chronic pancreatitis Arch Surg 1984 May 119(5):595 600 6712475
Ariyama J, Sumida M, Shimaguchi S, et al Integrated approach to the diagnosis of pancreatic carcinoma Radiat Med 1983 Jan-Mar 1(1):46 51 6387811
Arregui ME, Davis CJ, Arkush AM, et al Laparoscopic cholecystectomy combined with endoscopic sphincterotomy and stone extraction or laparoscopic choledochoscopy and electrohydraulic lithotripsy for management of cholelithiasis with choledocholithiasis Surg Endosc 1992 Jan-Feb 6(1):10 5 1344571
Arrowsmith JB, Gerstman BB, Fleischer DE, et al Results from the American Society for Gastrointestinal Endoscopy/U.S. Food and Drug Administration collaborative study on complication rates and drug use during gastrointestinal endoscopy Gastrointest Endosc 1991 Jul-Aug 37(4):421 7 1833259
Arslan A, Geitung JT, Viktil E, et al Pancreaticobiliary diseases. Comparison of 2D single-shot turbo spin-echo MR cholangiopancreatography with endoscopic retrograde cholangiopancreatography Acta Radiol 2000 Nov 41(6):621 6 11092486
Ashby K, Lo SK The role of pancreatic stenting in obstructive ductal disorders other than pancreas divisum Gastrointest Endosc 1995 Oct 42(4):306 11 8536897
Ashton CE, McNabb WR, Wilkinson ML, et al Endoscopic retrograde cholangiopancreatography in elderly patients Age Ageing 1998 Nov 27(6):683 8 Comment in: Age Ageing. 1999 Sep;28(5):498-9 10408661
Avisse C, Flament JB, Delattre JF Ampulla of Vater. Anatomic, embryologic, and surgical aspects Surg Clin North Am 2000 Feb 80(1):201 12 10685149
Axon AT Endoscopic retrograde cholangiopancreatography in chronic pancreatitis. Cambridge classification Radiol Clin North Am 1989 Jan 27(1):39 50 2642274
Bain VG, Abraham N, Jhangri GS, et al Prospective study of biliary strictures to determine the predictors of malignancy Can J Gastroenterol 2000 May 14(5):397 402 10851279
Bakkevold KE, Arnesjo B, Kambestad B Carcinoma of the pancreas and papilla of Vater--assessment of resectability and factors influencing resectability in stage I carcinomas. A prospective multicentre trial in 472 patients Eur J Surg Oncol 1992 Oct 18(5):494 507 1426302
Bakkevold KE, Arnesjo B, Kambestad B Carcinoma of the pancreas and papilla of Vater: presenting symptoms, signs, and diagnosis related to stage and tumour site. A prospective multicentre trial in 472 patients. Norwegian Pancreatic Cancer Trial Scand J Gastroenterol 1992 Apr 27(4):317 25 1589710
Balci NC, Semelka RC Radiologic diagnosis and staging of pancreatic ductal adenocarcinoma Eur J Radiol 2001 May 38(2):105 12 11335092
Banerjee AK, Grainger SL, Thompson RP Trial of low versus high osmolar contrast media in endoscopic retrograde cholangiopancreatography Br J Clin Pract 1990 Nov 44(11):445 7 2282293
Banks PA Practice guidelines in acute pancreatitis Am J Gastroenterol 1997 92(3):377 386 9068455
Barish M, Soto J, Ferrucci J Magnetic resonance pancreatography Endoscopy 1997 Aug 29(6):487 95 9342566
Barish MA, Ferrucci JT MR cholangiopancreatography challenges invasive methods Diagn Imaging (San Franc) 1998 Apr 20(4):32 6 10178820
Barish MA, Yucel EK, Soto JA, et al MR cholangiopancreatography: efficacy of three-dimensional turbo spin-echo technique AJR Am J Roentgenol 1995 Aug 165(2):295 300 7618543
Barkin JS, Goldstein JA Diagnostic approach to pancreatic cancer Gastroenterol Clin North Am 1999 Sep 28(3):709 22, xi 10503146
Barkun AN, Barkun JS, Fried GM, et al Useful predictors of bile duct stones in patients undergoing laparoscopic cholecystectomy. McGill Gallstone Treatment Group Ann Surg 1994 Jul 220(1):32 9 7517657 1234284
Barkun JS, Fried GM, Barkun AN, et al Cholecystectomy without operative cholangiography. Implications for common bile duct injury and retained common bile duct stones Ann Surg 1993 Sep 218(3):371 7 discussion 377-9. Comment in: Ann Surg 1995 Jan;221(1);117-9 8373278 1242982
Bar-Meir S, Rotmensch S A comparison between peroral choledochoscopy and endoscopic retrograde cholangiopancreatography Gastrointest Endosc 1987 Feb 33(1):13 4 3557026
Baron PL, Kay C, Hoffman B Pancreatic imaging Surg Oncol Clin N Am 1999 Jan 8(1):35 58 9824361
Barr LL, Frame BC, Coulanjon A Proposed criteria for preoperative endoscopic retrograde cholangiography in candidates for laparoscopic cholecystectomy Surg Endosc 1999 Aug 13(8):778 81 10430683
Barthet M, Affriat C, Bernard JP, et al Is biliary lithiasis associated with pancreatographic changes? Gut 1995 May 36(5):761 5 7797128 1382683
Barthet M, Portal I, Boujaoude J, et al Endoscopic ultrasonographic diagnosis of pancreatic cancer complicating chronic pancreatitis Endoscopy 1996 Aug 28(6):487 91 8886634
Barthet M, Sahel J, Bodiou-Bertei C, et al Endoscopic transpapillary drainage of pancreatic pseudocysts Gastrointest Endosc 1995 Sep 42(3):208 13 7498684
Barton P, Steininger R, Maier A, et al Biliary sludge after liver transplantation: 2. Treatment with interventional techniques versus surgery and/or oral chemolysis AJR Am J Roentgenol 1995 Apr 164(4):865 9 7537016
Bassi C, Falconi M, Caldiron E, et al Assessment and treatment of severe pancreatitis. Protease inhibitor Digestion 1999 60Suppl 1(5 8 10026423
Basso N, Pizzuto G, Surgo D, et al Laparoscopic cholecystectomy and intraoperative endoscopic sphincterotomy in the treatment of cholecysto-choledocholithiasis Gastrointest Endosc 1999 Oct 50(4):532 5 10502176
Bastid C, Sahel J, Filho M, et al Diameter of the main pancreatic duct in chronic calcifying pancreatitis. Measurement by ultrasonography versus pancreatography Pancreas 1990 Sep 5(5):524 7 2235964
Beck IT Critical review of diagnostic methods used in chronic pancreatic disease Can J Gastroenterol 1995 9(1):51 60
Becker CD, Grossholz M, Becker M, et al Choledocholithiasis and bile duct stenosis: diagnostic accuracy of MR cholangiopancreatography Radiology 1997 Nov 205(2):523 30 9356639
Becker CD, Grossholz M, Mentha G, et al MR cholangiopancreatography: technique, potential indications, and diagnostic features of benign, postoperative, and malignant conditions Eur Radiol 1997 7(6):865 74 9228102
Beebe DS, Bubrick MP, Onstad GR, et al Management of pancreatic pseudocysts Surg Gynecol Obstet 1984 Dec 159(6):562 4 6390759
Benjamin IS Surgical possibilities for bile duct cancer: standard surgical treatment Ann Oncol 1999 10(Suppl 4):239 42 10436831
Bentz JS, Kochman ML, Faigel DO, et al Endoscopic ultrasound-guided real-time fine needle aspiration: clinicopathologic features of 60 patients Diagn Cytopathol 1998 18(2):98 109 9484637
Berdah SV, Orsoni P, Bege T, et al Follow-up of selective endoscopic ultrasonography and/or endoscopic retrograde cholangiography prior to laparoscopic cholecystectomy: a prospective study of 300 patients Endoscopy 2001 Mar 33(3):216 20 11293752
Bergamaschi R, Tuech JJ, Braconier L, et al Selective endoscopic retrograde cholangiography prior to laparoscopic cholecystectomy for gallstones Am J Surg 1999 Jul 178(1):46 9 10456702
Bergman JJ, Rauws EA, Fockens P, et al Randomised trial of endoscopic balloon dilation versus endoscopic sphincterotomy for removal of bileduct stones Lancet 1997 Apr 19 349(9059):1124 9
Bergman JJ, Tytgat GN, Huibregtse K. Endoscopic dilatation of the biliary sphincter for removal of bile duct stones: an overview of current indications and limitations. Scand J Gastroenterol Suppl. 1998;225:59-65. [pmid: 9515754].
Bergman JJ, van Berkel AM, Bruno MJ, et al A randomized trial of endoscopic balloon dilation and endoscopic sphincterotomy for removal of bile duct stones in patients with a prior Billroth II gastrectomy Gastrointest Endosc 2001 Jan 53(1):19 26 11154484
Bergman JJ, van Berkel AM, Bruno MJ, et al Is endoscopic balloon dilation for removal of bile duct stones associated with an increased risk for pancreatitis or a higher rate of hyperamylasemia? Endoscopy 2001 May 33(5):416 20 11396759
Bergman JJ, van Berkel AM, Groen AK, et al Biliary manometry, bacterial characteristics, bile composition, and histologic changes fifteen to seventeen years after endoscopic sphincterotomy Gastrointest Endosc 1997 May 45(5):400 5 9165322
Bergman JJ, van der Mey S, Rauws EA, et al Long-term follow-up after endoscopic sphincterotomy for bile duct stones in patients younger than 60 years of age Gastrointest Endosc 1996 Dec 44(6):643 9 8979051
Bhutani MS, Hawes RH, Baron PL, et al. Endoscopic ultrasonography guided fine needle aspiration of malignant pancreatic lesions. Endoscopy. 1997;29:854-8. [pmid: 9476770].
Bhutani MS, Hawes RH, Baron PL, et al Endoscopic ultrasound guided fine needle aspiration of malignant pancreatic lesions Endoscopy 1997 Nov 29(9):854 8 9476770
Bhutani MS Endoscopic ultrasound in pancreatic diseases. Indications, limitations, and the future Gastroenterol Clin North Am 1999 Sep 28(3):747 70, xi 10503148
Bilbao MK, Dotter CT, Lee TG, et al Complications of endoscopic retrograde cholangiopancreatography (ERCP). A study of 10,000 cases Gastroenterology 1976 Mar 70(3):314 20 1248697
Binmoeller KF, Jue P, Seifert H, et al Endoscopic pancreatic stent drainage in chronic pancreatitis and a dominant stricture: long-term results Endoscopy 1995 Nov 27(9):638 44 8903975
Binmoeller KF, Schafer TW Endoscopic management of bile duct stones J Clin Gastroenterol 2001 Feb 32(2):106 18 11205644
Binmoeller KF, Seifert H, Gerke H, et al Papillary roof incision using the Erlangen-type pre-cut papillotome to achieve selective bile duct cannulation Gastrointest Endosc 1996 Dec 44(6):689 95 8979059
Birk D, Schoenberg MH, Gansauge F, et al Carcinoma of the head of the pancreas arising from the uncinate process Br J Surg 1998 Apr 85(4):498 501 9607531
Boender J, Nix GA, de Ridder MA, et al Endoscopic papillotomy for common bile duct stones: factors influencing the complication rate Endoscopy 1994 Feb 26(2):209 16 8026367
Boender J, Nix GA, Schutte HE, et al Malignant common bile duct obstruction: factors influencing the success rate of endoscopic drainage Endoscopy 1990 Nov 22(6):259 62 2176972
Boraschi P, Braccini G, Gigoni R, et al MR cholangiopancreatography: value of axial and coronal fast Spin-Echo fat-suppressed T2-weighted sequences Eur J Radiol 1999 Dec 32(3):171 81 10632554
Boraschi P, Neri E, Braccini G, et al Choledocolithiasis: diagnostic accuracy of MR cholangiopancreatography. Three-year experience Magn Reson Imaging 1999 Nov 17(9):1245 53 10576709
Born P, Rosch T, Bruhl K, et al Long-term outcome in patients with advanced hilar bile duct tumors undergoing palliative endoscopic or percutaneous drainage Z Gastroenterol 2000 Jun 38(6):483 9 10923359
Bornman PC, Beckingham IJ, Krige JE Gallstone pancreatitis--a critical review of current treatment strategies S Afr J Surg 2000 Dec 38(4):97 9 11424863
Bornman PC, Harries-Jones EP, Tobias R, et al. Prospective controlled trial of transhepatic biliary endoprosthesis versus bypass surgery for incurable carcinoma of head of pancreas. Lancet. 1986;I:69-71.
Bornman PC, Marks IN, Girdwood AH, et al Is pancreatic duct obstruction or stricture a major cause of pain in calcific pancreatitis? Br J Surg 1980 Jun 67(6):425 8 7388340
Borsch G, Wegener M, Wedmann B, et al Clinical evaluation, ultrasound, cholescintigraphy, and endoscopic retrograde cholangiography in cholestasis. A prospective comparative clinical study J Clin Gastroenterol 1988 Apr 10(2):185 90 3047216
Bortolotti M, Caletti GC, Brocchi E, et al Endoscopic manometry in the diagnosis of the postcholecystectomy pain syndrome Digestion (Digestion) 1983 28(3):153 157 150377
Bose SM, Mazumdar A, Prakash V S, et al Evaluation of the predictors of choledocholithiasis: comparative analysis of clinical, biochemical, radiological, radionuclear, and intraoperative parameters Surg Today 2001 31(2):117 22 11291704
Botoman VA, Kozarek RA, Novell LA, et al Long-term outcome after endoscopic sphincterotomy in patients with biliary colic and suspected sphincter of Oddi dysfunction Gastrointest Endosc 1994 Mar-Apr 40(2 Pt 1):165 70 8013815
Bottger T, Engelman R, Seifert JK, et al Preoperative diagnostics in pancreatic carcinoma: would less be better? Langenbecks Arch Surg 1998 Aug 383(3-4):243 8 9776450
Bottger TC, Boddin J, Duber C, et al Diagnosing and staging of pancreatic carcinoma-what is necessary? Oncology 1998 Mar-Apr 55(2):122 9 9499186
Bozkurt T, Braun U, Leferink S, et al Comparison of pancreatic morphology and exocrine functional impairment in patients with chronic pancreatitis Gut 1994 Aug 35(8):1132 6 7523260 1375069
Bozkurt T, Orth KH, Butsch B, et al Long-term clinical outcome of post-cholecystectomy patients with biliary-type pain: results of manometry, non-invasive techniques and endoscopic sphincterotomy Eur J Gastroenterol Hepatol 1996 Mar 8(3):245 9 8724025
Branch S ERCP-induced pancreatitis Curr Treat Options Gastroenterol 2000 Oct 3(5):363 370 11096597
Brand B, Wiese L, Thonke F, et al Outcome of endoscopic sphincterotomy in patients with pain of suspected biliary or papillary origin and inconclusive cholangiography findings Endoscopy 2001 May 33(5):405 8 11396757
Brand RE, Matamoros A Imaging techniques in the evaluation of adenocarcinoma of the pancreas Dig Dis 1998 Jul-Aug 16(4):242 52 9732184
Brandabur JJ, Kozarek RA, Ball TJ, et al Nonoperative versus operative treatment of obstructive jaundice in pancreatic cancer: cost and survival analysis Am J Gastroenterol 1988 Oct 83(10):1132 9 2458678
Brandwein SL, Farrell JJ, Centeno BA, et al Detection and tumor staging of malignancy in cystic, intraductal, and solid tumors of the pancreas by EUS Gastrointest Endosc 2001 Jun 53(7):722 727 11375578
Bret PM, Reinhold C, Taourel P, et al Pancreas divisum: evaluation with MR cholangiopancreatography Radiology 1996 Apr 199(1):99 103 8633179
Broughan TA, Sivak MV, Hermann RE The management of retained and recurrent bile duct stones Surgery 1985 Oct 98(4):746 51 3901377
Buffet C, Fourre C, Altman C, et al Bile levels of carcino-embryonic antigen in patients with hepatopancreatobiliary disease Eur J Gastroenterol Hepatol 1996 Feb 8(2):131 4 8723416
Bulkin AJ, Tebyani N, Dorazio RA Gallstone pancreatitis in the era of laparoscopic cholecystectomy Am Surg 1997 Oct 63(10):900 3 9322669
Burtin P, Palazzo L, Canard JM, et al Diagnostic strategies for extrahepatic cholestasis of indefinite origin: endoscopic ultrasonography or retrograde cholangiography? Results of a prospective study Endoscopy 1997 Jun 29(5):349 55 9270914
Buscail L, Escourrou J, Moreau J, et al Endoscopic ultrasonography in chronic pancreatitis: a comparative prospective study with conventional ultrasonography, computed tomography, and ERCP Pancreas 1995 Apr 10(3):251 7 7624302
Buscarini E, Buscarini L The role of endosonography in the diagnosis of choledocholithiasis Eur J Ultrasound 1999 Nov 10(2-3):117 25 10586016
Caletti G, Fusaroli P, Bocus P Endoscopic ultrasonography Digestion 1998 Aug 59(5):509 29 9705536
Calvo MM, Calderon A, Heras I, et al Magnetic resonance study of the pancreatic duct Rev Esp Enferm Dig 1999 Apr 91(4):287 96 10348928
Canto MI, Chak A, Stellato T, et al Endoscopic ultrasonography versus cholangiography for the diagnosis of choledocholithiasis Gastrointest Endosc 1998 Jun 47(6):439 48 9647366
Carlson GL, Rhodes M, Stock S, et al Role of endoscopic retrograde cholangiopancreatography in the investigation of pain after cholecystectomy Br J Surg 1992 Dec 79(12):1342 5 1486435
Caroli-Bosc FX, Montet JC, Salmon L, et al Effect of endoscopic sphincterotomy on bile lithogenicity in patients with gallbladder in situ Endoscopy 1999 Aug 31(6):437 41 10494681
Carr-Locke DL, Conn MI, Faigel DO, et al Technology status evaluation: Magnetic resonance cholangiopancreatography Gastrointest Endosc 1999 49(6):858 860 10343251
Carr-Locke DL Post-cholecystectomy symptoms and manometric data Ital J Gastroenterol 1989 21(3):183 186
Carroll BJ, Phillips EH, Rosenthal R, et al One hundred consecutive laparoscopic cholangiograms. Results and conclusions Surg Endosc 1996 Mar 10(3):319 23 8779067
Catalano MF, Lahoti S, Alcocer E, et al Dynamic imaging of the pancreas using real-time endoscopic ultrasonography with secretin stimulation Gastrointest Endosc 1998 Dec 48(6):580 7 9852447
Catalano MF, Lahoti S, Geenen JE, et al Prospective evaluation of endoscopic ultrasonography, endoscopic retrograde pancreatography, and secretin test in the diagnosis of chronic pancreatitis Gastrointest Endosc 1998 Jul 48(1):11 7 9684658
Cavina E, Franceschi M, Sidoti F, et al Laparo-endoscopic "rendezvous": a new technique in the choledocholithiasis treatment Hepatogastroenterology 1998 Sep-Oct 45(23):1430 5 9840078
Cellier C, Cuillerier E, Palazzo L, et al Intraductal papillary and mucinous tumors of the pancreas: accuracy of preoperative computed tomography, endoscopic retrograde pancreatography and endoscopic ultrasonography, and long-term outcome in a large surgical series Gastrointest Endosc 1998 Jan 47(1):42 9 9468422
Chak A, Hawes RH, Cooper GS, et al Prospective assessment of the utility of EUS in the evaluation of gallstone pancreatitis Gastrointest Endosc 1999 May 49(5):599 604 10228258
Chalmers AG The role of imaging in acute pancreatitis Eur J Gastroenterol Hepatol 1997 Feb 9(2):106 16 9058619
Chan AC, Chung SC, Wyman A, et al Selective use of preoperative endoscopic retrograde cholangiopancreatography in laparoscopic cholecystectomy Gastrointest Endosc 1996 Mar 43(3):212 5 8857136
Chan YL, Chan AC, Lam WW, et al Choledocholithiasis: comparison of MR cholangiography and endoscopic retrograde cholangiography Radiology 1996 Jul 200(1):85 9 8657949
Chang KJ, Katz KD, Durbin TE, et al. Endoscopic ultrasound-guided fine-needle aspiration. Gastrointest Endosc. 1994;40:(694-9. [pmid: 7859967].
Chang KJ, Nguyen P, Erickson RA, et al The clinical utility of endoscopic ultrasound-guided fine-needle aspiration in the diagnosis and staging of pancreatic carcinoma Gastrointest Endosc 1997 May 45(5):387 93 9165320
Chang L, Lo S, Stabile BE, et al Preoperative versus postoperative endoscopic retrograde cholangiopancreatography in mild to moderate gallstone pancreatitis: a prospective randomized trial Ann Surg 2000 Jan 231(1):82 7 10636106 1420969
Chang L, Lo SK, Stabile BE, et al Gallstone pancreatitis: a prospective study on the incidence of cholangitis and clinical predictors of retained common bile duct stones Am J Gastroenterol 1998 Apr 93(4):527 31 Comment in: Am J Gastroenterol. 1998 Apr;93(4):493-6 9576442
Chang WH, Kortan P, Haber GB Outcome in patients with bifurcation tumors who undergo unilateral versus bilateral hepatic duct drainage Gastrointest Endosc 1998 May 47(5):354 62 9609426
Changchien CS, Chuah SK, Chiu KW Is ERCP necessary for symptomatic gallbladder stone patients before laparoscopic cholecystectomy? Am J Gastroenterol 1995 Dec 90(12):2124 7 8540500
Chang-Chien CS Do juxtapapillary diverticula of the duodenum interfere with cannulation at endoscopic retrograde cholangiopancreatography? A prospective study Gastrointest Endosc 1987 Aug 33(4):298 300 3115861
Chari ST, DiMagno EP Chronic pancreatitis Curr Opin Gastroenterol 1999 15(5):398 403 17023980
Chen Yang K, Abdulian John D, Escalante-Glorsky Susana, et al Clinical outcome of post-ERCP pancreatitis: Relationship to history of previous pancreatitis American Journal of Gastroenterology 1995 90(12):2120 2123 8540499
Chen YK, Foliente RL, Santoror MJ, et al. Endoscopic sphincterotomy-induced pancreatitis: increased risk associated with non dilated bile ducts and sphincter of Oddi dysfunction. Am J Gastroenterol. 1994;89:327-333. [pmid: 8122639].
Chen YK, McCarter TL, Santoro MJ, et al Utility of endoscopic retrograde cholangiopancreatography in the evaluation of idiopathic abdominal pain Am J Gastroenterol 1993 Sep 88(9):1355 8 8362829
Chevillotte G, Sahel J, Pietri H, et al Acute recurrent pancreatitis associated with pancreas divisum clinical study of 12 cases Gastroenterol Clin Biol 1984 8(4):352 358 6735043
Chopra KB, Peters RA, O'Toole PA, et al Randomised study of endoscopic biliary endoprosthesis versus duct clearance for bileduct stones in high-risk patients Lancet 1996 Sep 21 348(9030):791 3
Choudari CP, Sherman S, Fogel EL, et al Success of ERCP at a referral center after a previously unsuccessful attempt Gastrointest Endosc 2000 Oct 52(4):478 83 11023563
Choudhry U, Ruffolo T, Jamidar P, et al Sphincter of Oddi dysfunction in patients with intact gallbladder: Therapeutic response to endoscopic sphincterotomy Gastrointest Endosc 1993 39(4):492 495 8365594
Chrysikopoulos H, Papanikolaou N, Pappas J, et al MR cholangiopancreatography at 0.5 T with a 3D inversion recovery turbo-spin-echo sequence Eur Radiol 1997 7(8):1318 22 9377521
Ciriza C, Dajil S, Jimenez C, et al Five-year analysis of endoscopic retrograde cholangiopancreatography in the Hospital del Bierzo Rev Esp Enferm Dig 1999 Oct 91(10):693 702 10601758
Clair DG, Carr-Locke DL, Becker JM, et al Routine cholangiography is not warranted during laparoscopic cholecystectomy Arch Surg 1993 May 128(5):551 4 8489389
Clarke BD, Lehman GA "Cloggology" revisited: endoscopic or surgical decompression of malignant biliary obstruction Am J Gastroenterol 1990 Nov 85(11):1533 4 2239887
Coakley FV, Schwartz LH Magnetic resonance cholangiopancreatography J Magn Reson Imaging 1999 Feb 9(2):157 62 10077008
Available online at http://www.cochrane.org/cochrane/sadtdoc1.htm; updated 6 June 1996.
Concato J, Feinstein AR, Holford TR. The risk of determining risk with multivariable models. Ann Intern Med. 1993;118:201-210. [pmid: 8417638].
Conio M, Demarquay JF, De Luca L, et al Endoscopic treatment of pancreatico-biliary malignancies Crit Rev Oncol Hematol 2001 Feb 37(2):127 35 11166586
Contractor QQ, Boujemla M, Contractor TQ, et al Abnormal common bile duct sonography. The best predictor of choledocholithiasis before laparoscopic cholecystectomy J Clin Gastroenterol 1997 Sep 25(2):429 32 9412943
Cooperman M, Ferrara JJ, Carey LC, et al Endoscopic retrograde cholangiopancreatography. Its use in the evaluation of nonjaundiced patients with the postcholecystectomy syndrome Arch Surg 1981 May 116(5):606 9 7235952
Cooperman M, Ferrara JJ, Carey LC, et al Idiopathic acute pancreatitis: the value of endoscopic retrograde cholangiopancreatography Surgery 1981 Oct 90(4):666 70 7281003
Coppola R, Riccioni ME, Ciletti S, et al Analysis of complications of endoscopic sphincterotomy for biliary stones in a consecutive series of 546 patients Surg Endosc 1997 Feb 11(2):129 32 9069143
Corazziari E, Cicala M, Habib FI. Hepatoduodenal bile transit in cholecystectomized subjects - relationship with sphincter of Oddi function and diagnostic value. Dig Dis Sci. 1994;39:1985-93. [pmid: 8082508].
Corazziari E, Shaffer EA, Hogan WJ, et al Functional disorders of the biliary tract and pancreas Gut 1999 Sep 45(Suppl 2):II48 54
Cortas GA, Mehta SN, Abraham NS, et al Selective cannulation of the common bile duct: a prospective randomized trial comparing standard catheters with sphincterotomes Gastrointest Endosc 1999 Dec 50(6):775 9 10570335
Cotton PB, Lehman G, Vennes J, et al Endoscopic sphincterotomy complications and their management: an attempt at consensus Gastrointest Endosc 1991 May-Jun 37(3):383 93 2070995
Cremer M, Deviere J, Delhaye M, et al Stenting in severe chronic pancreatitis: results of medium-term follow-up in seventy-six patients Endoscopy 1991 May 23(3):171 6 1860448
Cremer M, Deviere J, Dumonceau JM, et al Endoscopic management of chronic pancreatitis Dig Surg 11(3-6):290 299
Cuschieri A, Croce E, Faggioni A, et al EAES ductal stone study. Preliminary findings of multi-center prospective randomized trial comparing two-stage vs single-stage management Surg Endosc 1996 Dec 10(12):1130 5 8939828
Cuschieri A, Lezoche E, Morino M, et al E.A.E.S. multicenter prospective randomized trial comparing two-stage vs single-stage management of patients with gallstone disease and ductal calculi Surg Endosc 1999 Oct 13(10):952 7 10526025
Dancygier H, Nattermann C The role of endoscopic ultrasonography in biliary tract disease: obstructive jaundice Endoscopy 1994 Nov 26(9):800 2 7712994
Daradkeh S, Shennak M, Abu-Khalaf M Selective use of perioperative ERCP in patients undergoing laparoscopic cholecystectomy Hepatogastroenterology 2000 Sep 47(35):1213 5 11100315
Darweesh RM, Dodds WJ, Hogan WJ, et al Efficacy of quantitative hepatobiliary scintigraphy and fatty-meal sonography for evaluating patients with suspected partial common duct obstruction Gastroenterology 1988 Mar 94(3):779 86 3276574
Davids PH, Groen AK, Rauws EA, et al Randomised trial of self-expanding metal stents versus polyethylene stents for distal malignant biliary obstruction Lancet 1992 Dec 19-26 340(8834-8835):1488 92
Davids PHP, Tanka AKF, Rauws EAJ, et al Benign biliary strictures: Surgery or endoscopy? Ann Surg 1993 217(3):237 243 8452402 1242775
Davidson B, Varsamidakis N, Dooley J, et al Value of exfoliative cytology for investigating bile duct strictures Gut 1992 Oct 33(10):1408 11 1446870 1379614
Davis WZ, Cotton PB, Arias R, et al ERCP and sphincterotomy in the context of laparoscopic cholecystectomy: academic and community practice patterns and results Am J Gastroenterol 1997 Apr 92(4):597 601 9128306
de Ledinghen V, Lecesne R, Raymond JM, et al Diagnosis of choledocholithiasis: EUS or magnetic resonance cholangiography? A prospective controlled study Gastrointest Endosc 1999 Jan 49(1):26 31 9869719
de Peralta-Venturina MN, Wong DK, Purslow MJ, et al Biliary tract cytology in specimens obtained by direct cholangiographic procedures: a study of 74 cases Diagn Cytopathol 1996 Jun 14(4):334 48 8725136
De Waele B, Peterson T, Smekens L, et al Common bile duct stones in acute biliary pancreatitis: an endoscopic study Surg Laparosc Endosc 1997 Jun 7(3):248 50 9194289
Deans GT, Sedman P, Martin DF, et al Are complications of endoscopic sphincterotomy age related? Gut 1997 Oct 41(4):545 8 9391257 1891524
Del Favero G, Fabris C, Angonese C, et al Cytology in the diagnosis of pancreatic cancer Int J Pancreatol 1988 3(Suppl 1):S137 41 3209868
Delhaye M, Vandermeeren A, Baize M, et al Extracorporeal shock-wave lithotripsy of pancreatic calculi Gastroenterology 1992 Feb 102(2):610 20 1732129
Demarquay JF, Dumas R, Buckley MJ, et al Endoscopic retrograde cholangiopancreatography in patients with Billroth II gastrectomy Ital J Gastroenterol Hepatol 1998 Jun 30(3):297 300 9759600
Demartines N, Eisner L, Schnabel K, et al Evaluation of magnetic resonance cholangiography in the management of bile duct stones Arch Surg 2000 Feb 135(2):148 52 10668871
DePalma GD, Galloro G, Iovino P et al. Unilateral versus bilateral endoscopic hepatic duct drainage in patients with malignant hilar biliary obstruction. Results of a prospective, randomized, and controlled study. Gastrointest Endosc. 2001;53:547-53. [pmid: 11323577].
Deprez P Approach of suspected common bile duct stones: endoscopic ultrasonography Acta Gastroenterol Belg 2000 Jul-Sep 63(3):295 8 11189994
Desa LA, Williamson RC On-table pancreatography: importance in planning operative strategy Br J Surg 1990 Oct 77(10):1145 50 2224464
Devereaux CE, Binmoeller KF Endoscopic retrograde cholangiopancreatography in the next millennium Gastrointest Endosc Clin N Am 2000 Jan 10(1):117 33, vii 10618458
Deviere J, Baize M, Buset M, et al. Complications of internal endoscopic biliary drainage. Acta Endoscopica. 1986;16:(19-29.
Deviere J, Baize M, de Toeuf J, et al Long-term follow-up of patients with hilar malignant stricture treated by endoscopic internal biliary drainage Gastrointest Endosc 1988 Mar-Apr 34(2):95 101 2835282
Dickinson RJ, Davies S Post-ERCP pancreatitis and hyperamylasaemia: the role of operative and patient factors Eur J Gastroenterol Hepatol 1998 May 10(5):423 8 9619390
Diederichs CG, Staib L, Vogel J, et al Values and limitations of 18F-fluorodeoxyglucose-positron-emission tomography with preoperative evaluation of patients with pancreatic masses Pancreas 2000 Mar 20(2):109 16 10707924
Dilawari JB, Kataria S, Rao PN, et al Endoscopic retrograde cholangio pancreatography and percutaneous transhepatic cholangiography in obstructive jaundice Indian J Med Res 1982 75(Feb):287 293 7085027
DiMagno EP, Malagelada JR, Taylor WF, et al A prospective comparison of current diagnostic tests for pancreatic cancer N Engl J Med 1977 Oct 6 297(14):737 42
DiMagno EP Toward understanding (and management) of painful chronic pancreatitis Gastroenterology 1999 116(5):1252 7 10220520
DiSario JA, Freeman ML, Bjorkman DJ, et al Endoscopic balloon dilatation vs. sphincterotomy (EDES) for bile duct stones removal Digestion 1998 59(Suppl 3):
Dixit VK, Jain AK, Agrawal AK, et al Obstructive jaundice--a diagnostic appraisal J Assoc Physicians India 1993 Apr 41(4):200 2 8270556
Dorman JP, Franklin ME, Glass JL Laparoscopic common bile duct exploration by choledochotomy. An effective and efficient method of treatment of choledocholithiasis Surg Endosc 1998 Jul 12(7):926 8 9632862
Dowsett JF, Williams SJ, Hatfield ARW, et al. Does stent diameter matter in the endoscopic palliation of malignant biliary obstruction: a randomized trial of 10 FG versus 12 FG endoprostheses. Gastroenterology. 1989;96.
Drugova B, Balas V, Horacek F, et al Comparison of efficiency of pharmacoangiography and other investigative methods (endoscopic retrograde cholangiopancreatography, computer tomography, ultrasound) in the diagnosis of pancreatic tumors Acta Univ Carol Med 1984 30(7-8):545 564
Ducreux M, Liguory C, Lefebvre JF, et al Management of malignant hilar biliary obstruction by endoscopy. Results and prognostic factors Dig Dis Sci 1992 May 37(5):778 83 1373361
Duensing RA, Williams RA, Collins JC, et al Managing choledocholithiasis in the laparoscopic era Am J Surg 1995 Dec 170(6):619 23 7492013
Dumonceau JM, Deviere J, Le Moine O, et al Endoscopic pancreatic drainage in chronic pancreatitis associated with ductal stones: long-term results Gastrointest Endosc 1996 Jun 43(6):547 55 8781931
Duvnjak M, Rotkvic I, Vucelic B, et al The value of pancreatic pseudocyst amylase concentration in the detection of pseudocyst communication with the pancreatic duct Am J Gastroenterol 1991 May 86(5):595 8 1709337
Dwerryhouse SJ, Brown E, Vipond MN Prospective evaluation of magnetic resonance cholangiography to detect common bile duct stones before laparoscopic cholecystectomy Br J Surg 1998 Oct 85(10):1364 6 9782014
Earnshaw JJ, Hayter JT, Teastale C, et al. Should endoscopic stenting be the initial treatment of malignant biliary obstruction?. Ann R Coll Surg Engl. 1992;74:338-41. [pmid: 1384416].
Edmundowicz SA Common bile duct stones Gastrointest Endosc Clin N Am 1995 Oct 5(4):817 24 8535630
Eisen GM, Chutkan R, Goldstein JL, et al. Endoscopic therapy of chronic pancreatitis. Gastrointent Endosc. 2000;52:843-8.
Elias E, Hamlyn AN, Jain S, et al A randomized trial of percutaneous transhepatic cholangiography with the Chiba needle versus endoscopic retrograde cholangiography for bile duct visualization in jaundice Gastroenterology 1976 Sep 71(3):439 43 950094
Ell C, Rabenstein T, Schneider HT, et al Safety and efficacy of pancreatic sphincterotomy in chronic pancreatitis Gastrointest Endosc 1998 Sep 48(3):244 9 9744598
Elta GH, Barnett JL, Wille RT, et al Pure cut electrocautery current for sphincterotomy causes less post-procedure pancreatitis than blended current Gastrointest Endosc 1998 Feb 47(2):149 53 9512280
Elton E, Howell DA, Parsons WG, et al Endoscopic pancreatic sphincterotomy: indications, outcome, and a safe stentless technique Gastrointest Endosc 1998 Mar 47(3):240 9 9540876
Endo Y, Morii T, Tamura H, et al Cytodiagnosis of pancreatic malignant tumors by aspiration, under direct vision, using a duodenal fiberscope Gastroenterology 1974 67(5):944 951 4372126
England RE, Martin DF Endoscopic and percutaneous intervention in malignant obstructive jaundice Cardiovasc Intervent Radiol 1996 Nov-Dec 19(6):381 7 8994702
Enns R, Baillie J Review article: the treatment of acute biliary pancreatitis Aliment Pharmacol Ther 1999 Nov 13(11):1379 89 10571592
Erickson RA, Garza AA EUS with EUS-guided fine-needle aspiration as the first endoscopic test for the evaluation of obstructive jaundice Gastrointest Endosc 2001 Apr 53(4):475 84 11275889
Esber EJ, Sherman S The interface of endoscopic retrograde cholangiopancreatography and laparoscopic cholecystectomy Gastrointest Endosc Clin N Am 1996 Jan 6(1):57 80 8903563
Eversman D, Fogel EL, Rusche M, et al Frequency of abnormal pancreatic and biliary sphincter manometry compared with clinical suspicion of sphincter of Oddi dysfunction Gastrointest Endosc 1999 Nov 50(5):637 41 10536318
Falkenstein DB, Riccobono C, Sidhu G, et al The endoscopic intrahepatic cholangiogram. Clinicopathologic correlation with postmortem cholangiograms Invest Radiol 1975 Jul-Aug 10(4):358 65 1184325
Fan ST, Lai EC, Mok FP, et al Early treatment of acute biliary pancreatitis by endoscopic papillotomy N Engl J Med 1993 Jan 28 328(4):228 32
Fanelli RD, Gersin KS Laparoscopic endobiliary stenting: a simplified approach to the management of occult common bile duct stones J Gastrointest Surg 2001 Jan-Feb 5(1):74 80 11309651
Fanning NF, Horgan PG, Keane FB Evolving management of common bile duct stones in the laparoscopic era J R Coll Surg Edinb 1997 Dec 42(6):389 94 9448394
Farup PG, Tjora S Sphincter of Oddi dysfunction. Dynamic cholescintigraphy and endoscopic retrograde cholangiopancreatography with papillotomy in diagnosis, treatment, and follow-up study Scand J Gastroenterol 1989 Oct 24(8):956 60 2595257
Feinberg SB, Schreiber DR, Goodale R Comparison of ultrasound pancreatic scanning and encoscopic retrograde cholangiopancreatograms: a retrospective study J Clin Ultrasound 1977 Apr 5(2):96 100 404336
Feller ER Endoscopic retrograde cholangiopancreatography in the diagnosis of unexplained pancreatitis Arch Intern Med 1984 Sep 144(9):1797 9 6476999
Ferrari Jr AP, Lichtenstein DR, Slivka A, et al Brush cytology during ERCP for the diagnosis of biliary and pancreatic malignancies Gastrointest Endosc 1994 Mar-Apr 40(2 Pt 1):140 5 8013810
Ferrucci JT MRI and MRCP in pancreaticobiliary malignancy Ann Oncol 1999 10Suppl 4:18 9 10436777
Festen C, Severijnen R, vd Staak F, et al Chronic relapsing pancreatitis in childhood J Pediatr Surg 1991 Feb 26(2):182 3 2023080
Fiore NF, Ledniczky G, Wiebke EA, et al An analysis of perioperative cholangiography in one thousand laparoscopic cholecystectomies Surgery 1997 Oct 122(4):817 21 9347861
Fleischmann D, Ringl H, Schofl R, et al Three-dimensional spiral CT cholangiography in patients with suspected obstructive biliary disease: comparison with endoscopic retrograde cholangiography Radiology 1996 Mar 198(3):861 8 8628884
Fletcher DR, Hurley RA, Hardy KJ The effect of selective therapy on malignant obstructive jaundice Med J Aust 1989 Nov 20 151(10):560 4
Fockens P, Johnson TG, van Dullemen HM, et al Endosonographic imaging of pancreatic pseudocysts before endoscopic transmural drainage Gastrointest Endosc 1997 Nov 46(5):412 6 9402114
Foley WD, Stewart ET, Lawson TL, et al Computed tomography, ultrasonography, and endoscopic retrograde cholangiopancreatography in the diagnosis of pancreatic disease: a comparative study Gastrointest Radiol 1980 Feb 1 5(1):29 35
Folsch UR, Nitsche R, Ludtke R, et al Early ERCP and papillotomy compared with conservative treatment for acute biliary pancreatitis. The German Study Group on Acute Biliary Pancreatitis N Engl J Med 1997 Jan 23 336(4):237 42
Foutch PG, Kerr DM, Harlan JR, et al A prospective, controlled analysis of endoscopic cytotechniques for diagnosis of malignant biliary strictures Am J Gastroenterol 1991 May 86(5):577 80 2028947
Foutch PG A prospective assessment of results for needle-knife papillotomy and standard endoscopic sphincterotomy Gastrointest Endosc 1995 Jan 41(1):25 32 7698621
Franceschi D, Brandt C, Margolin D, et al The management of common bile duct stones in patients undergoing laparoscopic cholecystectomy Am Surg 1993 Aug 59(8):525 32 8338284
Frederic N, Deltenre M, d'Hondt M, et al Comparative study of ultrasound and ERCP in the diagnosis of hepatic, biliary and pancreatic diseases: a prospective study based on a continuous series of 424 patients Eur J Radiol 1983 Aug 3(3):208 11 6628399
Freeman M, DiSario JA, Nelson DB, et al Risk factors for post-ERCP pancreatitis: a prospective, multicenter study Gastrointest Endosc 2001 Oct 54(4):425 34 11577302
Freeman ML Complications of endoscopic biliary sphincterotomy: a review Endoscopy 1997 May 29(4):288 97 9255535
Freeman ML Outcome assessment for endoscopic retrograde cholangiopancreatography Clin Perspect Gastroenterol 2000 3(3):143 149
Freeman ML Procedure-specific outcomes assessment for endoscopic retrograde cholangiopancreatography Gastrointest Endosc Clin N Am 1999 Oct 9(4):639 47, vii 10495228
Freeman ML Toward improving outcomes of ERCP: Endoscopist's experience: Does it make a difference? Gastrointest Endosc 1998 48(1):96 102 9684679
Freeman ML, Nelson DB, Sherman S, et al Complications of endoscopic biliary sphincterotomy N Engl J Med 1996 Sep 26 335(13):909 18
Freeman ML, Nelson DB, Sherman S, et al Same-day discharge after endoscopic biliary sphincterotomy: observations from a prospective multicenter complication study. The Multicenter Endoscopic Sphincterotomy (MESH) Study Group Gastrointest Endosc 1999 May 49(5):580 6 10228255
Freeny PC, Ball TJ Endoscopic retrograde cholangiopancreatography (ERCP) and percutaneous transhepatic cholangiography (PTC) in the evaluation of suspected pancreatic carcinoma: diagnostic limitations and contemporary roles Cancer 1981 Mar 15 47(6 Suppl):1666 78
Frey CF, Burbige EJ, Meinke WB, et al Endoscopic retrograde cholangiopancreatography Am J Surg 1982 Jul 144(1):109 14 7091519
Frick MP, O'Leary JF, Walker Jr HC, et al Accuracy of endoscopic retrograde cholangiopancreatography (ERCP) in differentiating benign and malignant pancreatic disease Gastrointest Radiol 1982 7(3):241 244 7106488
Froeschle G, Meyer-Pannwitt U, Brueckner M, et al A comparison between surgical, endoscopic and percutaneous management of pancreatic pseudocysts--long term results Acta Chir Belg 1993 May-Jun 93(3):102 6 8372580
Frossard JL, Hadengue A, Amouyal G, et al Choledocholithiasis: a prospective study of spontaneous common bile duct stone migration Gastrointest Endosc 2000 Feb 51(2):175 9 10650260
Frossard JL, Sosa-Valencia L, Amouyal G, et al Usefulness of endoscopic ultrasonography in patients with "idiopathic" acute pancreatitis Am J Med 2000 Aug 15 109(3):196 200
Fuji T, Amano H, Ohmura R, et al Endoscopic pancreatic sphincterotomy--technique and evaluation Endoscopy 1989 Jan 21(1):27 30 2917533
Fulcher AS, Turner MA, Capps GW, et al Half-Fourier RARE MR cholangiopancreatography: experience in 300 subjects Radiology 1998 Apr 207(1):21 32 9530295
Fulcher AS, Turner MA, Capps GW MR cholangiography: technical advances and clinical applications Radiographics 1999 Jan-Feb 19(1):25 41 9925390
Fulcher AS, Turner MA, Franklin KJ, et al Primary sclerosing cholangitis: evaluation with MR cholangiography-a case-control study Radiology 2000 Apr 215(1):71 80 10751470
Fullarton GM, Allan A, Hilditch T, et al Quantitative 99mTc-DISIDA scanning and endoscopic biliary manometry in sphincter of Oddi dysfunction Gut 1988 29(10):1397 1401 3197984 1433998
Fullarton GM, Murray WR. Evaluation of endoscopic sphincterotomy in sphincter of Oddi dysfunction. Endoscopy. 1992;24:199-202. [pmid: 1587237].
Furukawa T, Tsukamoto Y, Naitoh Y, et al Differential diagnosis between benign and malignant localized stenosis of the main pancreatic duct by intraductal ultrasound of the pancreas Am J Gastroenterol 1994 Nov 89(11):2038 41 7942732
Furukawa T, Tsukamoto Y, Naitoh Y, et al Differential diagnosis of pancreatic diseases with an intraductal ultrasound system Gastrointest Endosc 1994 Mar-Apr 40(2 Pt 1):213 9 8013824
Furukawa T, Tsukamoto Y, Naitoh Y, et al Evaluation of intraductal ultrasonography in the diagnosis of pancreatic cancer Endoscopy 1993 Nov 25(9):577 81 8119207
Gagnon P, Boustiere C, Ponchon T, et al Percutaneous fine-needle aspiration cytologic study of main pancreatic duct stenosis under pancreatographic guidance Cancer 1991 May 1 67(9):2395 400
Geenen JE, Hogan WJ, Dodds WJ, et al The efficacy of endoscopic sphincterotomy after cholecystectomy in patients with sphincter-of-Oddi dysfunction N Engl J Med 1989 Jan 12 320(2):82 7
Geenen JE, Vennes JA, Silvis SE Resume of a seminar on endoscopic retrograde sphincterotomy (ERS) Gastrointest Endosc 1981 Feb 27(1):31 8 7215746
Georgopoulos SK, Schwartz LH, Jarnagin WR, et al Comparison of magnetic resonance and endoscopic retrograde cholangiopancreatography in malignant pancreaticobiliary obstruction Arch Surg 1999 Sep 134(9):1002 7 10487597
Gholson CF, Favrot D, Vickers B, et al Delayed hemorrhage following endoscopic retrograde sphincterotomy for choledocholithiasis Dig Dis Sci 1996 May 41(5):831 4 8625750
Gibbons JC, Williams SJ Progress in the endoscopic management of benign biliary strictures J Gastroenterol Hepatol 1998 Feb 13(2):116 24 10221811
Gigot JF Actual management of common bile duct stones: a continuous evolving approach Ann Ital Chir 1998 Nov-Dec 69(6):741 50 10213947
Gilinsky NH, Bornman PC, Girdwood AH, et al Diagnostic yield of endoscopic retrograde cholangiopancreatography in carcinoma of the pancreas Br J Surg 1986 Jul 73(7):539 43 3524740
Gillams A, Cheslyn-Curtis S, Russell RC, et al Can cholangiography be safely abandoned in laparoscopic cholecystectomy? Ann R Coll Surg Engl 1992 Jul 74(4):248 51 1416674
Gilmore IT, Pemberton J, Thompson RPH Retrograde cholangiopancreatography in the diagnosis of carcinoma of the pancreas Gastrointest Endosc 1982 28(2):77 78 7084647
Giovannini M, Seitz JF Endoscopic ultrasonography with a linear-type echoendoscope in the evaluation of 94 patients with pancreatobiliary disease Endoscopy 1994 Sep 26(7):579 85 8001484
Glasbrenner B, Ardan M, Boeck W, et al Prospective evaluation of brush cytology of biliary strictures during endoscopic retrograde cholangiopancreatography Endoscopy 1999 Nov 31(9):712 7 10604612
Glasbrenner B, Schwarz M, Pauls S, et al Prospective comparison of endoscopic ultrasound and endoscopic retrograde cholangiopancreatography in the preoperative assessment of masses in the pancreatic head Dig Surg 2000 17(5):468 74 11124550
Glattli A, Stain SC, Baer HU, et al. Unresectable malignant biliary obstruction: treatment by self-expandable biliary endoprosthesis. HTB Surg. 1993;6:175-84.
Gmelin E, Weiss HD Tumours in the region of the papilla of Vater. Diagnosis via endoscopy, biopsy, brush cytology, ERPC and CT-scan Eur J Radiol 1981 Nov 1(4):301 6 7346276
Go VL, Taylor WF, DiMagno EP Efforts at early diagnosis of pancreatic cancer: the Mayo Clinic Experience Cancer 1981 Mar 15 47(6 Suppl):1698 705
Godil A, Chen YK Endoscopic management of benign pancreatic disease Pancreas 2000 20(1):1 13 10630377
Goff JS. Common bile duct sphincter of Oddi stenting in patients with suspected sphincter dysfunction. Am J Gastroenterol. 1995;90:586-9. [pmid: 7717316].
Goldberg HI, Gordon R Diagnostic and interventional procedures for the biliary tract Curr Opin Radiol 1991 Jun 3(3):453 62 1859780
Goldberg HI Imaging of the biliary tract Curr Opin Radiol 1992 Jun 4(3):62 9 1581135
Golub R, Cantu R, Tan M The prediction of common bile duct stones using a neural network J Am Coll Surg 1998 Dec 187(6):584 90 9849730
Goodale RL, Condie RM, Gajl-Peczalska K, et al Clinical and secretory differences in pancreatic cancer and chronic pancreatitis Ann Surg 1981 Aug 194(2):193 8 7259347 1345240
Goodale RL, Gajl-Peczalska K, Dressel T, et al Cytologic studies for the diagnosis of pancreatic cancer Cancer 1981 Mar 15 47(6 Suppl):1652 5
Goodman AJ, Neoptolemos JP, Carr-Locke DL, et al Detection of gall stones after acute pancreatitis Gut 1985 Feb 26(2):125 32 2578422 1432439
Gorelick AB, Scheiman JM, Fendrick AM Identification of patients with resectable pancreatic cancer: at what stage are we? Am J Gastroenterol 1998 Oct 93(10):1995 6 9772077
Gorgul A, Kayhan B, Mentes BB, et al The comparison of the effect of somatostatin and SMS 201-995 on enzyme change following endoscopic retrograde cholangiopancreotography Gazi Med J 1998 9(1):9 13
Gottlieb K, Sherman S ERCP and biliary endoscopic sphincterotomy-induced pancreatitis Gastrointest Endosc Clin N Am 1998 Jan 8(1):87 114 9405753
Grace PA, Williamson RCN Modern management of pancreatic pseudocysts Br J Surg 1993 80(May):573 581 8518891
Graham SM, Flowers JL, Scott TR, et al Laparoscopic cholecystectomy and common bile duct stones. The utility of planned perioperative endoscopic retrograde cholangiography and sphincterotomy: experience with 63 patients Ann Surg 1993 Jul 218(1):61 7 8328830 1242901
Granke K, Jordan FT, Mazzeo RJ, et al Endoscopic papillotomy: impact on community hospital treatment of common duct stones Am Surg 1988 Jun 54(6):347 51 3377329
Grant TH, Efrusy ME Ultrasound in the evaluation of chronic pancreatitis J Am Osteopath Assoc 1981 81(3):183 188 7309584
Greenberger NJ, Toskes PP, Isselbacher KJ. Acute and chronic pancreatitis. Ch. 274 In: Isselbacher KJ, Braunwald E, Wilson JD, et al., eds. Harrison's Principles of Internal Medicine, 13th edition. 1994 McGraw-Hill, Inc.; New York, NY: 1520-32.
Greenen JE, Rolny P. Endoscopic therapy of acute and chronic pancreatitis. Gastrointestinal Endoscopy. 1991;37:377-382. [pmid: 2070994].
Greenlee RT, Hill-Harmon MB, Murray T, et al Cancer statistics, 2001 CA Cancer J Clin 2001 Jan-Feb 51(1):15 36 11577478
Gregg J, Solomon J, Clark G Pancreas divisum and its association with choledochal sphincter stenosis. Diagnosis by endoscopic retrograde cholangiopancreatography and endoscopic biliary manometry Am J Surg 1984 Mar 147(3):367 71 6703208
Gregg JA, Clark G, Barr C, et al Postcholecystectomy syndrome and its association with ampullary stenosis Am J Surg 1980 Mar 139(3):374 8 7362006
Gregg JA, McDonald DG Endoscopic retrograde cholangiopancreatography and gray-scale abdominal ultrasound in the diagnosis of jaundice Am J Surg 1979 May 137(5):611 5 453455
Gregg JA, Taddeo AE, Milano AF, et al Duodenoscopy and endoscopic pancreatography in patients with postive morphine prostigmine tests Am J Surg 1977 Sep 134(3):318 21 900332
Gregor JC, Ponich TP, Detsky AS Should ERCP be routine after an episode of "idiopathic" pancreatitis? A cost-utility analysis Gastrointest Endosc 1996 Aug 44(2):118 23 8858315
Gress F, Gottlieb K, Sherman S, et al Endoscopic ultrasonography-guided fine-needle aspiration biopsy of suspected pancreatic cancer Ann Intern Med 2001 Mar 20 134(6):459 64
Gress FG, Hawes RH, Savides TJ, et al. Endoscopic ultrasound-guided fine-needle aspiration biopsy using linear array and radial scanning endosonography. Gastrointest Endosc. 1997;45:243-50. [pmid: 9087830].
Griffanti-Bartoli F, Arnone GB, Ceppa P, et al Malignant tumors in the head of the pancreas and the periampullary region. Diagnostic and prognostic aspects Anticancer Res 1994 Mar-Apr 14(2B):657 66 8010724
Grimm H, Maydeo A, Soehendra N Endoluminal ultrasound for the diagnosis and staging of pancreatic cancer Baillieres Clin Gastroenterol 1990 Dec 4(4):869 88 2078789
Grimm H, Meyer WH, Nam VC, et al New modalities for treating chronic pancreatitis Endoscopy 1989 Mar 21(2):70 4 2707174
Grimon G, Buffet C, Andre L, et al Biliary pain in postcholecystectomy patients without biliary obstruction. A prospective radionuclide study Dig Dis Sci 1991 Mar 36(3):317 20 1995268
Gross GW Management of bile duct stones in the era of laparoscopic cholecystectomy Dig Dis 1998 Mar-Apr 16(2):99 110 9571375
Gross BH, Harter LP, Gore RM, et al Ultrasonic evaluation of common bile duct stones: prospective comparison with endoscopic retrograde cholangiopancreatography Radiology 1983 Feb 146(2):471 4 6849097
Guelrud M Papillary stenosis Endoscopy 1988 Aug 20Suppl 1:193 202 3049057
Guelrud M, Morera C, Rodriguez M, et al Normal and anomalous pancreaticobiliary union in children and adolescents Gastrointest Endosc 1999 Aug 50(2):189 93 10425411
Guelrud M, Morera C, Rodriguez M, et al Sphincter of Oddi dysfunction in children with recurrent pancreatitis and anomalous pancreaticobiliary union: an etiologic concept Gastrointest Endosc 1999 Aug 50(2):194 9 10425412
Guelrud M, Mujica C, Jaen D, et al The role of ERCP in the diagnosis and treatment of idiopathic recurrent pancreatitis in children and adolescents Gastrointest Endosc 1994 Jul-Aug 40(4):428 36 7926532
Guibaud L, Bret PM, Reinhold C, et al Bile duct obstruction and choledocholithiasis: diagnosis with MR cholangiography Radiology 1995 Oct 197(1):109 15 7568807
Gulla N, Patriti A, Patriti A, et al Minimally invasive treatment of cholelithiasis in the elderly Minerva Chir 2001 Jun 56(3):223 8 11423787
Guthrie CM, Haddock G, De Beaux AC, et al Changing trends in the management of extrahepatic cholangiocarcinoma Br J Surg 1993 Nov 80(11):1434 9 7504567
Hainsworth PJ, Rhodes M, Gompertz RH, et al Imaging of the common bile duct in patients undergoing laparoscopic cholecystectomy Gut 1994 Jul 35(7):991 5 8063230 1374850
Hall TJ, Blackstone MO, Cooper MJ, et al Prospective evaluation of endoscopic retrograde cholangiopancreatography in the diagnosis of periampullary cancers Ann Surg 1978 Mar 187(3):313 7 637590 1396429
Hall-Craggs MA, Allen CM, Owens CM, et al MR cholangiography: clinical evaluation in 40 cases Radiology 1993 Nov 189(2):423 7 8210370
Halme L, Doepel M, von Numers H, et al Complications of diagnostic and therapeutic ERCP Ann Chir Gynaecol 1999 88(2):127 31 10392249
Hamilton I, Lintott DJ, Rothwell J, et al Acute pancreatitis following endoscopic retrograde cholangiopancreatography Clin Radiol 1983 Sep 34(5):543 6 6617085
Hammarstrom LE, Andersson R, Stridbeck H, et al Influence of bile duct stones on patient features and effect of endoscopic sphincterotomy on early outcome of edematous gallstone pancreatitis World J Surg 1999 Jan 23(1):12 7 9841757
Hammarstrom LE, Holmin T, Stridbeck H, et al Long-term follow-up of a prospective randomized study of endoscopic versus surgical treatment of bile duct calculi in patients with gallbladder in situ Br J Surg 1995 Nov 82(11):1516 21 8535807
Hammarstrom LE, Stridbeck H, Ihse I Effect of endoscopic sphincterotomy and interval cholecystectomy on late outcome after gallstone pancreatitis Br J Surg 1998 Mar 85(3):333 6 9529486
Hammarstrom LE, Stridbeck H, Ihse I Endoscopic drainage in benign pancreatic disease: immediate and medium term outcome Eur J Surg 1997 Aug 163(8):577 89 9298910
Hammarstrom LE, Stridbeck H, Ihse I Factors predictive of early complications of endoscopic treatment of bile duct calculi Hepatogastroenterology 1997 Sep-Oct 44(17):1246 55 9356835
Hansen HH, Toftgaard C, Rokkjor MJ, et al Food-stimulated cholescintigraphy as a supplement to ERC in patients with suspected bile flow obstruction. A preliminary study Rontgenblatter 1990 Nov 43(11):484 6 2277931
Hanssen LE, Osnes M, Myren J Pancreatic secretion obtained by endoscopic cannulation of the main pancreatic duct and secretin release after duodenal acidification in man Scandinavian Journal of Gastroenterology (Scand. J. Gastroenterol.) 1978 13(3):325 330
Harada H, Sasaki T, Yamamoto N, et al Assessment of endoscopic aspiration cytology and endoscopic retrograde cholangio-pancreatography in patients with cancer of the hepato-biliary tract. Part II Gastroenterol Jpn 1977 12(1):59 64 863180
Harada H, Sasaki T, Yamamoto N, et al Assessment of endoscopic aspiration cytology and endoscopic retrograde cholangi-pancreatography (ERCP) in patients with cancer of the pancreas. Part I Gastroenterol Jpn 1977 12(1):52 8 863179
Harada H, Tanaka J, Shundo T, et al A diagnostic approach to inflammatory disease of the pancreas by means of endoscopic retrograde cholangio-pancreatography Gastroenterol Jpn 1977 12(5):387 94 598671
Harris A, Chan AC, Torres-Viera C, et al Meta-analysis of antibiotic prophylaxis in endoscopic retrograde cholangiopancreatography (ERCP) Endoscopy 1999 Nov 31(9):718 24 10604613
Hart R, Classen M Complications of diagnostic gastrointestinal endoscopy Endoscopy 1990 Sep 22(5):229 33 Comment in: Endoscopy. 1991 Jul;23(4):245-6 2147002
Hastbacka J, Jarvinen H, Kivilaakso E, et al Results of sphincteroplasty in patients with spastic sphincter of Oddi. Predictive value of operative biliary manometry and provocation tests Scand J Gastroenterol 1986 Jun 21(5):516 20 3749793
Hastier P, Buckley MJ, Francois E, et al A prospective study of pancreatic disease in patients with alcoholic cirrhosis: comparative diagnostic value of ERCP and EUS and long-term significance of isolated parenchymal abnormalities Gastrointest Endosc 1999 Jun 49(6):705 9 10343213
Hatfield ARW, Terblanche J, Fataar S, et al. Preoperative external biliary drainage in obstructive jaundice. Lancet. 1982;2:(896-9. [pmid: 6126752].
Hauer-Jensen M, Karesen R, Nygaard K, et al Predictive ability of choledocholithiasis indicators. A prospective evaluation Ann Surg 1985 Jul 202(1):64 8 4015213 1250838
Hauer-Jensen M, Karesen R, Nygaard K, et al Prospective randomized study of routine intraoperative cholangiography during open cholecystectomy: long-term follow-up and multivariate analysis of predictors of choledocholithiasis Surgery 1993 Mar 113(3):318 23 8441966
Hawasli A, Lloyd L, Cacucci B Management of choledocholithiasis in the era of laparoscopic surgery Am Surg 2000 May 66(5):425 30 10824741
Hawasli A, Lloyd L, Pozios V, et al The role of endoscopic retrograde cholangio-pancreaticrogram in laparoscopic cholecystectomy Am Surg 1993 May 59(5):285 8 8489095
Hawes RH, Zaidi S Endoscopic ultrasonography of the pancreas Gastrointest Endosc Clin N Am 1995 Jan 5(1):61 80 7728350
He X, Zheng C, Zhang Z, et al Congenital choledochal cyst - Report of 56 cases Chin Med Sci J 2000 15(1):52 54 12899402
Heili MJ, Wintz NK, Fowler DL Choledocholithiasis: endoscopic versus laparoscopic management Am Surg 1999 Feb 65(2):135 8 9926747
Heinerman M, Pimpl W, Waclawiczek HW, et al Combined endoscopic and surgical approach to primary gallstone disease Surg Endosc 1987 1(4):195 8 3455033
Heinerman PM, Boeckl O, Pimpl W Selective ERCP and preoperative stone removal in bile duct surgery Ann Surg 1989 Mar 209(3):267 72 2923513 1493934
Heslin MJ, Brooks AD, Hochwald SN, et al A preoperative biliary stent is associated with increased complications after pancreatoduodenectomy Arch Surg 1998 Feb 133(2):149 54 9484726
Hildell J, Aspelin P, Wehlin L Gray scale ultrasound and endoscopic ductography in the diagnosis of pancreatic disease Acta Chir Scand 1979 145(4):239 45 494971
Himal HS Common bile duct stones: the role of preoperative, intraoperative, and postoperative ERCP Semin Laparosc Surg 2000 Dec 7(4):237 45 11323761
Himal HS Preoperative endoscopic retrograde cholangiopancreatography (ERCP) is not necessary in mild gallstone pancreatitis Surg Endosc 1999 Aug 13(8):782 3 10430684
Hintze RE, Adler A, Veltzke W, et al Clinical significance of magnetic resonance cholangiopancreatography (MRCP) compared to endoscopic retrograde cholangiopancreatography (ERCP) Endoscopy 1997 Mar 29(3):182 7 9201467
Ho JT, Yap CK Magnetic resonance cholangiopancreatography: value of using the half-Fourier acquisition single-shot turbo spin-echo (HASTE) sequence Ann Acad Med Singapore 1999 May 28(3):366 70 10575520
Ho KY, Montes H, Sossenheimer MJ, et al Features that may predict hospital admission following outpatient therapeutic ERCP Gastrointest Endosc 1999 May 49(5):587 92 10228256
Hoare AM, West RJ, Cockel R The reasons for failure of endoscopic retrograde cholangio-pancreatography in patients with jaundice Clin Radiol 1978 Mar 29(2):201 3 639460
Hochwald SN, Burke EC, Jarnagin WR, et al Association of preoperative biliary stenting with increased postoperative infectious complications in proximal cholangiocarcinoma Arch Surg 1999 Mar 134(3):261 6 10088565
Hochwalk SN, Dobryansky M BA, Rofsky NM, et al Magnetic resonance cholangiopancreatography accurately predicts the presence or absence of choledocholithiasis J Gastrointest Surg 1998 Nov-Dec 2(6):573 9 10457316
Hogan WJ, Geenen JE Biliary dyskinesia Endoscopy 1988 Aug 20(Suppl 1):179 83 3168947
Holzknecht N, Gauger J, Sackmann M, et al Breath-hold MR cholangiography with snapshot techniques: prospective comparison with endoscopic retrograde cholangiography Radiology 1998 Mar 206(3):657 64 9494483
Homma T Criteria for pancreatic disease diagnosis in Japan: Diagnostic criteria for chronic pancreatitis Pancreas 1998 16(3):250 254 9548663
Honickman SP, Mueller PR, Wittenberg J, et al Ultrasound in obstructive jaundice: prospective evaluation of site and cause Radiology 1983 May 147(2):511 5 6836132
Horsmans Y, De Grez T, Lefebvre V, et al Double common bile duct with ectopic drainage of the left lobe into the stomach. Case report and review of the literature Acta Gastro-Enterol Belg 1996 59(4):256 257
Howard TJ, Tan T, Lehman GA, et al Classification and management of perforations complicating endoscopic sphincterotomy Surgery 1999 Oct 126(4):658 63 10520912
Howell DA, Beveridge RP, Bosco J, et al Endoscopic needle aspiration biopsy at ERCP in the diagnosis of biliary strictures Gastrointest Endosc 1992 Sep-Oct 38(5):531 5 1327937
Howell DA, Elton E, Parsons WG Endoscopic management of pseudocysts of the pancreas Gastrointest Endosc Clin N Am 1998 Jan 8(1):143 62 9405756
Hoyuela C, Cugat E, Bretcha P, et al Must ERCP Be routinely performed if choledocholithiasis is suspected? Dig Surg 1999 16(5):411 4 10567803
Huang MJ, Liaw YF, Wu CS Comparison of intravenous radionuclide cholescintigraphy and endoscopic retrograde cholangiography in the diagnosis of intrahepatic gall-stones Br J Radiol 1981 Apr 54(640):302 6 7225718
Huibregtse K. Biliary stenting: cosmetic or clinical value?. Scand J Gastroenterol Suppl. 1992;192:77-9. [pmid: 1279779].
Huibregtse K, Smits ME Endoscopic management of diseases of the pancreas Am J Gastroenterol 1994 89(8):S66 S77 8048416
Hunt DR, Blumgart LH Preoperative differentiation between carcinoma of the pancreas and chronic pancreatitis: the contribution of cytology Endoscopy 1982 Sep 14(5):171 3 7117208
Ihre T, Hellers G Complications and endoscopic retrograde cholangio-pancreatography. A review of the literature and presentation of a duodenal perforation Acta Chir Scand 1977 143(3):167 171 920014
Iida F, Kusama J Surgical evaluation of endoscopic retrograde cholangiography for biliary tract diseases Jpn J Surg 1982 12(4):257 61 7120704
Ikeda S, Tanaka M, Itoh H, et al Emergency decompression of bile duct in acute obstructive suppurative cholangitis by duodenoscopic cannulation: A lifesaving procedure World J Surg 1981 5(4):587 593 7324493
Ikeda S, Tanaka M, Matsumoto S, et al Endoscopic sphincterotomy: long-term results in 408 patients with complete follow-up Endoscopy 1988 Jan 20(1):13 7 3342766
Inamoto K, Tanaka S, Yamazaki H, et al Computed tomography of the carcinoma of the ampulla of vater Fortschr Geb Rontgenstr Nuklearmed 1982 136(6):689 693
Inui K, Nakazawa S, Yoshino J, et al Endoluminal ultrasonography for pancreatic diseases Gastroenterol Clin North Am 1999 Sep 28(3):771 81 10503149
Irie H, Honda H, Aibe H, et al MR cholangiopancreatographic differentiation of benign and malignant intraductal mucin-producing tumors of the pancreas Am J Roentgenol 2000 174(5):1403 1408 10789803
Irie H, Honda H, Tajima T, et al Optimal MR cholangiopancreatographic sequence and its clinical application Radiology 1998 Feb 206(2):379 87 9457189
Irwig L, Tosteson ANA, Gatsonis C et al. Guideline for meta-analysis evaluating diagnostic tests. Ann Intern Med. 1994;120:667-676. [pmid: 8135452].
Ishikawa M, Tagami Y, Toyota T, et al Can three-dimensional helical CT cholangiography before laparoscopic cholecystectomy be a substitute study for endoscopic retrograde cholangiography? Surg Laparosc Endosc Percutan Tech 2000 Dec 10(6):351 6 11147907
Itoh H, Shimono R, Hamamoto K Evaluation of common bile duct stenosis in chronic pancreatitis using cholescintigraphy Eur J Nucl Med 1988 14(3):137 40 3402503
Jacob L, Geenen JE, Catalano MF, et al Prevention of pancreatitis in patients with idiopathic recurrent pancreatitis: a prospective nonblinded randomized study using endoscopic stents Endoscopy 2001 Jul 33(7):559 62 11473324
Jailwala J, Fogel EL, Sherman S, et al Triple-tissue sampling at ERCP in malignant biliary obstruction Gastrointest Endosc 2000 Apr 51(4 Pt 1):383 90 10744806
Jamidar P, Sherman S, Hawes R. Efficacy of endoscopic sphincterotomy for patients with sphincter of Oddi dysfunction: randomized, controlled study. Gastrointest Endosc. 1992;38.
Jander HP, Galbraith J, Aldrete JS Percutaneous transhepatic cholangiography using the Chiba needle: comparison with retrograde pancreatocholecystography South Med J 1980 Apr 73(4):415 21 7367928
Jenkins SA, Berein A Review article: the relative effectiveness of somatostatin and octreotide therapy in pancreatic disease Aliment Pharmacol Ther 1995 Aug 9(4):349 61 Comment in: Aliment Pharmacol Ther. 1995 Oct;9(5):581-3 8527611
Jimenez Cuenca I, del Olmo Martinez L, Perez Homs M Helical CT without contrast in choledocholithiasis diagnosis Eur Radiol 2001 11(2):197 201 11218014
Johnson AS, Ferrara JJ, Steinberg SM, et al The role of endoscopic retrograde cholangiopancreatography: sphincterotomy versus common bile duct exploration as a primary technique in the management of choledocholithiasis Am Surg 1993 Feb 59(2):78 84 8476146
Johnson GK, Geenen JE, Johanson JF, et al Evaluation of post-ERCP pancreatitis: potential causes noted during controlled study of differing contrast media. Midwest Pancreaticobiliary Study Group Gastrointest Endosc 1997 Sep 46(3):217 22 9378207
Jowell PS, Baillie J, Branch MS, et al Quantitative assessment of procedural competence. A prospective study of training in endoscopic retrograde cholangiopancreatography Ann Intern Med 1996 Dec 15 125(12):983 9
Kalloo AN, Pasricha PJ Therapy of sphincter of Oddi dysfunction Gastrointest Endosc Clin N Am 1996 Jan 6(1):117 25 8903566
Kameya S, Kuno N, Kasugai T The diagnosis of pancreatic cancer by pancreatic juice cytology Acta Cytol 1981 Jul-Aug 25(4):354 60 6945001
Kaneko T, Nakao A, Inoue S, et al Intraoperative ultrasonography by high-resolution annular array transducer for intraductal papillary mucinous tumors of the pancreas Surgery 2001 Jan 129(1):55 65 11150034
Kaneko T, Nakao A, Nomoto S, et al Intraoperative pancreatoscopy with the ultrathin pancreatoscope for mucin-producing tumors of the pancreas Arch Surg 1998 Mar 133(3):263 7 9517737
Kapoor R, Kaushik SP, Saraswat VA, et al Prospective randomized trial comparing endoscopic sphincterotomy followed by surgery with surgery alone in good risk patients with choledocholithiasis HPB Surg 1996 9(3):145 8 8725454
Kapoor R, Pradeep R, Sikora SS, et al Appraisal of surgical and endoscopic management of choledocholithiasis Aust N Z J Surg 1994 Sep 64(9):599 603 8085972
Kapur BM, Mishra MC, Rao PS, et al Gall bladder and common bile duct stones--when is direct cholangiography indicated HPB Surg 1989 Oct 1(3):201 5 2487386
Karsten TM, Allema JH, Reinders M, et al Preoperative biliary drainage, colonisation of bile and postoperative complications in patients with tumours of the pancreatic head: a retrospective analysis of 241 consecutive patients Eur J Surg 1996 Nov 162(11):881 8 8956957
Katayama H, Spinazzi A, Fouillet X, et al Iomeprol: Current and future profile of a radiocontrast agent Investigative Radiology (Invest. Radiol.) 2001 36(2):87 96
Katon RM, Bilbao MK, Parent JA, et al Endoscopic retrograde cholangiopancreatography in patients with gastrectomy and gastrojejunostomy (Billroth II). A case for the forward look Gastrointestinal Endoscopy (Gastrointest. Endosc.) 1975 21(4):164 165 151520
Keith RG, Shapero TF, Saibil FG Treatment of pancreatitis associated with pancreas divisum by dorsal duct sphincterotomy alone Can J Surg 1982 25(6):622 626 7139415
Khaira HS, Ridings PC, Gompertz RH Routine laparoscopic cholangiography: a means of avoiding unnecessary endoscopic retrograde cholangiopancreatography J Laparoendosc Adv Surg Tech 1999 Feb 9(1):17 22
Khaira HS, Ridings PC, Gompertz RH Routine laparoscopic cholangiography: a means of avoiding unnecessary endoscopic retrograde cholangiopancreatography J Laparoendosc Adv Surg Tech A 1999 Feb 9(1):17 22 10194688
Kim KH, Kim W, Lee HI, et al Prediction of common bile duct stones: its validation in laparoscopic cholecystectomy Hepatogastroenterology 1997a Nov-Dec 44(18):1574 9 9427025
Kim MH, Lee SK, Lee MH, et al Endoscopic retrograde cholangiopancreatography and needle-knife sphincterotomy in patients with Billroth II gastrectomy: a comparative study of the forward-viewing endoscope and the side-viewing duodenoscope Endoscopy 1997b Feb 29(2):82 5 9101144
Kim MH, Myung SJ, Kim YS, et al Routine biliary sphincterotomy may not be indispensable for endoscopic pancreatic sphincterotomy Endoscopy 1998 Oct 30(8):697 701 9865559
Kim MJ, Mitchell DG, Ito K, et al Biliary dilatation: differentiation of benign from malignant causes--value of adding conventional MR imaging to MR cholangiopancreatography Radiology 2000 Jan 214(1):173 81 10644119
Kim SM, Kim SH, Choi SY, et al Surgical treatment of periampullary cancer--review of 766 surgical experiences of 8 hospitals J Korean Med Sci 1992 Dec 7(4):297 303 1299231
Kimchi NA, Mindrul V, Broide E, et al The contribution of endoscopy and biopsy to the diagnosis of periampullary tumors Endoscopy 1998 Aug 30(6):538 43 9746162
Kimmings AN, Van Deventer SJH, Rauws EAJ, et al Systemic inflammatory response in acute cholangitis and after subsequent treatment Eur J Surg 2000 166(9):700 705 11034466
Kinami S, Yao T, Kurachi M, et al Clinical evaluation of 3D-CT cholangiography for preoperative examination in laparoscopic cholecystectomy J Gastroenterol 1999 Feb 34(1):111 8 10204620
Kiviluoto T, Kivisaari L, Kivilaakso E, et al Pseudocysts in chronic pancreatitis. Surgical results in 102 consecutive patients Arch Surg 1989 Feb 124(2):240 3 2916944
Kloiber R, AuCoin R, Hershfield NB, et al Biliary obstruction after cholecystectomy: diagnosis with quantitative cholescintigraphy Radiology 1988 Dec 169(3):643 7 2460898
Knox TA Endoscopic ultrasound. Diagnostic and therapeutic uses Surg Endosc 1998 Aug 12(8):1088 90 9685549
Kocjan Gabrijela, Smith Ann Nisbet Bile duct brushings cytology: Potential pitfalls in diagnosis Diag Cytopathol 1997 16(4):358 363
Kohler A, Maier M, Benz C, et al A new HF current generator with automatically controlled system (Endocut mode) for endoscopic sphincterotomy--preliminary experience Endoscopy 1998 May 30(4):351 5 9689507
Kok T, Van der Sluis A, Klein JP, et al Ultrasound and cholangiography for the diagnosis of biliary complications after orthotopic liver transplantation: a comparative study J Clin Ultrasound 1996 Mar-Apr 24(3):103 15 8838298
Kolars JC, Allen MO, Ansel H, et al Pancreatic pseudocysts: clinical and endoscopic experience Am J Gastroenterol 1989 Mar 84(3):259 64 2919583
Komaki R, Wilson JF, Cox JD, et al Carcinoma of the pancreas: Results of irradiation for unresectable lesions Int J Radiat Oncol Biol Phys 1980 6(2):209 212 6967061
Kondylis PD, Simmons DR, Agarwal SK, et al Abnormal intraoperative cholangiography. Treatment options and long-term follow-up Arch Surg 1997 Apr 132(4):347 50 9108753
Koo KP, Traverso LW Do preoperative indicators predict the presence of common bile duct stones during laparoscopic cholecystectomy? Am J Surg 1996 May 171(5):495 9 8651393
Kositchaiwat S, Kositchaiwat C, Kanchanapitak A, et al Diagnostic value of endoscopic transampullary biopsy for malignant bile duct stricture J Med Assoc Thai 2000 Sep 83(9):992 8 11075963
Kozarek RA Endoscopy in the management of malignant obstructive jaundice Gastrointest Endosc Clin N Am 1996 Jan 6(1):153 76 8903569
Kozarek R, Terrance J Endoscopic pancreatic duct sphincterotomy: indications, technique and analysis of results Gastrointestinal Endoscopy 1994 40(5):592 8 7988825
Kozarek RA, Ball TJ, Patterson DJ, et al Endoscopic approach to pancreas divisum Dig Dis Sci 1995 Sep 40(9):1974 81 7555452
Kozarek RA, Ball TJ, Patterson DJ Endoscopic approach to pancreatic duct calculi and obstructive pancreatitis Am J Gastroenterol 1992 May 87(5):600 3 1595647
Kozarek RA, Patterson DJ, Ball TJ, et al Endoscopic placement of pancreatic stents and drains in the management of pancreatitis Ann Surg 1989 Mar 209(3):261 6 2923512 1493945
Kozarek RA, Traverso LW Endoscopic treatment of chronic pancreatitis - An alternative to surgery? Dig Surg 1996 13(2):90 100
Kubota Y, Takaoka M, Tani K, et al Endoscopic transpapillary biopsy for diagnosis of patients with pancreaticobiliary ductal strictures Am J Gastroenterol 1993 Oct 88(10):1700 4 8213710
Kuo WH, Pasricha PJ, Kalloo AN The role of sphincter of Oddi manometry in the diagnosis and therapy of pancreatic disease Gastrointest Endosc Clin N Am 1998 Jan 8(1):79 85 9405752
Kuo YT, Jaw TS, Wang CK, et al Diagnostic efficacy of non-breath-hold magnetic resonance cholangiopancreatography J Formos Med Assoc 1999 98(2):97 103 10083764
Kurzawinski T, Deery A, Davidson BR Diagnostic value of cytology for biliary stricture Br J Surg 1993 Apr 80(4):414 21 8495300
Kurzawinski T, Deery A, Dooley J, et al A prospective controlled study comparing brush and bile exfoliative cytology for diagnosing bile duct strictures Gut 1992 Dec 33(12):1675 7 1487170 1379581
Kurzawinski TR, Deery A, Dooley JS, et al A prospective study of biliary cytology in 100 patients with bile duct strictures Hepatology 1993 Dec 18(6):1399 403 8244264
Kwon AH, Inui H, Imamura A, et al Preoperative assessment for laparoscopic cholecystectomy: Feasibility of using spiral computed tomography Ann Surg 1998 227(3):351 356 9527057 1191272
Lachter J, Rubin A, Shiller M, et al Linear EUS for bile duct stones Gastrointest Endosc 2000 Jan 51(1):51 4 10625796
Lai EC, Lo CM, Choi TK, et al Urgent biliary decompression after endoscopic retrograde cholangiopancreatography Am J Surg 1989 Jan 157(1):121 5 2910117
Lai EC, Mok FP, Fan ST, et al. Preoperative endoscopic drainage for malignant obstructive jaundice. Br J Surg. 1994;81:1195-1198. [pmid: 7741850].
Lai ECS, Mok FPT, Tan ESY, et al Endoscopic biliary drainage for severe acute cholangitis New Engl J Med 1992 326(24):1582 6 1584258
Lambert ME, Betts CD, Hill J, et al Endoscopic sphincterotomy: the whole truth Br J Surg 1991 Apr 78(4):473 6 2032109
Lameris JS, Stoker J, Dees J, et al Non-surgical palliative treatment of patients with malignant biliary obstruction--the place of endoscopic and percutaneous drainage Clin Radiol 1987 Nov 38(6):603 8 2446814
Lammer J, Hausegger KA, Fluckiger F, et al. Common bile duct obstruction due to malignancy: Treatment with plastic versus metal stents. Radiology. 1996;201:(167-172. [pmid: 8816539].
Lans JI, Geenen JE, Johanson JF, et al Endoscopic therapy in patients with pancreas divisum and acute pancreatitis: a prospective, randomized, controlled clinical trial Gastrointest Endosc 1992 Jul-Aug 38(4):430 4 1511816
Lawson JM, Baillie J Endoscopic therapy for pancreatic pseudocysts Gastrointest Endosc Clin N Am 1995 Jan 5(1):181 93 7728343
Le Borgne J, de Calan L, Partensky C Cystadenomas and cystadenocarcinomas of the pancreas: a multiinstitutional retrospective study of 398 cases. French Surgical Association Ann Surg 1999 Aug 230(2):152 61 10450728 1420857
Lecesne R, Taourel P, Bret PM, et al Acute pancreatitis: interobserver agreement and correlation of CT and MR cholangiopancreatography with outcome Radiology 1999 Jun 211(3):727 35 10352598
Lee JG, Leung J Tissue sampling at ERCP in suspected pancreatic cancer Gastrointest Endosc Clin N Am 1998 Jan 8(1):221 35 9405759
Lee JG, Leung JW, Baillie J, et al Benign, dysplastic, or malignant--making sense of endoscopic bile duct brush cytology: results in 149 consecutive patients Am J Gastroenterol 1995 May 90(5):722 6 7733076
Lee MG, Lee HJ, Kim MH, et al Extrahepatic biliary diseases: 3D MR cholangiopancreatography compared with endoscopic retrograde cholangiopancreatography Radiology 1997 Mar 202(3):663 9 9051013
Leese T, Neoptolemos JP, Baker AR, et al Management of acute cholangitis and the impact of endoscopic sphincterotomy Br J Surg 1986 Dec 73(12):988 92 3790964
Lehman GA, Sherman S, Nisi R, et al Pancreas divisum: results of minor papilla sphincterotomy Gastrointest Endosc 1993 Jan-Feb 39(1):1 8 8454127
Lehman GA, Sherman S Diagnosis and therapy of pancreas divisum Gastrointest Endosc Clin N Am 1998 Jan 8(1):55 77 9405751
Lehman GA, Sherman S Sphincter of Oddi dysfunction Int J Pancratol 1996 20(1):11 25
Leung JWC, Emergy R, Cotton PB, et al. Management of malignant obstructive jaundice at the Middlesex hospital. Br J Surg. 1983;70:584-6. [pmid: 6626917].
Libera ED, Siqueira ES, Morais M, et al Pancreatic pseudocysts transpapillary and transmural drainage HPB Surg 2000 11(5):333 8 10674749
Lilly MC, Arregui ME A balanced approach to choledocholithiasis Surg Endosc 2001 May 15(5):467 72 11353963
Lin OS, Soetikno RM, Young HS The utility of liver function test abnormalities concomitant with biliary symptoms in predicting a favorable response to endoscopic sphincterotomy in patients with presumed sphincter of Oddi dysfunction Am J Gastroenterol 1998 93(10):1833 6 9772040
Liu CL, Lo CM, Chan JK, et al EUS for detection of occult cholelithiasis in patients with idiopathic pancreatitis Gastrointest Endosc 2000 Jan 51(1):28 32 10625791
Liu CL, Lo CM, Fan ST Acute biliary pancreatitis: diagnosis and management World J Surg 1997 Feb 21(2):149 54 8995070
Liu CL, Lo CM, Lai EC, et al Endoscopic retrograde cholangiopancreatography and endoscopic endoprosthesis insertion in patients with Klatskin tumors Arch Surg 1998 Mar 133(3):293 6 9517743
Liu TH, Consorti ET, Kawashima A, et al Patient evaluation and management with selective use of magnetic resonance cholangiography and endoscopic retrograde cholangiopancreatography before laparoscopic cholecystectomy Ann Surg 2001 Jul 234(1):33 40 11420481 1421945
Liu TH, Consorti ET, Kawashima A, et al The efficacy of magnetic resonance cholangiography for the evaluation of patients with suspected choledocholithiasis before laparoscopic cholecystectomy Am J Surg 1999 Dec 178(6):480 4 10670857
Lo CY, Lai ECS, Lo CM, et al Endoscopic sphincterotomy: 7-year experience World J Surg 1997 21(1):67 71 8943180
Lobo DN, Balfour TW, Iftikhar SY, et al Periampullary diverticula and pancreaticobiliary disease Br J Surg 1999 May 86(5):588 97 10361174
Lobo DN, Balfour TW, Iftikhar SY Periampullary diverticula: consequences of failed ERCP Ann R Coll Surg Engl 1998 Sep 80(5):326 31 9849331
LoGiudice JA, Geenen JE, Hogan WJ, et al Efficacy of the morphine-prostigmin test for evaluating patients with suspected papillary stenosis Dig Dis Sci 1979 Jun 24(6):455 8 456230
Logrono R, Kurtycz DF, Molina CP, et al Analysis of false-negative diagnoses on endoscopic brush cytology of biliary and pancreatic duct strictures: the experience at 2 university hospitals Arch Pathol Lab Med 2000 Mar 124(3):387 92 10705391
Lokich JJ, Kane RA, Harrison DA, et al Biliary tract obstruction secondary to cancer: management guidelines and selected literature review J Clin Oncol 1987 Jun 5(6):969 81 3295131
Lomanto D, Pavone P, Laghi A, et al Magnetic resonance-cholangiopancreatography in the diagnosis of biliopancreatic diseases Am J Surg 1997 Jul 174(1):33 8 9240949
Lomas DJ, Bearcroft PW, Gimson AE MR cholangiopancreatography: prospective comparison of a breath-hold 2D projection technique with diagnostic ERCP Eur Radiol 1999 9(7):1411 7 10460385
Loperfido S, Angelini G, Benedetti G, et al Major early complications from diagnostic and therapeutic ERCP: a prospective multicenter study Gastrointest Endosc 1998 Jul 48(1):1 10 9684657
Lygidakis NJ, van der Heyde MN, Lubbers MJ Evaluation of preoperative biliary drainage in the surgical management of pancreatic head carcinoma Acta Chir Scand 1987 Nov-Dec 153(11-12):665 8 3434110
Lygidakis NJ Surgical approaches to recurrent choledocholithiasis. Choledochoduodenostomy versus T-tube drainage after choledochotomy Am J Surg 1983 May 145(5):636 9 6846703
Macaulay SE, Schulte SJ, Sekijima JH, et al Evaluation of a non-breath-hold MR cholangiography technique Radiology 1995 Jul 196(1):227 32 7784572
Macken E, Drijkoningen M, Van Aken E, et al Brush cytology of ductal strictures during ERCP Acta Gastroenterol Belg 2000 Jul-Sep 63(3):254 9 11189981
Mackie CR, Cooper MJ, Lewis MH, et al Non-operative differentiation between pancreatic cancer and chronic pancreatitis Ann Surg 1979 Apr 189(4):480 7 443902 1397264
Mackie CR, Dhorajiwala J, Blackstone MO, et al Value of new diagnostic aids in relation to the disease process in pancreatic cancer Lancet 1979 Aug 25 2(8139):385 9
Madacsy L, Middelfart HV, Matzen P, et al Quantitative hepatobiliary scintigraphy and endoscopic sphincter of Oddi manometry in patients with suspected sphincter of Oddi dysfunction: Assessment of flow-pressure relationship in the biliary tract Eur J Gastroenterol Hepatol 2000 12(7):777 786 10929906
Madura JA Pancreas divisum: stenosis of the dorsally dominant pancreatic duct. A surgically correctable lesion Am J Surg 1986 Jun 151(6):742 5 3717505
Madura JA, Fiore AC, O'Connor KW, et al Pancreas divisum. Detection and management Am Surg 1985 Jun 51(6):353 7 3994178
Madura JA, McCammon RL, Paris JM, et al The Nardi test and biliary manometry in the diagnosis of pancreaticobiliary sphincter dysfunction Surgery 1981 90(4):588 595 7280999
Maes B, Hastier P, Buckley MJ, et al Extensive aetiological investigations in acute pancreatitis: results of a 1-year prospective study Eur J Gastroenterol Hepatol 1999 Aug 11(8):891 6 10514123
Magnuson TH, Bender JS, Duncan MD, et al Utility of magnetic resonance cholangiography in the evaluation of biliary obstruction J Am Coll Surg 1999 Jul 189(1):63 71 10401742
Maldonado ME, Brady PG, Mamel JJ, et al Incidence of pancreatitis in patients undergoing sphincter of Oddi manometry (SOM) Am J Gastroenterol 1999 Feb 94(2):387 90 10022634
Malfertheiner P, Buchler M. Indications for endoscopic or surgical therapy in chronic pancreatitis. Endoscopy. 1991;23:185-190. [pmid: 1830549].
Malka D, Hammel P, Vilgrain V, et al Chronic obstructive pancreatitis due to a pancreatic cyst in a patient with autosomal dominant polycystic kidney disease Gut 1998 42(1):131 134 9505899 1726968
Mallery S, Van Dam J Interventional endoscopic ultrasonography: current status and future direction J Clin Gastroenterol 1999 Dec 29(4):297 305 10599631
Manfredi R, Costamagna G, Brizi MG, et al Pancreas divisum and "santorinicele": diagnosis with dynamic MR cholangiopancreatography with secretin stimulation Radiology 2000 Nov 217(2):403 8 11058635
Mansfield JC, Griffin SM, Wadehra V, et al A prospective evaluation of cytology from biliary strictures Gut 1997 May 40(5):671 7 9203949 1027173
Marotta F, Hada R, Morello P, et al ERCP in the assessment of patients with post-cholecystectomy syndrome: benefits and limitations Neth J Med 1989 Dec 35(5-6):232 40 2635283
Marshall JB Acute pancreatitis. A review with an emphasis on new developments Arch Intern Med 1993 May 24 153(10):1185 98 8494472
Martin EW, Catalano P, Cooperman M, et al Surgical decision-making in the treatment of pancreatic pseudocysts. Internal versus external drainage Am J Surg 1979 Dec 138(6):821 4 507299
Masci E, Toti G, Mariani A, et al Complications of diagnostic and therapeutic ERCP: a prospective multicenter study Am J Gastroenterol 2001 Feb 96(2):417 23 11232684
Masetti R, Antinori A, Coppola R, et al Choledochocele: changing trends in diagnosis and management Surg Today 1996 26(4):281 5 8727951
Masui T, Takehara Y, Ichijo K, et al Evaluation of the pancreas: a comparison of single thick-slice MR cholangiopancreatography with multiple thin-slice volume reconstruction MR cholangiopancreatography AJR Am J Roentgenol 1999 Dec 173(6):1519 26 10584795
Materne R, Van Beers BE, Gigot JF, et al Extrahepatic biliary obstruction: magnetic resonance imaging compared with endoscopic ultrasonography Endoscopy 2000 Jan 32(1):3 9 10691265
Mathur SK, Soonawalla ZF, Shah SR, et al Role of biliary scintiscan in predicting the need for cholangiography Br J Surg 2000 Feb 87(2):181 5 10671924
Matos C, Nicaise N, Metens T, et al Secretin-enhanced MR pancreatography Semin Ultrasound CT MR 1999 Oct 20(5):340 51 10527139
Matsuda Y, Shimakura K, Akamatsu T Factors affecting the patency of stents in malignant biliary obstructive disease: Univariate and multivariate analysis Am J Gastroenterol 1991 86(7):843 849 2058626
Matsumoto S, Harada H, Tanaka J, et al Evaluation of cytology and tumor markers of pure pancreatic juice for the diagnosis of pancreatic cancer at early stages Pancreas 1994 Nov 9(6):741 7 7846018
Matzen P, Haubek A, Holst-Christensen J, et al Accuracy of direct cholangiography by endoscopic or transhepatic route in jaundice--a prospective study Gastroenterology 1981 Aug 81(2):237 41 7239132
Matzen P, Malchow-Moller A, Lejerstofte J, et al Endoscopic retrograde cholangiopancreatography and transhepatic cholangiography in patients with suspected obstructive jaundice. A randomized study Scand J Gastroenterol 1982 Sep 17(6):731 5 6760376
Mavrogiannis C, Liatsos C, Romanos A, et al Needle-knife fistulotomy versus needle-knife precut papillotomy for the treatment of common bile duct stones Gastrointest Endosc 1999 Sep 50(3):334 9 10462652
May GR, Cotton PB, Edmunds SE, et al Removal of stones from the bile duct at ERCP without sphincterotomy Gastrointest Endosc 1993 Nov-Dec 39(6):749 54 8293895
McCarthy J, Geenen JE, Hogan WJ Preliminary experience with endoscopic stent placement in benign pancreatic diseases Gastrointest Endosc 1988 Jan-Feb 34(1):16 8 3350298
McGuire DE, Venu RP, Brown RD, et al Brush cytology for pancreatic carcinoma: an analysis of factors influencing results Gastrointest Endosc 1996 Sep 44(3):300 4 8885350
McPherson GA, Benjamin IS, Hodgson JH, et al. Pre-operative percutaneous transhepatic biliary drainage: the results of a controlled trial. Br J Surg. 1984;71:(371-375. [pmid: 6372935].
Meakem TJ, Schnall MD Magnetic resonance cholangiography Gastroenterol Clin North Am 1995 Jun 24(2):221 38 7642242
Meguid A, Scheeres DE, Mellinger JD Endoscopic retrograde cholangiopancreatography in a general surgery training program Am Surg 1998 Jul 64(7):622 5 9655271
Mehta SN, Pavone E, Barkun JS, et al Predictors of post-ERCP complications in patients with suspected choledocholithiasis Endoscopy 1998 Jun 30(5):457 63 9693893
Memon MA, Hassaballa H, Memon MI Laparoscopic common bile duct exploration: the past, the present, and the future Am J Surg 2000 Apr 179(4):309 15 10875992
Mendler MH, Bouillet P, Sautereau D, et al Value of MR cholangiography in the diagnosis of obstructive diseases of the biliary tree: a study of 58 cases Am J Gastroenterol 1998 Dec 93(12):2482 90 9860413
Menezes N, Marson LP, Debeaux AC, et al Prospective analysis of a scoring system to predict choledocholithiasis Br J Surg 2000 Sep 87(9):1176 81 10971424
Menzel J, Poremba C, Dietl KH, et al Tumors of the papilla of Vater--inadequate diagnostic impact of endoscopic forceps biopsies taken prior to and following sphincterotomy Ann Oncol 1999 Oct 10(10):1227 31 10586341
Mergener K, Baillie J Endoscopic treatment for acute biliary pancreatitis. When and in whom? Gastroenterol Clin North Am 1999 Sep 28(3):601 13, ix 10503139
Meyer C, Le JV, Rohr S, et al Management of common bile duct stones by laparoscopic cholecystectomy and endoscopic sphincterotomy: pre-, per- or postoperative sphincterotomy? Dig Surg 1999 16(1):26 31 9949264
Millar AJ, Rode H, Stunden RJ, et al Management of pancreatic pseudocysts in children J Pediatr Surg 1988 Feb 23(2):122 7 3343644
Millat B, Borie F, Decker G Treatment of choledocholithiasis: therapeutic ERCP versus peroperative extraction during laparoscopic cholecystectomy Acta Gastroenterol Belg 2000 Jul-Sep 63(3):301 3 11189996
Millat B, Borie F, Fingerhut A Prospective trials in laparoscopic bile duct exploration Semin Laparosc Surg 2000 Dec 7(4):279 87 11323764
Misra SP, Dwivedi M Endoscopic management of choledocholithiasis: to cut, stretch or relax? J Gastroenterol Hepatol 1998 Dec 13(12):1180 2 9918422
Miyazaki T, Yamashita Y, Tang Y, et al Single-shot MR cholangiopancreatography of neonates, infants, and young children AJR Am J Roentgenol 1998 Jan 170(1):33 7 9423593
Mohandas KM, Swaroop VS, Gullar SU, et al Diagnosis of malignant obstructive jaundice by bile cytology: results improved by dilating the bile duct strictures Gastrointest Endosc 1994 Mar-Apr 40(2 Pt 1):150 4 8013812
Montariol T, Msika S, Charlier A, et al Diagnosis of asymptomatic common bile duct stones: preoperative endoscopic ultrasonography versus intraoperative cholangiography--a multicenter, prospective controlled study. French Associations for Surgical Research Surgery 1998 Jul 124(1):6 13 9663245
Moossa AR, Levin B The diagnosis of "early" pancreatic cancer: the University of Chicago experience Cancer 1981 Mar 15 47(6 Suppl):1688 97
Moossa AR Investigative approaches to the problem of pancreatic cancer Ann R Coll Surg Engl 1979 Mar 61(2):100 6 434747
Moreaux J Traditional surgical management of common bile duct stones: a prospective study during a 20-year experience Am J Surg 1995 Feb 169(2):220 6 7840384
Morgan DE, Logan K, Baron TH, et al Pancreas divisum: implications for diagnostic and therapeutic pancreatography AJR Am J Roentgenol 1999 Jul 173(1):193 8 10397125
Mori K, Nagakawa T, Ohta T, et al Acute pancreatitis associated with anomalous union of the pancreaticobiliary ductal system J Clin Gastroenterol 1991 Dec 13(6):673 7 1761840
Morrin MM, Farrell RJ, McEntee G, et al. MR cholangiopancreatography of pancreaticobiliary diseases: Comparison of single-shot RARE and multislice HASTE sequences. Clin Radiol. 2000;55:866-873. [pmid: 11069743].
Morrow CE, Cohen JI, Sutherland DE, et al Chronic pancreatitis: long-term surgical results of pancreatic duct drainage, pancreatic resection, and near-total pancreatectomy and islet autotransplantation Surgery 1984 Oct 96(4):608 16 6435270
Moss AA, Federle M, Shapiro HA, et al The combined use of computed tomography and endoscopic retrograde cholangiopancreatography in the assessment of suspected pancreatic neoplasm: a blind clinical evaluation Radiology 1980 Jan 134(1):159 63 6985736
Motte S, Deviere J, Dumonceau JM, et al Risk factors for septicemia following endoscopic biliary stenting Gastroenterology 1991 Nov 101(5):1374 81 1936809
Mujica VR, Barkin JS, Go VL Acute pancreatitis secondary to pancreatic carcinoma. Study Group Participants Pancreas 2000 Nov 21(4):329 32 11075985
Mukai H, Yasuda K, Nakajima M Differential diagnosis of mucin-producing tumors of the pancreas by intraductal ultrasonography and peroral pancreatoscopy Endoscopy 1998 Aug 30Suppl 1:A99 102
Mullens JE Endoscopic retrograde cholangiopancreatography (ERCP) in the diagnosis of chronic pancreatitis Surgery 1978 Sep 84(3):308 12 684622
Murison MS, Gartell PC, McGinn FP Does selective peroperative cholangiography result in missed common bile duct stones? J R Coll Surg Edinb 1993 Aug 38(4):220 4 7693932
Musella M, Barbalace G, Capparelli G, et al Magnetic resonance imaging in evaluation of the common bile duct Br J Surg 1998 Jan 85(1):16 9 9462374
Nagai N, Greenway CD, Shah SM, et al Nonsurgical diagnosis of pancreatic mass South Med J 1980 Apr 73(4):467 72 7367939
Nakaizumi A, Tatsuta M, Uehara H, et al Effectiveness of the cytologic examination of pure pancreatic juice in the diagnosis of early neoplasia of the pancreas Cancer 1995 Sep 1 76(5):750 7
Nakaizumi A, Tatsuta M, Uehara H, et al Usefulness of simple endoscopic aspiration cytology of pancreatic juice for diagnosis of early pancreatic neoplasm. A prospective study Dig Dis Sci 1997 Aug 42(8):1796 803 9286251
Nakaizumi A, Uehara H, Takenaka A, et al Diagnosis of pancreatic cancer by cytology and measurement of oncogene and tumor markers in pure pancreatic juice aspirated by endoscopy Hepatogastroenterology 1999 Jan-Feb 46(25):31 7 10228761
Nakamura R, Machado R, Amikura K, et al Role of fine needle aspiration cytology and endoscopic biopsy in the preoperative assessment of pancreatic and peripancreatic malignancies Int J Pancreatol 1994 Aug 16(1):17 21 7806910
Nattermann C, Goldschmidt AJ, Dancygier H Endosonography in chronic pancreatitis--a comparison between endoscopic retrograde pancreatography and endoscopic ultrasonography Endoscopy 1993 Nov 25(9):565 70 8119205
Nealon WH, Townsend CM, Thompson JC Preoperative endoscopic retrograde cholangiopancreatography (ERCP) in patients with pancreatic pseudocyst associated with resolving acute and chronic pancreatitis Ann Surg 1989 May 209(5):532 8 2705818 1494080
Nebel OT, Silvis SE, Rogers G, et al Complications associated with endoscopic retrograde cholangiopancreatography. Results of the 1974 A/S/G/E survey Gastrointest Endosc 1975 22(1):34 36 1205101
Neblett WW, O'Neill JA Surgical management of recurrent pancreatitis in children with pancreas divisum Ann Surg 2000 Jun 231(6):899 908 10816634 1421080
Neitlich JD, Topazian M, Smith RC, et al Detection of choledocholithiasis: comparison of unenhanced helical CT and endoscopic retrograde cholangiopancreatography Radiology 1997 Jun 203(3):753 7 9169700
Nelsen KM, Kastan DJ, Shetty PC, et al Utilization pattern and efficacy of nonsurgical techniques to establish drainage for high biliary obstruction J Vasc Interv Radiol 1996 Sep-Oct 7(5):751 6 8897346
Nelson DB, Freeman ML Major hemorrhage from endoscopic sphincterotomy: Risk factor analysis J Clin Gastroenterol 1994 19(4):283 287 7876506
Neoptolemos JP, Bailey IS, Carr-Locke DL Sphincter of Oddi dysfunction: results of treatment by endoscopic sphincterotomy Br J Surg 1988 May 75(5):454 9 3390677
Neoptolemos JP, Carr-Locke DL, London NJ, et al Controlled trial of urgent endoscopic retrograde cholangiopancreatography and endoscopic sphincterotomy versus conservative treatment for acute pancreatitis due to gallstones Lancet 1988 Oct 29 2(8618):979 83
Neoptolemos JP, London N, Slater ND, et al A prospective study of ERCP and endoscopic sphincterotomy in the diagnosis and treatment of gallstone acute pancreatitis. A rational and safe approach to management Arch Surg 1986 Jun 121(6):697 702 3518661
Neoptolemos JP, Shaw DE, Carr-Locke DL A multivariate analysis of preoperative risk factors in patients with common bile duct stones. Implications for treatment Ann Surg 1989 Feb 209(2):157 61 2916860 1493909
Neri E, Caramella D, Boraschi P, et al Magnetic resonance virtual endoscopy of the common bile duct stones Surgical Endoscopy (Surg. Endosc.) 1999 13(6):632 633 137251
Neuhaus H, Zillinger C, Born P, et al Randomized study of intracorporeal laser lithotripsy versus extracorporeal shock-wave lithotripsy for difficult bile duct stones Gastrointest Endosc 1998 May 47(5):327 34 9609422
Ng T, Amaral JF Timing of endoscopic retrograde cholangiopancreatography and laparoscopic cholecystectomy in the treatment of choledocholithiasis J Laparoendosc Adv Surg Tech A 1999 Feb 9(1):31 7 10194690
Ng WW, Lai KH, Tam TN, et al Palliation of malignant biliary obstruction with nasobiliary drainage prior to endoscopic stenting Adv Ther 1997 14(1):21 26
Niederau C, Grendell JH Diagnosis of pancreatic carcinoma. Imaging techniques and tumor markers Pancreas 1992 7(1):66 86 1557348
Nitsche R, Folsch UR, Ludtke R, et al Urgent ERCP in all cases of acute biliary pancreatitis? A prospective randomized multicenter study Eur J Med Res 1995 Dec 18 1(3):127 31
Nix GA, Schmitz PI, Wilson JH, et al Carcinoma of the head of the pancreas. Therapeutic implications of endoscopic retrograde cholangiopancreatography findings Gastroenterology 1984 Jul 87(1):37 43 6202585
Nix GA, Schmitz PI Diagnostic features of chronic pancreatitis distal to benign and to malignant pancreatic duct obstruction Diagn Imaging 1981 50(3):130 7 7261853
Nix GA, Van Overbeeke IC, Wilson JH, et al ERCP diagnosis of tumors in the region of the head of the pancreas. Analysis of criteria and computer-aided diagnosis Dig Dis Sci 1988 May 33(5):577 86 3359911
Noda T, Ohno Y, Oshibuchi T, et al A retrospective study in the diagnosis of 301 jaundiced cases Acta Med Nagasaki 1985 30(1-3):195 203
Norton ID, Clain JE The role of transabdominal ultrasonography, helical computed tomography, and magnetic resonance cholangiopancreatography in diagnosis and management of pancreatic disease Curr Gastroenterol Rep 2000 Apr 2(2):120 4 10981013
Norton ID, Petersen BT Interventional treatment of acute and chronic pancreatitis. Endoscopic procedures Surg Clin North Am 1999 Aug 79(4):895 911, xii 10470334
Norton SA, Alderson D. Endoscopic ultrasonography in the evaluation of idiopathic acute pancreatitis. Br J Surg. 2000;87:1650-1655. [pmid: 11122178].
Norton SA, Alderson D Prospective comparison of endoscopic ultrasonography and endoscopic retrograde cholangiopancreatography in the detection of bile duct stones Br J Surg 1997 Oct 84(10):1366 9 9361590
Novis BH, Bornman PC, Girdwood AW, et al Endoscopic manometry of the pancreatic duct and sphincter zone in patients with chronic pancreatitis Dig Dis Sci 1985 Mar 30(3):225 8 3971834
Novis BH, Narunsky L, Bank S Endoscopic retrograde cholangiopancreatography in the evaluation of pancreatic disease S Afr Med J 1976 Sep 11 50(39):1501 5
Nowak A, Nowakowska-Dulawa E, Marek TE, et al. Final results of the prospective, randomized controlled study on endoscopic sphincterotomy versus conventional management in acute biliary pancreatitis. Gastroenterol. 1995;108.
Obertop H, Gouma DJ Essentials in biliopancreatic staging: a decision analysis Ann Oncol 1999 10Suppl 4:150 2 10436810
Ochi Y, Mukawa K, Kiyosawa K, et al Comparing the treatment outcomes of endoscopic papillary dilation and endoscopic sphincterotomy for removal of bile duct stones J Gastroenterol Hepatol 1999 Jan 14(1):90 6 10029284
Ohara H, Hoshino M Single application extracorporeal shock wave lithotrispy is the first choice for patients with pancreatic duct stones Am J Gastroenterol 1996 91(7):1388 1394 8678001
Ohtsuka T, Inoue K, Ohuchida J, et al Carcinoma arising in choledochocele Endoscopy 2001 Jul 33(7):614 9 11473335
Ohtsuka T, Tanaka M, Inoue K, et al Is peripapillary choledochoduodenal fistula an indication for endoscopic sphincterotomy? Gastrointest Endosc 2001 Mar 53(3):313 317 11231389
Okai T, Watanabe H, Yamaguchi Y, et al EUS and K-ras analysis of pure pancreatic juice collected via a duodenoscope after secretin stimulation for diagnosis of pancreatic mass lesion: a prospective study Gastrointest Endosc 1999 Dec 50(6):797 803 10570339
Onken JE, Brazer SR, Eisen GM, et al Predicting the presence of choledocholithiasis in patients with symptomatic cholelithiasis Am J Gastroenterol 1996 91(4):762 7 8677945
Ono K, Kobayashi S, Sakamoto K, et al A clinical study of acute pancreatitis following endoscopic retrograde cholangiopancreatography Dig Endosc 1997 9(1):38 42
Oren A, Breumelhof R, Timmer R, et al Abnormal clotting parameters before therapeutic ERCP: do they predict major bleeding? Eur J Gastroenterol Hepatol 1999 Oct 11(10):1093 7 10524637
Osnes M, Serck-Hanssen A, Kristensen O, et al Endoscopic retrograde brush cytology in patients with primary and secondary malignancies of the pancreas Gut 1979 Apr 20(4):279 84 447107 1412389
Pace RF, Chamberlain MJ, Passi RB Diagnosing papillary stenosis by technetium-99m HIDA scanning Can J Surg 1983 Mar 26(2):191 3 6825012
Palazzo L, Girollet PP, Salmeron M, et al Value of endoscopic ultrasonography in the diagnosis of common bile duct stones: comparison with surgical exploration and ERCP Gastrointest Endosc 1995 Sep 42(3):225 31 7498687
Pasanen P, Partanen K, Pikkarainen P, et al Complications of endoscopic retrograde cholangiopancreatography in jaundiced and cholestatic patients Ann Chir Gynaecol 1992 81(1):28 31 1622048
Pasanen P, Partanen K, Pikkarainen P, et al Diagnostic accuracy of ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the detection of pancreatic cancer in patients with jaundice or cholestasis In Vivo 1992 May-Jun 6(3):297 301 1391698
Pasanen P, Partanen K, Pikkarainen P, et al Ultrasonography, CT, and ERCP in the diagnosis of choledochal stones Acta Radiol 1992 Jan 33(1):53 6 1731843
Pasanen PA, Eskelinen M, Partanen K, et al A prospective study of the value of imaging, serum markers and their combination in the diagnosis of pancreatic carcinoma in symptomatic patients Anticancer Res 1992 Nov-Dec 12(6B):2309 14 1295478
Pasanen PA, Partanen K, Pikkarainen P, et al A prospective study on the value of ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the diagnosis of unjaundiced cholestasis In Vivo 1994 Mar-Apr 8(2):227 30 7919126
Pasanen PA, Partanen K, Pikkarainen P, et al Diagnostic accuracy of ultrasound, computed tomography, and endoscopic retrograde cholangiopancreatography in the detection of obstructive jaundice Scand J Gastroenterol 1991 Nov 26(11):1157 64 1754851
Pasanen PA, Partanen KP, Pikkarainen PH, et al A comparison of ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the differential diagnosis of benign and malignant jaundice and cholestasis Eur J Surg 1993 Jan 159(1):23 9 8095802
Pasanen PA, Pikkarainen PH, Alhava EM, et al Clinical evaluation and imaging methods in the diagnosis of jaundice and cholestasis Theor Surg 1992 7(4):180 185
Pathak R, Cooperman AM Surgery and pancreas divisum: A dwindling role? Surg Clin North Am 2001 81(2):479 482 11392433
Paul A Diagnosis and treatment of common bile duct stones (CBDS). Results of a consensus development conference. Scientific Committee of the European Association for Endoscopic Surgery (E.A.E.S.) Surg Endosc 1998 Jun 12(6):856 64 9602006
Pavone P, Laghi A, Catalano C, et al MR cholangiopancreatography (MRCP) at 0.5 T: technique optimisation and preliminary results Eur Radiol 1996 6(2):147 52 8797971
Pavone P, Laghi A, Catalano C, et al Non-invasive evaluation of the biliary tree with magnetic resonance cholangiopancreatography: initial clinical experience Ital J Gastroenterol 1996 Feb-Mar 28(2):63 9 8781996
Pedersen FM, Lassen AT, De Muckadell OBS Randomized trial of stent placed above and across the sphincter of Oddi in malignant bile duct obstruction Gastrointest Endosc 1998 48(6):574 579 9852446
Pedersen FM Endoscopic management of malignant biliary obstruction. Is stent size of 10 French gauge better than 7 French gauge? Scand J Gastroenterol 1993 Feb 28(2):185 9 8441913
Peng NJ, Lai KH, Tsay DG, et al Efficacy of quantitative cholescintigraphy in the diagnosis of sphincter of Oddi dysfunction Nucl Med Commun 1994 Nov 15(11):899 904 7870397
Pereira-Lima JC, Jakobs R, Busnello JV, et al The Role of Serum Liver Enzymes in the Diagnosis Ofcholedocholithiasis Hepatogastroenterology 2000 47(36):1522 1525 11148992
Persson B Relation of size and number of common duct calculi to success of sphincterotomy and stone extraction Gastrointest Radiol 1991 Summer 16(3):212 4 1879635
Pezzilli R, Billi P, Barakat B, et al Ultrasonographic evaluation of the common bile duct in biliary acute pancreatitis patients: comparison with endoscopic retrograde cholangiopancreatography J Ultrasound Med 1999 Jun 18(6):391 4 10361843
Pfau PR, Kochman ML Endoscopic management of biliary tract disease Curr Opin Gastroenterol 1999 15(5):448 453 17023988
Phillips EH, Carroll BJ, Pearlstein AR, et al Laparoscopic choledochoscopy and extraction of common bile duct stones World J Surg 1993 Jan-Feb 17(1):22 8 8447135
Pickuth D, Spielmann RP Detection of choledocholithiasis: comparison of unenhanced spiral CT, US, and ERCP Hepatogastroenterology 2000 Nov-Dec 47(36):1514 7 11148990
Pitt HA, Gomes AS, Lois JF, et al. Does preoperative percutaneous biliary drainage reduce operative risk or increase hospital cost?. Ann Surg. 1985;201:(545-553. [pmid: 2986562]. [pmcid: 1250755].
Podolsky I, Kortan P, Haber GB Endoscopic sphincterotomy in outpatients Gastrointest Endosc 1989 35(5):372 376 2792670
Polkowski M, Palucki J, Regula J, et al Helical computed tomographic cholangiography versus endosonography for suspected bile duct stones: a prospective blinded study in non-jaundiced patients Gut 1999 Nov 45(5):744 9 10517914 1727710
Polkowski M, Palucki J, Regula J, et al Helical computed tomographic cholangiography versus endosonography for suspected bile duct stones: a prospective blinded study in non-jaundiced patients Gut 1999 Nov 45(5):744 9 10517914 1727710
Ponchon T, Bory R, Hedelius F, et al. Endoscopic stenting for pain relief in chronic pancreatitis: results of a standardized protocol. Gastrointestinal Endoscopy. 1999;42:(452-456.
Ponchon T, Gagnon P, Berger F, et al Value of endobiliary brush cytology and biopsies for the diagnosis of malignant bile duct stenosis: results of a prospective study Gastrointest Endosc 1995 Dec 42(6):565 72 8674929
Ponsky JL, Duppler DW Endoscopic sphincterotomy and removal of pancreatic duct stones Am Surg 1987 Oct 53(10):613 6 3674609
Prat F, Amouyal G, Amouyal P, et al Prospective controlled study of endoscopic ultrasonography and endoscopic retrograde cholangiography in patients with suspected common-bile duct lithiasis Lancet 1996 Jan 13 347(8994):75 9
Prat F, Chapat O, Ducot B, et al A randomized trial of endoscopic drainage methods for inoperable malignant strictures of the common bile duct Gastrointest Endosc 1998 Jan 47(1):1 7 9468416
Pugliese V, Antonelli G, Vincenti M, et al Endoductal tissue sampling of biliary strictures through endoscopic retrograde cholangiopancreatography (ERCP) Tumori 1997 May-Jun 83(3):698 702 9267491
Pugliese V, Conio M, Nicolo G, et al Endoscopic retrograde forceps biopsy and brush cytology of biliary strictures: a prospective study Gastrointest Endosc 1995 Dec 42(6):520 6 8674921
Rabenstein T, Ruppert T, Schneider HT, et al Benefits and risks of needle-knife papillotomy Gastrointest Endosc 1997 46(3):207 211 9378205
Rabenstein T, Schneider HT, Bulling D, et al. Analysis of the risk factors associated with endoscopic sphincterotomy techniques: Preliminary results of a prospective study, with emphasis on the reduced risk of acute pancreatitis with low-dose anticoagulation treatment. Endoscopy. 2000;32:10-19. [pmid: 10691266].
Raikar GV, Melin MM, Ress A, et al Cost-effective analysis of surgical palliation versus endoscopic stenting in the management of unresectable pancreatic cancer Ann Surg Oncol 1996 Sep 3(5):470 5 8876889
Rao KJ, Varghese NM, Blake H, et al Endoscopic biliary stenting in a district general hospital Gut 1995 Aug 37(2):279 83 7557582 1382732
Rawat B, Loewy J Value of three-dimensional gradient-echo magnetic resonance cholangiography in diagnosing choledocholithiasis Can Assoc Radiol J 1996 Aug 47(4):265 9 8696993
Regan F, Fradin J, Khazan R, et al Choledocholithiasis: evaluation with MR cholangiography AJR Am J Roentgenol 1996 Dec 167(6):1441 5 8956574
Regan F, Schaefer DC, Smith DP, et al The diagnostic utility of HASTE MRI in the evaluation of acute cholecystitis. Half-Fourier acquisition single-shot turbo SE J Comput Assist Tomogr 1998 Jul-Aug 22(4):638 42 9676460
Regan F, Smith D, Khazan R, et al MR cholangiography in biliary obstruction using half-Fourier acquisition J Comput Assist Tomogr 1996 Jul-Aug 20(4):627 32 8708069
Regan F Clinical applications of half-Fourier (HASTE) MR sequences in abdominal imaging Magn Reson Imaging Clin N Am 1999 May 7(2):275 88 10382161
Reinhold C, Taourel P, Bret PM, et al Choledocholithiasis: evaluation of MR cholangiography for diagnosis Radiology 1998 Nov 209(2):435 42 9807570
Rhodes M, Sussman L, Cohen L, et al Randomised trial of laparoscopic exploration of common bile duct versus postoperative endoscopic retrograde cholangiography for common bile duct stones Lancet 1998 Jan 17 351(9097):159 61
Rhodes M, Sussman L, Cohen L, et al Randomised trial of laparoscopic exploration of common bile duct versus postoperative endoscopic retrograde cholangiography for common bile duct stones Lancet 1998 Jan 17 351(9097):159 61
Rieger R, Sulzbacher H, Woisetschlager R, et al Selective use of ERCP in patients undergoing laparoscopic cholecystectomy World J Surg 1994 Nov-Dec 18(6):900 4 7846916
Rieger R, Wayand W Yield of prospective, noninvasive evaluation of the common bile duct combined with selective ERCP/sphincterotomy in 1390 consecutive laparoscopic cholecystectomy patients Gastrointest Endosc 1995 Jul 42(1):6 12 7557180
Rijna H, Borgstein PJ, Meuwissen SG, et al Selective preoperative endoscopic retrograde cholangiopancreatography in laparoscopic biliary surgery Br J Surg 1995 Aug 82(8):1130 3 7648173
Riker A, Libutti SK, Bartlett DL Advances in the early detection, diagnosis, and staging of pancreatic cancer Surg Oncol 1997 Nov 6(3):157 69 9576631
Robertson GS, Jagger C, Johnson PR, et al Selection criteria for preoperative endoscopic retrograde cholangiopancreatography in the laparoscopic era Arch Surg 1996 Jan 131(1):89 94 8546585
Roberts-Thomson IC, Toouli J Abnormal responses to morphine-neostigmine in patients with undefined biliary type pain Gut 1985 26(12):1367 1372 2417918 1433122
Roesch W, Phillip J, Gebhardt CH Endoscopic duct obstruction in chronic pancreatitis Endoscopy 1979 11(1):43 46 428351
Rolny P, Anderberg B, Ihse I, et al Pancreatitis after sphincter of Oddi manometry Gut 1990 31(7):821 824 2370018 1378544
Rolny P. Endoscopic bile duct stent placement as a predictor of outcome following endoscopic sphincterotomy in patients with suspected sphincter of Oddi dysfunction. Euro J Gastroenterol Hepatol. 1997;9:(467-471.
Rosch T, Lorenz R, Braig C, et al Endoscopic ultrasound in pancreatic tumor diagnosis Gastrointest Endosc 1991 May-Jun 37(3):347 52 2070987
Rosch T, Schusdziarra V, Born P, et al Modern imaging methods versus clinical assessment in the evaluation of hospital in-patients with suspected pancreatic disease Am J Gastroenterol 2000 Sep 95(9):2261 70 11007227
Rosseland AR, Solhaug JH Early or delayed endoscopic papillotomy (EPT) in gallstone pancreatitis Ann Surg 1984 Feb 199(2):165 7 6696531 1353326
Roston AD, Jacobson IM Evaluation of the pattern of liver tests and yield of cholangiography in symptomatic choledocholithiasis: a prospective study Gastrointest Endosc 1997 May 45(5):394 9 9165321
Rothschild JG, Kaplan MM, Millan VG, et al Management of biliary obstruction. A comparison of percutaneous, endoscopic, and operative techniques Arch Surg 1989 May 124(5):556 9 2653278
Rupp N, Kramann B, Gullotta U, et al Biliary drainage by teflon endoprosthesis in obstructive jaundice--experiences in 69 patients treated by PTCD or ERCD Eur J Radiol 1983 Feb 3(1):42 50 6840105
Ruppin H, Amon R, Ettl W, et al Acute pancreatitis after endoscopic/radiological pancreaticography (ERP) Endoscopy 1974 6(2):94 98
Ryan ME Cytologic brushings of ductal lesions during ERCP Gastrointest Endosc 1991 Mar-Apr 37(2):139 42 1851708
Ryan ME, Baldauf MC Comparison of flow cytometry for DNA content and brush cytology for detection of malignancy in pancreaticobiliary strictures Gastrointest Endosc 1994 Mar-Apr 40(2 Pt 1):133 9 8013809
Sahai AV, Zimmerman M, Aabakken L, et al Prospective assessment of the ability of endoscopic ultrasound to diagnose, exclude, or establish the severity of chronic pancreatitis found by endoscopic retrograde cholangiopancreatography Gastrointest Endosc 1998 Jul 48(1):18 25 9684659
Sandy JT, Taylor RH, Christensen RM, et al Pancreatic pseudocyst. Changing concepts in management Am J Surg 1981 May 141(5):574 6 7223950
Santucci L, Natalini G, Sarpi L, et al Selective endoscopic retrograde cholangiography and preoperative bile duct stone removal in patients scheduled for laparoscopic cholecystectomy: a prospective study Am J Gastroenterol 1996 Jul 91(7):1326 30 8677988
Santucci L, Natalini G, Sarpi L, et al Selective endoscopic retrograde cholangiography and preoperative bile duct stone removal in patients scheduled for laparoscopic cholecystectomy: a prospective study Am J Gastroenterol 1996 Jul 91(7):1326 30 8677988
Sarli L, Costi R, Gobbi S, et al Asymptomatic bile duct stones: selection criteria for intravenous cholangiography and/or endoscopic retrograde cholangiography prior to laparoscopic cholecystectomy Eur J Gastroenterol Hepatol 2000 Nov 12(11):1175 80 11111772
Satterfield ST, McCarthy JH, Geenen JE, et al Clinical experience in 82 patients with pancreas divisum: preliminary results of manometry and endoscopic therapy Pancreas 1988 3(3):248 53 3387418
Sauter G, Grabein B, Huber G, et al Antibiotic prophylaxis of infectious complications with endoscopic retrograde cholangiopancreatography. A randomized controlled study Endoscopy 1990 Jul 22(4):164 7 2209498
Sbeih F, Aljohani M, Altraif I, et al Role of endoscopic retrograde cholangiopancreatography before and after laparoscopic cholecystectomy Ann Saudi Med 1998 18(2):117 119 17341940
Scheurer U Acute pancreatitis: ERCP and papillotomy Dig Surg 11(3-6):226 230
Schlup MM, Williams SM, Barbezat GO ERCP: a review of technical competency and workload in a small unit Gastrointest Endosc 1997 Jul 46(1):48 52 9260705
Schmassmann A, Von Gunten E, Knuchel J, et al Wallstents versus plastic stents in malignant biliary obstruction: Effects of stent patency of the first and second stent on patient compliance and survival Am J Gastroenterol 1996 91(4):654 659 8677925
Schneider HT, May A Piezoelectric shock wave lithotripsy of pancreatic duct stones Am J Gastroenterol 1994 89(11):2042 2048 7942733
Schoefl R, Haefner M, Wrba F, et al Forceps biopsy and brush cytology during endoscopic retrograde cholangiopancreatography for the diagnosis of biliary stenoses Scand J Gastroenterol 1997 Apr 32(4):363 8 9140159
Schoeman MN, Huibregtse K Pancreatic and ampullary carcinoma Gastrointest Endosc Clin N Am 1995 Jan 5(1):217 36 7728345
Schreiber F, Gurakuqi GC, Pristautz H, et al Sonographically-guided extracorporeal shockwave lithotripsy for pancreatic stones in patients with chronic pancreatitis J Gastroenterol Hepatol 1996 Mar 11(3):247 51 8742921
Schumacher B, Frieling T, Haussinger D, et al Endoscopic treatment of symptomatic choledocholithiasis Hepatogastroenterology 1998 May-Jun 45(21):672 6 9684115
Schutte H, Yarmuch J, Latorre R, et al Endoscopic bile duct stone removal prior to laparoscopic cholecystectomy J Laparoendosc Surg 1994 Jun 4(3):191 7 7919507
Schutz SM, Abbott RM Grading ERCPs by degree of difficulty: a new concept to produce more meaningful outcome data Gastrointest Endosc 2000 May 51(5):535 9 10805837
Schwacha H, Allgaier HP, Deibert P, et al A sphincterotome-based technique for selective transpapillary common bile duct cannulation Gastrointest Endosc 2000 Sep 52(3):387 91 10968855
Scudera PL, Koizumi J, Jacobson IM Brush cytology evaluation of lesions encountered during ERCP Gastrointest Endosc 1990 May-Jun 36(3):281 4 2163940
Sears RJ, Duckworth CW, Decaestecker C, et al Image cytometry as a discriminatory tool for cytologic specimens obtained by endoscopic retrograde cholangiopancreatography Cancer 1998 Apr 25 84(2):119 26
Sees DW, Martin RR Comparison of preoperative endoscopic retrograde cholangiopancreatography and laparoscopic cholecystectomy with operative management of gallstone pancreatitis Am J Surg 1997 Dec 174(6):719 22 9409604
Seifert E Endoscopic retrograde cholangiopancreatography. Evaluation based on experience with 805 examinations Am J Gastroenterol 1977 Dec 68(6):542 9 612209
Seki K, Suda T, Aoyagi Y, et al Diagnosis of pancreatic adenocarcinoma by detection of human telomerase reverse transcriptase messenger RNA in pancreatic juice with sample qualification Clin Cancer Res 2001 Jul 7(7):1976 81 11448913
Semelka RC, Kroeker MA, Shoenut JP, et al Pancreatic disease: prospective comparison of CT, ERCP, and 1.5-T MR imaging with dynamic gadolinium enhancement and fat suppression Radiology 1991 Dec 181(3):785 91 1947098
Sewnath ME, Birjmohun RS, Rauws EA, et al The effect of preoperative biliary drainage on postoperative complications after pancreaticoduodenectomy J Am Coll Surg 2001 Jun 192(6):726 34 11400966
Shah RJ, Martin SP Endoscopic retrograde cholangiopancreatography in the diagnosis and management of pancreatic diseases Curr Gastroenterol Rep 2000 Apr 2(2):133 45 10981015
Shahmir M, Schuman BM Complications of fiberoptic endoscopy Gastrointest Endosc 1980 Aug 26(3):86 91 6998829
Sharma VK, Howden CW Metaanalysis of randomized controlled trials of endoscopic retrograde cholangiography and endoscopic sphincterotomy for the treatment of acute biliary pancreatitis Am J Gastroenterol 1999 Nov 94(11):3211 4 10566716
Sherman S Endoscopic drainage of malignant hilar obstruction: Is one biliary stent enough or should we work to place two? Gastrointest Endosc 2001 53(6):681 4 11323609
Shepherd HA, Royle G, Ross APR, et al. Endoscopic biliary endoprosthesis in the palliation of malignant obstruction of the distal common bile duct: a randomized trial. Br J Surg. 1988;75:1166-8. [pmid: 2466520].
Sherman S, Troiano FP, Hawes RH, et al Frequency of abnormal sphincter of Oddi manometry compared with the clinical suspicion of sphincter of Oddi dysfunction Am J Gastroenterol 1991 May 86(5):586 90 2028949
Sherman S, Lehman G, Jamidar P Efficacy of endoscopic sphincterotomy and surgical sphincteroplasty for patients with sphincter of Oddi dysfunction (SOD): randomized, controlled study Gastrointest Endosc 1994 40(2 of 2):
Sherman S, Hawes RH, Savides TJ, et al Stent-induced pancreatic ductal and parenchymal changes: correlation of endoscopic ultrasound with ERCP Gastrointest Endosc 1996 Sep 44(3):276 82 8885346
Sherman S, Lehman GA, Hawes RH, et al Pancreatic ductal stones: frequency of successful endoscopic removal and improvement in symptoms Gastrointest Endosc 1991 Sep-Oct 37(5):511 7 1936826
Sherman S, Lehman GA Endoscopic therapy of pancreatic disease Gastroenterologist 1997 Dec 5(4):262 77 9436003
Sherman S, Ruffolo TA, Hawes RH, et al Complications of endoscopic sphincterotomy. A prospective series with emphasis on the increased risk associated with sphincter of Oddi dysfunction and nondilated bile ducts Gastroenterology 1991 Oct 101(4):1068 75 1889699
Sherman S, Troiano FP, Hawes RH, et al Frequency of abnormal sphincter of Oddi manometry compared with the clinical suspicion of sphincter of Oddi dysfunction Am J Gastroenterol 1991 May 86(5):586 90 2028949
Shim CS, Joo JH, Park CW, et al Effectiveness of endoscopic ultrasonography in the diagnosis of choledocholithiasis prior to laparoscopic cholecystectomy Endoscopy 1995 Aug 27(6):428 32 8549439
Siegel JH, Cooperman AM, Pullano W, et al Pancreas divisum: observation, endoscopic drainage, and surgical treatment results in 65 patients Surg Laparosc Endosc 1993 Aug 3(4):281 5 8269244
Siegel JH, Rodriquez R, Cohen SA, et al Endoscopic management of cholangitis: critical review of an alternative technique and report of a large series Am J Gastroenterol 1994 Aug 89(8):1142 6 8053424
Siegel JH, Veerappan A, Tucker R Bipolar versus monopolar sphincterotomy: a prospective trial Am J Gastroenterol 1994 Oct 89(10):1827 30 7942676
Siegman-Igra Y, Spinrad S, Rattan J Septic complications following endoscopic retrograde cholangiopancreatography: the experience in Tel Aviv Medical Center J Hosp Infect 1988 Jul 12(1):7 12 2905378
Smith AC, Dowsett JF, Russell RC, et al Randomised trial of endoscopic stenting versus surgical bypass in malignant low bile duct obstruction Lancet 1994 Dec 17 344(8938):1655 60
Smith AC, Dowsett JS, Hattfield ARW, et al. Prospective randomized trial of bypass surgery versus endoscopic stenting in patients with malignant obstructive jaundice. Gut. 1989;30. (abstract).
Smith M, Sherman S Alterations in pancreatic ductal morphology following polyethylene pancreatic stent therapy Gastrointest Endosc 1996 44(3):268 75 8885345
Smithline A, Silverman W, Rogers D et al Effect of prophylactic main pancreatic duct stenting on the incidence of biliary endoscopic sphincertotomy-induced pancreatitis in high-risk patients Gastrointestinal Endoscopy 1993 39(5)):652 7 8224687
Smits ME, Badiga SM, Rauws EA, et al Long-term results of pancreatic stents in chronic pancreatitis Gastrointest Endosc 1995 Nov 42(5):461 7 8566639
Smits ME, Rauws EA, Tytgat GN, et al Endoscopic treatment of pancreatic stones in patients with chronic pancreatitis Gastrointest Endosc 1996 Jun 43(6):556 60 8781932
Snady H, Cooperman A, Siegel J Endoscopic ultrasonography compared with computed tomography with ERCP in patients with obstructive jaundice or small peri-pancreatic mass Gastrointest Endosc 1992 Jan-Feb 38(1):27 34 1612375
Songur Y, Oguz D, Gurkaynak G, et al Endoscopic ultrasonography and endoscopic retrograde pancreatography in the diagnosis of chronic pancreatitis Dig Endosc 2000 12(1):37 41
Sostre S, Kalloo AN, Spiegler EJ, et al A noninvasive test of sphincter of Oddi dysfunction in postcholecystectomy patients: the scintigraphic score J Nucl Med 1992 Jun 33(6):1216 22 1597742
Soto JA, Alvarez O, Munera F, et al Diagnosing bile duct stones: comparison of unenhanced helical CT, oral contrast-enhanced CT cholangiography, and MR cholangiography AJR Am J Roentgenol 2000 Oct 175(4):1127 34 11000177
Soto JA, Barish MA, Alvarez O, et al Detection of choledocholithiasis with MR cholangiography: comparison of three-dimensional fast spin-echo and single- and multisection half-Fourier rapid acquisition with relaxation enhancement sequences Radiology 2000 Jun 215(3):737 45 10831692
Soto JA, Barish MA, Yucel EK, et al Magnetic resonance cholangiography: comparison with endoscopic retrograde cholangiopancreatography Gastroenterology 1996 Feb 110(2):589 97 8566608
Soto JA, Barish MA, Yucel EK, et al Pancreatic duct: MR cholangiopancreatography with a three-dimensional fast spin-echo technique Radiology 1995 Aug 196(2):459 64 7617861
Soto JA, Velez SM, Guzman J Choledocholithiasis: diagnosis with oral-contrast-enhanced CT cholangiography AJR Am J Roentgenol 1999 Apr 172(4):943 8 10587126
Speer AG, Cotton PB, MacRae KD Endoscopic management of malignant biliary obstruction: stents of 10 French gauge are preferable to stents of 8 French gauge Gastrointest Endosc 1988 34(5):412 417 2460394
Speer AG, Cotton PB, Russell RCG, et al. Randomized trial of endoscopic versus percutaneous stent insertion in malignant obstructive jaundice. Lancet. 1987;ii:57-62. [pmid: 2439854].
Speer AG, Cotton PB Endoscopic treatment of pancreatic cancer Int J Pancreatology 1988 3(Suppl. 1):S147 S158
Srinathan SK, Barkun JS, Mehta SN, et al Evolving management of mild-to-moderate gallstone pancreatitis J Gastrointest Surg 1998 Jul-Aug 2(4):385 90 9841997
Stahl TJ, Allen MO, Ansel HJ, et al Partial biliary obstruction caused by chronic pancreatitis. An appraisal of indications for surgical biliary drainage Ann Surg 1988 Jan 207(1):26 32 3337559 1493263
Stain SC, Cohen H, Tsuishoysha M, et al Choledocholithiasis. Endoscopic sphincterotomy or common bile duct exploration Ann Surg 1991 Jun 213(6):627 33 2039294 1358591
Stain SC, Marsri LS, Froes ET, et al Laparoscopic cholecystectomy: laboratory predictors of choledocholithiasis Am Surg 1994 Oct 60(10):767 71 7944040
Stephens RV, Burdick GE Microscopic transduodenal sphincteroplasty and transampullary septoplasty for papillary stenosis Am J Surg 1986 Dec 152(6):621 7 3789286
Stiegmann GV Bile duct calculi--the new challenges HPB Surg 1998 10(6):409 10 9515241
Stiegmann GV, Goff JS, Mansour A, et al Precholecystectomy endoscopic cholangiography and stone removal is not superior to cholecystectomy, cholangiography, and common duct exploration Am J Surg 1992 Feb 163(2):227 30 1739177
Stiris MG, Tennoe B, Aadland E, et al MR cholangiopancreaticography and endoscopic retrograde cholangiopancreaticography in patients with suspected common bile duct stones Acta Radiol 2000 May 41(3):269 72 10866083
Strohm WD, Kurtz W, Hagenmuller F, et al. Diagnostic efficacy of endoscopic ultrasound tomography in pancreatic cancer and cholestasis. Scand J Gastroenterol Suppl. 1984;102:(18-23. [pmid: 6591373].
Suc B, Escat J, Cherqui D, et al Surgery vs endoscopy as primary treatment in symptomatic patients with suspected common bile duct stones. A multicenter randomized trial Arch Surg 1998 133(7):702 708 9687996
Sugawa C, Clift D, Walt AJ Endoscopic retrograde cholangiopancreatography after cholecystectomy Surg Gynecol Obstet 1983 Sep 157(3):247 51 6612573
Sugawa C, Raouf R, Bradley V, et al Peroral endoscopic cholangiography and pancreatography. The surgeon's helper Arch Surg 1974 109(2):231 237 4846492
Sugawa C, Walt AJ Endoscopic retrograde pancreatography in the surgery of pancreatic pseudocysts Surgery 1979 Oct 86(4):639 47 483173
Sugiyama M, Atomi Y, Hachiya J Magnetic resonance cholangiography using half-Fourier acquisition for diagnosing choledocholithiasis Am J Gastroenterol 1998 Oct 93(10):1886 90 9772049
Sugiyama M, Atomi Y, Wada N, et al Endoscopic transpapillary bile duct biopsy without sphincterotomy for diagnosing biliary strictures: a prospective comparative study with bile and brush cytology Am J Gastroenterol 1996 Mar 91(3):465 7 8633492
Sugiyama M, Atomi Y Acute biliary pancreatitis: the roles of endoscopic ultrasonography and endoscopic retrograde cholangiopancreatography Surgery 1998 Jul 124(1):14 21 9663246
Sugiyama M, Atomi Y Endoscopic ultrasonography for diagnosing choledocholithiasis: a prospective comparative study with ultrasonography and computed tomography Gastrointest Endosc 1997 Feb 45(2):143 6 9040999
Sung JY, Chung SCS, Tsui CP, et al. Omitting side-holes in biliary stents does not improve drainage of the obstructed biliary system: a prospective randomized trial. Gastrointest Endosc. 1994;40:321-5. [pmid: 8056235].
Suramo I, Lehtola J, Leinonen A, et al The diagnostic accuracy of gray-scale ultrasonography compared with ERP and arteriography in the detection of pancreatic carcinoma Scand J Gastroenterol 1979 14(8):993 6 531519
Swobodnik W, Meyer W, Brecht-Kraus D, et al Ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the morphologic diagnosis of pancreatic disease Klin Wochenschr 1983 Mar 15 61(6):291 6
Takahashi M, Saida Y, Itai Y, et al. Reevaluation of spiral CT cholangiography: Basic considerations and reliability for detecting choledocholithiasis in 80 patients. J Comput Assist Tomography. 2000;24:859-865.
Takehara Y, Ichijo K, Tooyama N, et al Breath-hold MR cholangiopancreatography with a long-echo-train fast spin-echo sequence and a surface coil in chronic pancreatitis Radiology 1994 Jul 192(1):73 8 8208969
Talamini G, Bassi C The "natural" history of pain in chronic pancreatitis Gastroenterology 2000 118(1):235 43
Tanaka M, Sada M, Eguchi T, et al Comparison of routine and selective endoscopic retrograde cholangiography before laparoscopic cholecystectomy World J Surg 1996 Mar-Apr 20(3):267 70 8661829
Tandon M, Topazian M Endoscopic ultrasound in idiopathic acute pancreatitis Am J Gastroenterol 2001 Mar 96(3):705 9 11280538
Tanner AR, Dwarakanath AD, Tait NP The potential impact of high-quality MRI of the biliary tree on ERCP workload Eur J Gastroenterol Hepatol 2000 Jul 12(7):773 6 10929905
Tanner AR ERCP: present practice in a single region. Suggested standards for monitoring performance Eur J Gastroenterol Hepatol 1996 Feb 8(2):145 8 8723419
Targarona EM, Ayuso RM, Bordas JM, et al Randomised trial of endoscopic sphincterotomy with gallbladder left in situ versus open surgery for common bileduct calculi in high-risk patients Lancet 1996 Apr 6 347(9006):926 9
Tarnasky PR, Hawes RH Endoscopic diagnosis and therapy of unexplained (idiopathic) acute pancreatitis Gastrointest Endosc Clin N Am 1998 Jan 8(1):13 37 9405749
Tarnasky PR, Palesch YY, Cunningham JT, et al Pancreatic stenting prevents pancreatitis after biliary sphincterotomy in patients with sphincter of Oddi dysfunction Gastroenterology 1998 Dec 115(6):1518 24 9834280
Tascilar M, Sturm PD, Caspers E, et al Diagnostic p53 immunostaining of endobiliary brush cytology: preoperative cytology compared with the surgical specimen Cancer 1999 Oct 25 87(5):306 11
Taylor BR, Ho CS Nonsurgical treatment of common-bile-duct stones Can J Surg 1984 Jan 27(1):28 32 6467098
ten Hoopen-Neumann H, Gerhards MF, van Gulik TM, et al Occurrence of implantation metastases after resection of Klatskin tumors Dig Surg 1999 16(3):209 13 10436369
Teplick SK, Flick P, Brandon JC Transhepatic cholangiography in patients with suspected biliary disease and nondilated intrahepatic bile ducts Gastrointest Radiol 1991 Summer 16(3):193 7 1879632
Testoni PA, Caporuscio S, Bagnolo F, et al Idiopathic recurrent pancreatitis: long-term results after ERCP, endoscopic sphincterotomy, or ursodeoxycholic acid treatment Am J Gastroenterol 2000 Jul 95(7):1702 7 10925971
Tham TC, Lichtenstein DR, Vandervoort J, et al Role of endoscopic retrograde cholangiopancreatography for suspected choledocholithiasis in patients undergoing laparoscopic cholecystectomy Gastrointest Endosc 1998 Jan 47(1):50 6 9468423
Thatcher BS, Sivak MV, Tedesco FJ, et al Endoscopic sphincterotomy for suspected dysfunction of the sphincter of Oddi Gastrointest Endosc 1987 Apr 33(2):91 5 3569807
Thomas MJ, Pellegrini CA, Way LW Usefulness of diagnostic tests for biliary obstruction Am J Surg 1982 Jul 144(1):102 8 7091518
Thompson MH Influence of endoscopic papillotomy on the management of bile duct stones Br J Surg 1986 73(10):779 781 3768645
Thornton JR, Lobo AJ, Lintott DJ, et al Value of ultrasound and liver function tests in determining the need for endoscopic retrograde cholangiopancreatography in unexplained abdominal pain Gut 1992 Nov 33(11):1559 61 1452084 1379546
Tio TL, Tytgat GNJ, Cikot RJLM, et al Ampullopancreatic carcinoma: Preoperative TNM classification with endosonography Radiology 1990 175(2):455 461 2183284
Tio TL, Wijers OB, Sars PR, et al Preoperative TNM classification of proximal extrahepatic bile duct carcinoma by endosonography Semin Liver Dis 1990 May 10(2):114 20 2162563
Tobin RS, Vogelzang RL, Gore RM, et al A comparative study of computed tomography and ERCP in pancreaticobiliary disease J Comput Tomogr 1987 Jul 11(3):261 6 3608551
Toouli J What is sphincter of Oddi dysfunction? Gut 1989 30(6):753 761 2666281 1434151
Toouli J, Craig A. Sphincter of Oddi function and dysfunction. Canadian J Gastroenterol. 2000;14:411-419.
Toouli J, Roberts-Thomson IC, Kellow J, et al Manometry based randomised trial of endoscopic sphincterotomy for sphincter of Oddi dysfunction Gut 2000 Jan 46(1):98 102 10601063 1727795
Topazian M, Kozarek R, Stoler R, et al Clinical utility of endoscopic retrograde cholangiopancreatography Gastrointest Endosc 1997 Nov 46(5):393 9 9402111
Traverso LW A cost analysis of the treatment of common bile duct stones discovered during cholecystectomy Semin Laparosc Surg 2000 Dec 7(4):302 7 11323767
Treacy PJ, Worthley CS Pancreatic stents in the management of chronic pancreatitis Aust NZ J Surg 1996 Apr 66(4):210 3
Trede M, Rumstadt B, Wendl K, et al Ultrafast magnetic resonance imaging improves the staging of pancreatic tumors Ann Surg 1997 Oct 226(4):393 405 9351708 1191049
Trias M, Targarona EM, Ros E, et al Prospective evaluation of a minimally invasive approach for treatment of bile-duct calculi in the high-risk patient Surg Endosc 1997 Jun 11(6):632 5 9171121
Trondsen E, Edwin B, Reiertsen O, et al Prediction of common bile duct stones prior to cholecystectomy: a prospective validation of a discriminant analysis function Arch Surg 1998 Feb 133(2):162 6 9484728
Trondsen E, Edwin B, Reiertsen O, et al Selection criteria for endoscopic retrograde cholangiopancreaticography (ERCP) in patients with gallstone disease World J Surg 1995 Nov-Dec 19(6):852 6 8553678
Tsitouridis I, Kouklakis G, Tsitouridis K, et al MR cholangiopancreatography evaluation of the biliary tree Hellenic Journal of Gastroenterology (Hell. J. Gastroenterol.) 1997 10(4):307 310
Tzovaras G, Rowlands BJ Diagnosis and treatment of sphincter of Oddi dysfunction Br J Surg 1998 May 85(5):588 95 9635801
Tzovaras G, Shukla P, Kow L, et al What are the risks of diagnostic and therapeutic endoscopic retrograde cholangiopancreatography? Aust N Z J Surg 2000 Nov 70(11):778 82 11147436
Uomo G, Galloro V, Rabitti PG, et al Early endoscopic cholangiopancreatography and sphincterotomy in acute biliary pancreatitis: report of 50 cases Ital J Gastroenterol 1991 Dec 23(9):564 6 1760564
Uomo G, Manes G, Ragozzino A, et al Periampullary extraluminal duodenal diverticula and acute pancreatitis: an underestimated etiological association Am J Gastroenterol 1996 Jun 91(6):1186 8 8651168
Urbach DR, Khajanchee YS, Jobe BA, et al Cost-effective management of common bile duct stones: a decision analysis of the use of endoscopic retrograde cholangiopancreatography (ERCP), intraoperative cholangiography, and laparoscopic bile duct exploration Surg Endosc 2001 Jan 15(1):4 13 11178753
Vahldiek G, Broemel T, Klapdor R MR-cholangiopancreaticography (MRCP) and MR-angiography: morphologic changes with magnetic resonance imaging Anticancer Res 1999 Jul-Aug 19(4A):2451 8 10470174
Vaira D, Dowsett JF, Hatfield AR, et al Is duodenal diverticulum a risk factor for sphincterotomy? Gut 1989 Jul 30(7):939 42 2503431 1434299
van Berkel AM, Boland C, Redekop WK, et al A prospective randomized trial of Teflon versus polyethylene stents for distal malignant biliary obstruction Endoscopy 1998 Oct 30(8):681 6 9865556
Van Camp JM, Polley TZ, Coran AG Pancreatitis in children: Diagnosis and etiology in 57 patients Pediatr Surg Int 1994 9(7):492 497
Van Dam J, Sivak MV Mechanical lithotripsy of large common bile duct stones Cleve Clin J Med 1993 Jan-Feb 60(1):38 42 8443933
van der Hul RL, Plaisier PW, Lameris JS, et al Proximal cholangiocarcinoma: a multidisciplinary approach Eur J Surg 1994 Apr 160(4):213 8 8049311
Van Stiegmann G, Pearlman NW, Goff JS, et al Endoscopic cholangiography and stone removal prior to cholecystectomy. A more cost-effective approach than operative duct exploration? Arch Surg 1989 Jul 124(7):787 9 2500925
Vandervoort J, Soetikno RM, Montes H, et al Accuracy and complication rate of brush cytology from bile duct versus pancreatic duct Gastrointest Endosc 1999 Mar 49(3 Pt 1):322 7 10049415
Varghese JC, Farrell MA, Courtney G, et al A prospective comparison of magnetic resonance cholangiopancreatography with endoscopic retrograde cholangiopancreatography in the evaluation of patients with suspected biliary tract disease Clin Radiol 1999 Aug 54(8):513 20 10484218
Varghese JC, Liddell RP, Farrell MA, et al Diagnostic accuracy of magnetic resonance cholangiopancreatography and ultrasound compared with direct cholangiography in the detection of choledocholithiasis Clin Radiol 2000 Jan 55(1):25 35 10650107
Varghese JC, Liddell RP, Farrell MA, et al Diagnostic accuracy of magnetic resonance cholangiopancreatography and ultrasound compared with direct cholangiography in the detection of choledocholithiasis Clin Radiol 2000 Jan 55(1):25 35 10650107
Varshney S, Johnson CD Pancreas divisum Int J Pancreatol 1999 Apr 25(2):135 41 10360226
Venu RP, Geenen JE, Hogan W, et al Idiopathic recurrent pancreatitis. An approach to diagnosis and treatment Dig Dis Sci 1989 Jan 34(1):56 60 2631687
Venu RP, Geenen JE, Kini M, et al Endoscopic retrograde brush cytology. A new technique Gastroenterology 1990 Nov 99(5):1475 9 2210255
Vitale GC, Larson GM, George M, et al Management of malignant biliary stricture with self-expanding metallic stent Surg Endosc 1996 Oct 10(10):970 3 8864087
Vitale GC, Reed DN, Nguyen CT, et al Endoscopic treatment of distal bile duct stricture from chronic pancreatitis Surg Endosc 2000 Mar 14(3):227 31 10741437
Voyles CR, Sanders DL, Hogan R Common bile duct evaluation in the era of laparoscopic cholecystectomy. 1050 cases later Ann Surg 1994 Jun 219(6):744 50 discussion 750-2 8203985 1243236
Wagner HJ, Knyrim K, Vakil N et al Plastic endoprostheses versus metal stents in the palliative treatment of malignant hilar biliary obstruction. A prospective and randomized trial Endoscopy 1993 Mar 25(3):213 8 7686100
Wang CH, Mo LR, Lin RC, et al Rapid diagnosis of choledocholithiasis using biochemical tests in patients undergoing laparoscopic cholecystectomy Hepatogastroenterology 2001 May-Jun 48(39):619 21 11462888
Warshaw AL, Banks PA, Fernandez-del Castillo C. AGA Technical Review: Treatment of Pain in Chronic Pancreatitis. Gastroenterology. 1998;115:765-76. [pmid: 9721175].
Warshaw AL, Richter JM, Schapiro RH The cause and treatment of pancreatitis associated with pancreas divisum Ann Surg 1983 Oct 198(4):443 52 6625715 1353182
Watanabe Y, Dohke M, Ishimori T, et al High-resolution MR cholangiopancreatography Crit Rev Diagn Imaging 1998 Apr 39(2-3):115 258 9589841
Choledocholithiasis. Web page from Adam.com, available at: http://webmd.lycos.com/content/asset/adam_disease_bile_calculus. Last dated: 1999; last accessed: November 2001.
Wehrmann T, Schmitt T, Stergiou N, et al Topical application of nitrates onto the papilla of Vater: manometric and clinical results Endoscopy 2001 Apr 33(4):323 8 11315893
Wehrmann T, Schmitt TH, Arndt A, et al Endoscopic injection of botulinum toxin in patients with recurrent acute pancreatitis due to pancreatic sphincter of Oddi dysfunction Aliment Pharmacol Ther 2000 14(11):1469 1477 11069318
Wehrmann T, Wiemer K, Lembcke B, et al Do patients with sphincter of Oddi dysfunction benefit from endoscopic sphincterotomy? A 5-year prospective trial Eur J Gastroenterol Hepatol 1996 Mar 8(3):251 6 8724026
Weizel A, Czygan P Demonstration of a liver abscess by ERC Endoscopy 1976 8(2):110 111
Weltz C, Pappas TN Pancreatography and the surgical management of pseudocysts Gastrointest Endosc Clin N Am 1995 Jan 5(1):269 79 7728348
Wiersema MJ, Kochman ML, Cramer HM, et al Endosonography-guided real-time fine-needle aspiration biopsy Gastrointest Endosc 1994 Nov-Dec 40(6):700 7 7859968
Wiersema MJ, Vilmann P, Giovannini M, et al. Endosonography-guided fine-needle aspiration biopsy: diagnostic accuracy and complication assessment. Gastroenterology. 1997;112:1087-95. [pmid: 9097990].
Williams DB, Sahai AV, Aabakken L, et al. Endoscopic ultrasound guided fine needle aspiration biopsy: a large single center experience. Gut. 1999;44:720-6. [pmid: 10205212]. [pmcid: 1727480].
Wojtun S, Gil J, Gietka W, et al Endoscopic sphincterotomy for choledocholithiasis: a prospective single-center study on the short-term and long-term treatment results in 483 patients Endoscopy 1997 May 29(4):258 65 9255528
Yamaguchi T, Saisho H, Ohto M Usefulness of percutaneous histological biopsy in the diagnosis of chronic pancreatitis with inflammatory mass (CPM) J Intervent Radiol 1994 9(4):165 170
Yamakawa T, Sakai S, Mu ZB, et al Laparoscopic management of common bile duct stones J Hepatobiliary Pancreat Surg 2000 7(1):9 14 10982585
Yamashita Y, Abe Y, Tang Y, et al In vitro and clinical studies of image acquisition in breath-hold MR cholangiopancreatography: single-shot projection technique versus multislice technique AJR Am J Roentgenol 1997 Jun 168(6):1449 54 9168706
Yap I, Wee A, Tay HH, et al Primary biliary cirrhosis--an uncommon disease in Singapore Singapore Med J 1996 Feb 37(1):48 50 8783913
Yeh TS, Jan YY, Tseng JH, et al Malignant perihilar biliary obstruction: magnetic resonance cholangiopancreatographic findings Am J Gastroenterol 2000 Feb 95(2):432 40 10685746
Yeoh KG, Zimmerman MJ, Cunningham JT, et al Comparative costs of metal versus plastic biliary stent strategies for malignant obstructive jaundice by decision analysis Gastrointest Endosc 1999 Apr 49(4 Pt 1):466 71 10202060
Zeman RK, Burrell MI, Dobbins J, et al Postcholecystectomy syndrome: evaluation using biliary scintigraphy and endoscopic retrograde cholangiopancreatography Radiology 1985 Sep 156(3):787 92 4023244
Zidi SH, Prat F, Le Guen O, et al Use of magnetic resonance cholangiography in the diagnosis of choledocholithiasis: prospective comparison with a reference imaging method Gut 1999 Jan 44(1):118 22 9862837 1760072
Zoepf T, Zoepf DS, Arnold JC, et al The relationship between juxtapapillary duodenal diverticula and disorders of the biliopancreatic system: Analysis of 350 patients Gastrointest Endosc 2001 Jul 54(1):56 61 11427842
Zuckerman GR Negative outcomes related to gastrointestinal endoscopic procedures. Definitions, classification, and quality review process Gastrointest Endosc Clin N Am 1996 Apr 6(2):461 70 8673337