# References

Adamek HE, Albert J, Breer H, et al Pancreatic cancer detection with magnetic resonance cholangiopancreatography and endoscopic retrograde cholangiopancreatography: a prospective controlled study Lancet 2000 Jul 15 356(9225):190 3
Adamek HE, Albert J, Weitz M, et al A prospective evaluation of magnetic resonance cholangiopancreatography in patients with suspected bile duct obstruction Gut 1998 Nov 43(5):680 3 9824351 1727306
Adamek HE, Maier M, Jakobs R, et al Management of retained bile duct stones: a prospective open trial comparing extracorporeal and intracorporeal lithotripsy Gastrointest Endosc 1996 Jul 44(1):40 7 8836715
Ahearne PM, Baillie JM, Cotton PB, et al An endoscopic retrograde cholangiopancreatography (ERCP)-based algorithm for the management of pancreatic pseudocysts Am J Surg 1992 Jan 163(1):111 5 1733357
Aiyer MK, Burdick JS, Sonnenberg A Outcome of surgical and endoscopic management of biliary pancreatitis Dig Dis Sci 1999 Aug 44(8):1684 90 10492153
al Karawi MA, el Shiekh Mohamed AR, al Shahri, et al Endoscopic sphincterotomy in acute gallstone pancreatitis and cholangitis: a Saudi hospital experience Hepatogastroenterology 1993 Aug 40(4):396 401 8406313
Alponat A, Kum CK, Rajnakova A, et al Predictive factors for synchronous common bile duct stones in patients with cholelithiasis Surg Endosc 1997 Sep 11(9):928 32 9294275
Amman RW, Akovbiantz A, Larglader F, et al. Course and outcome of chronic pancreatitis: Longitudinal study of a mixed medical-surgical series of 245 patients. Gastroenterology. 1984;86:820-828. [pmid: 6706066].
Andersen JR, Sorensen SM, Kruse A, et al Randomised trial of endoscopic endoprosthesis versus operative bypass in malignant obstructive jaundice Gut 1989 Aug 30(8):1132 5 2475392 1434171
Arslan A, Geitung JT, Viktil E, et al Pancreaticobiliary diseases. Comparison of 2D single-shot turbo spin-echo MR cholangiopancreatography with endoscopic retrograde cholangiopancreatography Acta Radiol 2000 Nov 41(6):621 6 11092486
Ashby K, Lo SK The role of pancreatic stenting in obstructive ductal disorders other than pancreas divisum Gastrointest Endosc 1995 Oct 42(4):306 11 8536897
Barkun AN, Barkun JS, Fried GM, et al Useful predictors of bile duct stones in patients undergoing laparoscopic cholecystectomy. McGill Gallstone Treatment Group Ann Surg 1994 Jul 220(1):32 9 7517657 1234284
Barthet M, Sahel J, Bodiou-Bertei C, et al Endoscopic transpapillary drainage of pancreatic pseudocysts Gastrointest Endosc 1995 Sep 42(3):208 13 7498684
Bentz JS, Kochman ML, Faigel DO, et al Endoscopic ultrasound-guided real-time fine needle aspiration: clinicopathologic features of 60 patients Diagn Cytopathol 1998 18(2):98 109 9484637
Bergamaschi R, Tuech JJ, Braconier L, et al Selective endoscopic retrograde cholangiography prior to laparoscopic cholecystectomy for gallstones Am J Surg 1999 Jul 178(1):46 9 10456702
Bergman JJ, Rauws EA, Fockens P, et al Randomised trial of endoscopic balloon dilation versus endoscopic sphincterotomy for removal of bileduct stones Lancet 1997 Apr 19 349(9059):1124 9
Bhutani MS, Hawes RH, Baron PL, et al Endoscopic ultrasound guided fine needle aspiration of malignant pancreatic lesions Endoscopy 1997 Nov 29(9):854 8 9476770
Binmoeller KF, Jue P, Seifert H, et al Endoscopic pancreatic stent drainage in chronic pancreatitis and a dominant stricture: long-term results Endoscopy 1995 Nov 27(9):638 44 8903975
Boender J, Nix GA, de Ridder MA, et al Endoscopic papillotomy for common bile duct stones: factors influencing the complication rate Endoscopy 1994 Feb 26(2):209 16 8026367
Bornman PC, Marks IN, Girdwood AH, et al Is pancreatic duct obstruction or stricture a major cause of pain in calcific pancreatitis? Br J Surg 1980 Jun 67(6):425 8 7388340
Botoman VA, Kozarek RA, Novell LA, et al Long-term outcome after endoscopic sphincterotomy in patients with biliary colic and suspected sphincter of Oddi dysfunction Gastrointest Endosc 1994 Mar-Apr 40(2 Pt 1):165 70 8013815
Brand B, Wiese L, Thonke F, et al Outcome of endoscopic sphincterotomy in patients with pain of suspected biliary or papillary origin and inconclusive cholangiography findings Endoscopy 2001 May 33(5):405 8 11396757
Brandwein SL, Farrell JJ, Centeno BA, et al Detection and tumor staging of malignancy in cystic, intraductal, and solid tumors of the pancreas by EUS Gastrointest Endosc 2001 Jun 53(7):722 727 11375578
Bret PM, Reinhold C, Taourel P, et al Pancreas divisum: evaluation with MR cholangiopancreatography Radiology 1996 Apr 199(1):99 103 8633179
Burtin P, Palazzo L, Canard JM, et al Diagnostic strategies for extrahepatic cholestasis of indefinite origin: endoscopic ultrasonography or retrograde cholangiography? Results of a prospective study Endoscopy 1997 Jun 29(5):349 55 9270914
Canto MI, Chak A, Stellato T, et al Endoscopic ultrasonography versus cholangiography for the diagnosis of choledocholithiasis Gastrointest Endosc 1998 Jun 47(6):439 48 9647366
Carlson GL, Rhodes M, Stock S, et al Role of endoscopic retrograde cholangiopancreatography in the investigation of pain after cholecystectomy Br J Surg 1992 Dec 79(12):1342 5 1486435
Carroll BJ, Phillips EH, Rosenthal R, et al One hundred consecutive laparoscopic cholangiograms. Results and conclusions Surg Endosc 1996 Mar 10(3):319 23 8779067
Cellier C, Cuillerier E, Palazzo L, et al Intraductal papillary and mucinous tumors of the pancreas: accuracy of preoperative computed tomography, endoscopic retrograde pancreatography and endoscopic ultrasonography, and long-term outcome in a large surgical series Gastrointest Endosc 1998 Jan 47(1):42 9 9468422
Chak A, Hawes RH, Cooper GS, et al Prospective assessment of the utility of EUS in the evaluation of gallstone pancreatitis Gastrointest Endosc 1999 May 49(5):599 604 10228258
Chang KJ, Nguyen P, Erickson RA, et al The clinical utility of endoscopic ultrasound-guided fine-needle aspiration in the diagnosis and staging of pancreatic carcinoma Gastrointest Endosc 1997 May 45(5):387 93 9165320
Chang L, Lo S, Stabile BE, et al Preoperative versus postoperative endoscopic retrograde cholangiopancreatography in mild to moderate gallstone pancreatitis: a prospective randomized trial Ann Surg 2000 Jan 231(1):82 7 10636106 1420969
Chang KJ, Katz KD, Durbin TE, et al Endoscopic ultrasound-guided fine-needle aspiration Gastrointest Endosc 1994 Nov-Dec 40(6):694 9 7859967
Chang WH, Kortan P, Haber GB Outcome in patients with bifurcation tumors who undergo unilateral versus bilateral hepatic duct drainage Gastrointest Endosc 1998 May 47(5):354 62 9609426
Chevillotte G, Sahel J, Pietri H, et al Acute recurrent pancreatitis associated with pancreas divisum clinical study of 12 cases Gastroenterol Clin Biol 1984 8(4):352 358 6735043
Chopra KB, Peters RA, O'Toole PA, et al Randomised study of endoscopic biliary endoprosthesis versus duct clearance for bileduct stones in high-risk patients Lancet 1996 Sep 21 348(9030):791 3
Choudhry U, Ruffolo T, Jamidar P, et al Sphincter of Oddi dysfunction in patients with intact gallbladder: Therapeutic response to endoscopic sphincterotomy Gastrointest Endosc 1993 39(4):492 495 8365594
Clarke BD, Lehman GA "Cloggology" revisited: endoscopic or surgical decompression of malignant biliary obstruction Am J Gastroenterol 1990 Nov 85(11):1533 4 2239887
Available online at http://www.cochrane.org/cochrane/sadtdoc1.htm; updated 6 June 1996.
Concato J, Feinstein AR, Holford TR. The risk of determining risk with multivariable models. Ann Intern Med. 1993;118:201-210. [pmid: 8417638].
Conio M, Demarquay JF, De Luca L, et al Endoscopic treatment of pancreatico-biliary malignancies Crit Rev Oncol Hematol 2001 Feb 37(2):127 35 11166586
Cortas GA, Mehta SN, Abraham NS, et al Selective cannulation of the common bile duct: a prospective randomized trial comparing standard catheters with sphincterotomes Gastrointest Endosc 1999 Dec 50(6):775 9 10570335
Cotton PB, Lehman G, Vennes J, et al Endoscopic sphincterotomy complications and their management: an attempt at consensus Gastrointest Endosc 1991 May-Jun 37(3):383 93 2070995
Cremer M, Deviere J, Delhaye M, et al Stenting in severe chronic pancreatitis: results of medium-term follow-up in seventy-six patients Endoscopy 1991 May 23(3):171 6 1860448
Cuschieri A, Lezoche E, Morino M, et al E.A.E.S. multicenter prospective randomized trial comparing two-stage vs single-stage management of patients with gallstone disease and ductal calculi Surg Endosc 1999 Oct 13(10):952 7 10526025
Dancygier H, Nattermann C The role of endoscopic ultrasonography in biliary tract disease: obstructive jaundice Endoscopy 1994 Nov 26(9):800 2 7712994
Davids PH, Groen AK, Rauws EA, et al. Randomised trial of self-expanding metal stents versus polyethylene stents for distal malignant biliary obstruction. Lancet. 8834-8835). 1992 Dec 19-26;340:1488-92.
de Peralta-Venturina MN, Wong DK, Purslow MJ, et al Biliary tract cytology in specimens obtained by direct cholangiographic procedures: a study of 74 cases Diagn Cytopathol 1996 Jun 14(4):334 48 8725136
Delhaye M, Vandermeeren A, Baize M, et al Extracorporeal shock-wave lithotripsy of pancreatic calculi Gastroenterology 1992 Feb 102(2):610 20 1732129
Demartines N, Eisner L, Schnabel K, et al Evaluation of magnetic resonance cholangiography in the management of bile duct stones Arch Surg 2000 Feb 135(2):148 52 10668871
DePalma GD, Galloro G, Iovino P, et al. Unilateral versus bilateral endoscopic hepatic duct drainage in patients with malignant hilar biliary obstruction. Results of a prospective, randomized, and controlled study. Gastrointest Endosc. 2001;53:547-53. [pmid: 11323577].
Deviere J, Baize M, de Toeuf J, et al Long-term follow-up of patients with hilar malignant stricture treated by endoscopic internal biliary drainage Gastrointest Endosc 1988 Mar-Apr 34(2):95 101 2835282
DiSario JA, Freeman ML, Bjorkman DJ, et al Endoscopic balloon dilatation vs. sphincterotomy (EDES) for bile duct stones removal Digestion 1998 59(Suppl 3):
Dumonceau JM, Deviere J, Le Moine O, et al Endoscopic pancreatic drainage in chronic pancreatitis associated with ductal stones: long-term results Gastrointest Endosc 1996 Jun 43(6):547 55 8781931
Duvnjak M, Rotkvic I, Vucelic B, et al The value of pancreatic pseudocyst amylase concentration in the detection of pseudocyst communication with the pancreatic duct Am J Gastroenterol 1991 May 86(5):595 8 1709337
Ell C, Rabenstein T, Schneider HT, et al Safety and efficacy of pancreatic sphincterotomy in chronic pancreatitis Gastrointest Endosc 1998 Sep 48(3):244 9 9744598
Elta GH, Barnett JL, Wille RT, et al Pure cut electrocautery current for sphincterotomy causes less post-procedure pancreatitis than blended current Gastrointest Endosc 1998 Feb 47(2):149 53 9512280
England RE, Martin DF Endoscopic and percutaneous intervention in malignant obstructive jaundice Cardiovasc Intervent Radiol 1996 Nov-Dec 19(6):381 7 8994702
Fan ST, Lai EC, Mok FP, et al Early treatment of acute biliary pancreatitis by endoscopic papillotomy N Engl J Med 1993 Jan 28 328(4):228 32
Ferrari Jr AP, Lichtenstein DR, Slivka A, et al Brush cytology during ERCP for the diagnosis of biliary and pancreatic malignancies Gastrointest Endosc 1994 Mar-Apr 40(2 Pt 1):140 5 8013810
Festen C, Severijnen R, vd Staak F, et al Chronic relapsing pancreatitis in childhood J Pediatr Surg 1991 Feb 26(2):182 3 2023080
Fleischmann D, Ringl H, Schofl R, et al Three-dimensional spiral CT cholangiography in patients with suspected obstructive biliary disease: comparison with endoscopic retrograde cholangiography Radiology 1996 Mar 198(3):861 8 8628884
Folsch UR, Nitsche R, Ludtke R, et al Early ERCP and papillotomy compared with conservative treatment for acute biliary pancreatitis. The German Study Group on Acute Biliary Pancreatitis N Engl J Med 1997 Jan 23 336(4):237 42
Foutch PG, Kerr DM, Harlan JR, et al A prospective, controlled analysis of endoscopic cytotechniques for diagnosis of malignant biliary strictures Am J Gastroenterol 1991 May 86(5):577 80 2028947
Freeman M, DiSario JA, Nelson DB, et al Risk factors for post-ERCP pancreatitis: a prospective, multicenter study Gastrointest Endosc 2001 Oct 54(4):425 34 11577302
Freeman ML, Nelson DB, Sherman S, et al Complications of endoscopic biliary sphincterotomy N Engl J Med 1996 Sep 26 335(13):909 18
Froeschle G, Meyer-Pannwitt U, Brueckner M, et al A comparison between surgical, endoscopic and percutaneous management of pancreatic pseudocysts--long term results Acta Chir Belg 1993 May-Jun 93(3):102 6 8372580
Fuji T, Amano H, Ohmura R, et al Endoscopic pancreatic sphincterotomy--technique and evaluation Endoscopy 1989 Jan 21(1):27 30 2917533
Geenen JE, Hogan WJ, Dodds WJ, et al The efficacy of endoscopic sphincterotomy after cholecystectomy in patients with sphincter-of-Oddi dysfunction N Engl J Med 1989 Jan 12 320(2):82 7
Glasbrenner B, Schwarz M, Pauls S, et al Prospective comparison of endoscopic ultrasound and endoscopic retrograde cholangiopancreatography in the preoperative assessment of masses in the pancreatic head Dig Surg 2000 17(5):468 74 11124550
Gmelin E, Weiss HD Tumours in the region of the papilla of Vater. Diagnosis via endoscopy, biopsy, brush cytology, ERPC and CT-scan Eur J Radiol 1981 Nov 1(4):301 6 7346276
Greenberger NJ, Toskes PP, Isselbacher KJ. Acute and chronic pancreatitis. Ch. 274 In: Isselbacher KJ, Braunwald E, Wilson JD, et al., eds. Harrison's Principles of Internal Medicine, 13th edition. 1994 McGraw-Hill, Inc.; New York, NY: 1520-32.
Greenlee RT, Hill-Harmon MB, Murray T, et al Cancer statistics, 2001 CA Cancer J Clin 2001 Jan-Feb 51(1):15 36 11577478
Gress F, Gottlieb K, Sherman S, et al Endoscopic ultrasonography-guided fine-needle aspiration biopsy of suspected pancreatic cancer Ann Intern Med 2001 Mar 20 134(6):459 64
Gress FG, Hawes RH, Savides TJ, et al. Endoscopic ultrasound-guided fine-needle aspiration biopsy using linear array and radial scanning endosonography. Gastrointest Endosc. 1997;45:(243-50. [pmid: 9087830].
Grimm H, Meyer WH, Nam VC, et al New modalities for treating chronic pancreatitis Endoscopy 1989 Mar 21(2):70 4 2707174
Guelrud M, Morera C, Rodriguez M, et al Sphincter of Oddi dysfunction in children with recurrent pancreatitis and anomalous pancreaticobiliary union: an etiologic concept Gastrointest Endosc 1999 Aug 50(2):194 9 10425412
Guelrud M, Mujica C, Jaen D, et al The role of ERCP in the diagnosis and treatment of idiopathic recurrent pancreatitis in children and adolescents Gastrointest Endosc 1994 Jul-Aug 40(4):428 36 7926532
Guibaud L, Bret PM, Reinhold C, et al Bile duct obstruction and choledocholithiasis: diagnosis with MR cholangiography Radiology 1995 Oct 197(1):109 15 7568807
Hammarstrom LE, Holmin T, Stridbeck H, et al Long-term follow-up of a prospective randomized study of endoscopic versus surgical treatment of bile duct calculi in patients with gallbladder in situ Br J Surg 1995 Nov 82(11):1516 21 8535807
Hammarstrom LE, Stridbeck H, Ihse I Endoscopic drainage in benign pancreatic disease: immediate and medium term outcome Eur J Surg 1997 Aug 163(8):577 89 9298910
Hauer-Jensen M, Karesen R, Nygaard K, et al Predictive ability of choledocholithiasis indicators. A prospective evaluation Ann Surg 1985 Jul 202(1):64 8 4015213 1250838
Hawasli A, Lloyd L, Cacucci B Management of choledocholithiasis in the era of laparoscopic surgery Am Surg 2000 May 66(5):425 30 discussion 430-1 10824741
Hawasli A, Lloyd L, Pozios V, et al The role of endoscopic retrograde cholangio-pancreaticrogram in laparoscopic cholecystectomy Am Surg 1993 May 59(5):285 8 8489095
He X, Zheng C, Zhang Z, et al Congenital choledochal cyst - Report of 56 cases Chin Med Sci J 2000 15(1):52 54 12899402
Heslin MJ, Brooks AD, Hochwald SN, et al A preoperative biliary stent is associated with increased complications after pancreatoduodenectomy Arch Surg 1998 Feb 133(2):149 54 9484726
Himal HS Preoperative endoscopic retrograde cholangiopancreatography (ERCP) is not necessary in mild gallstone pancreatitis Surg Endosc 1999 Aug 13(8):782 3 10430684
Hogan WJ, Geenen JE Biliary dyskinesia Endoscopy 1988 Aug 20(Suppl 1):179 83 3168947
Holzknecht N, Gauger J, Sackmann M, et al Breath-hold MR cholangiography with snapshot techniques: prospective comparison with endoscopic retrograde cholangiography Radiology 1998 Mar 206(3):657 64 9494483
Howell DA, Beveridge RP, Bosco J, et al Endoscopic needle aspiration biopsy at ERCP in the diagnosis of biliary strictures Gastrointest Endosc 1992 Sep-Oct 38(5):531 5 1327937
Irwig L, Tosteson ANA, Gatsonis C et al. Guideline for meta-analysis evaluating diagnostic tests. Ann Intern Med. 1994;120:667-676. [pmid: 8135452].
Ishikawa M, Tagami Y, Toyota T, et al Can three-dimensional helical CT cholangiography before laparoscopic cholecystectomy be a substitute study for endoscopic retrograde cholangiography? Surg Laparosc Endosc Percutan Tech 2000 Dec 10(6):351 6 11147907
Jacob L, Geenen JE, Catalano MF, et al Prevention of pancreatitis in patients with idiopathic recurrent pancreatitis: a prospective nonblinded randomized study using endoscopic stents Endoscopy 2001 Jul 33(7):559 62 11473324
Jailwala J, Fogel EL, Sherman S, et al Triple-tissue sampling at ERCP in malignant biliary obstruction Gastrointest Endosc 2000 Apr 51(4 Pt 1):383 90 10744806
Jamidar P, Sherman S, Hawes R. Efficacy of endoscopic sphincterotomy for patients with sphincter of Oddi dysfunction: randomized, controlled study. Gastrointest Endosc. 1992;38.
Jimenez Cuenca I, del Olmo Martinez L, Perez Homs M Helical CT without contrast in choledocholithiasis diagnosis Eur Radiol 2001 11(2):197 201 11218014
Kaneko T, Nakao A, Inoue S, et al Intraoperative ultrasonography by high-resolution annular array transducer for intraductal papillary mucinous tumors of the pancreas Surgery 2001 Jan 129(1):55 65 11150034
Karsten TM, Allema JH, Reinders M, et al Preoperative biliary drainage, colonisation of bile and postoperative complications in patients with tumours of the pancreatic head: a retrospective analysis of 241 consecutive patients Eur J Surg 1996 Nov 162(11):881 8 8956957
Keith RG, Shapero TF, Saibil FG Treatment of pancreatitis associated with pancreas divisum by dorsal duct sphincterotomy alone Can J Surg 1982 25(6):622 626 7139415
Khaira HS, Ridings PC, Gompertz RH Routine laparoscopic cholangiography: a means of avoiding unnecessary endoscopic retrograde cholangiopancreatography J Laparoendosc Adv Surg Tech 1999 Feb 9(1):17 22
Kim KH, Kim W, Lee HI, et al Prediction of common bile duct stones: its validation in laparoscopic cholecystectomy Hepatogastroenterology 1997a Nov-Dec 44(18):1574 9 9427025
Kim MH, Lee SK, Lee MH, et al Endoscopic retrograde cholangiopancreatography and needle-knife sphincterotomy in patients with Billroth II gastrectomy: a comparative study of the forward-viewing endoscope and the side-viewing duodenoscope Endoscopy 1997b Feb 29(2):82 5 9101144
Kim MH, Myung SJ, Kim YS, et al Routine biliary sphincterotomy may not be indispensable for endoscopic pancreatic sphincterotomy Endoscopy 1998 Oct 30(8):697 701 9865559
Kloiber R, AuCoin R, Hershfield NB, et al Biliary obstruction after cholecystectomy: diagnosis with quantitative cholescintigraphy Radiology 1988 Dec 169(3):643 7 2460898
Kolars JC, Allen MO, Ansel H, et al Pancreatic pseudocysts: clinical and endoscopic experience Am J Gastroenterol 1989 Mar 84(3):259 64 2919583
Koo KP, Traverso LW Do preoperative indicators predict the presence of common bile duct stones during laparoscopic cholecystectomy? Am J Surg 1996 May 171(5):495 9 8651393
Kozarek RA, Ball TJ, Patterson DJ, et al Endoscopic approach to pancreas divisum Dig Dis Sci 1995 Sep 40(9):1974 81 7555452
Kozarek RA, Ball TJ, Patterson DJ Endoscopic approach to pancreatic duct calculi and obstructive pancreatitis Am J Gastroenterol 1992 May 87(5):600 3 1595647
Kozarek RA, Traverso LW Endoscopic treatment of chronic pancreatitis - An alternative to surgery? Dig Surg 1996 13(2):90 100
Kurzawinski TR, Deery A, Dooley JS, et al A prospective study of biliary cytology in 100 patients with bile duct strictures Hepatology 1993 Dec 18(6):1399 403 8244264
Lai EC, Lo CM, Choi TK, et al Urgent biliary decompression after endoscopic retrograde cholangiopancreatography Am J Surg 1989 Jan 157(1):121 5 2910117
Lai EC, Mok FP, Fan ST, et al. Preoperative endoscopic drainage for malignant obstructive jaundice. Br J Surg. 1994;81:1195-1198. [pmid: 7741850].
Lai ECS, Mok FPT, Tan ESY, et al Endoscopic biliary drainage for severe acute cholangitis New Engl J Med 1992 326(24):1582 6 1584258
Lans JI, Geenen JE, Johanson JF, et al Endoscopic therapy in patients with pancreas divisum and acute pancreatitis: a prospective, randomized, controlled clinical trial Gastrointest Endosc 1992 Jul-Aug 38(4):430 4 1511816
Lee MG, Lee HJ, Kim MH, et al Extrahepatic biliary diseases: 3D MR cholangiopancreatography compared with endoscopic retrograde cholangiopancreatography Radiology 1997 Mar 202(3):663 9 9051013
Lee JG, Leung J Tissue sampling at ERCP in suspected pancreatic cancer Gastrointest Endosc Clin N Am 1998 Jan 8(1):221 35 9405759
Leese T, Neoptolemos JP, Baker AR, et al Management of acute cholangitis and the impact of endoscopic sphincterotomy Br J Surg 1986 Dec 73(12):988 92 3790964
Lehman GA, Sherman S, Nisi R, et al Pancreas divisum: results of minor papilla sphincterotomy Gastrointest Endosc 1993 Jan-Feb 39(1):1 8 8454127
Leung JWC, Emergy R, Cotton PB, et al. Management of malignant obstructive jaundice at the Middlesex hospital. Br J Surg. 1983;70:(584-6. [pmid: 6626917].
Libera ED, Siqueira ES, Morais M, et al Pancreatic pseudocysts transpapillary and transmural drainage HPB Surg 2000 11(5):333 8 10674749
Lomas DJ, Bearcroft PW, Gimson AE MR cholangiopancreatography: prospective comparison of a breath-hold 2D projection technique with diagnostic ERCP Eur Radiol 1999 9(7):1411 7 10460385
Loperfido S, Angelini G, Benedetti G, et al Major early complications from diagnostic and therapeutic ERCP: a prospective multicenter study Gastrointest Endosc 1998 Jul 48(1):1 10 9684657
Lygidakis NJ, van der Heyde MN, Lubbers MJ Evaluation of preoperative biliary drainage in the surgical management of pancreatic head carcinoma Acta Chir Scand 1987 Nov-Dec 153(11-12):665 8 3434110
Maldonado ME, Brady PG, Mamel JJ, et al Incidence of pancreatitis in patients undergoing sphincter of Oddi manometry (SOM) Am J Gastroenterol 1999 Feb 94(2):387 90 10022634
Malfertheiner P, Buchler M. Indications for endoscopic or surgical therapy in chronic pancreatitis. Endoscopy. 1991;23:185-190. [pmid: 1830549].
Mansfield JC, Griffin SM, Wadehra V, et al A prospective evaluation of cytology from biliary strictures Gut 1997 May 40(5):671 7 9203949 1027173
Masci E, Toti G, Mariani A, et al Complications of diagnostic and therapeutic ERCP: a prospective multicenter study Am J Gastroenterol 2001 Feb 96(2):417 23 11232684
Materne R, Van Beers BE, Gigot JF, et al Extrahepatic biliary obstruction: magnetic resonance imaging compared with endoscopic ultrasonography Endoscopy 2000 Jan 32(1):3 9 10691265
Mavrogiannis C, Liatsos C, Romanos A, et al Needle-knife fistulotomy versus needle-knife precut papillotomy for the treatment of common bile duct stones Gastrointest Endosc 1999 Sep 50(3):334 9 10462652
Mehta SN, Pavone E, Barkun JS, et al Predictors of post-ERCP complications in patients with suspected choledocholithiasis Endoscopy 1998 Jun 30(5):457 63 9693893
Menezes N, Marson LP, Debeaux AC, et al Prospective analysis of a scoring system to predict choledocholithiasis Br J Surg 2000 Sep 87(9):1176 81 10971424
Mori K, Nagakawa T, Ohta T, et al Acute pancreatitis associated with anomalous union of the pancreaticobiliary ductal system J Clin Gastroenterol 1991 Dec 13(6):673 7 1761840
Motte S, Deviere J, Dumonceau JM, et al Risk factors for septicemia following endoscopic biliary stenting Gastroenterology 1991 Nov 101(5):1374 81 1936809
Neitlich JD, Topazian M, Smith RC, et al Detection of choledocholithiasis: comparison of unenhanced helical CT and endoscopic retrograde cholangiopancreatography Radiology 1997 Jun 203(3):753 7 9169700
Nelson DB, Freeman ML Major hemorrhage from endoscopic sphincterotomy: Risk factor analysis J Clin Gastroenterol 1994 19(4):283 287 7876506
Neoptolemos JP, Carr-Locke DL, London NJ, et al Controlled trial of urgent endoscopic retrograde cholangiopancreatography and endoscopic sphincterotomy versus conservative treatment for acute pancreatitis due to gallstones Lancet 1988 Oct 29 2(8618):979 83
Neoptolemos JP, Shaw DE, Carr-Locke DL A multivariate analysis of preoperative risk factors in patients with common bile duct stones. Implications for treatment Ann Surg 1989 Feb 209(2):157 61 2916860 1493909
Neuhaus H, Zillinger C, Born P, et al Randomized study of intracorporeal laser lithotripsy versus extracorporeal shock-wave lithotripsy for difficult bile duct stones Gastrointest Endosc 1998 May 47(5):327 34 9609422
Norton SA, Alderson D Prospective comparison of endoscopic ultrasonography and endoscopic retrograde cholangiopancreatography in the detection of bile duct stones Br J Surg 1997 Oct 84(10):1366 9 9361590
Nowak A, Nowakowska-Dulawa E, Marek TE, et al. Final results of the prospective, randomized controlled study on endoscopic sphincterotomy versus conventional management in acute biliary pancreatitis. Gastroenterol. 1995;108.
Ochi Y, Mukawa K, Kiyosawa K, et al Comparing the treatment outcomes of endoscopic papillary dilation and endoscopic sphincterotomy for removal of bile duct stones J Gastroenterol Hepatol 1999 Jan 14(1):90 6 10029284
Ohara H, Hoshino M Single application extracorporeal shock wave lithotrispy is the first choice for patients with pancreatic duct stones Am J Gastroenterol 1996 91(7):1388 1394 8678001
Pedersen FM, Lassen AT, De Muckadell OBS Randomized trial of stent placed above and across the sphincter of Oddi in malignant bile duct obstruction Gastrointest Endosc 1998 48(6):574 579 9852446
Pedersen FM Endoscopic management of malignant biliary obstruction. Is stent size of 10 French gauge better than 7 French gauge? Scand J Gastroenterol 1993 Feb 28(2):185 9 8441913
Peng NJ, Lai KH, Tsay DG, et al Efficacy of quantitative cholescintigraphy in the diagnosis of sphincter of Oddi dysfunction Nucl Med Commun 1994 Nov 15(11):899 904 7870397
Polkowski M, Palucki J, Regula J, et al Helical computed tomographic cholangiography versus endosonography for suspected bile duct stones: a prospective blinded study in non-jaundiced patients Gut 1999 Nov 45(5):744 9 10517914 1727710
Ponchon T, Gagnon P, Berger F, et al Value of endobiliary brush cytology and biopsies for the diagnosis of malignant bile duct stenosis: results of a prospective study Gastrointest Endosc 1995 Dec 42(6):565 72 8674929
Ponsky JL, Duppler DW Endoscopic sphincterotomy and removal of pancreatic duct stones Am Surg 1987 Oct 53(10):613 6 3674609
Prat F, Amouyal G, Amouyal P, et al Prospective controlled study of endoscopic ultrasonography and endoscopic retrograde cholangiography in patients with suspected common-bile duct lithiasis Lancet 1996 Jan 13 347(8994):75 9
Prat F, Chapat O, Ducot B, et al A randomized trial of endoscopic drainage methods for inoperable malignant strictures of the common bile duct Gastrointest Endosc 1998 Jan 47(1):1 7 9468416
Pugliese V, Antonelli G, Vincenti M, et al Endoductal tissue sampling of biliary strictures through endoscopic retrograde cholangiopancreatography (ERCP) Tumori 1997 May-Jun 83(3):698 702 9267491
Rabenstein T, Schneider HT, Bulling D, et al. Analysis of the risk factors associated with endoscopic sphincterotomy techniques: Preliminary results of a prospective study, with emphasis on the reduced risk of acute pancreatitis with low-dose anticoagulation treatment. Endoscopy. 2000;32:10-19. [pmid: 10691266].
Raikar GV, Melin MM, Ress A, et al Cost-effective analysis of surgical palliation versus endoscopic stenting in the management of unresectable pancreatic cancer Ann Surg Oncol 1996 Sep 3(5):470 5 8876889
Rhodes M, Sussman L, Cohen L, et al Randomised trial of laparoscopic exploration of common bile duct versus postoperative endoscopic retrograde cholangiography for common bile duct stones Lancet 1998 Jan 17 351(9097):159 61
Rosch T, Schusdziarra V, Born P, et al Modern imaging methods versus clinical assessment in the evaluation of hospital in-patients with suspected pancreatic disease Am J Gastroenterol 2000 Sep 95(9):2261 70 11007227
Rosseland AR, Solhaug JH Early or delayed endoscopic papillotomy (EPT) in gallstone pancreatitis Ann Surg 1984 Feb 199(2):165 7 6696531 1353326
Santucci L, Natalini G, Sarpi L, et al Selective endoscopic retrograde cholangiography and preoperative bile duct stone removal in patients scheduled for laparoscopic cholecystectomy: a prospective study Am J Gastroenterol 1996 Jul 91(7):1326 30 8677988
Satterfield ST, McCarthy JH, Geenen JE, et al Clinical experience in 82 patients with pancreas divisum: preliminary results of manometry and endoscopic therapy Pancreas 1988 3(3):248 53 3387418
Schmassmann A, Von Gunten E, Knuchel J, et al Wallstents versus plastic stents in malignant biliary obstruction: Effects of stent patency of the first and second stent on patient compliance and survival Am J Gastroenterol 1996 91(4):654 659 8677925
Schneider HT, May A Piezoelectric shock wave lithotripsy of pancreatic duct stones Am J Gastroenterol 1994 89(11):2042 2048 7942733
Schoefl R, Haefner M, Wrba F, et al Forceps biopsy and brush cytology during endoscopic retrograde cholangiopancreatography for the diagnosis of biliary stenoses Scand J Gastroenterol 1997 Apr 32(4):363 8 9140159
Schreiber F, Gurakuqi GC, Pristautz H, et al Sonographically-guided extracorporeal shockwave lithotripsy for pancreatic stones in patients with chronic pancreatitis J Gastroenterol Hepatol 1996 Mar 11(3):247 51 8742921
Schwacha H, Allgaier HP, Deibert P, et al A sphincterotome-based technique for selective transpapillary common bile duct cannulation Gastrointest Endosc 2000 Sep 52(3):387 91 10968855
Sewnath ME, Birjmohun RS, Rauws EA, et al The effect of preoperative biliary drainage on postoperative complications after pancreaticoduodenectomy J Am Coll Surg 2001 Jun 192(6):726 34 11400966
Shepherd HA, Royle G, Ross APR, et al. Endoscopic biliary endoprosthesis in the palliation of malignant obstruction of the distal common bile duct: a randomized trial. Br J Surg. 1988;75:1166-8. [pmid: 2466520].
Sherman S, Hawes RH, Savides TJ, et al Stent-induced pancreatic ductal and parenchymal changes: correlation of endoscopic ultrasound with ERCP Gastrointest Endosc 1996 Sep 44(3):276 82 8885346
Sherman S, Lehman GA, Hawes RH, et al Pancreatic ductal stones: frequency of successful endoscopic removal and improvement in symptoms Gastrointest Endosc 1991 Sep-Oct 37(5):511 7 1936826
Sherman S, Troiano FP, Hawes RH, et al Frequency of abnormal sphincter of Oddi manometry compared with the clinical suspicion of sphincter of Oddi dysfunction Am J Gastroenterol 1991 May 86(5):586 90 2028949
Siegel JH, Veerappan A, Tucker R Bipolar versus monopolar sphincterotomy: a prospective trial Am J Gastroenterol 1994 Oct 89(10):1827 30 7942676
Smith AC, Dowsett JF, Russell RC, et al Randomised trial of endoscopic stenting versus surgical bypass in malignant low bile duct obstruction Lancet 1994 Dec 17 344(8938):1655 60
Smith M, Sherman S Alterations in pancreatic ductal morphology following polyethylene pancreatic stent therapy Gastrointest Endosc 1996 44(3):268 75 8885345
Smithline A, Silverman W, Rogers D, et al . Effect of prophylactic main pancreatic duct stenting on the incidence of biliary endoscopic sphincterotomy-induced pancreatitis in high-risk patients Gastrointest Endosc 1993 39(5):652 7 8224687
Smits ME, Badiga SM, Rauws EA, et al Long-term results of pancreatic stents in chronic pancreatitis Gastrointest Endosc 1995 Nov 42(5):461 7 8566639
Smits ME, Rauws EA, Tytgat GN, et al Endoscopic treatment of pancreatic stones in patients with chronic pancreatitis Gastrointest Endosc 1996 Jun 43(6):556 60 8781932
Snady H, Cooperman A, Siegel J Endoscopic ultrasonography compared with computed tomography with ERCP in patients with obstructive jaundice or small peri-pancreatic mass Gastrointest Endosc 1992 Jan-Feb 38(1):27 34 1612375
Sostre S, Kalloo AN, Spiegler EJ, et al A noninvasive test of sphincter of Oddi dysfunction in postcholecystectomy patients: the scintigraphic score J Nucl Med 1992 Jun 33(6):1216 22 1597742
Soto JA, Alvarez O, Munera F, et al Diagnosing bile duct stones: comparison of unenhanced helical CT, oral contrast-enhanced CT cholangiography, and MR cholangiography AJR Am J Roentgenol 2000 Oct 175(4):1127 34 11000177
Soto JA, Barish MA, Alvarez O, et al Detection of choledocholithiasis with MR cholangiography: comparison of three-dimensional fast spin-echo and single- and multisection half-Fourier rapid acquisition with relaxation enhancement sequences Radiology 2000 Jun 215(3):737 45 10831692
Soto JA, Velez SM, Guzman J Choledocholithiasis: diagnosis with oral-contrast-enhanced CT cholangiography AJR Am J Roentgenol 1999 Apr 172(4):943 8 10587126
Speer AG, Cotton PB, MacRae KD Endoscopic management of malignant biliary obstruction: stents of 10 French gauge are preferable to stents of 8 French gauge Gastrointest Endosc 1988 34(5):412 417 2460394
Speer AG, Cotton PB, Russell RCG, et al. Randomized trial of endoscopic versus percutaneous stent insertion in malignant obstructive jaundice. Lancet. 1987;ii:57-62. [pmid: 2439854].
Stiris MG, Tennoe B, Aadland E, et al MR cholangiopancreaticography and endoscopic retrograde cholangiopancreaticography in patients with suspected common bile duct stones Acta Radiol 2000 May 41(3):269 72 10866083
Sugiyama M, Atomi Y, Hachiya J Magnetic resonance cholangiography using half-Fourier acquisition for diagnosing choledocholithiasis Am J Gastroenterol 1998 Oct 93(10):1886 90 9772049
Sugiyama M, Atomi Y, Wada N, et al Endoscopic transpapillary bile duct biopsy without sphincterotomy for diagnosing biliary strictures: a prospective comparative study with bile and brush cytology Am J Gastroenterol 1996 Mar 91(3):465 7 8633492
Sugiyama M, Atomi Y Acute biliary pancreatitis: the roles of endoscopic ultrasonography and endoscopic retrograde cholangiopancreatography Surgery 1998 Jul 124(1):14 21 9663246
Sugiyama M, Atomi Y Endoscopic ultrasonography for diagnosing choledocholithiasis: a prospective comparative study with ultrasonography and computed tomography Gastrointest Endosc 1997 Feb 45(2):143 6 9040999
Sung JY, Chung SCS, Tsui CP, et al. Omitting side-holes in biliary stents does not improve drainage of the obstructed biliary system: a prospective randomized trial. Gastrointest Endosc. 1994;40:321-5. [pmid: 8056235].
Takehara Y, Ichijo K, Tooyama N, et al Breath-hold MR cholangiopancreatography with a long-echo-train fast spin-echo sequence and a surface coil in chronic pancreatitis Radiology 1994 Jul 192(1):73 8 8208969
Targarona EM, Ayuso RM, Bordas JM, et al Randomised trial of endoscopic sphincterotomy with gallbladder left in situ versus open surgery for common bileduct calculi in high-risk patients Lancet 1996 Apr 6 347(9006):926 9
Tarnasky PR, Palesch YY, Cunningham JT, et al Pancreatic stenting prevents pancreatitis after biliary sphincterotomy in patients with sphincter of Oddi dysfunction Gastroenterology 1998 Dec 115(6):1518 24 9834280
ten Hoopen-Neumann H, Gerhards MF, van Gulik TM, et al Occurrence of implantation metastases after resection of Klatskin tumors Dig Surg 1999 16(3):209 13 10436369
Testoni PA, Caporuscio S, Bagnolo F, et al Idiopathic recurrent pancreatitis: long-term results after ERCP, endoscopic sphincterotomy, or ursodeoxycholic acid treatment Am J Gastroenterol 2000 Jul 95(7):1702 7 10925971
Thatcher BS, Sivak MV, Tedesco FJ, et al Endoscopic sphincterotomy for suspected dysfunction of the sphincter of Oddi Gastrointest Endosc 1987 Apr 33(2):91 5 3569807
Toouli J, Roberts-Thomson IC, Kellow J, et al Manometry based randomised trial of endoscopic sphincterotomy for sphincter of Oddi dysfunction Gut 2000 Jan 46(1):98 102 10601063 1727795
Treacy PJ, Worthley CS Pancreatic stents in the management of chronic pancreatitis Aust NZ J Surg 1996 Apr 66(4):210 3
Trias M, Targarona EM, Ros E, et al Prospective evaluation of a minimally invasive approach for treatment of bile-duct calculi in the high-risk patient Surg Endosc 1997 Jun 11(6):632 5 9171121
Trondsen E, Edwin B, Reiertsen O, et al Prediction of common bile duct stones prior to cholecystectomy: a prospective validation of a discriminant analysis function Arch Surg 1998 Feb 133(2):162 6 9484728
Trondsen E, Edwin B, Reiertsen O, et al Selection criteria for endoscopic retrograde cholangiopancreaticography (ERCP) in patients with gallstone disease World J Surg 1995 Nov-Dec 19(6):852 6 discussion 857 8553678
Tzovaras G, Rowlands BJ Diagnosis and treatment of sphincter of Oddi dysfunction Br J Surg 1998 May 85(5):588 95 9635801
Tzovaras G, Shukla P, Kow L, et al What are the risks of diagnostic and therapeutic endoscopic retrograde cholangiopancreatography? Aust NZ J Surg 2000 Nov 70(11):778 82
Uomo G, Galloro V, Rabitti PG, et al Early endoscopic cholangiopancreatography and sphincterotomy in acute biliary pancreatitis: report of 50 cases Ital J Gastroenterol 1991 Dec 23(9):564 6 1760564
van Berkel AM, Boland C, Redekop WK, et al A prospective randomized trial of Teflon versus polyethylene stents for distal malignant biliary obstruction Endoscopy 1998 Oct 30(8):681 6 9865556
Varghese JC, Farrell MA, Courtney G, et al A prospective comparison of magnetic resonance cholangiopancreatography with endoscopic retrograde cholangiopancreatography in the evaluation of patients with suspected biliary tract disease Clin Radiol 1999 Aug 54(8):513 20 10484218
Varghese JC, Liddell RP, Farrell MA, et al Diagnostic accuracy of magnetic resonance cholangiopancreatography and ultrasound compared with direct cholangiography in the detection of choledocholithiasis Clin Radiol 2000 Jan 55(1):25 35 10650107
Vitale GC, Reed DN, Nguyen CT, et al Endoscopic treatment of distal bile duct stricture from chronic pancreatitis Surg Endosc 2000 Mar 14(3):227 31 10741437
Warshaw AL, Richter JM, Schapiro RH The cause and treatment of pancreatitis associated with pancreas divisum Ann Surg 1983 Oct 198(4):443 52 6625715 1353182
Choledocholithiasis. Web page from Adam.com, available at: http://webmd.lycos.com/content/asset/adam_disease_bile_calculus. Last dated: 1999; last accessed: November 2001.
Wehrmann T, Wiemer K, Lembcke B, et al Do patients with sphincter of Oddi dysfunction benefit from endoscopic sphincterotomy? A 5-year prospective trial Eur J Gastroenterol Hepatol 1996 Mar 8(3):251 6 8724026
Wiersema MJ, Vilmann P, Giovannini M, et al. Endosonography-guided fine-needle aspiration biopsy: diagnostic accuracy and complication assessment. Gastroenterology. 1997;112:1087-95. [pmid: 9097990].
Wiersema MJ, Kochman ML, Cramer HM, et al Endosonography-guided real-time fine-needle aspiration biopsy Gastrointest Endosc 1994 Nov-Dec 40(6):700 7 7859968
Williams DB, Sahai AV, Aabakken L, et al. Endoscopic ultrasound guided fine needle aspiration biopsy: a large single center experience. Gut. 1999;44:720-6. [pmid: 10205212]. [pmcid: 1727480].