# Appendix C. Abbreviations

Appendix C. Abbreviations

Appendix C. Abbreviations

Adeq | adequate
AHRQ | Agency for Healthcare Research and Quality
Alk phos | alkaline phosphatase
ALT | alanine transaminase (see also SGPT)
ARP | acute, recurrent pancreatitis
ASA | American Society of Anesthesiology
ASA/NSAID | aspirin/nonsteroidal anti-inflammatory drugs
AST | aspartate transaminase (see also SGOT)
BCBSA | Blue Cross Blue Shield Association
Bili | bilirubin
BUN | blood urea nitrogen
ca, CA | cancer, carcinoma
CAP | chronic abdominal pain
CBD | common bile duct
CCK | cholecystokinin
CHD | common hepatic duct
cont'd | continued
CP | chronic pancreatitis
CT | computed tomography
CTC | computed tomography cholangiography
cx | control
D | diagnostic
D/S | delayed/selective
Diag | diagnostic
DIC | disseminated intravascular coagulation
dx | diagnosis, diagnostic
EHL | electrohydraulic lithotripsy
EPC | Evidence-based Practice Center
ER | emergency room
ERCP | endoscopic retrograde cholangiopancreatography
ES | endoscopic sphincterotomy
ESWL | extracorporeal shock wave lithotripsy
EUS | endoscopic ultrasound
F/U, f/u | follow-up
FNA | fine-needle aspiration
Fr | French
FV | forward-viewing
GGT | gamma glutamyltransferase
GI | gastrointestinal
Gr | grade
h, hr(s) | hour(s)
HASTE | half-Fourier acquisition single-shot turbo spin echo (a.k.a., "half-Fourier RARE")
Hb | hemoglobin
Hb conc | hemoglobin concentration
Hct | hematocrit
ILL | intracorporeal laser lithotripsy
IOC | intraoperative cholangiogram
IPMT | intraductal papillary mucinous tumor
IU | international units
IV | intravenous
lap | laparoscopic
LCBDE | laparoscopic common bile duct exploration
les | lesion
LFTs | liver function tests
M | manometry
MAP | Medical Advisory Panel
MeSH^®^ | Medical Subject Headings^®^
mo, mos. | month(s)
MRCP | magnetic resonance cholangiography
n | number
n.r. | not reported
n.s., NS | not significant
N/A | not applicable
neg | negative
NIH | National Institutes of Health
NKF | needle-knife fistulotomy
NKPP | needle-knife precut papillotomy
nl | normal
NPV | negative predictive value
OMAR | Office of Medical Applications of Research
OR | odds ratio
pos | positive
postop | postoperative
PPV | positive predictive value
preop | preoperative
prev | prevalence
PS | performance status
pt, pts | patients
PTC | percutaneous transhepatic cholangiographic
PTH | percutaneous transhepatic
RARE | rapid acquisition with relaxation enhancement
RCT | randomized controlled trial
ROC | receiver-operating characteristic
RUQ | right upper quadrant
sens | sensitivity
SGOT | serum glutamic oxaloacetic transaminase (see also AST)
SGPT | serum glutamic pyruvic transaminase (see also ALT)
SO | sphincter of Oddi
SOD | sphincter of Oddi dysfunction
SOI | severity of illness
SOM | sphincter of Oddi manometry
spec | specificity
SSD | statistically significant difference
Stud | study
susp | suspected
SV | side-viewing
T | therapeutic
TAG | Technical Advisory Group
TEC | Technology Evaluation Center
tx | treatment
UGI | upper GI
US | ultrasound
VA | Veterans Administration
WBC | white blood count
yr, yr. | year(s)