# Appendix B. Technical Advisory Group (TAG) Members and Affiliations

- Sidney Cohen, M.D.
- NIH State-of-the-Science Conference Panel Chair
- Professor of Medicine
- Director, Research Programs
- Division of Gastroenterology and Hepatology
- Jefferson Medical College

- Glenn M. Eisen, M.D., M.P.H.
- Associate Professor of Medicine/Gastroenterology
- Vanderbilt University Medical Center

- Michael B. Kimmey, M.D.
- Professor of Medicine
- Assistant Chief of Clinical Affairs
- Division of Gastroenterology
- University of Washington

## External Expert Peer Reviewers

### Gastroenterologists

- Mimi Canto, M.D.
- Assistant Professor of Medicine
- Division of Gastroenterology and Hepatology
- Johns Hopkins University School of Medicine

- Grace Elta, M.D.
- Professor of Medicine
- University of Michigan

- David Weinberg, M.D., M.Sc.
- Associate Professor of Medicine
- Jefferson Medical College

### Surgeons

- Theodore Pappas, M.D., M.S.
- Professor of Surgery
- Duke University

- Michael Sarr, M.D.
- Professor of Surgery
- Mayo Clinic

### Radiologists

- Barbara McNeil, M.D., Ph.D.
- Professor of Radiology
- Harvard Medical School

### Oncologists

- Al B. Benson III, M.D.
- Professor or Medicine
- Division of Hematology Oncology
- Northwestern University

- Alan P. Venook, M.D.
- Associate Professor of Medicine
- Division of Hematology and Oncology
- Department of Medicine, Cancer Research
- University of California San Francisco