# Appendix A. All Retrieved, Excluded Publications

The following reference list shows all publications that were retrieved for review and then not included in the final group of studies for evidence review. The possible reasons for exclusion are listed in the table. Abbreviations denoting the reason for exclusion are printed within each citation (following).

Appendix A. All Retrieved, Excluded Publications

Appendix A. All Retrieved, Excluded Publications

AND | Not prospective in Design OR does Not have consecutively enrolled patients in a retrospective design OR is a single-arm study.
ANMJ | Not a full length report in a peer-reviewed Medical Journal
ANNQ | Content does not address one of the key questions
AN25 | Study is not clearly only diagnostic or therapeutic but is excluded for having less than 25 subjects
R | REVIEW=Article presents no original data
DCOM | No comparison between an eligible diagnostic alternative and ERCP for KQ1-4 Diagnostic.
DPOP | No relevant patient population
DN25 | Fewer than 25 subjects.
DN50 | Fewer than 50 subjects (KQ1 stones only).
DNSI | Not Sufficient Information in study to calculate 2X2 contingency tables
DNCC | Diagnostic populations are not comparable
TCOM | No comparison between an eligible therapeutic alternative and ERCP for KQ1-4 Therapeutic.
TPOP | No relevant patient population
TN25 | Fewer than 25 subjects in each treatment group analyzed separately
TNRO | No Relevant Outcome measure reported
TNCC | Not a Contemporaneous Comparison Study, OR Not comparable populations or treatment settings in a noncontemporaneous study.
TNFU | No follow-up in required # of months.
TNRS | ERCP outcomes not reported separately
NOBJ | No objective pre and post measurement of outcomes in a single arm observational study
NBH | MRCP technique used only non-breath hold technique
5NA | No analysis of relationship between patient, procedure, or provider covariates, and outcome after ERCP.
5N100 | Fewer than 100 patients enrolled in cohort study
5N25 | Fewer than 25 cases in case-controlled study.
5NCV | Does not address potential confounding variables in subject selection or analysis
NOMVA | No multivariate analysis reported
6NCPR | No Clinical Prediction Rule or model predicting likelihood of a relevant pancreaticobiliary condition requiring intervention.
X6 | Duplicative and noncontributory information for prediction of common bile duct stones. This section was not a systematic review
6N100 | Fewer than 100 patients enrolled.

Excluded Studies

Aabakken L, Karesen R, Serck-Hanssen A, and Osnes M. Transpapillary biopsies and brush cytology from the common bile duct. Endoscopy 86 18(2):49-51. Exclusion Code(s): DN25

Abdul Ghani AK. Selective per-operative cholangiography and scoring method for selection. Bangladesh Medical Research Council Bulletin 89 15(2):81-9. Exclusion Code(s): X6

Acosta JM, Ronzano GD, and Pellegrini CA. Ampullary obstruction monitoring in acute gallstone pancreatitis: a safe, accurate, and reliable method to detect pancreatic ductal obstruction. American Journal of Gastroenterology 2000 95(1):122-7. Comment in: Am J Gastroenterol. 2000 Jan;95(1):2-3. Exclusion Code(s): ANNQ

Acosta JM, Rubio Galli OM, Rossi R, Chinellato AV, and Pellegrini CA. Effect of duration of ampullary gallstone obstruction on severity of lesions of acute pancreatitis. Journal of the American College of Surgeons 97 184(5):499-505. Erratum in: J Am Coll Surg 1997 Oct;185(4):423-4. Exclusion Code(s): AND

Adams DB and Anderson MC. Changing concepts in the surgical management of pancreatic pseudocysts. American Surgeon 92 58(3):173-80. Exclusion Code(s): AND

Adams DB and Srinivasan A. Failure of percutaneous catheter drainage of pancreatic pseudocyst. American Surgeon 2000 66(3):256-61. Exclusion Code(s): TN25

Adams DB, Tarnasky PR, Hawes RH, Cunningham JT, Brooker C, Brothers TE, and Cotton PB. Outcome after laparoscopic cholecystectomy for chronic acalculous cholecystitis. American Surgeon 98 64(1):1-5; discussion 5-6. Exclusion Code(s): TCOM

Adzick NS, Shamberger RC, Winter HS, and Hendren WH. Surgical treatment of pancreas divisum causing pancreatitis in children. Journal of Pediatric Surgery 89 24(1):54-8; discussion 58. Exclusion Code(s): DCOM, DN25, TCOM

Agenant DM, Bartelsman JF, and Tijtgat GN. Endoscopic retrograde cholangiopancreaticographic aspects of choledocholithiasis and its sequelae. Radiologia Clinica 78 47(6):397-411. Exclusion Code(s): DPOP, TCOM, ANNQ

Ahearne PM, Baillie JM, Cotton PB, Baker ME, Meyers WC, and Pappas TN. An endoscopic retrograde cholangiopancreatography (ERCP)-based algorithm for the management of pancreatic pseudocysts. American Journal of Surgery 92 163(1):111-5; discussion 115-6. Exclusion Code(s): TCOM TNRO ANNQ

al-Hadeedi S and Leaper DJ. Falls in hemoglobin saturation during ERCP and upper gastrointestinal endoscopy. World Journal of Surgery 91 15(1):88-94. Comment in: World J Surg. 1992 Jan-Feb;16(1):153. Exclusion Code(s): 5NA

al Karawi MA, el Shiekh Mohamed AR, al Shahri MG, and Yasawy MI. Endoscopic sphincterotomy in acute gallstone pancreatitis and cholangitis: a Saudi hospital experience. Hepato-Gastroenterology 93 40(4):396-401. Exclusion Code(s): TCOM

al-Mofarreh MA and Laajam MA. Periampullary cysts: endoscopic management. American Journal of Gastroenterology 92 87(2):211-3. Exclusion Code(s): TN25

AL SHAHRI A M, MOHAMED A R E S, BUSHNAK M A, and AL KARAWI M A. ACUTE BILIARY PANCREATITIS SIX-AND-A-HALF YEARS' EXPERIENCE. SAUDI MED J 92 13(1):46-48. Exclusion Code(s): TN25

Alam MK. Assessment of indicators for predicting choledocholithiasis before laparoscopic cholecystectomy. Annals of Saudi Medicine (Ann. Saudi Med.) 98 18(6):511-513. Exclusion Code(s): DPOP

Alcaraz MJ, De la Morena EJ, Polo A, Ramos A, De la Cal MA, and Gonzalez Mandly A. A comparative study of magnetic resonance cholangiography and direct cholangiography. Revista Espanola de Enfermedades Digestivas 2000 92(7):427-38. Comment in: Rev Esp Enferm Dig. 2000 Jul;92(7):423-6. Exclusion Code(s): DPOP4, AND2, DPOP3

Alhalel R and Haber GB. Endoscopic therapy of pancreatic stones. Gastrointestinal Endoscopy Clinics of North America 95 5(1):195-215. Exclusion Code(s): REVIEW

Aliperti G. Complications related to diagnostic and therapeutic endoscopic retrograde cholangiopancreatography. Gastrointestinal Endoscopy Clinics of North America 96 6(2):379-407. Exclusion Code(s): REVIEW 5NA

Alonso Casado O, Hernandez Gallardo D, Moreno Gonzalez E, Manzanera Diaz M, Gimeno Calvo A, Perez Saborido B, Marques Medina E, and Gutierrez Martin A. Intraductal papillary-mucinous tumors: an entity which is infrequent and difficult to diagnose. Hepato-Gastroenterology 2000 47(31):275-84. Exclusion Code(s): ANNQ

AlQasabi Q, Mofti AB, Suleiman SI, AlMomen A, and Anwar IM. Operative cholangiography in laparoscopic cholecystectomy: Is it essential? Annals of Saudi Medicine (Ann. Saudi Med.) 97 17(2):167-169. Exclusion Code(s): DNSI

Alsumait AR, Jabbari M, and Goresky CA. Pancreaticocolonic fistula: a complication of pancreatitis. Canadian Medical Association Journal 78 119(7):715-9. Exclusion Code(s): DN25, DCOM

Alvarez C, Livingston EH, Ashley SW, Schwarz M, and Reber HA. Cost-benefit analysis of the work-up for pancreatic cancer. American Journal of Surgery 93 165(1):53-8; discussion 58-60. Exclusion Code(s): AND, DN25, DNCC

Alveyn CG, Robertson DA, Wright R, Lowes JA, and Tillotson G. Prevention of sepsis following endoscopic retrograde cholangiopancreatography. Journal of Hospital Infection 91 19 Suppl C(65-70. Exclusion Code(s): ANNQ

Amman RW, Akovbiantz A, Larglader F, and Schueler G. Course and outcome of chronic pancreatitis: Longitudinal study of a mixed medical-surgical series of 245 patients. Gastroenterology 84 86):820-828. Exclusion Code(s): ANNQ

Ammori BJ, Birbas K, Davides D, Vezakis A, Larvin M, and McMahon MJ. Routine vs "on demand" postoperative ERCP for small bile duct calculi detected at intraoperative cholangiography. Clinical evaluation and cost analysis. Surgical Endoscopy 2000 14(12):1123-6. Exclusion Code(s): TN25, X6

Amouyal P, Amouyal G, Levy P, Tuzet S, Palazzo L, Vilgrain V, Gayet B, Belghiti J, Fekete F, and Bernades P. Diagnosis of choledocholithiasis by endoscopic ultrasonography. Gastroenterology 94 106(4):1062-7. Comment in: ACP J Club. 1994 Sep-Oct;121 Suppl 2:50. Exclusion Code(s): DCOM

Anacker H, Lamarque JL, and Pistolesi GF. Efficiency of different radiodiagnostic techniques in pancreatic disorders. European Journal of Radiology 81 1(1):79-84. Exclusion Code(s): AND

Anacker H, Rupp N, and Reiser M. Magnetic resonance (MR) in the diagnosis of pancreatic disease. European Journal of Radiology 84 4(4):265-9. Exclusion Code(s): DPOP, DCOM

Anacker H, Weiss HD, and Kramann B. Endoscopic retrograde pancreaticocholangiography in chronic diseases of the pancreas and in papillary stenoses. Gastrointestinal Radiology 78 3(3):325-34. Exclusion Code(s): AND

Anderson SD, Holley HC, Berland LL, Van Dyke JA, and Stanley RJ. Causes of jaundice during hepatic artery infusion chemotherapy. Radiology 86 161(2):439-42. Exclusion Code(s): DCOM

Andonov V, Tcholakova E, Ananoshtev N, Stanchev I, and Djurkov V. Diagnostic strategies for evaluation and prognosticating the outcome of jaundice among patients with cholestasis caused by neoplastic diseases of the hepatobiliary system and the pancreas. Folia Medica 99 41(1):72-4. Exclusion Code(s): ANNQ

Andriulli A, Leandro G, Niro G, Mangia A, Festa V, Gambassi G, Villani MR, Facciorusso D, Conoscitore P, Spirito F, and De Maio G. Pharmacologic treatment can prevent pancreatic injury after ERCP: a meta-analysis. Gastrointestinal Endoscopy 2000 51(1):1-7. Comment in: Gastrointest Endosc. 2000 Jan;51(1):100-3. Exclusion Code(s): AND BACKGROUND

Andrus CH, Dean PA, and Ponsky JL. Evaluation of safe, effective intravenous sedation for utilization in endoscopic procedures. Surgical Endoscopy 90 4(3):179-83. Exclusion Code(s): ANNQ, NOMVA

Appelros S and Borgstrom A. Incidence, aetiology and mortality rate of acute pancreatitis over 10 years in a defined urban population in Sweden. British Journal of Surgery 99 86(4):465-70. Exclusion Code(s): AND

Aranha GV, Prinz RA, Freeark RJ, and Greenlee HB. The spectrum of biliary tract obstruction from chronic pancreatitis. Archives of Surgery 84 119(5):595-600. Exclusion Code(s): AND

Ariyama J, Sumida M, Shimaguchi S, and Shirakabe H. Integrated approach to the diagnosis of pancreatic carcinoma. Radiation Medicine 83 1(1):46-51. Exclusion Code(s): DCOM

Arregui ME, Davis CJ, Arkush AM, and Nagan RF. Laparoscopic cholecystectomy combined with endoscopic sphincterotomy and stone extraction or laparoscopic choledochoscopy and electrohydraulic lithotripsy for management of cholelithiasis with choledocholithiasis. Surgical Endoscopy 92 6(1):10-5. Exclusion Code(s): TCOM

Arrowsmith JB, Gerstman BB, Fleischer DE, and Benjamin SB. Results from the American Society for Gastrointestinal Endoscopy/U.S. Food and Drug Administration collaborative study on complication rates and drug use during gastrointestinal endoscopy. Gastrointestinal Endoscopy 91 37(4):421-7. Exclusion Code(s): NOMVA

Ashby K and Lo SK. The role of pancreatic stenting in obstructive ductal disorders other than pancreas divisum. Gastrointestinal Endoscopy 95 42(4):306-11. Exclusion Code(s): [TN25]

Ashton CE, McNabb WR, Wilkinson ML, and Lewis RR. Endoscopic retrograde cholangiopancreatography in elderly patients. Age and Ageing 98 27(6):683-8. Comment in: Age Ageing. 1999 Sep;28(5):498-9. Exclusion Code(s): DCOM ANNQ

Bain VG, Abraham N, Jhangri GS, Alexander TW, Henning RC, Hoskinson ME, Maguire CG, Lalor EA, and Sadowski DC. Prospective study of biliary strictures to determine the predictors of malignancy. Canadian Journal of Gastroenterology 2000 14(5):397-402. Exclusion Code(s): DCOM

Bakkevold KE, Arnesjo B, and Kambestad B. Carcinoma of the pancreas and papilla of Vater--assessment of resectability and factors influencing resectability in stage I carcinomas. A prospective multicentre trial in 472 patients. European Journal of Surgical Oncology 92 18(5):494-507. Exclusion Code(s): TNCC, AND

Bakkevold KE, Arnesjo B, and Kambestad B. Carcinoma of the pancreas and papilla of Vater: presenting symptoms, signs, and diagnosis related to stage and tumour site. A prospective multicentre trial in 472 patients. Norwegian Pancreatic Cancer Trial. Scandinavian Journal of Gastroenterology 92 27(4):317-25. Exclusion Code(s): TNCC, AND

Balci NC and Semelka RC. Radiologic diagnosis and staging of pancreatic ductal adenocarcinoma. European Journal of Radiology 2001 38(2):105-12. Exclusion Code(s): AND

Banerjee AK, Grainger SL, and Thompson RP. Trial of low versus high osmolar contrast media in endoscopic retrograde cholangiopancreatography. British Journal of Clinical Practice 90 44(11):445-7. Exclusion Code(s): ANNQ, 5N100

Bar-Meir S and Rotmensch S. A comparison between peroral choledochoscopy and endoscopic retrograde cholangiopancreatography. Gastrointestinal Endoscopy 87 33(1):13-4. Exclusion Code(s): ANNQ

Barish MA, Yucel EK, Soto JA, Chuttani R, and Ferrucci JT. MR cholangiopancreatography: efficacy of three-dimensional turbo spin-echo technique. AJR. American Journal of Roentgenology 95 165(2):295-300. Comment in: AJR Am J Roentgenol. 1995 Aug;165(2):301-2. Comment in: AJR Am J Roentgenol. 1997 Apr;168(4):1115-6. Exclusion Code(s): DN25, DCOM, NBH

Barkun JS, Fried GM, Barkun AN, Sigman HH, Hinchey EJ, Garzon J, Wexler MJ, and Meakins JL. Cholecystectomy without operative cholangiography. Implications for common bile duct injury and retained common bile duct stones. Annals of Surgery 93 218(3):371-7; discussion 377-9. Comment in: Ann Surg. 1995 Jan;221(1);117-9. Exclusion Code(s): TCOM, X6

Barr LL, Frame BC, and Coulanjon A. Proposed criteria for preoperative endoscopic retrograde cholangiography in candidates for laparoscopic cholecystectomy. Surgical Endoscopy 99 13(8):778-81. Exclusion Code(s): 6N100

Barthet M, Affriat C, Bernard JP, Berthezene P, Dagorn JC, and Sahel J. Is biliary lithiasis associated with pancreatographic changes? Gut 95 36(5):761-5. Exclusion Code(s): AND

Barthet M, Portal I, Boujaoude J, Bernard JP, and Sahel J. Endoscopic ultrasonographic diagnosis of pancreatic cancer complicating chronic pancreatitis. Endoscopy 96 28(6):487-91. Exclusion Code(s): DCOM

Barton P, Steininger R, Maier A, Muhlbacher F, and Lechner G. Biliary sludge after liver transplantation: 2. Treatment with interventional techniques versus surgery and/or oral chemolysis. AJR. American Journal of Roentgenology 95 164(4):865-9. Exclusion Code(s): ANNQ

Bassi C, Falconi M, Caldiron E, Salvia R, Sartori N, Butturini G, Contro C, Marcucci S, Casetti L, and Pederzoli P. Assessment and treatment of severe pancreatitis. Protease inhibitor. Digestion 99 60 Suppl 1(5-8. Exclusion Code(s): ANNQ, 5NA

Basso N, Pizzuto G, Surgo D, Materia A, Silecchia G, Fantini A, Fiocca F, and Trentino P. Laparoscopic cholecystectomy and intraoperative endoscopic sphincterotomy in the treatment of cholecysto-choledocholithiasis. Gastrointestinal Endoscopy 99 50(4):532-5. Exclusion Code(s): X6

Bastid C, Sahel J, Filho M, and Sarles H. Diameter of the main pancreatic duct in chronic calcifying pancreatitis. Measurement by ultrasonography versus pancreatography. Pancreas 90 5(5):524-7. Exclusion Code(s): ANNQ

Becker CD, Grossholz M, Becker M, Mentha G, de Peyer R, and Terrier F. Choledocholithiasis and bile duct stenosis: diagnostic accuracy of MR cholangiopancreatography. Radiology 97 205(2):523-30. Exclusion Code(s): DCOM, NBH

Beebe DS, Bubrick MP, Onstad GR, and Hitchcock CR. Management of pancreatic pseudocysts. Surgery, Gynecology and Obstetrics 84 159(6):562-4. Exclusion Code(s): AND

Benjamin IS. Surgical possibilities for bile duct cancer: standard surgical treatment. Annals of Oncology 99 10(Suppl 4):239-42. Exclusion Code(s): AND

Berdah SV, Orsoni P, Bege T, Barthet M, Grimaud JC, and Picaud R. Follow-up of selective endoscopic ultrasonography and/or endoscopic retrograde cholangiography prior to laparoscopic cholecystectomy: a prospective study of 300 patients. Endoscopy 2001 33(3):216-20. Exclusion Code(s): TCOM

Bergman JJ, Tytgat GN, and Huibregtse K. Endoscopic dilatation of the biliary sphincter for removal of bile duct stones: an overview of current indications and limitations. Scandinavian Journal of Gastroenterology. Supplement 98 225(59-65. Exclusion Code(s): DUPLICATE

Bergman JJ, van Berkel AM, Bruno MJ, Fockens P, Rauws EA, Tijssen JG, Tytgat GN, and Huibregtse K. Is endoscopic balloon dilation for removal of bile duct stones associated with an increased risk for pancreatitis or a higher rate of hyperamylasemia? Endoscopy 2001 33(5):416-20. Exclusion Code(s): DUPLICATE 1338

Bergman JJ, van Berkel AM, Bruno MJ, Fockens P, Rauws EA, Tijssen JG, Tytgat GN, and Huibregtse K. A randomized trial of endoscopic balloon dilation and endoscopic sphincterotomy for removal of bile duct stones in patients with a prior Billroth II gastrectomy. Gastrointestinal Endoscopy 2001 53(1):19-26. Exclusion Code(s): ANNQ

Bhutani MS, Hawes RH, Baron PL, Sanders-Cliette A, van Velse A, Osborne JF, and et al. Endoscopic ultrasonography guided fine needle aspiration of malignant pancreatic lesions. Endoscopy 97 29(854-8. Exclusion Code(s): DUP 14049

Bilbao MK, Dotter CT, Lee TG, and Katon RM. Complications of endoscopic retrograde cholangiopancreatography (ERCP). A study of 10,000 cases. Gastroenterology 76 70(3):314-20. Exclusion Code(s): 5NA, NOMVA

Binmoeller KF, Jue P, Seifert H, Nam WC, Izbicki J, and Soehendra N. Endoscopic pancreatic stent drainage in chronic pancreatitis and a dominant stricture: long-term results. Endoscopy 95 27(9):638-44. Exclusion Code(s): [TCOM] TNRO

Binmoeller KF, Seifert H, Gerke H, Seitz U, Portis M, and Soehendra N. Papillary roof incision using the Erlangen-type pre-cut papillotome to achieve selective bile duct cannulation. Gastrointestinal Endoscopy 96 44(6):689-95. Exclusion Code(s): NOMVA

Birk D, Schoenberg MH, Gansauge F, Formentini A, Fortnagel G, and Beger HG. Carcinoma of the head of the pancreas arising from the uncinate process. British Journal of Surgery 98 85(4):498-501. Exclusion Code(s): ANNQ

Bismuth H. Postoperative strictures of the bile duct. 82 209-218. Exclusion Code(s): AND

Boender J, Nix GA, Schutte HE, Lameris JS, van Blankenstein M, and Dees J. Malignant common bile duct obstruction: factors influencing the success rate of endoscopic drainage. Endoscopy 90 22(6):259-62. Exclusion Code(s): TCOM, 5NA, NMOVA

Boraschi P, Braccini G, Gigoni R, Geloni M, and Perri G. MR cholangiopancreatography: value of axial and coronal fast Spin-Echo fat-suppressed T2-weighted sequences. European Journal of Radiology 99 32(3):171-81. Exclusion Code(s): DNSI

Boraschi P, Neri E, Braccini G, Gigoni R, Caramella D, Perri G, and Bartolozzi C. Choledocolithiasis: diagnostic accuracy of MR cholangiopancreatography. Three-year experience. Magnetic Resonance Imaging 99 17(9):1245-53. Exclusion Code(s): DCOM

Born P, Rosch T, Bruhl K, Sandschin W, Weigert N, Ott R, Frimberger E, Allescher HD, Hoffmann W, Neuhaus H, and Classen M. Long-term outcome in patients with advanced hilar bile duct tumors undergoing palliative endoscopic or percutaneous drainage. Zeitschrift fur Gastroenterologie 2000 38(6):483-9. Exclusion Code(s): TNCC, ANI

Bornman PC, Beckingham IJ, and Krige JE. Gallstone pancreatitis--a critical review of current treatment strategies. South African Journal of Surgery 2000 38(4):97-9. Exclusion Code(s): AND

Bornman PC, Harries-Jones EP, Tobias R, vanStiegmann B, and Terblanche J. Prospective controlled trial of transhepatic biliary endoprosthesis versus bypass surgery for incurable carcinoma of head of pancreas. Lancet 86 i(69-71. Exclusion Code(s): TCOM

Bornman PC, Marks IN, Girdwood AH, Clain JE, Narunsky L, Clain DJ, and Wright JP. Is pancreatic duct obstruction or stricture a major cause of pain in calcific pancreatitis? British Journal of Surgery 80 67(6):425-8. Exclusion Code(s): ANNQ AND

Borsch G, Wegener M, Wedmann B, Kissler M, and Glocke M. Clinical evaluation, ultrasound, cholescintigraphy, and endoscopic retrograde cholangiography in cholestasis. A prospective comparative clinical study. Journal of Clinical Gastroenterology 88 10(2):185-90. Exclusion Code(s): DCOM, DNRO

Bortolotti M, Caletti GC, Brocchi E, and et al. Endoscopic manometry in the diagnosis of the postcholecystectomy pain syndrome. Digestion (Digestion) 83 28(3):153-157. Exclusion Code(s): DN25

Bose SM, Mazumdar A, Prakash V S, Kocher R, Katariya S, and Pathak CM. Evaluation of the predictors of choledocholithiasis: comparative analysis of clinical, biochemical, radiological, radionuclear, and intraoperative parameters. Surgery Today 2001 31(2):117-22. Exclusion Code(s): X6

Bottger T, Engelman R, Seifert JK, Low R, and Junginger T. Preoperative diagnostics in pancreatic carcinoma: would less be better? Langenbecks Archives of Surgery 98 383(3-4):243-8. Exclusion Code(s): DCOM

Bottger TC, Boddin J, Duber C, Heintz A, Kuchle R, and Junginger T. Diagnosing and staging of pancreatic carcinoma-what is necessary? Oncology 98 55(2):122-9. Exclusion Code(s): DCOM

Bozkurt T, Braun U, Leferink S, Gilly G, and Lux G. Comparison of pancreatic morphology and exocrine functional impairment in patients with chronic pancreatitis. Gut 94 35(8):1132-6. Exclusion Code(s): ANNQ

Bozkurt T, Orth KH, Butsch B, and Lux G. Long-term clinical outcome of post-cholecystectomy patients with biliary-type pain: results of manometry, non-invasive techniques and endoscopic sphincterotomy. European Journal of Gastroenterology and Hepatology 96 8(3):245-9. Exclusion Code(s): TN25

Brandabur JJ, Kozarek RA, Ball TJ, Hofer BO, Ryan JA, Traverso LW, Freeny PC, and Lewis GP. Nonoperative versus operative treatment of obstructive jaundice in pancreatic cancer: cost and survival analysis. American Journal of Gastroenterology 88 83(10):1132-9. Exclusion Code(s): TNRS

Broughan TA, Sivak MV, and Hermann RE. The management of retained and recurrent bile duct stones. Surgery 85 98(4):746-51. Exclusion Code(s): TCOM

Buffet C, Fourre C, Altman C, Prat F, Fritsch J, Choury A, Briantais MJ, Desgrez A, and Etienne JP. Bile levels of carcino-embryonic antigen in patients with hepatopancreatobiliary disease. European Journal of Gastroenterology and Hepatology 96 8(2):131-4. Exclusion Code(s): DCOM

Bulkin AJ, Tebyani N, and Dorazio RA. Gallstone pancreatitis in the era of laparoscopic cholecystectomy. American Surgeon 97 63(10):900-3. Exclusion Code(s): TN25

Buscail L, Escourrou J, Moreau J, Delvaux M, Louvel D, Lapeyre F, Tregant P, and Frexinos J. Endoscopic ultrasonography in chronic pancreatitis: a comparative prospective study with conventional ultrasonography, computed tomography, and ERCP. Pancreas 95 10(3):251-7. Exclusion Code(s): ANNQ

Calvo MM, Calderon A, Heras I, Duran M, Orive V, Cabriada J, and Astigarraga E. Magnetic resonance study of the pancreatic duct. Revista Espanola de Enfermedades Digestivas 99 91(4):287-96. Exclusion Code(s): DNSI, DNRO, DPOP3

Caroli-Bosc FX, Montet JC, Salmon L, Demarquay JF, Dumas R, Montet AM, Bernard JL, and Delmont JP. Effect of endoscopic sphincterotomy on bile lithogenicity in patients with gallbladder in situ. Endoscopy 99 31(6):437-41. Exclusion Code(s): ANNQ

CARR-LOCKE D L. POST-CHOLECYSTECTOMY SYMPTOMS AND MANOMETRIC DATA. Italian Journal of Gastroenterology 89 21(3):183-186. Exclusion Code(s): OVERLAPS WITH #3969

Carroll BJ, Phillips EH, Rosenthal R, Gleischman S, and Bray JF. One hundred consecutive laparoscopic cholangiograms. Results and conclusions. Surgical Endoscopy 96 10(3):319-23. Exclusion Code(s): TCOM

Catalano MF, Lahoti S, Alcocer E, Geenen JE, and Hogan WJ. Dynamic imaging of the pancreas using real-time endoscopic ultrasonography with secretin stimulation. Gastrointestinal Endoscopy 98 48(6):580-7. Exclusion Code(s): DCOM

Catalano MF, Lahoti S, Geenen JE, and Hogan WJ. Prospective evaluation of endoscopic ultrasonography, endoscopic retrograde pancreatography, and secretin test in the diagnosis of chronic pancreatitis. Gastrointestinal Endoscopy 98 48(1):11-7. Comment in: Gastrointest Endosc. 1998 Jul;48(1):102-6. Comment in: Gastrointest Endosc. 1999 Aug;50(2):303-4. Exclusion Code(s): ANNQ

Cavina E, Franceschi M, Sidoti F, Goletti O, Buccianti P, and Chiarugi M. Laparo-endoscopic "rendezvous": a new technique in the choledocholithiasis treatment. Hepato-Gastroenterology 98 45(23):1430-5. Exclusion Code(s): TN25

Chak A, Hawes RH, Cooper GS, Hoffman B, Catalano MF, Wong RC, Herbener TE, and Sivak MV. Prospective assessment of the utility of EUS in the evaluation of gallstone pancreatitis. Gastrointestinal Endoscopy 99 49(5):599-604. Exclusion Code(s): AND3

Chan AC, Chung SC, Wyman A, Kwong KH, Ng EK, Lau JY, Lau WY, Lai CW, Sung JJ, and Li AK. Selective use of preoperative endoscopic retrograde cholangiopancreatography in laparoscopic cholecystectomy. Gastrointestinal Endoscopy 96 43(3):212-5. Exclusion Code(s): X6

Chan YL, Chan AC, Lam WW, Lee DW, Chung SS, Sung JJ, Cheung HS, Li AK, and Metreweli C. Choledocholithiasis: comparison of MR cholangiography and endoscopic retrograde cholangiography. Radiology 96 200(1):85-9. Exclusion Code(s): DCOM NBH

Chang-Chien CS. Do juxtapapillary diverticula of the duodenum interfere with cannulation at endoscopic retrograde cholangiopancreatography? A prospective study. Gastrointestinal Endoscopy 87 33(4):298-300. Exclusion Code(s): NOMVA

Chang KJ, Katz KD, Durbin TE, Erickson RA, Butler JA, Lin F, and et al. Endoscopic ultrasound-guided fine-needle aspiration. Gastrointestinal Endoscopy 94 40(694-9. Exclusion Code(s): DUP 1648

Chang L, Lo SK, Stabile BE, Lewis RJ, and de Virgilio C. Gallstone pancreatitis: a prospective study on the incidence of cholangitis and clinical predictors of retained common bile duct stones. American Journal of Gastroenterology 98 93(4):527-31. Comment in: Am J Gastroenterol. 1998 Apr;93(4):493-6. Exclusion Code(s): X6

Changchien CS, Chuah SK, and Chiu KW. Is ERCP necessary for symptomatic gallbladder stone patients before laparoscopic cholecystectomy? American Journal of Gastroenterology 95 90(12):2124-7. Exclusion Code(s): X6

Chen Yang K, Abdulian John D, Escalante-Glorsky Susana, Youssef Adel I, Foliente Roy L, and Collen Martin J. Clinical outcome of post-ERCP pancreatitis: Relationship to history of previous pancreatitis. American Journal of Gastroenterology 95 90(12):2120-2123. Exclusion Code(s): NOMVA

Chen YK, Foliente RL, Santoror MJ, Walter MH, and Collen MJ. Endoscopic sphincterotomy-induced pancreatitis: increased risk associated with non dilated bile ducts and sphincter of Oddi dysfunction. American Journal of Gastroenterology 94 89(327-333. Exclusion Code(s): NOMVA

Chen YK, McCarter TL, Santoro MJ, Hanson BL, and Collen MJ. Utility of endoscopic retrograde cholangiopancreatography in the evaluation of idiopathic abdominal pain. American Journal of Gastroenterology 93 88(9):1355-8. Exclusion Code(s): DCOM

CHEVILLOTTE G, SAHEL J, PIETRI H, and SARLES H. ACUTE RECURRENT PANCREATITIS ASSOCIATED WITH PANCREAS DIVISUM CLINICAL STUDY OF 12 CASES. Gastroenterologie Clinique et Biologique 84 8(4):352-358. Exclusion Code(s): TNRO

Choudari CP, Sherman S, Fogel EL, Phillips S, Kochell A, Flueckiger J, and Lehman GA. Success of ERCP at a referral center after a previously unsuccessful attempt. Gastrointestinal Endoscopy 2000 52(4):478-83. Exclusion Code(s): 5NCV

Chrysikopoulos H, Papanikolaou N, Pappas J, Roussakis A, and Andreou J. MR cholangiopancreatography at 0.5 T with a 3D inversion recovery turbo-spin-echo sequence. European Radiology 97 7(8):1318-22. Exclusion Code(s): DNSI

Ciriza C, Dajil S, Jimenez C, Urquiza O, Karpman G, Garcia L, and Romero MJ. Five-year analysis of endoscopic retrograde cholangiopancreatography in the Hospital del Bierzo. Revista Espanola de Enfermedades Digestivas 99 91(10):693-702. Exclusion Code(s): 5NCV, NOMVA

Clair DG, Carr-Locke DL, Becker JM, and Brooks DC. Routine cholangiography is not warranted during laparoscopic cholecystectomy. Archives of Surgery 93 128(5):551-4; discussion 554-5. Exclusion Code(s): TCOM

Clarke BD and Lehman GA. "Cloggology" revisited: endoscopic or surgical decompression of malignant biliary obstruction. American Journal of Gastroenterology 90 85(11):1533-4. Exclusion Code(s): Overlap with #1124

Contractor QQ, Boujemla M, Contractor TQ, and el-Essawy OM. Abnormal common bile duct sonography. The best predictor of choledocholithiasis before laparoscopic cholecystectomy. Journal of Clinical Gastroenterology 97 25(2):429-32. Exclusion Code(s): DPOP

Cooperman M, Ferrara JJ, Carey LC, Thomas FB, Martin EW, and Fromkes JJ. Endoscopic retrograde cholangiopancreatography. Its use in the evaluation of nonjaundiced patients with the postcholecystectomy syndrome. Archives of Surgery 81 116(5):606-9. Exclusion Code(s): Exclusion Code: DCOM

Cooperman M, Ferrara JJ, Carey LC, Thomas FB, Martin EW, and Fromkes JJ. Idiopathic acute pancreatitis: the value of endoscopic retrograde cholangiopancreatography. Surgery 81 90(4):666-70. Exclusion Code(s): TCOM

Coppola R, Riccioni ME, Ciletti S, Cosentino L, Coco C, Magistrelli P, and Picciocchi A. Analysis of complications of endoscopic sphincterotomy for biliary stones in a consecutive series of 546 patients. Surgical Endoscopy 97 11(2):129-32. Exclusion Code(s): NOMVA [pending]

Corazziari E, Cicala M, and Habib FI. Hepatoduodenal bile transit in cholecystectomized subjects - relationship with sphincter of Oddi function and diagnostic value. Digestive Diseases and Sciences 94 39(1985-93. Exclusion Code(s): DN25

Cremer M, Deviere J, Delhaye M, Baize M, and Vandermeeren A. Stenting in severe chronic pancreatitis: results of medium-term follow-up in seventy-six patients. Endoscopy 91 23(3):171-6. Exclusion Code(s): [TCOM] TNRO

Cuschieri A, Croce E, Faggioni A, Jakimowicz J, Lacy A, Lezoche E, Morino M, Ribeiro VM, Toouli J, Visa J, and Wayand W. EAES ductal stone study. Preliminary findings of multi-center prospective randomized trial comparing two-stage vs single-stage management. Surgical Endoscopy 96 10(12):1130-5. Comment in: Surg Endosc. 1996 Dec;10(12):1124. Comment in: Surg Endosc. 1997 Oct;11(10):1057-8. Exclusion Code(s): AND--ACTUALLY A DUPLICATE STUDY FROM AN INCLUDED STUDY

Daradkeh S, Shennak M, and Abu-Khalaf M. Selective use of perioperative ERCP in patients undergoing laparoscopic cholecystectomy. Hepato-Gastroenterology 2000 47(35):1213-5. Exclusion Code(s): X6

Darweesh RM, Dodds WJ, Hogan WJ, Geenen JE, Collier BD, Shaker R, Kishk SM, Stewart ET, Lawson TL, Hassanein EH, and et al. Efficacy of quantitative hepatobiliary scintigraphy and fatty-meal sonography for evaluating patients with suspected partial common duct obstruction. Gastroenterology 88 94(3):779-86. Exclusion Code(s): DCOM

Davids PHP, Tanka AKF, Rauws EAJ, Van Gulik TM, Van LeeuwenDJ, De Wit LT, Verbeek PCM, Huibregtse K, Van der Heyde MN, and Tytgat GNJ. Benign biliary strictures: Surgery or endoscopy? Annals of Surgery (Ann. Surg.) 93 217(3):237-243. Exclusion Code(s): TPOP2, ANNQ3

Davidson B, Varsamidakis N, Dooley J, Deery A, Dick R, Kurzawinski T, and Hobbs K. Value of exfoliative cytology for investigating bile duct strictures. Gut 92 33(10):1408-11. Exclusion Code(s): DCOM

Davis WZ, Cotton PB, Arias R, Williams D, and Onken JE. ERCP and sphincterotomy in the context of laparoscopic cholecystectomy: academic and community practice patterns and results. American Journal of Gastroenterology 97 92(4):597-601. Exclusion Code(s): NOMVA

de Ledinghen V, Lecesne R, Raymond JM, Gense V, Amouretti M, Drouillard J, Couzigou P, and Silvain C. Diagnosis of choledocholithiasis: EUS or magnetic resonance cholangiography? A prospective controlled study. Gastrointestinal Endoscopy 99 49(1):26-31. Exclusion Code(s): DCOM

De Waele B, Peterson T, Smekens L, and Willems G. Common bile duct stones in acute biliary pancreatitis: an endoscopic study. Surgical Laparoscopy and Endoscopy 97 7(3):248-50. Exclusion Code(s): DCOM

Deans GT, Sedman P, Martin DF, Royston CM, Leow CK, Thomas WE, and Brough WA. Are complications of endoscopic sphincterotomy age related? Gut 97 41(4):545-8. Comment in: Gut. 1998 May;42(5):758. Exclusion Code(s): NOMVA

Del Favero G, Fabris C, Angonese C, Basso D, Rebuffi A, Costantin G, Matarazzo R, Di Mario F, and Naccarato R. Cytology in the diagnosis of pancreatic cancer. International Journal of Pancreatology 88 3 Suppl 1(S137-41. Exclusion Code(s): DCOM

Delhaye M, Vandermeeren A, Baize M, and Cremer M. Extracorporeal shock-wave lithotripsy of pancreatic calculi. Gastroenterology 92 102(2):610-20. Exclusion Code(s): [TCOM] TNRO

Demarquay JF, Dumas R, Buckley MJ, Conio M, Zanaldi H, Hastier P, Caroli-Bosc FX, and Delmont JP. Endoscopic retrograde cholangiopancreatography in patients with Billroth II gastrectomy. Italian Journal of Gastroenterology and Hepatology 98 30(3):297-300. Comment in: Ital J Gastroenterol Hepatol. 1998 Jun;30(3):306-9. Exclusion Code(s): NOMVA

Desa LA and Williamson RC. On-table pancreatography: importance in planning operative strategy. British Journal of Surgery 90 77(10):1145-50. Exclusion Code(s): AND

Deviere J, Baize M, Buset M, and et al. Complications of internal endoscopic biliary drainage. Acta Endoscopica 86 16(19-29. Exclusion Code(s): ANNQ TCOM TPOP 5N100

Dickinson RJ and Davies S. Post-ERCP pancreatitis and hyperamylasaemia: the role of operative and patient factors. European Journal of Gastroenterology and Hepatology 98 10(5):423-8. Erratum in: Eur J Gastroenterol Hepatol 1998 Aug;10(8):731. Exclusion Code(s): NOMVA

Diederichs CG, Staib L, Vogel J, Glasbrenner B, Glatting G, Brambs HJ, Beger HG, and Reske SN. Values and limitations of 18F-fluorodeoxyglucose-positron-emission tomography with preoperative evaluation of patients with pancreatic masses. Pancreas 2000 20(2):109-16. Exclusion Code(s): DCOM, AND

DILAWARI J B, KATARIA S, RAO P N, ANAND B S, and SHARMA V P. ENDOSCOPIC RETROGRADE CHOLANGIO PANCREATOGRAPHY AND PERCUTANEOUS TRANSHEPATIC CHOLANGIOGRAPHY IN OBSTRUCTIVE JAUNDICE. Indian Journal of Medical Research 82 75(FEB):287-293. Exclusion Code(s): DCOM, DNSI

DiMagno EP, Malagelada JR, Taylor WF, and Go VL. A prospective comparison of current diagnostic tests for pancreatic cancer. New England Journal of Medicine 77 297(14):737-42. Exclusion Code(s): DCOM

Dixit VK, Jain AK, Agrawal AK, and Gupta JP. Obstructive jaundice--a diagnostic appraisal. Journal of the Association of Physicians of India 93 41(4):200-2. Exclusion Code(s): DCOM, DNSI

Dorman JP, Franklin ME, and Glass JL. Laparoscopic common bile duct exploration by choledochotomy. An effective and efficient method of treatment of choledocholithiasis. Surgical Endoscopy 98 12(7):926-8. Exclusion Code(s): TCOM AND

Dowsett JF, Williams SJ, Hatfield ARW, Houghton LT, and Russell RCG. Does stent diameter matter in the endoscopic palliation of malignant biliary obstruction: a randomized trial of 10 FG versus 12 FG endoprostheses. Gastroenterology 89 96(A128. Exclusion Code(s): ANMJ

DRUGOVA B, BALAS V, HORACEK F, and KRIVANEK J. COMPARISON OF EFFICIENCY OF PHARMACOANGIOGRAPHY AND OTHER INVESTIGATIVE METHODS (ENDOSCOPIC RETROGRADE CHOLANGIOPANCREATOGRAPHY, COMPUTER TOMOGRAPHY, ULTRASOUND) IN THE DIAGNOSIS OF PANCREATIC TUMORS. ACTA UNIV CAROL MED 84 30(7-8):545-564. Exclusion Code(s): DNSI

Ducreux M, Liguory C, Lefebvre JF, Ink O, Choury A, Fritsch J, Bonnel D, Derhy S, and Etienne JP. Management of malignant hilar biliary obstruction by endoscopy. Results and prognostic factors. Digestive Diseases and Sciences 92 37(5):778-83. Exclusion Code(s): TCOM

Duensing RA, Williams RA, Collins JC, and Wilson SE. Managing choledocholithiasis in the laparoscopic era. American Journal of Surgery 95 170(6):619-23. Exclusion Code(s): 6NCPR

Dumonceau JM, Deviere J, Le Moine O, Delhaye M, Vandermeeren A, Baize M, Van Gansbeke D, and Cremer M. Endoscopic pancreatic drainage in chronic pancreatitis associated with ductal stones: long-term results. Gastrointestinal Endoscopy 96 43(6):547-55. Comment in: Gastrointest Endosc. 1996 Jun;43(6):625-6. Exclusion Code(s): [TCOM] TNRO

Dwerryhouse SJ, Brown E, and Vipond MN. Prospective evaluation of magnetic resonance cholangiography to detect common bile duct stones before laparoscopic cholecystectomy. British Journal of Surgery 98 85(10):1364-6. Exclusion Code(s): DCOM, NBH

Earnshaw JJ, Hayter JT, Teastale C, and Beckly DE. Should endoscopic stenting be the initial treatment of malignant biliary obstruction? Annals of the Royal College of Surgeons of England 92 74(338-41. Exclusion Code(s): TCOM

Elias E, Hamlyn AN, Jain S, Long RG, Summerfield JA, Dick R, and Sherlock S. A randomized trial of percutaneous transhepatic cholangiography with the Chiba needle versus endoscopic retrograde cholangiography for bile duct visualization in jaundice. Gastroenterology 76 71(3):439-43. Exclusion Code(s): ANNQ, DNSI

Ell C, Rabenstein T, Schneider HT, Ruppert T, Nicklas M, and Bulling D. Safety and efficacy of pancreatic sphincterotomy in chronic pancreatitis. Gastrointestinal Endoscopy 98 48(3):244-9. Exclusion Code(s): TNCC

Elton E, Howell DA, Parsons WG, Qaseem T, and Hanson BL. Endoscopic pancreatic sphincterotomy: indications, outcome, and a safe stentless technique. Gastrointestinal Endoscopy 98 47(3):240-9. Exclusion Code(s): 5NVCV, NOMVA

Endo Y, Morii T, Tamura H, and Okuda S. Cytodiagnosis of pancreatic malignant tumors by aspiration, under direct vision, using a duodenal fiberscope. Gastroenterology (Gastroenterology) 74 67(5):944-951. Exclusion Code(s): DCOM

Erickson RA and Garza AA. EUS with EUS-guided fine-needle aspiration as the first endoscopic test for the evaluation of obstructive jaundice. Gastrointestinal Endoscopy 2001 53(4):475-84. Exclusion Code(s): AND

Eversman D, Fogel EL, Rusche M, Sherman S, and Lehman GA. Frequency of abnormal pancreatic and biliary sphincter manometry compared with clinical suspicion of sphincter of Oddi dysfunction. Gastrointestinal Endoscopy 99 50(5):637-41. Exclusion Code(s): TCOM BACKGROUND

Falkenstein DB, Riccobono C, Sidhu G, Abrams RM, Seliger G, and Zimmon DS. The endoscopic intrahepatic cholangiogram. Clinicopathologic correlation with postmortem cholangiograms. Investigative Radiology 75 10(4):358-65. Exclusion Code(s): ANNQ

Fanelli RD and Gersin KS. Laparoscopic endobiliary stenting: a simplified approach to the management of occult common bile duct stones. Journal of Gastrointestinal Surgery 2001 5(1):74-80. Exclusion Code(s): TCOM

Fanning NF, Horgan PG, and Keane FB. Evolving management of common bile duct stones in the laparoscopic era. Journal of the Royal College of Surgeons of Edinburgh 97 42(6):389-94. Exclusion Code(s): TNCC

Farup PG and Tjora S. Sphincter of Oddi dysfunction. Dynamic cholescintigraphy and endoscopic retrograde cholangiopancreatography with papillotomy in diagnosis, treatment, and follow-up study. Scandinavian Journal of Gastroenterology 89 24(8):956-60. Exclusion Code(s): DN25, DCOM

Feinberg SB, Schreiber DR, and Goodale R. Comparison of ultrasound pancreatic scanning and encoscopic retrograde cholangiopancreatograms: a retrospective study. Journal of Clinical Ultrasound 77 5(2):96-100. Exclusion Code(s): DCOM

Feller ER. Endoscopic retrograde cholangiopancreatography in the diagnosis of unexplained pancreatitis. Archives of Internal Medicine 84 144(9):1797-9. Exclusion Code(s): DCOM

Festen C, Severijnen R, vd Staak F, and Rieu P. Chronic relapsing pancreatitis in childhood. Journal of Pediatric Surgery 91 26(2):182-3. Exclusion Code(s): AND

Fiore NF, Ledniczky G, Wiebke EA, Broadie TA, Pruitt AL, Goulet RJ, Grosfeld JL, and Canal DF. An analysis of perioperative cholangiography in one thousand laparoscopic cholecystectomies. Surgery 97 122(4):817-21; discussion 821-3. Exclusion Code(s): DNSI

Fletcher DR, Hurley RA, and Hardy KJ. The effect of selective therapy on malignant obstructive jaundice. Medical Journal of Australia 89 151(10):560-4. Exclusion Code(s): TNCC, 2NCV

Fockens P, Johnson TG, van Dullemen HM, Huibregtse K, and Tytgat GN. Endosonographic imaging of pancreatic pseudocysts before endoscopic transmural drainage. Gastrointestinal Endoscopy 97 46(5):412-6. Exclusion Code(s): DCOM

Foley WD, Stewart ET, Lawson TL, Geenan J, Loguidice J, Maher L, and Unger GF. Computed tomography, ultrasonography, and endoscopic retrograde cholangiopancreatography in the diagnosis of pancreatic disease: a comparative study. Gastrointestinal Radiology 80 5(1):29-35. Exclusion Code(s): DCOM

Foutch PG. A prospective assessment of results for needle-knife papillotomy and standard endoscopic sphincterotomy. Gastrointestinal Endoscopy 95 41(1):25-32. Exclusion Code(s): 5NCV NOMVA

Franceschi D, Brandt C, Margolin D, Szopa B, Ponsky J, Priebe P, Stellato T, and Eckhauser ML. The management of common bile duct stones in patients undergoing laparoscopic cholecystectomy. American Surgeon 93 59(8):525-32. Exclusion Code(s): AND

Frederic N, Deltenre M, d'Hondt M, de Reuck M, Hermanus A, and Potvliege R. Comparative study of ultrasound and ERCP in the diagnosis of hepatic, biliary and pancreatic diseases: a prospective study based on a continuous series of 424 patients. European Journal of Radiology 83 3(3):208-11. Exclusion Code(s): DCOM

Freeman ML, Nelson DB, Sherman S, Haber GB, Fennerty MB, DiSario JA, Ryan ME, Kortan PP, Dorsher PJ, Shaw MJ, Herman ME, Cunningham JT, Moore JP, Silverman WB, Imperial JC, Mackie RD, Jamidar PA, Yakshe PN, Logan GM, and Pheley AM. Same-day discharge after endoscopic biliary sphincterotomy: observations from a prospective multicenter complication study. The Multicenter Endoscopic Sphincterotomy (MESH) Study Group. Gastrointestinal Endoscopy 99 49(5):580-6. Comment in: Gastrointest Endosc. 1999 May;49(5):660-2. Exclusion Code(s): 5NRO

Freeny PC and Ball TJ. Endoscopic retrograde cholangiopancreatography (ERCP) and percutaneous transhepatic cholangiography (PTC) in the evaluation of suspected pancreatic carcinoma: diagnostic limitations and contemporary roles. Cancer 81 47(6 Suppl):1666-78. Exclusion Code(s): AND

Frey CF, Burbige EJ, Meinke WB, Pullos TG, Wong HN, Hickman DM, and Belber J. Endoscopic retrograde cholangiopancreatography. American Journal of Surgery 82 144(1):109-14. Exclusion Code(s): AND

Frick MP, O'Leary JF, Walker Jr HC, and Goodale RL. Accuracy of endoscopic retrograde cholangiopancreatography (ERCP) in differentiating benign and malignant pancreatic disease. Gastrointestinal Radiology (Gastrointest. Radiol.) 82 7(3):241-244. Exclusion Code(s): Exclusion Code: DCOM

Frossard JL, Sosa-Valencia L, Amouyal G, Marty O, Hadengue A, and Amouyal P. Usefulness of endoscopic ultrasonography in patients with "idiopathic" acute pancreatitis. American Journal of Medicine 2000 109(3):196-200. Exclusion Code(s): DCOM

Fuji T, Amano H, Ohmura R, Akiyama T, Aibe T, and Takemoto T. Endoscopic Pancreatic Sphincterotomy--Technique and Evaluation. Endoscopy 89 21):27-30. Exclusion Code(s): TN25 TNRO

Fulcher AS, Turner MA, Capps GW, Zfass AM, and Baker KM. Half-Fourier RARE MR cholangiopancreatography: experience in 300 subjects. Radiology 98 207(1):21-32. Exclusion Code(s): AND

Fulcher AS, Turner MA, Franklin KJ, Shiffman ML, Sterling RK, Luketic VA, and Sanyal AJ. Primary sclerosing cholangitis: evaluation with MR cholangiography-a case-control study. Radiology 2000 215(1):71-80. Exclusion Code(s): ANNQ

Fullarton GM, Allan A, Hilditch T, and Murray WR. Quantitative sup 9sup 9sup mTc-DISIDA scanning and endoscopic biliary manometry in sphincter of Oddi dysfunction. Gut (Gut) 88 29(10):1397-1401. Exclusion Code(s): DN25

Fullarton GM and Murray WR. Evaluation of endoscopic sphincterotomy in sphincter of oddi dysfunction. Endoscopy 92 24(199-202. Exclusion Code(s): TN25

Furukawa T, Tsukamoto Y, Naitoh Y, Hirooka Y, and Hayakawa T. Differential diagnosis between benign and malignant localized stenosis of the main pancreatic duct by intraductal ultrasound of the pancreas. American Journal of Gastroenterology 94 89(11):2038-41. Exclusion Code(s): DCOM2, DCOM3

Furukawa T, Tsukamoto Y, Naitoh Y, Hirooka Y, and Katoh T. Evaluation of intraductal ultrasonography in the diagnosis of pancreatic cancer. Endoscopy 93 25(9):577-81. Comment in: Endoscopy. 1993 Nov;25(9):600-2. Exclusion Code(s): DCOM

Furukawa T, Tsukamoto Y, Naitoh Y, Mitake M, Hirooka Y, and Hayakawa T. Differential diagnosis of pancreatic diseases with an intraductal ultrasound system. Gastrointestinal Endoscopy 94 40(2 Pt 1):213-9. Exclusion Code(s): DCOM2, DCOM3

Gagnon P, Boustiere C, Ponchon T, Valette PJ, Genin G, and Labadie M. Percutaneous fine-needle aspiration cytologic study of main pancreatic duct stenosis under pancreatographic guidance. Cancer 91 67(9):2395-400. Exclusion Code(s): DCOM

Georgopoulos SK, Schwartz LH, Jarnagin WR, Gerdes H, Breite I, Fong Y, Blumgart LH, and Kurtz RC. Comparison of magnetic resonance and endoscopic retrograde cholangiopancreatography in malignant pancreaticobiliary obstruction. Archives of Surgery 99 134(9):1002-7. Exclusion Code(s): DN25

Gholson CF, Favrot D, Vickers B, Dies D, and Wilder W. Delayed hemorrhage following endoscopic retrograde sphincterotomy for choledocholithiasis. Digestive Diseases and Sciences 96 41(5):831-4. Exclusion Code(s): 5NCV, NOMVA

Gigot JF. Actual management of common bile duct stones: a continuous evolving approach. Annali Italiani di Chirurgia 98 69(6):741-50. Exclusion Code(s): AND

Gilinsky NH, Bornman PC, Girdwood AH, and Marks IN. Diagnostic yield of endoscopic retrograde cholangiopancreatography in carcinoma of the pancreas. British Journal of Surgery 86 73(7):539-43. Exclusion Code(s): DCOM

Gillams A, Cheslyn-Curtis S, Russell RC, and Lees WR. Can cholangiography be safely abandoned in laparoscopic cholecystectomy? Annals of the Royal College of Surgeons of England 92 74(4):248-51. Comment in: Ann R Coll Surg Engl. 1992 Nov;74(6):439-40. Comment in: Ann R Coll Surg Engl. 1992 Nov;74(6):440. Comment in: Ann R Coll Surg Engl. 1993 Jan;75(1):67-9. Exclusion Code(s): X6

Gilmore IT, Pemberton J, and Thompson RPH. Retrograde cholangiopancreatography in the diagnosis of carcinoma of the pancreas. Gastrointestinal Endoscopy (Gastrointest. Endosc.) 82 28(2):77-78. Exclusion Code(s): DCOM

Giovannini M and Seitz JF. Endoscopic ultrasonography with a linear-type echoendoscope in the evaluation of 94 patients with pancreatobiliary disease. Endoscopy 94 26(7):579-85. Exclusion Code(s): DCOM

Glasbrenner B, Ardan M, Boeck W, Preclik G, Moller P, and Adler G. Prospective evaluation of brush cytology of biliary strictures during endoscopic retrograde cholangiopancreatography. Endoscopy 99 31(9):712-7. Comment in: Endoscopy. 1999 Nov;31(9):758-60. Exclusion Code(s): DCOM

Glattli A, Stain SC, Baer HU, Schweizer W, Triller G, and Blumgart LH. Unresectable malignant biliary obstruction: treatment by self-expandable biliary endoprosthesis. HTB Surg 93 6(175-84. Exclusion Code(s): TCOM

Go VL, Taylor WF, and DiMagno EP. Efforts at early diagnosis of pancreatic cancer: the Mayo Clinic Experience. Cancer 81 47(6 Suppl):1698-705. Exclusion Code(s): DCOM

Goff JS. Common bile duct sphincter of Oddi stenting in patients with suspected sphincter dysfunction. American Journal of Gastroenterology 95 90(586-9. Exclusion Code(s): TN25

Golub R, Cantu R, and Tan M. The prediction of common bile duct stones using a neural network. Journal of the American College of Surgeons 98 187(6):584-90. Exclusion Code(s): X6

Goodale RL, Condie RM, Gajl-Peczalska K, Taylor T, O'Leary J, Dressel T, Borner JW, Frick MP, and Fryd DS. Clinical and secretory differences in pancreatic cancer and chronic pancreatitis. Annals of Surgery 81 194(2):193-8. Exclusion Code(s): DCOM, DPOP

Goodale RL, Gajl-Peczalska K, Dressel T, and Samuelson J. Cytologic studies for the diagnosis of pancreatic cancer. Cancer 81 47(6 Suppl):1652-5. Exclusion Code(s): DCOM

Goodman AJ, Neoptolemos JP, Carr-Locke DL, Finlay DB, and Fossard DP. Detection of gall stones after acute pancreatitis. Gut 85 26(2):125-32. Exclusion Code(s): DCOM

Gorelick AB, Scheiman JM, and Fendrick AM. Identification of patients with resectable pancreatic cancer: at what stage are we? American Journal of Gastroenterology 98 93(10):1995-6. Exclusion Code(s): ANNQ

Gorgul A, Kayhan B, Mentes BB, Kayhan B, and Aki Z. The comparison of the effect of somatostatin and SMS 201-995 on enzyme change following endoscopic retrograde cholangiopancreotography. Gazi Medical Journal (Gazi Med. J.) 98 9(1):9-13. Exclusion Code(s): ANNQ

Grace PA and Williamson RCN. Modern management of pancreatic pseudocysts. British Journal of Surgery 93 80(May):573-581. Exclusion Code(s): AND [pending]

Graham SM, Flowers JL, Scott TR, Bailey RW, Scovill WA, Zucker KA, and Imbembo AL. Laparoscopic cholecystectomy and common bile duct stones. The utility of planned perioperative endoscopic retrograde cholangiography and sphincterotomy: experience with 63 patients. Annals of Surgery 93 218(1):61-7. Comment in: Ann Surg. 1995 Jan;221(1):117-9. Exclusion Code(s): TNCC

Granke K, Jordan FT, Mazzeo RJ, and Strasius SR. Endoscopic papillotomy: impact on community hospital treatment of common duct stones. American Surgeon 88 54(6):347-51. Exclusion Code(s): TNCC

GRANT T H and EFRUSY M E. ULTRASOUND IN THE EVALUATION OF CHRONIC PANCREATITIS. Journal of the American Osteopathic Association 81 81(3):183-188. Exclusion Code(s): DCOM

Greenen JE and Rolny P. Endoscopic therapy of acute and chronic pancreatitis. Gastrointestinal Endoscopy 91 37(377-382. Exclusion Code(s): AND [pending]

Gregg J, Solomon J, and Clark G. Pancreas divisum and its association with choledochal sphincter stenosis. Diagnosis by endoscopic retrograde cholangiopancreatography and endoscopic biliary manometry. American Journal of Surgery 84 147(3):367-71. Exclusion Code(s): DCOM

Gregg JA, Clark G, Barr C, McCartney A, Milano A, and Volcjak C. Postcholecystectomy syndrome and its association with ampullary stenosis. American Journal of Surgery 80 139(3):374-8. Exclusion Code(s): DCOM

Gregg JA and McDonald DG. Endoscopic retrograde cholangiopancreatography and gray-scale abdominal ultrasound in the diagnosis of jaundice. American Journal of Surgery 79 137(5):611-5. Exclusion Code(s): DCOM

Gregg JA, Taddeo AE, Milano AF, McCartney AJ, Santoro BT, Frager SH, and Capobianco AG. Duodenoscopy and endoscopic pancreatography in patients with postive morphine prostigmine tests. American Journal of Surgery 77 134(3):318-21. Exclusion Code(s): DPOP, DCOM

Griffanti-Bartoli F, Arnone GB, Ceppa P, Ravera G, Carrabetta S, and Civalleri D. Malignant tumors in the head of the pancreas and the periampullary region. Diagnostic and prognostic aspects. Anticancer Research 94 14(2B):657-66. Exclusion Code(s): DCOM

Grimon G, Buffet C, Andre L, Etienne JP, and Desgrez A. Biliary pain in postcholecystectomy patients without biliary obstruction. A prospective radionuclide study. Digestive Diseases and Sciences 91 36(3):317-20. Exclusion Code(s): TCOM

Gross BH, Harter LP, Gore RM, Callen PW, Filly RA, Shapiro HA, and Goldberg HI. Ultrasonic evaluation of common bile duct stones: prospective comparison with endoscopic retrograde cholangiopancreatography. Radiology 83 146(2):471-4. Exclusion Code(s): DCOM

Guelrud M. Papillary stenosis. Endoscopy 88 20 Suppl 1(193-202. Exclusion Code(s): AND

Guelrud M, Morera C, Rodriguez M, Jaen D, and Pierre R. Sphincter of Oddi dysfunction in children with recurrent pancreatitis and anomalous pancreaticobiliary union: an etiologic concept. Gastrointestinal Endoscopy 99 50(2):194-9. Exclusion Code(s): TPOP, ANNQ

Guelrud M, Morera C, Rodriguez M, Prados JG, and Jaen D. Normal and anomalous pancreaticobiliary union in children and adolescents. Gastrointestinal Endoscopy 99 50(2):189-93. Exclusion Code(s): ANNQ, DPOP

Guelrud M, Mujica C, Jaen D, Plaz J, and Arias J. The role of ERCP in the diagnosis and treatment of idiopathic recurrent pancreatitis in children and adolescents. Gastrointestinal Endoscopy 94 40(4):428-36. Exclusion Code(s): DCOM. TCOM, TN25, TNRO

Gulla N, Patriti A, Patriti A, and Tristaino B. Minimally invasive treatment of cholelithiasis in the elderly. Minerva Chirurgica 2001 56(3):223-8. Exclusion Code(s): ANNQ

Guthrie CM, Haddock G, De Beaux AC, Garden OJ, and Carter DC. Changing trends in the management of extrahepatic cholangiocarcinoma. British Journal of Surgery 93 80(11):1434-9. Exclusion Code(s): TCOM TPOP

Hainsworth PJ, Rhodes M, Gompertz RH, Armstrong CP, and Lennard TW. Imaging of the common bile duct in patients undergoing laparoscopic cholecystectomy. Gut 94 35(7):991-5. Exclusion Code(s): NRO

Hall-Craggs MA, Allen CM, Owens CM, Theis BA, Donald JJ, Paley M, Wilkinson ID, Chong WK, Hatfield AR, Lees WR, and et al. MR cholangiography: clinical evaluation in 40 cases. Radiology 93 189(2):423-7. Exclusion Code(s): ANNQ, DNSI

Hall TJ, Blackstone MO, Cooper MJ, Hughes RG, and Moossa AR. Prospective evaluation of endoscopic retrograde cholangiopancreatography in the diagnosis of periampullary cancers. Annals of Surgery 78 187(3):313-7. Exclusion Code(s): DPOP

Halme L, Doepel M, von Numers H, Edgren J, and Ahonen J. Complications of diagnostic and therapeutic ERCP. Annales Chirurgiae et Gynaecologiae 99 88(2):127-31. Exclusion Code(s): 5NCV NOMVA

Hamilton I, Lintott DJ, Rothwell J, and Axon AT. Acute pancreatitis following endoscopic retrograde cholangiopancreatography. Clinical Radiology 83 34(5):543-6. Exclusion Code(s): 5NCV, NOMVA

Hammarstrom LE, Andersson R, Stridbeck H, and Ihse I. Influence of bile duct stones on patient features and effect of endoscopic sphincterotomy on early outcome of edematous gallstone pancreatitis. World Journal of Surgery 99 23(1):12-7. Exclusion Code(s): TCOM

Hammarstrom LE, Stridbeck H, and Ihse I. Effect of endoscopic sphincterotomy and interval cholecystectomy on late outcome after gallstone pancreatitis. British Journal of Surgery 98 85(3):333-6. Comment in: Br J Surg. 1998 Sep;85(9):1305. Exclusion Code(s): ANNQ

Hammarstrom LE, Stridbeck H, and Ihse I. Endoscopic drainage in benign pancreatic disease: immediate and medium term outcome. European Journal of Surgery 97 163(8):577-89. Exclusion Code(s): TCOM TPOP TNRO

Hammarstrom LE, Stridbeck H, and Ihse I. Factors predictive of early complications of endoscopic treatment of bile duct calculi. Hepato-Gastroenterology 97 44(17):1246-55. Exclusion Code(s): 5NCV, NOMVA

Hansen HH, Toftgaard C, Rokkjor MJ, Kruse A, Funch-Jensen P, and Thommesen P. Food-stimulated cholescintigraphy as a supplement to ERC in patients with suspected bile flow obstruction. A preliminary study. Rontgen-Blatter 90 43(11):484-6. Exclusion Code(s): DN25

Hanssen LE, Osnes M, and Myren J. Pancreatic secretion obtained by endoscopic cannulation of the main pancreatic duct and secretin release after duodenal acidification in man. Scandinavian Journal of Gastroenterology (Scand. J. Gastroenterol.) 78 13(3):325-330. Exclusion Code(s): ANNQ

Harada H, Sasaki T, Yamamoto N, Tanaka J, and Tomiyama Y. Assessment of endoscopic aspiration cytology and endoscopic retrograde cholangio-pancreatography in patients with cancer of the hepato-biliary tract. Part II. Gastroenterologia Japonica 77 12(1):59-64. Exclusion Code(s): DCOM

Harada H, Sasaki T, Yamamoto N, Tanaka J, and Tomiyama Y. Assessment of endoscopic aspiration cytology and endoscopic retrograde cholangi-pancreatography (ERCP) in patients with cancer of the pancreas. Part I. Gastroenterologia Japonica 77 12(1):52-8. Exclusion Code(s): DCOM

Harada H, Tanaka J, Shundo T, Hayashi T, Sasaki T, Yamamoto N, Sato T, Mishima K, and Kimura I. A diagnostic approach to inflammatory disease of the pancreas by means of endoscopic retrograde cholangio-pancreatography. Gastroenterologia Japonica 77 12(5):387-94. Exclusion Code(s): DCOM

Hastbacka J, Jarvinen H, Kivilaakso E, and Turunen MT. Results of sphincteroplasty in patients with spastic sphincter of Oddi. Predictive value of operative biliary manometry and provocation tests. Scandinavian Journal of Gastroenterology 86 21(5):516-20. Exclusion Code(s): DN25

Hastier P, Buckley MJ, Francois E, Peten EP, Dumas R, Caroli-Bosc FX, and Delmont JP. A prospective study of pancreatic disease in patients with alcoholic cirrhosis: comparative diagnostic value of ERCP and EUS and long-term significance of isolated parenchymal abnormalities. Gastrointestinal Endoscopy 99 49(6):705-9. Exclusion Code(s): DPOP, ANNQ

Hatfield ARW, Terblanche J, Fataar S, and et al. Preoperative external biliary drainage in obstructive jaundice. Lancet 82 2(896-9. Exclusion Code(s): TCOM

Hauer-Jensen M, Karesen R, Nygaard K, Solheim K, Amlie EJ, Havig O, and Rosseland AR. Prospective randomized study of routine intraoperative cholangiography during open cholecystectomy: long-term follow-up and multivariate analysis of predictors of choledocholithiasis. Surgery 93 113(3):318-23. Exclusion Code(s): 6NCPR

He Xiaodong, Zheng Chaoji, Zhang Zhenhua, and Zhang Jianxi. Congenital choledochal cyst - Report of 56 cases. Chinese Medical Sciences Journal 2000 15(1):52-54. Exclusion Code(s): AND

Heili MJ, Wintz NK, and Fowler DL. Choledocholithiasis: endoscopic versus laparoscopic management. American Surgeon 99 65(2):135-8. Exclusion Code(s): TCOM

Heinerman M, Pimpl W, Waclawiczek HW, and Boeckl O. Combined endoscopic and surgical approach to primary gallstone disease. Surgical Endoscopy 87 1(4):195-8. Exclusion Code(s): TCOM

Heinerman PM, Boeckl O, and Pimpl W. Selective ERCP and preoperative stone removal in bile duct surgery. Annals of Surgery 89 209(3):267-72. Exclusion Code(s): TCOM

Hildell J, Aspelin P, and Wehlin L. Gray scale ultrasound and endoscopic ductography in the diagnosis of pancreatic disease. Acta Chirurgica Scandinavica 79 145(4):239-45. Exclusion Code(s): DCOM2, ANNQ3

Himal HS. Common bile duct stones: the role of preoperative, intraoperative, and postoperative ERCP. Seminars in Laparoscopic Surgery 2000 7(4):237-45. Exclusion Code(s): AND

Hintze RE, Adler A, Veltzke W, Abou-Rebyeh H, Hammerstingl R, Vogl T, and Felix R. Clinical significance of magnetic resonance cholangiopancreatography (MRCP) compared to endoscopic retrograde cholangiopancreatography (ERCP). Endoscopy 97 29(3):182-7. Exclusion Code(s): DCOM, NBH,

Ho JT and Yap CK. Magnetic resonance cholangiopancreatography: value of using the half-Fourier acquisition single-shot turbo spin-echo (HASTE) sequence. Annals of the Academy of Medicine, Singapore 99 28(3):366-70. Exclusion Code(s): DNRO

Ho KY, Montes H, Sossenheimer MJ, Tham TC, Ruymann F, Van Dam J, and Carr-Locke DL. Features that may predict hospital admission following outpatient therapeutic ERCP. Gastrointestinal Endoscopy 99 49(5):587-92. Comment in: Gastrointest Endosc. 1999 May;49(5):660-2. Exclusion Code(s): 5NRO

Hoare AM, West RJ, and Cockel R. The reasons for failure of endoscopic retrograde cholangio-pancreatography in patients with jaundice. Clinical Radiology 78 29(2):201-3. Exclusion Code(s): 5NCV, NOMVA

Hochwald SN, Burke EC, Jarnagin WR, Fong Y, and Blumgart LH. Association of preoperative biliary stenting with increased postoperative infectious complications in proximal cholangiocarcinoma. Archives of Surgery 99 134(3):261-6. Exclusion Code(s): TNRS

Hochwalk SN, Dobryansky M BA, Rofsky NM, Naik KS, Shamamian P, Coppa G, and Marcus SG. Magnetic resonance cholangiopancreatography accurately predicts the presence or absence of choledocholithiasis. Journal of Gastrointestinal Surgery 98 2(6):573-9. Exclusion Code(s): DNSI

Homma T. Criteria for pancreatic disease diagnosis in Japan: Diagnostic criteria for chronic pancreatitis. Pancreas (Pancreas) 98 16(3):250-254. Exclusion Code(s): ANNQ

Honickman SP, Mueller PR, Wittenberg J, Simeone JF, Ferrucci JT, Cronan JJ, and vanSonnenberg E. Ultrasound in obstructive jaundice: prospective evaluation of site and cause. Radiology 83 147(2):511-5. Exclusion Code(s): DCOM

Horsmans Y, De Grez T, Lefebvre V, and Witterwulghe M. Double common bile duct with ectopic drainage of the left lobe into the stomach. Case report and review of the literature. Acta Gastro-Enterologica Belgica (Acta Gastro-Enterol. Belg.) 96 59(4):256-257. Exclusion Code(s): ANNQ

Howard TJ, Tan T, Lehman GA, Sherman S, Madura JA, Fogel E, Swack ML, and Kopecky KK. Classification and management of perforations complicating endoscopic sphincterotomy. Surgery 99 126(4):658-63; discussion 664-5. Exclusion Code(s): 5NCV, NOMVA

Hoyuela C, Cugat E, Bretcha P, Collera P, Espinos J, and Marco C. Must ERCP Be routinely performed if choledocholithiasis is suspected? Digestive Surgery 99 16(5):411-4. Exclusion Code(s): TCOM

Huang MJ, Liaw YF, and Wu CS. Comparison of intravenous radionuclide cholescintigraphy and endoscopic retrograde cholangiography in the diagnosis of intrahepatic gall-stones. British Journal of Radiology 81 54(640):302-6. Exclusion Code(s): DCOM

Huibregtse K and Smits ME. Endoscopic management of diseases of the pancreas. American Journal of Gastroenterology 94 89(8):S66-S77. Exclusion Code(s): AND [pending]

Hunt DR and Blumgart LH. Preoperative differentiation between carcinoma of the pancreas and chronic pancreatitis: the contribution of cytology. Endoscopy 82 14(5):171-3. Exclusion Code(s): DCOM

Ihre T and Hellers G. Complications and endoscopic retrograde cholangio-pancreatography. A review of the literature and presentation of a duodenal perforation. Acta Chirurgica Scandinavica (Acta Chir. Scand.) 77 143(3):167-171. Exclusion Code(s): AND

Iida F and Kusama J. Surgical evaluation of endoscopic retrograde cholangiography for biliary tract diseases. Japanese Journal of Surgery 82 12(4):257-61. Exclusion Code(s): 5NCV, NOMVA

Ikeda S, Tanaka M, Itoh H, and et al. Emergency decompression of bile duct in acute obstructive suppurative cholangitis by duodenoscopic cannulation: A lifesaving procedure. World Journal of Surgery (World J. Surg.) 81 5(4):587-593. Exclusion Code(s): AND

Ikeda S, Tanaka M, Matsumoto S, Yoshimoto H, and Itoh H. Endoscopic sphincterotomy: long-term results in 408 patients with complete follow-up. Endoscopy 88 20(1):13-7. Exclusion Code(s): Exclusion Code: 5NCV, NOMVA

Inamoto K, Tanaka S, Yamazaki H, and et al. Computed tomography of the carcinoma of the ampulla of vater. Fortschritte Auf Den Gebiete Der Rontgenstrahlen Und Der Nuklearmedizin (Fortschr. Geb. Rontgenstr. Nuklearmed.) 82 136(6):689-693. Exclusion Code(s): AND

Inui K, Nakazawa S, Yoshino J, Okushima K, and Nakamura Y. Endoluminal ultrasonography for pancreatic diseases. Gastroenterology Clinics of North America 99 28(3):771-81. Exclusion Code(s): DCOM AND BACKGROUND

Irie H, Honda H, Aibe H, Kuroiwa T, Yoshimitsu K, Shinozaki K, Yamaguchi K, Shimada M, and Masuda K. MR cholangiopancreatographic differentiation of benign and malignant intraductal mucin-producing tumors of the pancreas. American Journal of Roentgenology (Am. J. Roentgenol.) 2000 174(5):1403-1408. Exclusion Code(s): AND

Irie H, Honda H, Tajima T, Kuroiwa T, Yoshimitsu K, Makisumi K, and Masuda K. Optimal MR cholangiopancreatographic sequence and its clinical application. Radiology 98 206(2):379-87. Exclusion Code(s): ANNQ

Itoh H, Shimono R, and Hamamoto K. Evaluation of common bile duct stenosis in chronic pancreatitis using cholescintigraphy. European Journal of Nuclear Medicine 88 14(3):137-40. Exclusion Code(s): ANNQ

Jamidar P, Sherman S, and Hawes R. Efficacy of endoscopic sphincterotomy for patients with sphincter of Oddi dysfunction: randomized, controlled study [Abstract]. Gastrointestinal Endoscopy 92 38(253. Exclusion Code(s): ANMJ

Jander HP, Galbraith J, and Aldrete JS. Percutaneous transhepatic cholangiography using the Chiba needle: comparison with retrograde pancreatocholecystography. Southern Medical Journal 80 73(4):415-21. Exclusion Code(s): 5NCV, NOMVA

Johnson AS, Ferrara JJ, Steinberg SM, Gassen GM, Hollier LH, and Flint LM. The role of endoscopic retrograde cholangiopancreatography: sphincterotomy versus common bile duct exploration as a primary technique in the management of choledocholithiasis. American Surgeon 93 59(2):78-84. Exclusion Code(s): TNCC

Johnson GK, Geenen JE, Bedford RA, Johanson J, Cass O, Sherman S, Hogan WJ, Ryan M, Silverman W, Edmundowicz S, and et al. A comparison of nonionic versus ionic contrast media: results of a prospective, multicenter study. Midwest Pancreaticobiliary Study Group. Gastrointestinal Endoscopy 95 42(4):312-6. Exclusion Code(s): ANNQ

Johnson GK, Geenen JE, Johanson JF, Sherman S, Hogan WJ, and Cass O. Evaluation of post-ERCP pancreatitis: potential causes noted during controlled study of differing contrast media. Midwest Pancreaticobiliary Study Group. Gastrointestinal Endoscopy 97 46(3):217-22. Exclusion Code(s): NOMVA results reported in paper

Jowell PS, Baillie J, Branch MS, Affronti J, Browning CL, and Bute BP. Quantitative assessment of procedural competence. A prospective study of training in endoscopic retrograde cholangiopancreatography. Annals of Internal Medicine 96 125(12):983-9. Comment in: Ann Intern Med. 1996 Dec 15;125(12):1003-4. Exclusion Code(s): AND ANNQ

Kameya S, Kuno N, and Kasugai T. The diagnosis of pancreatic cancer by pancreatic juice cytology. Acta Cytologica 81 25(4):354-60. Exclusion Code(s): DCOM

Kaneko T, Nakao A, Nomoto S, Furukawa T, Hirooka Y, Nakashima N, and Nagasaka T. Intraoperative pancreatoscopy with the ultrathin pancreatoscope for mucin-producing tumors of the pancreas. Archives of Surgery 98 133(3):263-7. Exclusion Code(s): DCOM

Kapoor R, Kaushik SP, Saraswat VA, Choudhuri G, Sikora SS, Saxena R, and Kapoor VK. Prospective randomized trial comparing endoscopic sphincterotomy followed by surgery with surgery alone in good risk patients with choledocholithiasis. HPB Surgery 96 9(3):145-8. Exclusion Code(s): TN25

Kapoor R, Pradeep R, Sikora SS, Saxena R, Kapoor VK, and Kaushik SP. Appraisal of surgical and endoscopic management of choledocholithiasis. Australian and New Zealand Journal of Surgery 94 64(9):599-603. Exclusion Code(s): TNCC

Kapur BM, Mishra MC, Rao PS, and Tandon RK. Gall bladder and common bile duct stones--when is direct cholangiography indicated. HPB Surgery 89 1(3):201-5. Exclusion Code(s): X6

Katayama H, Spinazzi A, Fouillet X, Kirchin MA, Taroni P, and Davies A. Iomeprol: Current and future profile of a radiocontrast agent. Investigative Radiology (Invest. Radiol.) 2001 36(2):87-96. Exclusion Code(s): ANNQ

Katon RM, Bilbao MK, Parent JA, and Smith FW. Endoscopic retrograde cholangiopancreatography in patients with gastrectomy and gastrojejunostomy (Billroth II). A case for the forward look. Gastrointestinal Endoscopy (Gastrointest. Endosc.) 75 21(4):164-165. Exclusion Code(s): ANNQ

Keith RG, Shapero TF, and Saibil FG. Treatment of pancreatitis associated with pancreas divisum by dorsal duct sphincterotomy alone. Canadian Journal of Surgery (Can. J. Surg.) 82 25(6):622-626. Exclusion Code(s): TNRO

Khaira HS, Ridings PC, and Gompertz RH. Routine laparoscopic cholangiography: a means of avoiding unnecessary endoscopic retrograde cholangiopancreatography. Journal of Laparoendoscopic and Advanced Surgical Techniques. Part A 99 9(1):17-22. Exclusion Code(s): TCOM

Kim MH, Myung SJ, Kim YS, Kim HJ, Seo DW, Nam SW, Ahn JH, Lee SK, and Min YI. Routine biliary sphincterotomy may not be indispensable for endoscopic pancreatic sphincterotomy. Endoscopy 98 30(8):697-701. Exclusion Code(s): TNRO

Kim MJ, Mitchell DG, Ito K, and Outwater EK. Biliary dilatation: differentiation of benign from malignant causes--value of adding conventional MR imaging to MR cholangiopancreatography. Radiology 2000 214(1):173-81. Exclusion Code(s): TCOM

Kim SM, Kim SH, Choi SY, and Kim YC. Surgical treatment of periampullary cancer--review of 766 surgical experiences of 8 hospitals. Journal of Korean Medical Science 92 7(4):297-303. Exclusion Code(s): TCOM

Kimchi NA, Mindrul V, Broide E, and Scapa E. The contribution of endoscopy and biopsy to the diagnosis of periampullary tumors. Endoscopy 98 30(6):538-43. Exclusion Code(s): DCOM

Kimmings AN, Van Deventer SJH, Rauws EAJ, Huibregtse K, and Gouma DJ. Systemic inflammatory response in acute cholangitis and after subsequent treatment. European Journal of Surgery (Eur. J. Surg.) 2000 166(9):700-705. Exclusion Code(s): ANNQ

Kinami S, Yao T, Kurachi M, and Ishizaki Y. Clinical evaluation of 3D-CT cholangiography for preoperative examination in laparoscopic cholecystectomy. Journal of Gastroenterology 99 34(1):111-8. Exclusion Code(s): DN25

Kiviluoto T, Kivisaari L, Kivilaakso E, and Lempinen M. Pseudocysts in chronic pancreatitis. Surgical results in 102 consecutive patients. Archives of Surgery 89 124(2):240-3. Exclusion Code(s): TCOM

Kloiber R, AuCoin R, Hershfield NB, Logan K, Molnar CP, Blair KM, and Shaffer EA. Biliary obstruction after cholecystectomy: diagnosis with quantitative cholescintigraphy. Radiology 88 169(3):643-7. Exclusion Code(s): ANNQ1

Kocjan Gabrijela and Smith Ann Nisbet. Bile duct brushings cytology: Potential pitfalls in diagnosis. Diagnostic Cytopathology 97 16(4):358-363. Exclusion Code(s): DCOM

Kok T, Van der Sluis A, Klein JP, Van der Jagt EJ, Peeters PM, Slooff MJ, Bijleveld CM, and Haagsma EB. Ultrasound and cholangiography for the diagnosis of biliary complications after orthotopic liver transplantation: a comparative study. Journal of Clinical Ultrasound 96 24(3):103-15. Exclusion Code(s): ANNQ

Kolars JC, Allen MO, Ansel H, Silvis SE, and Vennes JA. Pancreatic pseudocysts: clinical and endoscopic experience. American Journal of Gastroenterology 89 84(3):259-64. Exclusion Code(s): DCOM

Komaki R, Wilson JF, Cox JD, and Kline RW. Carcinoma of the pancreas: Results of irradiation for unresectable lesions. International Journal of Radiation Oncology Biology Physics (Int. J. Radiat. Oncol. Biol. Phys.) 80 6(2):209-212. Exclusion Code(s): ANNQ

Kondylis PD, Simmons DR, Agarwal SK, Ciardiello KA, and Reinhold RB. Abnormal intraoperative cholangiography. Treatment options and long-term follow-up. Archives of Surgery 97 132(4):347-50. Exclusion Code(s): ANNQ

Kositchaiwat S, Kositchaiwat C, Kanchanapitak A, Lerkpatanakit P, and Tinnakornrasamee C. Diagnostic value of endoscopic transampullary biopsy for malignant bile duct stricture. Journal of the Medical Association of Thailand 2000 83(9):992-8. Exclusion Code(s): DCOM

Kozarek R and Terrance j. Endoscopic pancreatic duct sphincterotomy: indications, technique and analysis of results. Gastrointestinal Endoscopy 94 40(5):592-8. Exclusion Code(s): ANNQ

Kozarek RA. Endoscopy in the management of malignant obstructive jaundice. Gastrointestinal Endoscopy Clinics of North America 96 6(1):153-76. Exclusion Code(s): AND

Kozarek RA, Ball TJ, and Patterson DJ. Endoscopic approach to pancreatic duct calculi and obstructive pancreatitis. American Journal of Gastroenterology 92 87(5):600-3. Exclusion Code(s): TCOM (requested later)TNRO TN25

Kozarek RA, Patterson DJ, Ball TJ, and Traverso LW. Endoscopic placement of pancreatic stents and drains in the management of pancreatitis. Annals of Surgery 89 209(3):261-6. Exclusion Code(s): TN25

Kozarek RA and Traverso LW. Endoscopic treatment of chronic pancreatitis - An alternative to surgery? Digestive Surgery (Dig. Surg.) 96 13(2):90-100. Exclusion Code(s): [AND]

Kubota Y, Takaoka M, Tani K, Ogura M, Kin H, Fujimura K, Mizuno T, and Inoue K. Endoscopic transpapillary biopsy for diagnosis of patients with pancreaticobiliary ductal strictures. American Journal of Gastroenterology 93 88(10):1700-4. Exclusion Code(s): DCOM

Kuo YT, Jaw TS, Wang CK, Lee LW, Shen PC, and Liu GC. Diagnostic efficacy of non-breath-hold magnetic resonance cholangiopancreatography. Journal of the Formosan Medical Association (J. Formos. Med. Assoc.) 99 98(2):97-103. Exclusion Code(s): DNSI, AND

Kurzawinski T, Deery A, Dooley J, Dick R, Hobbs K, and Davidson B. A prospective controlled study comparing brush and bile exfoliative cytology for diagnosing bile duct strictures. Gut 92 33(12):1675-7. Exclusion Code(s): OVERLAP 3251

Kwon AH, Inui H, Imamura A, Uetsuji S, and Kamiyama Y. Preoperative assessment for laparoscopic cholecystectomy: Feasibility of using spiral computed tomography. Annals of Surgery (Ann. Surg.) 98 227(3):351-356. Exclusion Code(s): DNSI ANNQ

Lachter J, Rubin A, Shiller M, Lavy A, Yasin K, Suissa A, and Reshef R. Linear EUS for bile duct stones. Gastrointestinal Endoscopy 2000 51(1):51-4. Exclusion Code(s): AND

Lambert ME, Betts CD, Hill J, Faragher EB, Martin DF, and Tweedle DE. Endoscopic sphincterotomy: the whole truth. British Journal of Surgery 91 78(4):473-6. Exclusion Code(s): 5NCV, NOMVA

Lameris JS, Stoker J, Dees J, Nix GA, Van Blankenstein M, and Jeekel J. Non-surgical palliative treatment of patients with malignant biliary obstruction--the place of endoscopic and percutaneous drainage. Clinical Radiology 87 38(6):603-8. Exclusion Code(s): AND

Lammer J, Hausegger KA, Fluckiger F, Winkelbauer FW, Wildling R, Klein GE, Thurnher SA, and Havelec L. Common bile duct obstruction due to malignancy: Treatment with plastic versus metal stents. Radiology 96 201(167-172. Exclusion Code(s): TCOM, transhepatic stent

Le Borgne J, de Calan L, and Partensky C. Cystadenomas and cystadenocarcinomas of the pancreas: a multiinstitutional retrospective study of 398 cases. French Surgical Association. Annals of Surgery 99 230(2):152-61. Exclusion Code(s): ANNQ, DPOP, DCOM

Lecesne R, Taourel P, Bret PM, Atri M, and Reinhold C. Acute pancreatitis: interobserver agreement and correlation of CT and MR cholangiopancreatography with outcome. Radiology 99 211(3):727-35. Exclusion Code(s): ANNQ

Lee JG and Leung J. Tissue sampling at ERCP in suspected pancreatic cancer. Gastrointestinal Endoscopy Clinics of North America 98 8(1):221-35. Exclusion Code(s): AND

Lee JG, Leung JW, Baillie J, Layfield LJ, and Cotton PB. Benign, dysplastic, or malignant--making sense of endoscopic bile duct brush cytology: results in 149 consecutive patients. American Journal of Gastroenterology 95 90(5):722-6. Exclusion Code(s): DCOM

Lee MG, Lee HJ, Kim MH, Kang EM, Kim YH, Lee SG, Kim PN, Ha HK, and Auh YH. Extrahepatic biliary diseases: 3D MR cholangiopancreatography compared with endoscopic retrograde cholangiopancreatography. Radiology 97 202(3):663-9. Exclusion Code(s): DNSI (1)

Lilly MC and Arregui ME. A balanced approach to choledocholithiasis. Surgical Endoscopy 2001 15(5):467-72. Exclusion Code(s): AND

Lin OS, Soetikno RM, and Young HS. The utility of liver function test abnormalities concomitant with biliary symptoms in predicting a favorable response to endoscopic sphincterotomy in patients with presumed sphincter of Oddi dysfunction. American Journal of Gastroenterology 98 93(10):1833-6. Exclusion Code(s): TN25

Liu CL, Lo CM, Chan JK, Poon RT, and Fan ST. EUS for detection of occult cholelithiasis in patients with idiopathic pancreatitis. Gastrointestinal Endoscopy 2000 51(1):28-32. Exclusion Code(s): DCOM

Liu CL, Lo CM, and Fan ST. Acute biliary pancreatitis: diagnosis and management. World Journal of Surgery 97 21(2):149-54. Exclusion Code(s): TCOM

Liu CL, Lo CM, Lai EC, and Fan ST. Endoscopic retrograde cholangiopancreatography and endoscopic endoprosthesis insertion in patients with Klatskin tumors. Archives of Surgery 98 133(3):293-6. Exclusion Code(s): TCOM BACKGROUND

Liu TH, Consorti ET, Kawashima A, Ernst RD, Black CT, Greger PH, Fischer RP, and Mercer DW. The efficacy of magnetic resonance cholangiography for the evaluation of patients with suspected choledocholithiasis before laparoscopic cholecystectomy. American Journal of Surgery 99 178(6):480-4. Exclusion Code(s): DN25

Liu TH, Consorti ET, Kawashima A, Tamm EP, Kwong KL, Gill BS, Sellin JH, Peden EK, and Mercer DW. Patient evaluation and management with selective use of magnetic resonance cholangiography and endoscopic retrograde cholangiopancreatography before laparoscopic cholecystectomy. Annals of Surgery 2001 234(1):33-40. Exclusion Code(s): TCOM

Lo CY, Lai ECS, Lo CM, Mok FPT, Chu KM, Liu CL, Fan S T, and Liguory C. Endoscopic sphincterotomy: 7-Year experience. World Journal of Surgery (World J. Surg.) 97 21(1):67-71. Exclusion Code(s): 5NCV, NOMVA

Lobo DN, Balfour TW, and Iftikhar SY. Periampullary diverticula: consequences of failed ERCP. Annals of the Royal College of Surgeons of England 98 80(5):326-31. Exclusion Code(s): 5NCV, NOMVA

LoGiudice JA, Geenen JE, Hogan WJ, and Dodds WJ. Efficacy of the morphine-prostigmin test for evaluating patients with suspected papillary stenosis. Digestive Diseases and Sciences 79 24(6):455-8. Exclusion Code(s): DN25

Logrono R, Kurtycz DF, Molina CP, Trivedi VA, Wong JY, and Block KP. Analysis of false-negative diagnoses on endoscopic brush cytology of biliary and pancreatic duct strictures: the experience at 2 university hospitals. Archives of Pathology and Laboratory Medicine 2000 124(3):387-92. Exclusion Code(s): DCOM

Lokich JJ, Kane RA, Harrison DA, and McDermott WV. Biliary tract obstruction secondary to cancer: management guidelines and selected literature review. Journal of Clinical Oncology 87 5(6):969-81. Exclusion Code(s): AND

Lomanto D, Pavone P, Laghi A, Panebianco V, Mazzocchi P, Fiocca F, Lezoche E, Passariello R, and Speranza V. Magnetic resonance-cholangiopancreatography in the diagnosis of biliopancreatic diseases. American Journal of Surgery 97 174(1):33-8. Exclusion Code(s): DNSI, AND, ANNQ3, DCOM1, NBH1

Lygidakis NJ. Surgical approaches to recurrent choledocholithiasis. Choledochoduodenostomy versus T-tube drainage after choledochotomy. American Journal of Surgery 83 145(5):636-9. Exclusion Code(s): ANNQ

Macaulay SE, Schulte SJ, Sekijima JH, Obregon RG, Simon HE, Rohrmann CA, Freeny PC, and Schmiedl UP. Evaluation of a non-breath-hold MR cholangiography technique. Radiology 95 196(1):227-32. Exclusion Code(s): DN25, NBH

Macken E, Drijkoningen M, Van Aken E, and Van Steenbergen W. Brush cytology of ductal strictures during ERCP. Acta Gastroenterologica Belgica 2000 63(3):254-9. Exclusion Code(s): DCOM

Mackie CR, Cooper MJ, Lewis MH, and Moossa AR. Non-operative differentiation between pancreatic cancer and chronic pancreatitis. Annals of Surgery 79 189(4):480-7. Exclusion Code(s): DCOM

Mackie CR, Dhorajiwala J, Blackstone MO, Bowie J, and Moossa AR. Value of new diagnostic aids in relation to the disease process in pancreatic cancer. Lancet 79 2(8139):385-9. Exclusion Code(s): DCOM

Madacsy L, Middelfart HV, Matzen P, Hojgaard L, and FunchJensen P. Quantitative hepatobiliary scintigraphy and endoscopic sphincter of Oddi manometry in patients with suspected sphincter of Oddi dysfunction: Assessment of flow-pressure relationship in the biliary tract. European Journal of Gastroenterology and Hepatology (Eur. J. Gastroenterol. Hepatol.) 2000 12(7):777-786. Exclusion Code(s): DPOP. DN25

Madura JA. Pancreas divisum: stenosis of the dorsally dominant pancreatic duct. A surgically correctable lesion. American Journal of Surgery 86 151(6):742-5. Exclusion Code(s): ANNQ

Madura JA, Fiore AC, O'Connor KW, Lehman GA, and McCammon RL. Pancreas divisum. Detection and management. American Surgeon 85 51(6):353-7. Exclusion Code(s): AND

Madura JA, McCammon RL, Paris JM, and Jesseph JE. The Nardi test and biliary manometry in the diagnosis of pancreaticobiliary sphincter dysfunction. Surgery (Surgery) 81 90(4):588-595. Exclusion Code(s): DCOM DNSI AND

Maes B, Hastier P, Buckley MJ, Peten EP, Paolini O, Staccini P, Conio M, Caroli-Bosc FX, Demarquay JF, Dumas R, and Delmont JP. Extensive aetiological investigations in acute pancreatitis: results of a 1-year prospective study. European Journal of Gastroenterology and Hepatology 99 11(8):891-6. Exclusion Code(s): AND

Magnuson TH, Bender JS, Duncan MD, Ahrendt SA, Harmon JW, and Regan F. Utility of magnetic resonance cholangiography in the evaluation of biliary obstruction. Journal of the American College of Surgeons 99 189(1):63-71; discussion 71-2. Exclusion Code(s): AND

Malfertheiner P and Buchler M. Indications for endoscopic or surgical therapy in chronic pancreatitis. Endoscopy 91 23):185-190. Exclusion Code(s): AND

Malka D, Hammel P, Vilgrain V, Flejou J-F, Belghiti J, and Bernades P. Chronic obstructive pancreatitis due to a pancreatic cyst in a patient with autosomal dominant polycystic kidney disease. Gut 98 42(1):131-134. Exclusion Code(s): AND

Manfredi R, Costamagna G, Brizi MG, Spina S, Maresca G, Vecchioli A, Mutignani M, and Marano P. Pancreas divisum and "santorinicele": diagnosis with dynamic MR cholangiopancreatography with secretin stimulation. Radiology 2000 217(2):403-8. Exclusion Code(s): DCOM

Marotta F, Hada R, Morello P, Vitale G, Sasaki M, Ragno F, and Ono K. ERCP in the assessment of patients with post-cholecystectomy syndrome: benefits and limitations. Netherlands Journal of Medicine 89 35(5-6):232-40. Exclusion Code(s): DCOM

Martin EW, Catalano P, Cooperman M, Hecht C, and Carey LC. Surgical decision-making in the treatment of pancreatic pseudocysts. Internal versus external drainage. American Journal of Surgery 79 138(6):821-4. Exclusion Code(s): ANNQ

Masui T, Takehara Y, Ichijo K, Naito M, Watahiki H, Kaneko M, Nozaki A, and Sun Y. Evaluation of the pancreas: a comparison of single thick-slice MR cholangiopancreatography with multiple thin-slice volume reconstruction MR cholangiopancreatography. AJR. American Journal of Roentgenology 99 173(6):1519-26. Exclusion Code(s): DCOM. ANNQ

Mathur SK, Soonawalla ZF, Shah SR, Goel M, and Shikare S. Role of biliary scintiscan in predicting the need for cholangiography. British Journal of Surgery 2000 87(2):181-5. Comment in: ACP J Club. 2000 Sep-Oct;133(2):65. Exclusion Code(s): ANNQ

Matsuda Y, Shimakura K, and Akamatsu T. Factors affecting the patency of stents in malignant biliary obstructive disease: Univariate and multivariate analysis. American Journal of Gastroenterology (Am. J. Gastroenterol.) 91 86(7):843-849. Exclusion Code(s): AND

Matsumoto S, Harada H, Tanaka J, Ochi K, Seno T, Tsurumi T, and Kunichika K. Evaluation of cytology and tumor markers of pure pancreatic juice for the diagnosis of pancreatic cancer at early stages. Pancreas 94 9(6):741-7. Exclusion Code(s): DCOM

Matzen P, Haubek A, Holst-Christensen J, Lejerstofte J, and Juhl E. Accuracy of direct cholangiography by endoscopic or transhepatic route in jaundice--a prospective study. Gastroenterology 81 81(2):237-41. Exclusion Code(s): DCOM, DNRS

Matzen P, Malchow-Moller A, Lejerstofte J, Stage P, and Juhl E. Endoscopic retrograde cholangiopancreatography and transhepatic cholangiography in patients with suspected obstructive jaundice. A randomized study. Scandinavian Journal of Gastroenterology 82 17(6):731-5. Exclusion Code(s): ANNQ, DNSI

May GR, Cotton PB, Edmunds SE, and Chong W. Removal of stones from the bile duct at ERCP without sphincterotomy. Gastrointestinal Endoscopy 93 39(6):749-54. Exclusion Code(s): TN25

McCarthy J, Geenen JE, and Hogan WJ. Preliminary experience with endoscopic stent placement in benign pancreatic diseases. Gastrointestinal Endoscopy 88 34(1):16-8. Exclusion Code(s): TPOP TNRO

McGuire DE, Venu RP, Brown RD, Etzkorn KP, Glaws WR, and Abu-Hammour A. Brush cytology for pancreatic carcinoma: an analysis of factors influencing results. Gastrointestinal Endoscopy 96 44(3):300-4. Exclusion Code(s): DCOM

McPherson GA, Benjamin IS, Hodgson JH, Bowley NB, Allison DJ, and Blumgart LH et al. Pre-operative percutaneous transhepatic biliary drainage: the results of a controlled trial. British Journal of Surgery 84 71(371-375. Exclusion Code(s): TCOM

Mendler MH, Bouillet P, Sautereau D, Chaumerliac P, Cessot F, Le Sidaner A, and Pillegand B. Value of MR cholangiography in the diagnosis of obstructive diseases of the biliary tree: a study of 58 cases. American Journal of Gastroenterology 98 93(12):2482-90. Exclusion Code(s): DCOM, NBH

Menzel J, Poremba C, Dietl KH, Bocker W, and Domschke W. Tumors of the papilla of Vater--inadequate diagnostic impact of endoscopic forceps biopsies taken prior to and following sphincterotomy. Annals of Oncology 99 10(10):1227-31. Exclusion Code(s): DCOM

Meyer C, Le JV, Rohr S, Thiry LC, Bourtoul C, Duclos B, Reimund JM, and Baumann R. Management of common bile duct stones by laparoscopic cholecystectomy and endoscopic sphincterotomy: pre-, per- or postoperative sphincterotomy? Digestive Surgery 99 16(1):26-31. Exclusion Code(s): TNCC

Millar AJ, Rode H, Stunden RJ, and Cywes S. Management of pancreatic pseudocysts in children. Journal of Pediatric Surgery 88 23(2):122-7. Exclusion Code(s): TWM, AND

Millat B, Borie F, and Fingerhut A. Prospective trials in laparoscopic bile duct exploration. Seminars in Laparoscopic Surgery 2000 7(4):279-87. Exclusion Code(s): AND

Mohandas KM, Swaroop VS, Gullar SU, Dave UR, Jagannath P, and DeSouza LJ. Diagnosis of malignant obstructive jaundice by bile cytology: results improved by dilating the bile duct strictures. Gastrointestinal Endoscopy 94 40(2 Pt 1):150-4. Comment in: Gastrointest Endosc. 1994 Mar-Apr;40(2 Pt 1):249-52. Comment in: Gastrointest Endosc. 1994 Mar-Apr;40(2 Pt 1):249-52. Comment in: Gastrointest Endosc. 1994 Mar-Apr;40(2 Pt 1):249-52. Exclusion Code(s): DCOM

Montariol T, Msika S, Charlier A, Rey C, Bataille N, Hay JM, Lacaine F, and Fingerhut A. Diagnosis of asymptomatic common bile duct stones: preoperative endoscopic ultrasonography versus intraoperative cholangiography--a multicenter, prospective controlled study. French Associations for Surgical Research. Surgery 98 124(1):6-13. Exclusion Code(s): DCOM

Moossa AR. Investigative approaches to the problem of pancreatic cancer. Annals of the Royal College of Surgeons of England 79 61(2):100-6. Exclusion Code(s): DCOM

Moossa AR and Levin B. The diagnosis of "early" pancreatic cancer: the University of Chicago experience. Cancer 81 47(6 Suppl):1688-97. Exclusion Code(s): DCOM

Morgan DE, Logan K, Baron TH, Koehler RE, and Smith JK. Pancreas divisum: implications for diagnostic and therapeutic pancreatography. AJR. American Journal of Roentgenology 99 173(1):193-8. Exclusion Code(s): ANNQ

Mori K, Nagakawa T, Ohta T, Nakano T, Kadoya N, Kayahara M, Kanno M, Akiyama T, Ueno K, Konishi I, and et al. Acute pancreatitis associated with anomalous union of the pancreaticobiliary ductal system. Journal of Clinical Gastroenterology 91 13(6):673-7. Exclusion Code(s): ANNQ

Morrin MM, Farrell RJ, McEntee G, Macmathuna P, Stack JP, and MurrayJG. MR cholangiopancreatography of pancreaticobiliary diseases: Comparison of single-shot RARE and multislice HASTE sequences. CLINICAL RADIOLOGY 2000 55(866-873. Exclusion Code(s): DNSI1, DNSI2

Morrow CE, Cohen JI, Sutherland DE, and Najarian JS. Chronic pancreatitis: long-term surgical results of pancreatic duct drainage, pancreatic resection, and near-total pancreatectomy and islet autotransplantation. Surgery 84 96(4):608-16. Exclusion Code(s): TCOM

Moss AA, Federle M, Shapiro HA, Ohto M, Goldberg H, Korobkin M, and Clemett A. The combined use of computed tomography and endoscopic retrograde cholangiopancreatography in the assessment of suspected pancreatic neoplasm: a blind clinical evaluation. Radiology 80 134(1):159-63. Exclusion Code(s): DCOM

Mujica VR, Barkin JS, and Go VL. Acute pancreatitis secondary to pancreatic carcinoma. Study Group Participants. Pancreas 2000 21(4):329-32. Exclusion Code(s): ANNQ

Mukai H, Yasuda K, and Nakajima M. Differential diagnosis of mucin-producing tumors of the pancreas by intraductal ultrasonography and peroral pancreatoscopy. Endoscopy 98 30 Suppl 1(A99-102. Exclusion Code(s): DCOM

Mullens JE. Endoscopic retrograde cholangiopancreatography (ERCP) in the diagnosis of chronic pancreatitis. Surgery 78 84(3):308-12. Exclusion Code(s): DCOM

Murison MS, Gartell PC, and McGinn FP. Does selective peroperative cholangiography result in missed common bile duct stones? Journal of the Royal College of Surgeons of Edinburgh 93 38(4):220-4. Exclusion Code(s): TCOM

Musella M, Barbalace G, Capparelli G, Carrano A, Castaldo P, Tamburrini O, and Musella S. Magnetic resonance imaging in evaluation of the common bile duct. British Journal of Surgery 98 85(1):16-9. Comment in: Br J Surg. 1998 Jun;85(6):873. Exclusion Code(s): TDN25

Nagai N, Greenway CD, Shah SM, McKnight WD, and Texter EC. Nonsurgical diagnosis of pancreatic mass. Southern Medical Journal 80 73(4):467-72. Exclusion Code(s): DN25

Nakaizumi A, Tatsuta M, Uehara H, Takenaka A, Iishi H, Kitamra T, Ohigashi H, Ishikawa O, Okuda S, and Wada A. Effectiveness of the cytologic examination of pure pancreatic juice in the diagnosis of early neoplasia of the pancreas. Cancer 95 76(5):750-7. Exclusion Code(s): DCOM

Nakaizumi A, Tatsuta M, Uehara H, Takenaka A, Ohigashi H, Ishikawa O, and Ishiguro S. Usefulness of simple endoscopic aspiration cytology of pancreatic juice for diagnosis of early pancreatic neoplasm. A prospective study. Digestive Diseases and Sciences 97 42(8):1796-803. Exclusion Code(s): DCOM

Nakaizumi A, Uehara H, Takenaka A, Uedo N, Sakai N, Yano H, Ohigashi H, Ishikawa O, Ishiguro S, Sugano K, and Tatsuta M. Diagnosis of pancreatic cancer by cytology and measurement of oncogene and tumor markers in pure pancreatic juice aspirated by endoscopy. Hepato-Gastroenterology 99 46(25):31-7. Exclusion Code(s): DCOM

Nakamura R, Machado R, Amikura K, Ruebner B, and Frey CF. Role of fine needle aspiration cytology and endoscopic biopsy in the preoperative assessment of pancreatic and peripancreatic malignancies. International Journal of Pancreatology 94 16(1):17-21. Exclusion Code(s): DCOM

Nattermann C, Goldschmidt AJ, and Dancygier H. Endosonography in chronic pancreatitis--a comparison between endoscopic retrograde pancreatography and endoscopic ultrasonography. Endoscopy 93 25(9):565-70. Comment in: Endoscopy. 1993 Nov;25(9):600-2. Exclusion Code(s): ANNQ

Nealon WH, Townsend CM, and Thompson JC. Preoperative endoscopic retrograde cholangiopancreatography (ERCP) in patients with pancreatic pseudocyst associated with resolving acute and chronic pancreatitis. Annals of Surgery 89 209(5):532-8; discussion 538-40. Exclusion Code(s): ANNQ

Nebel OT, Silvis SE, Rogers G, and et al. Complications associated with endoscopic retrograde cholangiopancreatography. Results of the 1974 A/S/G/E survey. Gastrointestinal Endoscopy (Gastrointest. Endosc.) 75 22(1):34-36. Exclusion Code(s): NOMVA [pending]

Neblett WW and O'Neill JA. Surgical management of recurrent pancreatitis in children with pancreas divisum. Annals of Surgery 2000 231(6):899-908. Exclusion Code(s): TCOM, ANNQ

Nelsen KM, Kastan DJ, Shetty PC, Burke MW, Sharma RP, and Venugopal C. Utilization pattern and efficacy of nonsurgical techniques to establish drainage for high biliary obstruction. Journal of Vascular and Interventional Radiology 96 7(5):751-6. Exclusion Code(s): TNCC

Neoptolemos JP, Bailey IS, and Carr-Locke DL. Sphincter of Oddi dysfunction: results of treatment by endoscopic sphincterotomy. British Journal of Surgery 88 75(5):454-9. Exclusion Code(s): TCOM, TNRO

Neoptolemos JP, London N, Slater ND, Carr-Locke DL, Fossard DP, and Moosa AR. A prospective study of ERCP and endoscopic sphincterotomy in the diagnosis and treatment of gallstone acute pancreatitis. A rational and safe approach to management. Archives of Surgery 86 121(6):697-702. Exclusion Code(s): DUPLICATE

Neri E, Caramella D, Boraschi P, Braccini G, Lehmann ED, Perri G, and Bartolozzi C. Magnetic resonance virtual endoscopy of the common bile duct stones. Surgical Endoscopy (Surg. Endosc.) 99 13(6):632-633. Exclusion Code(s): DNSI

Ng T and Amaral JF. Timing of endoscopic retrograde cholangiopancreatography and laparoscopic cholecystectomy in the treatment of choledocholithiasis. Journal of Laparoendoscopic and Advanced Surgical Techniques. Part A 99 9(1):31-7. Exclusion Code(s): AND

Ng WW, Lai KH, Tam TN, Lin WL, Chang FY, and Lee SD. Palliation of malignant biliary obstruction with nasobiliary drainage prior to endoscopic stenting. Advances in Therapy (Adv. Ther.) 97 14(1):21-26. Exclusion Code(s): TCOM

Nitsche R, Folsch UR, Ludtke R, Hilgers RA, and Creutzfeldt W. Urgent ERCP in all cases of acute biliary pancreatitis? A prospective randomized multicenter study. European Journal of Medical Research 95 1(3):127-31. Exclusion Code(s): DUP TO FOLSCH

Nix GA and Schmitz PI. Diagnostic features of chronic pancreatitis distal to benign and to malignant pancreatic duct obstruction. Diagnostic Imaging 81 50(3):130-7. Exclusion Code(s): DCOM

Nix GA, Schmitz PI, Wilson JH, Van Blankenstein M, Groeneveld CF, and Hofwijk R. Carcinoma of the head of the pancreas. Therapeutic implications of endoscopic retrograde cholangiopancreatography findings. Gastroenterology 84 87(1):37-43. Exclusion Code(s): DCOM

Nix GA, Van Overbeeke IC, Wilson JH, and ten Kate FJ. ERCP diagnosis of tumors in the region of the head of the pancreas. Analysis of criteria and computer-aided diagnosis. Digestive Diseases and Sciences 88 33(5):577-86. Exclusion Code(s): DCOM

NODA T, OHNO Y, OSHIBUCHI T, NAKAGO S, MORITA S, MIZUTANI A, MIYAMOTO T, YAMAGUCHI T, and ET AL. A RETROSPECTIVE STUDY IN THE DIAGNOSIS OF 301 JAUNDICED CASES. Acta Medica Nagasakiensia 85 30(1-3):195-203. Exclusion Code(s): AND

Norton SA and Alderson D. Endoscopic ultrasonography in the evaluation of idiopathic acute pancreatitis. BRITISH JOURNAL OF SURGERY 2000 87(1650-1655. Exclusion Code(s): DCOM

Novis BH, Bornman PC, Girdwood AW, and Marks IN. Endoscopic manometry of the pancreatic duct and sphincter zone in patients with chronic pancreatitis. Digestive Diseases and Sciences 85 30(3):225-8. Exclusion Code(s): DCOM

Novis BH, Narunsky L, and Bank S. Endoscopic retrograde cholangiopancreatography in the evaluation of pancreatic disease. South African Medical Journal 76 50(39):1501-5. Exclusion Code(s): DCOM

Ohara H and Hoshino M. Single application extracorporeal shock wave lithotrispy is the first choice for patients with pancreatic duct stones. American Journal of Gastroenterology 96 91(7):1388-1394. Exclusion Code(s): NOBJ

Ohtsuka T, Inoue K, Ohuchida J, Nabae T, Takahata S, Niiyama H, Yokohata K, Ogawa Y, Yamaguchi K, Chijiiwa K, and Tanaka M. Carcinoma arising in choledochocele. Endoscopy 2001 33(7):614-9. Exclusion Code(s): ANNQ

Ohtsuka T, Tanaka M, Inoue K, Nabae T, Takahata S, Yokohata K, Yamaguchi K, Chijiiwa K, and Ikeda S. Is peripapillary choledochoduodenal fistula an indication for endoscopic sphincterotomy? Gastrointestinal Endoscopy 2001 53(3):313-317. Exclusion Code(s): ANNQ

Okai T, Watanabe H, Yamaguchi Y, Mouri I, Motoo Y, and Sawabu N. EUS and K-ras analysis of pure pancreatic juice collected via a duodenoscope after secretin stimulation for diagnosis of pancreatic mass lesion: a prospective study. Gastrointestinal Endoscopy 99 50(6):797-803. Exclusion Code(s): DCOM

Ono K, Kobayashi S, Sakamoto K, Hayashida Y, and Sakakibara N. A clinical study of acute pancreatitis following endoscopic retrograde cholangiopancreatography. Digestive Endoscopy (Dig. Endosc.) 97 9(1):38-42. Exclusion Code(s): 5NCV, NOMVA

Oren A, Breumelhof R, Timmer R, Biesma DH, and Hoekstra JB. Abnormal clotting parameters before therapeutic ERCP: do they predict major bleeding? European Journal of Gastroenterology and Hepatology 99 11(10):1093-7. Exclusion Code(s): 5NCV NOMVA

Osnes M, Serck-Hanssen A, Kristensen O, Swensen T, Aune S, and Myren J. Endoscopic retrograde brush cytology in patients with primary and secondary malignancies of the pancreas. Gut 79 20(4):279-84. Exclusion Code(s): DCOM

Pace RF, Chamberlain MJ, and Passi RB. Diagnosing papillary stenosis by technetium-99m HIDA scanning. Canadian Journal of Surgery 83 26(2):191-3. Exclusion Code(s): DNSI

Palazzo L, Girollet PP, Salmeron M, Silvain C, Roseau G, Canard JM, Chaussade S, Couturier D, and Paolaggi JA. Value of endoscopic ultrasonography in the diagnosis of common bile duct stones: comparison with surgical exploration and ERCP. Gastrointestinal Endoscopy 95 42(3):225-31. Exclusion Code(s): AND

Pasanen P, Partanen K, Pikkarainen P, Alhava E, Pirinen A, and Janatuinen E. Complications of endoscopic retrograde cholangiopancreatography in jaundiced and cholestatic patients. Annales Chirurgiae et Gynaecologiae 92 81(1):28-31. Exclusion Code(s): 5NA, 5NCV, NOMVA

Pasanen P, Partanen K, Pikkarainen P, Alhava E, Pirinen A, and Janatuinen E. Diagnostic accuracy of ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the detection of pancreatic cancer in patients with jaundice or cholestasis. In Vivo 92 6(3):297-301. Exclusion Code(s): DCOM

Pasanen P, Partanen K, Pikkarainen P, Alhava E, Pirinen A, and Janatuinen E. Ultrasonography, CT, and ERCP in the diagnosis of choledochal stones. Acta Radiologica 92 33(1):53-6. Exclusion Code(s): DCOM

Pasanen PA, Eskelinen M, Partanen K, Pikkarainen P, Penttila I, and Alhava E. A prospective study of the value of imaging, serum markers and their combination in the diagnosis of pancreatic carcinoma in symptomatic patients. Anticancer Research 92 12(6B):2309-14. Exclusion Code(s): DCOM

Pasanen PA, Partanen K, Pikkarainen P, Alhava E, Pirinen A, and Janatuinen E. Diagnostic accuracy of ultrasound, computed tomography, and endoscopic retrograde cholangiopancreatography in the detection of obstructive jaundice. Scandinavian Journal of Gastroenterology 91 26(11):1157-64. Exclusion Code(s): DCOM

Pasanen PA, Partanen K, Pikkarainen P, Alhava E, Pirinen A, and Janatuinen E. A prospective study on the value of ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the diagnosis of unjaundiced cholestasis. In Vivo 94 8(2):227-30. Exclusion Code(s): DCOM

Pasanen PA, Partanen KP, Pikkarainen PH, Alhava EM, Janatuinen EK, and Pirinen AE. A comparison of ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the differential diagnosis of benign and malignant jaundice and cholestasis. European Journal of Surgery 93 159(1):23-9. Exclusion Code(s): DCOM

Pasanen PA, Pikkarainen PH, Alhava EM, Partanen KP, and Janatuinen EK. Clinical evaluation and imaging methods in the diagnosis of jaundice and cholestasis. Theoretical Surgery (Theor. Surg.) 92 7(4):180-185. Exclusion Code(s): DCOM

Pavone P, Laghi A, Catalano C, Broglia L, Fiocca F, and Passariello R. Non-invasive evaluation of the biliary tree with magnetic resonance cholangiopancreatography: initial clinical experience. Italian Journal of Gastroenterology 96 28(2):63-9. Exclusion Code(s): DCOM, NBH

Pavone P, Laghi A, Catalano C, Broglia L, Messina A, Scipioni A, Di Girolamo M, and Passariello R. MR cholangiopancreatography (MRCP) at 0.5 T: technique optimisation and preliminary results. European Radiology 96 6(2):147-52. Exclusion Code(s): DCOM, NBH

Pereira-Lima JC, Jakobs R, Busnello JV, Benz C, Blaya C, and Riemann JF. The Role of Serum Liver Enzymes in the Diagnosis Ofcholedocholithiasis. Hepato-Gastroenterology 2000 47(36):1522-1525. Exclusion Code(s): DNSI

Persson B. Relation of size and number of common duct calculi to success of sphincterotomy and stone extraction. Gastrointestinal Radiology 91 16(3):212-4. Comment in: Gastrointest Radiol. 1992 Summer;17(3):277. Exclusion Code(s): NOMVA

Pezzilli R, Billi P, Barakat B, D'Imperio N, and Miglio F. Ultrasonographic evaluation of the common bile duct in biliary acute pancreatitis patients: comparison with endoscopic retrograde cholangiopancreatography. Journal of Ultrasound in Medicine 99 18(6):391-4. Exclusion Code(s): DCOM

Phillips EH, Carroll BJ, Pearlstein AR, Daykhovsky L, and Fallas MJ. Laparoscopic choledochoscopy and extraction of common bile duct stones. World Journal of Surgery 93 17(1):22-8. Exclusion Code(s): TCOM

Pickuth D and Spielmann RP. Detection of choledocholithiasis: comparison of unenhanced spiral CT, US, and ERCP. Hepato-Gastroenterology 2000 47(36):1514-7. Exclusion Code(s): DCOM

Pitt HA, Gomes AS, Lois JF, MannLL, Deutsch LS, and Longmire WP Jr. Does preoperative percutaneous biliary drainage reduce operative risk or increase hospital cost? Annals of Surgery 85 201(545-553. Exclusion Code(s): TCOM

Podolsky I, Kortan P, and Haber GB. Endoscopic sphincterotomy in outpatients. Gastrointestinal Endoscopy (Gastrointest. Endosc.) 89 35(5):372-376. Exclusion Code(s): 5NCV, NOMVA

Ponchon T, Bory R, Hedelius F, Roebein L, Paliard P, Napoleon B, and Chavaillon A. Endoscopic stenting for pain relief in chronic pancreatitis: results of a standardized protocol. Gastrointestinal Endoscopy 99 42(452-456. Exclusion Code(s): AND [pending]

Ponsky JL and Duppler DW. Endoscopic sphincterotomy and removal of pancreatic duct stones. American Surgeon 87 53(10):613-6. Exclusion Code(s): AND TN25 TNRO

Pugliese V, Conio M, Nicolo G, Saccomanno S, and Gatteschi B. Endoscopic retrograde forceps biopsy and brush cytology of biliary strictures: a prospective study. Gastrointestinal Endoscopy 95 42(6):520-6. Exclusion Code(s): OVERLAP 4381

Rabenstein T, Ruppert T, Schneider HT, Hahn EG, and Ell C. Benefits and risks of needle-knife papillotomy. Gastrointestinal Endoscopy (Gastrointest. Endosc.) 97 46(3):207-211. Exclusion Code(s): 5NCV, NOMVA

Rao KJ, Varghese NM, Blake H, and Theodossi A. Endoscopic biliary stenting in a district general hospital. Gut 95 37(2):279-83. Exclusion Code(s): 5NA, 5NCV, NOMVA

Rawat B and Loewy J. Value of three-dimensional gradient-echo magnetic resonance cholangiography in diagnosing choledocholithiasis. Canadian Association of Radiologists Journal 96 47(4):265-9. Exclusion Code(s): DN25

Regan F, Fradin J, Khazan R, Bohlman M, and Magnuson T. Choledocholithiasis: evaluation with MR cholangiography. AJR. American Journal of Roentgenology 96 167(6):1441-5. Exclusion Code(s): DN25

Regan F, Schaefer DC, Smith DP, Petronis JD, Bohlman ME, and Magnuson TH. The diagnostic utility of HASTE MRI in the evaluation of acute cholecystitis. Half-Fourier acquisition single-shot turbo SE. Journal of Computer Assisted Tomography 98 22(4):638-42. Exclusion Code(s): DCOM

Regan F, Smith D, Khazan R, Bohlman M, Schultze-Haakh H, Campion J, and Magnuson TH. MR cholangiography in biliary obstruction using half-Fourier acquisition. Journal of Computer Assisted Tomography 96 20(4):627-32. Exclusion Code(s): DN25, DNSI

Reinhold C, Taourel P, Bret PM, Cortas GA, Mehta SN, Barkun AN, Wang L, and Tafazoli F. Choledocholithiasis: evaluation of MR cholangiography for diagnosis. Radiology 98 209(2):435-42. Exclusion Code(s): DCOM NBH

Rieger R, Sulzbacher H, Woisetschlager R, Schrenk P, and Wayand W. Selective use of ERCP in patients undergoing laparoscopic cholecystectomy. World Journal of Surgery 94 18(6):900-4; discussion 904-5. Exclusion Code(s): DPOP

Rieger R and Wayand W. Yield of prospective, noninvasive evaluation of the common bile duct combined with selective ERCP/sphincterotomy in 1390 consecutive laparoscopic cholecystectomy patients. Gastrointestinal Endoscopy 95 42(1):6-12. Exclusion Code(s): X6

Rijna H, Borgstein PJ, Meuwissen SG, de Brauw LM, Wildenborg NP, and Cuesta MA. Selective preoperative endoscopic retrograde cholangiopancreatography in laparoscopic biliary surgery. British Journal of Surgery 95 82(8):1130-3. Exclusion Code(s): DNSI

Robertson GS, Jagger C, Johnson PR, Rathbone BJ, Wicks AC, Lloyd DM, and Veitch PS. Selection criteria for preoperative endoscopic retrograde cholangiopancreatography in the laparoscopic era. Archives of Surgery 96 131(1):89-94. Exclusion Code(s): TNRO

RobertsThomson IC and Toouli J. Abnormal responses to morphine-neostigmine in patients with undefined biliary type pain. Gut (Gut) 85 26(12):1367-1372. Exclusion Code(s): AND, DCOM

Roesch W, Phillip J, and Gebhardt Ch. Endoscopic duct obstruction in chronic pancreatitis. Endoscopy (Endoscopy) 79 11(1):43-46. Exclusion Code(s): ANNQ

Rolny P, Anderberg B, Ihse I, Lindstrom E, Olaison G, and Arvill A. Pancreatitis after sphincter of Oddi manometry. Gut (Gut) 90 31(7):821-824. Exclusion Code(s): 5NCV, NOMVA

Rolny, Peter. Endoscopic bile duct stent placement as a predictor of outcome following endoscopic sphincterotomy in patients with suspected sphincter of Oddi dysfunction. European journal of Gastroenterology and Hepatology 97 9(467-471. Exclusion Code(s): TN25

Rosch T, Lorenz R, Braig C, Feuerbach S, Siewert JR, Schusdziarra V, and Classen M. Endoscopic ultrasound in pancreatic tumor diagnosis. Gastrointestinal Endoscopy 91 37(3):347-52. Exclusion Code(s): DUP 4543

Rosseland AR and Solhaug JH. Early or delayed endoscopic papillotomy (EPT) in gallstone pancreatitis. Annals of Surgery 84 199(2):165-7. Exclusion Code(s): TCOM

Roston AD and Jacobson IM. Evaluation of the pattern of liver tests and yield of cholangiography in symptomatic choledocholithiasis: a prospective study. Gastrointestinal Endoscopy 97 45(5):394-9. Exclusion Code(s): X6

Rothschild JG, Kaplan MM, Millan VG, and Reinhold RB. Management of biliary obstruction. A comparison of percutaneous, endoscopic, and operative techniques. Archives of Surgery 89 124(5):556-9; discussion 560. Exclusion Code(s): TPOP

Rupp N, Kramann B, Gullotta U, and Reiser M. Biliary drainage by teflon endoprosthesis in obstructive jaundice--experiences in 69 patients treated by PTCD or ERCD. European Journal of Radiology 83 3(1):42-50. Exclusion Code(s): TCOM

Ruppin H, Amon R, Ettl W, and et al. Acute pancreatitis after endoscopic/radiological pancreaticography (ERP). Endoscopy (Endoscopy) 74 6(2):94-98. Exclusion Code(s): 5NCV, NOMVA

Ryan ME. Cytologic brushings of ductal lesions during ERCP. Gastrointestinal Endoscopy 91 37(2):139-42. Exclusion Code(s): DCOM

Ryan ME and Baldauf MC. Comparison of flow cytometry for DNA content and brush cytology for detection of malignancy in pancreaticobiliary strictures. Gastrointestinal Endoscopy 94 40(2 Pt 1):133-9. Comment in: Gastrointest Endosc. 1994 Mar-Apr;40(2 Pt 1):249-52. Exclusion Code(s): DCOM

Sahai AV, Zimmerman M, Aabakken L, Tarnasky PR, Cunningham JT, van Velse A, Hawes RH, and Hoffman BJ. Prospective assessment of the ability of endoscopic ultrasound to diagnose, exclude, or establish the severity of chronic pancreatitis found by endoscopic retrograde cholangiopancreatography. Gastrointestinal Endoscopy 98 48(1):18-25. Comment in: Gastrointest Endosc. 1998 Jul;48(1):102-6. Comment in: Gastrointest Endosc. 1999 Aug;50(2):303-4. Exclusion Code(s): ANNQ

Sandy JT, Taylor RH, Christensen RM, Scudamore C, and Leckie P. Pancreatic pseudocyst. Changing concepts in management. American Journal of Surgery 81 141(5):574-6. Exclusion Code(s): TCOM

Sarli L, Costi R, Gobbi S, Sansebastiano G, and Roncoroni L. Asymptomatic bile duct stones: selection criteria for intravenous cholangiography and/or endoscopic retrograde cholangiography prior to laparoscopic cholecystectomy. European Journal of Gastroenterology and Hepatology 2000 12(11):1175-80. Exclusion Code(s): DNSI

Satterfield ST, McCarthy JH, Geenen JE, Hogan WJ, Venu RP, Dodds WJ, and Johnson GK. Clinical experience in 82 patients with pancreas divisum: preliminary results of manometry and endoscopic therapy. Pancreas 88 3(3):248-53. Exclusion Code(s): TCOM TN25

Sauter G, Grabein B, Huber G, Mannes GA, Ruckdeschel G, and Sauerbruch T. Antibiotic prophylaxis of infectious complications with endoscopic retrograde cholangiopancreatography. A randomized controlled study. Endoscopy 90 22(4):164-7. Exclusion Code(s): ANNQ

Sbeih F, Aljohani M, Altraif I, and Khan H. Role of endoscopic retrograde cholangiopancreatography before and after laparoscopic cholecystectomy. Annals of Saudi Medicine (Ann. Saudi Med.) 98 18(2):117-119. Exclusion Code(s): DNSI

Schlup MM, Williams SM, and Barbezat GO. ERCP: a review of technical competency and workload in a small unit. Gastrointestinal Endoscopy 97 46(1):48-52. Exclusion Code(s): 5NCV, NOMVA

Schneider H. T and May A. Piezoelectric shock wave lithotripsy of pancreatic duct stones. American Journal of Gastroenterology 94 89(11):2042-2048. Exclusion Code(s): NOBJ

Schreiber F, Gurakuqi GC, Pristautz H, Trauner M, and Schnedl W. Sonographically-guided extracorporeal shockwave lithotripsy for pancreatic stones in patients with chronic pancreatitis. Journal of Gastroenterology and Hepatology 96 11(3):247-51. Exclusion Code(s): [AND] TNRO TN25

Schutte H, Yarmuch J, Latorre R, Gallo G, Buhler J, Scavenius R, and Silva J. Endoscopic bile duct stone removal prior to laparoscopic cholecystectomy. Journal of Laparoendoscopic Surgery 94 4(3):191-7. Exclusion Code(s): X6

Schutz SM and Abbott RM. Grading ERCPs by degree of difficulty: a new concept to produce more meaningful outcome data. Gastrointestinal Endoscopy 2000 51(5):535-9. Exclusion Code(s): NOMVA

Scudera PL, Koizumi J, and Jacobson IM. Brush cytology evaluation of lesions encountered during ERCP. Gastrointestinal Endoscopy 90 36(3):281-4. Exclusion Code(s): DCOM

Sears RJ, Duckworth CW, Decaestecker C, Bourgeois N, Ledent T, Deviere J, Salmon I, Kiss R, and Yeaton P. Image cytometry as a discriminatory tool for cytologic specimens obtained by endoscopic retrograde cholangiopancreatography. Cancer 98 84(2):119-26. Exclusion Code(s): DCOM

Sees DW and Martin RR. Comparison of preoperative endoscopic retrograde cholangiopancreatography and laparoscopic cholecystectomy with operative management of gallstone pancreatitis. American Journal of Surgery 97 174(6):719-22. Exclusion Code(s): AND

Seifert E. Endoscopic retrograde cholangiopancreatography. Evaluation based on experience with 805 examinations. American Journal of Gastroenterology 77 68(6):542-9. Exclusion Code(s): 5NA

Seki K, Suda T, Aoyagi Y, Sugawara S, Natsui M, Motoyama H, Shirai Y, Sekine T, Kawai H, Mita Y, Waguri N, Kuroiwa T, Igarashi M, and Asakura H. Diagnosis of pancreatic adenocarcinoma by detection of human telomerase reverse transcriptase messenger RNA in pancreatic juice with sample qualification. Clinical Cancer Research 2001 7(7):1976-81. Exclusion Code(s): ANNQ

Semelka RC, Kroeker MA, Shoenut JP, Kroeker R, Yaffe CS, and Micflikier AB. Pancreatic disease: prospective comparison of CT, ERCP, and 1.5-T MR imaging with dynamic gadolinium enhancement and fat suppression. Radiology 91 181(3):785-91. Exclusion Code(s): DCOM

Shah RJ and Martin SP. Endoscopic retrograde cholangiopancreatography in the diagnosis and management of pancreatic diseases. Curr Gastroenterol Rep 2000 2(2):133-45. Exclusion Code(s): AND

Sharma BC, Agarwal DK, Baijal SS, Saraswat VA, Choudhuri G, and Naik SR. Endoscopic management of acute calculous cholangitis. Journal of Gastroenterology and Hepatology 97 12(12):874-6. Exclusion Code(s): TNCC

Sharma VK and Howden CW. Metaanalysis of randomized controlled trials of endoscopic retrograde cholangiography and endoscopic sphincterotomy for the treatment of acute biliary pancreatitis. American Journal of Gastroenterology 99 94(11):3211-4. Exclusion Code(s): ANNQ

Sherman S. Endoscopic drainage of malignant hilar obstruction: Is one biliary stent enough or should we work to place two? Gastrointestinal Endoscopy 2001 53(6):681-4. Exclusion Code(s): AND

Sherman S, Hawes RH, Savides TJ, Gress FG, Ikenberry SO, Smith MT, Zaidi S, and Lehman GA. Stent-induced pancreatic ductal and parenchymal changes: correlation of endoscopic ultrasound with ERCP. Gastrointestinal Endoscopy 96 44(3):276-82. Exclusion Code(s): [ANNQ]

Sherman S, Lehman G, and Jamidar P. Efficacy of endoscopic sphincterotomy and surgical sphincteroplasty for patients with sphincter of Oddi dysfunction (SOD): randomized, controlled study. Gastrointestinal Endoscopy 94 40(2 of 2):125A. Exclusion Code(s): ANMJ

Sherman S, Lehman GA, Hawes RH, Ponich T, Miller LS, Cohen LB, Kortan P, and Haber GB. Pancreatic ductal stones: frequency of successful endoscopic removal and improvement in symptoms. Gastrointestinal Endoscopy 91 37(5):511-7. Exclusion Code(s): [AND]

Sherman S, Ruffolo TA, Hawes RH, and Lehman GA. Complications of endoscopic sphincterotomy. A prospective series with emphasis on the increased risk associated with sphincter of Oddi dysfunction and nondilated bile ducts. Gastroenterology 91 101(4):1068-75. Exclusion Code(s): 5NCV, NOMVA

Shim CS, Joo JH, Park CW, Kim YS, Lee JS, Lee MS, and Hwang SG. Effectiveness of endoscopic ultrasonography in the diagnosis of choledocholithiasis prior to laparoscopic cholecystectomy. Endoscopy 95 27(6):428-32. Comment in: Endoscopy. 1995 Aug;27(6):443-4. Exclusion Code(s): DNSI

Siegel JH, Cooperman AM, Pullano W, and Hammerman H. Pancreas divisum: observation, endoscopic drainage, and surgical treatment results in 65 patients. Surgical Laparoscopy and Endoscopy 93 3(4):281-5. Exclusion Code(s): NRO

Siegel JH, Rodriquez R, Cohen SA, Kasmin FE, and Cooperman AM. Endoscopic management of cholangitis: critical review of an alternative technique and report of a large series. American Journal of Gastroenterology 94 89(8):1142-6. Exclusion Code(s): TCOM2

Siegman-Igra Y, Spinrad S, and Rattan J. Septic complications following endoscopic retrograde cholangiopancreatography: the experience in Tel Aviv Medical Center. Journal of Hospital Infection 88 12(1):7-12. Exclusion Code(s): 5NCV NOMVA

Smith AC, Dowsett JS, and Hattfield ARW et al. Prospective randomized trial of bypass surgery versus endoscopic stenting in patients with malignant obstructive jaundice. Gut 89 30 (1513 (abstract). Exclusion Code(s): ANMJ, OVERLAP WITH 4937

Smith M and Sherman S. Alterations in pancreatic ductal morphology following polyethylene pancreatic stent therapy. Gastrointestinal Endoscopy 96 44(3):268-75. Exclusion Code(s): ANNQ

Smits ME, Badiga SM, Rauws EA, Tytgat GN, and Huibregtse K. Long-term results of pancreatic stents in chronic pancreatitis. Gastrointestinal Endoscopy 95 42(5):461-7. Exclusion Code(s): AND (requested later) TNRO

Smits ME, Rauws EA, Tytgat GN, and Huibregtse K. Endoscopic treatment of pancreatic stones in patients with chronic pancreatitis. Gastrointestinal Endoscopy 96 43(6):556-60. Comment in: Gastrointest Endosc. 1996 Jun;43(6):625-6. Exclusion Code(s): [AND]TNRO

Songur Y, Oguz D, Gurkaynak G, Demirci F, and Sahin B. Endoscopic ultrasonography and endoscopic retrograde pancreatography in the diagnosis of chronic pancreatitis. Digestive Endoscopy (Dig. Endosc.) 2000 12(1):37-41. Exclusion Code(s): ANNQ, AND

Soto JA, Barish MA, Yucel EK, Clarke P, Siegenberg D, Chuttani R, and Ferrucci JT. Pancreatic duct: MR cholangiopancreatography with a three-dimensional fast spin-echo technique. Radiology 95 196(2):459-64. Exclusion Code(s): ANNQ

Soto JA, Barish MA, Yucel EK, Siegenberg D, Ferrucci JT, and Chuttani R. Magnetic resonance cholangiography: comparison with endoscopic retrograde cholangiopancreatography. Gastroenterology 96 110(2):589-97. Comment in: ACP J Club. 1996 Sep-Oct;125(2):45. Exclusion Code(s): DNSI, DCOM, NBH

Speer AG and Cotton PB. Endoscopic treatment of pancreatic cancer. International Journal of Pancreatology (Int. J. Pancreatology) 88 3(SUPPL. 1):S147-S158. Exclusion Code(s): TCOM AND BACKGROUND

Srinathan SK, Barkun JS, Mehta SN, Meakins JL, and Barkun AN. Evolving management of mild-to-moderate gallstone pancreatitis. Journal of Gastrointestinal Surgery 98 2(4):385-90. Exclusion Code(s): AND, TCOM

Stahl TJ, Allen MO, Ansel HJ, and Vennes JA. Partial biliary obstruction caused by chronic pancreatitis. An appraisal of indications for surgical biliary drainage. Annals of Surgery 88 207(1):26-32. Exclusion Code(s): TCOM

Stain SC, Cohen H, Tsuishoysha M, and Donovan AJ. Choledocholithiasis. Endoscopic sphincterotomy or common bile duct exploration. Annals of Surgery 91 213(6):627-33; discussion 633-4. Comment in: Ann Surg. 1992 Jul;216(1):102. Exclusion Code(s): TCOM

Stain SC, Marsri LS, Froes ET, Sharma V, and Parekh D. Laparoscopic cholecystectomy: laboratory predictors of choledocholithiasis. American Surgeon 94 60(10):767-71. Exclusion Code(s): DNSI

Stephens RV and Burdick GE. Microscopic transduodenal sphincteroplasty and transampullary septoplasty for papillary stenosis. American Journal of Surgery 86 152(6):621-7. Exclusion Code(s): TCOM

Stiegmann GV. Bile duct calculi--the new challenges. HPB Surgery 98 10(6):409-10. Exclusion Code(s): TN25

Stiegmann GV, Goff JS, Mansour A, Pearlman N, Reveille RM, and Norton L. Precholecystectomy endoscopic cholangiography and stone removal is not superior to cholecystectomy, cholangiography, and common duct exploration. American Journal of Surgery 92 163(2):227-30. Exclusion Code(s): TCOM

Strohm WD, Kurtz W, Hagenmuller F, and Classen M. Diagnostic efficacy of endoscopic ultrasound tomography in pancreatic cancer and cholestasis. Scandinavian Journal of Gastroenterology. Supplement 84 102(18-23. Exclusion Code(s): DPOP, DN25, DNSI

Suc B, Escat J, Cherqui D, Fourtanier G, Hay JM, Fingerhut A, and Millat B. Surgery vs endoscopy as primary treatment in symptomatic patients with suspected common bile duct stones. A multicenter randomized trial. Archives of Surgery (Arch. Surg.) 98 133(7):702-708. Exclusion Code(s): TCOM

Sugawa C, Clift D, and Walt AJ. Endoscopic retrograde cholangiopancreatography after cholecystectomy. Surgery, Gynecology and Obstetrics 83 157(3):247-51. Exclusion Code(s): DCOM

Sugawa C, Raouf R, Bradley V, and et al. Peroral endoscopic cholangiography and pancreatography. The surgeon's helper. Archives of Surgery (Arch. Surg.) 74 109(2):231-237. Exclusion Code(s): AND

Sugawa C and Walt AJ. Endoscopic retrograde pancreatography in the surgery of pancreatic pseudocysts. Surgery 79 86(4):639-47. Exclusion Code(s): DCOM

Sugiyama M and Atomi Y. Acute biliary pancreatitis: the roles of endoscopic ultrasonography and endoscopic retrograde cholangiopancreatography. Surgery 98 124(1):14-21. Exclusion Code(s): ANNQ3

Suramo I, Lehtola J, Leinonen A, and Kairaluoma M. The diagnostic accuracy of gray-scale ultrasonography compared with ERP and arteriography in the detection of pancreatic carcinoma. Scandinavian Journal of Gastroenterology 79 14(8):993-6. Exclusion Code(s): DCOM

Swobodnik W, Meyer W, Brecht-Kraus D, Wechsler JG, Geiger S, Malfertheiner P, Junge U, and Ditschuneit H. Ultrasound, computed tomography and endoscopic retrograde cholangiopancreatography in the morphologic diagnosis of pancreatic disease. Klinische Wochenschrift 83 61(6):291-6. Exclusion Code(s): DCOM

Takahashi M, Saida Y, Itai Y, Gunji N, Orii K, and Watanabe Y. Reevaluation of spiral CT cholangiography: Basic considerations and reliability for detecting choledocholithiasis in 80 patients. JOURNAL OF COMPUTER ASSISTED TOMOGRAPHY 2000 24(859-865. Exclusion Code(s): DNSI

Tanaka M, Sada M, Eguchi T, Konomi H, Naritomi G, Takeda T, Ogawa Y, Chijiiwa K, and Deenitchin GP. Comparison of routine and selective endoscopic retrograde cholangiography before laparoscopic cholecystectomy. World Journal of Surgery 96 20(3):267-70; discussion 271. Exclusion Code(s): TNRO

Tandon M and Topazian M. Endoscopic ultrasound in idiopathic acute pancreatitis. American Journal of Gastroenterology 2001 96(3):705-9. Exclusion Code(s): DCOM

Tanner AR. ERCP: present practice in a single region. Suggested standards for monitoring performance. European Journal of Gastroenterology and Hepatology 96 8(2):145-8. Exclusion Code(s): ANNQ, 5NA

Tascilar M, Sturm PD, Caspers E, Smit M, Polak MM, Huibregtse K, Noorduyn LA, and Offerhaus GJ. Diagnostic p53 immunostaining of endobiliary brush cytology: preoperative cytology compared with the surgical specimen. Cancer 99 87(5):306-11. Exclusion Code(s): DCOM

Taylor BR and Ho CS. Nonsurgical treatment of common-bile-duct stones. Canadian Journal of Surgery 84 27(1):28-32. Exclusion Code(s): TCOM

Teplick SK, Flick P, and Brandon JC. Transhepatic cholangiography in patients with suspected biliary disease and nondilated intrahepatic bile ducts. Gastrointestinal Radiology 91 16(3):193-7. Exclusion Code(s): DCOM

Testoni PA, Caporuscio S, Bagnolo F, and Lella F. Idiopathic recurrent pancreatitis: long-term results after ERCP, endoscopic sphincterotomy, or ursodeoxycholic acid treatment. American Journal of Gastroenterology 2000 95(7):1702-7. Comment in: Am J Gastroenterol. 2000 Jul;95(7):1615-8. Exclusion Code(s): TN25

Tham TC, Lichtenstein DR, Vandervoort J, Wong RC, Brooks D, Van Dam J, Ruymann F, Farraye F, and Carr-Locke DL. Role of endoscopic retrograde cholangiopancreatography for suspected choledocholithiasis in patients undergoing laparoscopic cholecystectomy. Gastrointestinal Endoscopy 98 47(1):50-6. Exclusion Code(s): DNSI

Thomas MJ, Pellegrini CA, and Way LW. Usefulness of diagnostic tests for biliary obstruction. American Journal of Surgery 82 144(1):102-8. Exclusion Code(s): DCOM DNSI

Thompson MH. Influence of endoscopic papillotomy on the management of bile duct stones. British Journal of Surgery (Br. J. Surg.) 86 73(10):779-781. Exclusion Code(s): ANNQ

Thornton JR, Lobo AJ, Lintott DJ, and Axon AT. Value of ultrasound and liver function tests in determining the need for endoscopic retrograde cholangiopancreatography in unexplained abdominal pain. Gut 92 33(11):1559-61. Exclusion Code(s): DCOM, X6

Tio TL, Tytgat GNJ, Cikot RJLM, Houthoff HJ, and Sars PRA. Ampullopancreatic carcinoma: Preoperative TNM classification with endosonography. Radiology (Radiology) 90 175(2):455-461. Exclusion Code(s): DCOM

Tio TL, Wijers OB, Sars PR, and Tytgat GN. Preoperative TNM classification of proximal extrahepatic bile duct carcinoma by endosonography. Seminars in Liver Disease 90 10(2):114-20. Exclusion Code(s): DCOM

Tobin RS, Vogelzang RL, Gore RM, and Keigley B. A comparative study of computed tomography and ERCP in pancreaticobiliary disease. Journal of Computed Tomography 87 11(3):261-6. Exclusion Code(s): DPOP, DCOM

Traverso LW. A cost analysis of the treatment of common bile duct stones discovered during cholecystectomy. Seminars in Laparoscopic Surgery 2000 7(4):302-7. Exclusion Code(s): AND

Treacy PJ and Worthley CS. Pancreatic stents in the management of chronic pancreatitis. Australian and New Zealand Journal of Surgery (Aust. New Zealand J. Surg.) 96 66(4):210-213. Exclusion Code(s): TN25

Trede M, Rumstadt B, Wendl K, Gaa J, Tesdal K, Lehmann KJ, Meier-Willersen HJ, Pescatore P, and Schmoll J. Ultrafast magnetic resonance imaging improves the staging of pancreatic tumors. Annals of Surgery 97 226(4):393-405; discussion 405-7. Exclusion Code(s): ANNQ

Tsitouridis I, Kouklakis G, Tsitouridis K, Papastergiou C, and Xiarchos P. MR cholangiopancreatography evaluation of the biliary tree. Hellenic Journal of Gastroenterology (Hell. J. Gastroenterol.) 97 10(4):307-310. Exclusion Code(s): DNSI, AND, TCOM

Tzovaras G and Rowlands BJ. Diagnosis and treatment of sphincter of Oddi dysfunction. British Journal of Surgery 98 85(5):588-95. Exclusion Code(s): AND

Uomo G, Galloro V, Rabitti PG, Marcopido B, Laccetti M, and Visconti M. Early endoscopic cholangiopancreatography and sphincterotomy in acute biliary pancreatitis: report of 50 cases. Italian Journal of Gastroenterology 91 23(9):564-6. Exclusion Code(s): TCOM

Uomo G, Manes G, Ragozzino A, Cavallera A, and Rabitti PG. Periampullary extraluminal duodenal diverticula and acute pancreatitis: an underestimated etiological association. American Journal of Gastroenterology 96 91(6):1186-8. Exclusion Code(s): ANNQ

Vahldiek G, Broemel T, and Klapdor R. MR-cholangiopancreaticography (MRCP) and MR-angiography: morphologic changes with magnetic resonance imaging. Anticancer Research 99 19(4A):2451-8. Exclusion Code(s): DNRO DNSI AND

Vaira D, Dowsett JF, Hatfield AR, Cairns SR, Polydorou AA, Cotton PB, Salmon PR, and Russell RC. Is duodenal diverticulum a risk factor for sphincterotomy? Gut 89 30(7):939-42. Exclusion Code(s): NOMVA

Van Camp JM, Polley TZ, and Coran AG. Pancreatitis in children: Diagnosis and etiology in 57 patients. Pediatric Surgery International (Pediatr. Surg. Int.) 94 9(7):492-497. Exclusion Code(s): ANNQ

Van Dam J and Sivak MV. Mechanical lithotripsy of large common bile duct stones. Cleveland Clinic Journal of Medicine 93 60(1):38-42. Exclusion Code(s): TCOM

van der Hul RL, Plaisier PW, Lameris JS, Veeze-Kuijpers B, van Blankenstein M, and Terpstra OT. Proximal cholangiocarcinoma: a multidisciplinary approach. European Journal of Surgery 94 160(4):213-8. Exclusion Code(s): TNCC, 2NCV

Vandervoort J, Soetikno RM, Montes H, Lichtenstein DR, Van Dam J, Ruymann FW, Cibas ES, and Carr-Locke DL. Accuracy and complication rate of brush cytology from bile duct versus pancreatic duct. Gastrointestinal Endoscopy 99 49(3 Pt 1):322-7. Comment in: Gastrointest Endosc. 2000 Jun;51(6):774. Exclusion Code(s): DCOM

Varghese JC, Liddell RP, Farrell MA, Murray FE, Osborne H, and Lee MJ. The diagnostic accuracy of magnetic resonance cholangiopancreatography and ultrasound compared with direct cholangiography in the detection of choledocholithiasis. Clinical Radiology 99 54(9):604-14. Comment in: Clin Radiol. 2000 Jul;55(7):579. Exclusion Code(s): DUP OF 5466

Venu RP, Geenen JE, Hogan W, Stone J, Johnson GK, and Soergel K. Idiopathic recurrent pancreatitis. An approach to diagnosis and treatment. Digestive Diseases and Sciences 89 34(1):56-60. Comment in: Dig Dis Sci. 1989 Dec;34(12):1943-5. Exclusion Code(s): DCOM TN25

Venu RP, Geenen JE, Kini M, Hogan WJ, Payne M, Johnson GK, and Schmalz MJ. Endoscopic retrograde brush cytology. A new technique. Gastroenterology 90 99(5):1475-9. Exclusion Code(s): DCOM

Vitale GC, Larson GM, George M, and Tatum C. Management of malignant biliary stricture with self-expanding metallic stent. Surgical Endoscopy 96 10(10):970-3. Exclusion Code(s): TCOM

Vitale GC, Reed DN, Nguyen CT, Lawhon JC, and Larson GM. Endoscopic treatment of distal bile duct stricture from chronic pancreatitis. Surgical Endoscopy 2000 14(3):227-31. Erratum in: Surg Endosc 2000 Apr;14(4):411. Exclusion Code(s): NOBJ

Voyles CR, Sanders DL, and Hogan R. Common bile duct evaluation in the era of laparoscopic cholecystectomy. 1050 cases later. Annals of Surgery 94 219(6):744-50; discussion 750-2. Exclusion Code(s): X6

Wagner HJ, Knyrim K Vakil N Klose KJ. Plastic endoprostheses versus metal stents in the palliative treatment of malignant hilar biliary obstruction. A prospective and randomized trial. Endoscopy 93 25):213-218. Exclusion Code(s): TN25

Wang CH, Mo LR, Lin RC, Kuo JY, and Chang KK. Rapid diagnosis of choledocholithiasis using biochemical tests in patients undergoing laparoscopic cholecystectomy. Hepato-Gastroenterology 2001 48(39):619-21. Exclusion Code(s): 6NCPR

Warshaw AL, Richter JM, and Schapiro RH. The cause and treatment of pancreatitis associated with pancreas divisum. Annals of Surgery 83 198(4):443-52. Exclusion Code(s): TNRO

Wehrmann T, Schmitt T, Stergiou N, Caspary WF, and Seifert H. Topical application of nitrates onto the papilla of Vater: manometric and clinical results. Endoscopy 2001 33(4):323-8. Exclusion Code(s): 5NRO, TECHNICAL SUCCESS

Wehrmann T, Schmitt TH, Arndt A, Lembcke B, Caspary WF, and Seifert H. Endoscopic injection of botulinum toxin in patients with recurrent acute pancreatitis due to pancreatic sphincter of Oddi dysfunction. Alimentary Pharmacology and Therapeutics (Aliment. Pharmacol. Ther.) 2000 14(11):1469-1477. Exclusion Code(s): TN25

Weizel A and Czygan P. Demonstration of a liver abscess by ERC. Endoscopy (Endoscopy) 76 8(2):110-111. Exclusion Code(s): AND

Wiersema MJ, Kochman ML, Cramer HM, Tao LC, and Wiersema LM. Endosonography-guided real-time fine-needle aspiration biopsy. Gastrointestinal Endoscopy 94 40(6):700-7. Exclusion Code(s): DN25

Wojtun S, Gil J, Gietka W, and Gil M. Endoscopic sphincterotomy for choledocholithiasis: a prospective single-center study on the short-term and long-term treatment results in 483 patients. Endoscopy 97 29(4):258-65. Exclusion Code(s): NOMVA

Yamaguchi T, Saisho H, and Ohto M. Usefulness of percutaneous histological biopsy in the diagnosis of chronic pancreatitis with inflammatory mass (CPM). Journal of Interventional Radiology (J. Intervent. Radiol.) 94 9(4):165-170. Exclusion Code(s): DN25

Yamakawa T, Sakai S, Mu ZB, and Pineres G. Laparoscopic management of common bile duct stones. Journal of Hepato-Biliary-Pancreatic Surgery 2000 7(1):9-14. Exclusion Code(s): AND

Yamashita Y, Abe Y, Tang Y, Urata J, Sumi S, and Takahashi M. In vitro and clinical studies of image acquisition in breath-hold MR cholangiopancreatography: single-shot projection technique versus multislice technique. AJR. American Journal of Roentgenology 97 168(6):1449-54. Exclusion Code(s): ANNQ

Yap I, Wee A, Tay HH, Guan R, and Kang JY. Primary biliary cirrhosis--an uncommon disease in Singapore. Singapore Medical Journal 96 37(1):48-50. Exclusion Code(s): ANNQ

Yeh TS, Jan YY, Tseng JH, Chiu CT, Chen TC, Hwang TL, and Chen MF. Malignant perihilar biliary obstruction: magnetic resonance cholangiopancreatographic findings. American Journal of Gastroenterology 2000 95(2):432-40. Exclusion Code(s): AND, DNSI

Zeman RK, Burrell MI, Dobbins J, Jaffe MH, and Choyke PL. Postcholecystectomy syndrome: evaluation using biliary scintigraphy and endoscopic retrograde cholangiopancreatography. Radiology 85 156(3):787-92. Exclusion Code(s): DNSI

Zoepf T, Zoepf DS, Arnold JC, Benz C, and Riemann JF. The relationship between juxtapapillary duodenal diverticula and disorders of the biliopancreatic system: Analysis of 350 patients. Gastrointestinal Endoscopy 2001 54(1):56-61. Exclusion Code(s): 5NA