# Evidence Tables

Evidence Table 1. Studies of Accuracy of Screening Cervical Cytology

| Study Design & Characteristics | Interventions | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations ^1^ | Quality Evaluation ^2^
AutoPap
Colgan, Patten, and Lee, 1995 | Prospective blinded comparison | AutoPap 300 QC rescreening vs. manual rescreening in smears initially categorized as negative | Ontario, Canada Time period not specified Independent service cytopathology laboratory | 3,487 smears screened manually as negative | Blind interpretation No. of FN/No. rescreened No. of FN with AutoPap/total FN GS: cytology (independent panel) applied to discrepant cases | AutoPap 20% review rate Yield: (ASCUS+) = 57/3487 (1.6%) (LSIL+) = 10/3487 (0.29%) FN (AutoPap)/FN total (ASCUS+) = 57/86 (66.3%) FN (AutoPap)/total (LSIL+) = 10/13 (76.9%) | Quality Score=6 Ref. Std.: 0 Blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Lee, Kuan, Oh et al., 1998 | Diagnostic test evaluation | AutoPap primary screening system | 9 cytopathology laboratories c. 1997 | 683 Pap smears (264 normal) | Sensitivity and workload reduction GS: cytology (independent panel) | Se (ASCUS+) = 330/357 (92.4%) Se (LSIL+) = 195/199 (98%) Feasibility study of location-guided screening. No results for slides initially read as normal. | Quality Score=6 Ref. Std.: 0 Blind: 2 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 0
Patten, Lee, Wilbur et al., 1997b | Diagnostic test evaluation No reference standard. No histological verification. | AutoPap 300 QC vs. initial reading | US 1997 Commercial or hospital/academic laboratories | Current archive sensitivity: 2,339 Pap smears including positives and negative controls;Historic sensitivity study 3,028 Pap smears comprising positive and negative controls | No. of FN detected by AutoPap/total FN (estimate of sensitivity) | AutoPap 10% review rate: Est. Se (ASCUS+) = 67/203 (33%) Est. Se (LSIL+) = 18/32 (56%) AutoPap 20% review rate: Est. Se (ASCUS+) = 103/203 (51%) Est. Se (LSIL+) = 21/32 (66%) No data on specificity of AutoPap rescreen | Quality Score=4 Ref. Std.: 0 Blind: 2 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 0
Stevens, Milne, James et al., 1997 | Prospective comparison | AutoPap 300 QC vs. random manual rescreening | Australia 3/95-4/95 Cytology laboratory | 1,840 Pap smears initially read as "normal" | No. of FN detected by AutoPap/total FN (estimated sensitivity) GS: cytology (independent panel review of discrepant cases) | AutoPap: Est. Se: 30% review rate: 4/7 (52%) 20% review rate 3/7 (43%) 10% manual review: Est. Se 0/7 = 0% | Quality Score = 6 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Wilbur, Bonfiglio, Rutkowski et al., 1996 | Diagnostic test evaluation | AutoPap 300 QC 10% or 20% rescreening rate | New York Commercial and academic cytopathology laboratories | 86 cases of known HSIL+ from archives of two labs | Sensitivity of AutoPap to detect known HSIL+ GS: histology | In 86 biopsy-positive cases with cytological diagnosis of HSIL+, AutoPap selected 66 (77%) at 10% review fraction and 74 (86%) at 20% review fraction Limitation: not rescreening use | Quality Score=4 Ref. Std.: 2 blind: 0 Verification: 1 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 0
Wilbur, Prey, Miller et al., 1998 | Prospective two-armed comparison | AutoPap primary screening system vs. manual screening | Time period not specified 5 commercial cytopathology laboratories | 25,124 Pap smear slides, excluding "high-risk" slides | Estimated sensitivity Relative TPR Relative FPR GS: cytology (independent panel review of discrepant cases) No histological verification | Est Se (ASCUS+) = 1199/1397 (85.8%) Est Se (LSIL+) = 321/348 (92.2%) Relative TPR (AutoPap/conv) = 1199/1106 = 1.08 Relative FPR (AutoPap/conv) = 1123/1322 = 0.85 Limitation: results not reported for performance of AutoPap System on slides with manual screen witin normal limits. AutoPap system uses a different algorithm from AutoPap 300 QC | Quality Score=6 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Papnet
Ashfaq, Liang, and Saboorian, 1995 | Diagnostic test evaluation Prospective validation of Papnet rescreening | Papnet rescreening vs. manual rescreening among samples initially categorized as negative | Dallas, TX Time period not specified Academic medical center | 2,238 smears screened manually as negative. No patients with known prior dysplasia, radiation or chemo-therapy, post-menopausal vaginal bleeding; symptomatic | No. of FN/ No rescreened GS: cytology (single independent cytopathologist) only for slides called unsatisfactory or atypical on Papnet review | Papnet rescreening resulted in 91/2,238 "review," 45/2,238 "inadequate," 2,102/2,238 negative (94%) Manual rescreen of 91 atypical cases found: 5/91 ASCUS or LSIL. 86/91 negative (20% BCC) Detection rate 0.2% Manual rescreen of 45 inadequate found: 36/45 negative, 9 truly unsatisfactory. | Quality Score=5 Ref. Std.: 0 blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Ashfaq, Saliger, Solares et al., 1997 | Diagnostic test evaluation Prospective, blind comparison of Papnet. | Papnet (pre-) screening vs. manual screening diagnosis | Dallas, TX Time period not specified Academic medical center | 5,170 consecutive Pap smears | Sensitivity and specificity to known abnormals GS:cytology (single independent cytopathologist) for discrepant cases only | Papnet: Se 86.1% Sp (ASCUS+) = 82% Sp (LSIL+) = 93.6% Manual screening: Se = 77.3% Sp (ASCUS+) = 77.3% Sp (LSIL+) = 92.5% Performance among manually screened negative slides not reported. | Quality Score=7 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Duggan and Brasher, 1997 | Prospective, blind comparison of Papnet vs. manual screening | Papnet pre-screening vs. manual screening | Alberta, Canada 3-month period in 1995 Pathology laboratory | 5,037 consecutive Pap tests for cervical cancer screening (smears from colposcopy or gynecology-oncology clinics excluded), 4,574 of which were negative on manual screening. | No. of FN/No. rescreened GS: cytology (panel). Verification of discrepant cases. | Papnet: 17/4574 = 0.37% | Quality Score=7 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Farnsworth, Chambers, Goldschmidt, 1996 | Prospective, blind comparison | Papnet rescreening vs. manual rescreening | Sydney, Australia 1/95-9/95 Large cytopathology laboratory | 54,658 Pap smears initially read as normal, and 1,022 Pap smears classified as abnormal | No. of FN/No. rescreened GS:cytology (single cytopathologist). Histological validation for small subset of Papnet positive smears | Papnet identified 266/54658 = 0.49%(32 ASCUS, 217 LSIL, 17 HSIL) Papnet detected all 122 HSIL and ICC, but failed to detect 112 (14 ASCUS, 98 LSIL) of 1,022 known positive smears. | Quality Score=7 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Halford, Wright, Ditchmen, 1997 | Prospective comparison of Papnet rescreening vs. historical rapid rescreening No independent cytology panel. No histological verification. | Papnet rescreening vs. rapid manual rescreening | Australia Time period not specified | 1,000 negative smears seeded with 20 "difficult" cases | No. of FN/No. rescreened Sensitivity to known abnormals | Results not given for false negative detection Se (known abn ASCUS+) 19/20 (95%) Rapid manual rescreening Se (known abn ASCUS+) = 9/20 (45%) | Quality Score=2 Ref. Std.: 0 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Jenny, Isenegger, Boon et al., 1997 | Diagnostic test evaluation | Papnet | Zurich, Switzerland 1988-94 Private cytopathology laboratory | 1,200 smears 516 with histologically proven diagnosis; 29 of which had been manually screened as negative | No. of FN/No. rescreened GS: Histological validation. No validation of test negatives. | Papnet rescreening: Se (LSIL+) = 26/29 = 89% In primary screening: 2 independent Papnet reviews identified 435 & 469 of 516 (91% & 84%) Manual screening: 403/561 (78.1%) Relative TPR 1.08-1.16 Papnet compared with manual screening | Quality Score=7 Ref. Std.: 2 blind: 2 Verification: 1 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Kaufman, Schreiber, and Carter, 1998 | Diagnostic test evaluation, Papnet rescreening compared with colposcope- directed biopsy All subjects verified | Rescreening of conventional Pap smear using Papnet | Texas 1993-95 | 160 women with colposcopy and biopsy within 1 year of a smear initially reported as ASCUS | Blind interpretation Papnet diagnosis (ASCUS/ AGUS, LSIL, HSIL, Ca) GS: colposcope-directed biopsy (normal, HPV, CIN1, CIN2, CIN3) | Prevalence (CIN1)=69/160=43% Se (LSIL,CIN1)=26/69=38% Sp (LSIL,CIN1)=84/91=92% Prevalence (CIN2/3)=22/160=14% Se (LSIL,CIN2/3)=9/22=41% Sp (LSIL,CIN2/3)=114/138=83% Limitations: Narrow spectrum of disease (ASCUS/AGUS), | Quality Score=10 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 0
Mango and Valente, 1998 | Diagnostic test evaluation | Papnet rescreening vs. manual rescreening | 1985-92 Academic cytopathology laboratories | 2,293 smears underwent Papnet rescreening; 13,761 underwent manual rescreening. | No. of FN/No. rescreened GS: cytology (single pathologist). No verification of rescreen negatives. No histological validation | Papnet: FN yield (ASCUS+)142/2,293 (6.3%) FN yield (LSIL+) 48/2,293 (2.1%) Manual rescreen: FN yield (ASCUS+) 82/13761 (0.6%) FN yield (LSIL+) 36/13,761 (0.3%) | Quality Score=4 Ref. Std.: 0 blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 0
Mitchell and Medley, 1998 | Evaluation of Papnet rescreening | Papnet rescreening | Australia 1990-92 | 19,805 Pap smears with 2 negative manual screens | No. of FN/No. rescreened GS: cytology (panel). No verification of rescreen negatives. Histologic validation of some rescreen positives. | FN yield (single cytologist): 212/19,805 (1.1%) FN yield (cytology panel): 162/212 (0.82%) FN yield (histology): 14/26 high-grade and 33/102 low-grade abnormalities histologically confirmed | Quality Score=5 Ref. Std.: 0 blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
O'Leary, Tellado, Buckner et al., 1998 | Prospective evaluation of Papnet rescreening | Papnet rescreening | Washington, DC 1994-95 Government pathology organization | 5,478 consecutive Pap smears read as normal or benign cell changes on initial and random rescreening. | No. FN/No. rescreened GS: cytology (independent panel). Verification of discrepant cases only. | Papnet identified 1,614 (29%) of slides requiring review; 1,166 because no endocervical component was identified. 448 (8% of total) Only 11 cases demonstrated abnormal cells (5 ASCUS, 1 AGUS, 6 LSIL+) 11/5,478 (0.2%) | Quality Score=5 Ref. Std.: 0 blind: 0 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Slagel, Zaleski, and Cohen, 1995 | Diagnostic test evaluation | Papnet screening | Iowa City, IA 10/90 | 500 previously screened Pap smears; 435 of which had been screened previously as normal | No. of FN/No. rescreened GS: cytology (single independent pathologist). Discrepant cases reviewed. | FN yield: 15/450 (3.3%) | Quality Score=7 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
ThinPrep 2000
Bolick, Hellman, 1998 | Diagnostic test evaluation Selection of negative smears uncertain | Conventional Pap (broom-type sampling device or a combination endocervical brush and plastic spatula) vs. ThinPrep | Utah 1996-97 | 39,408 conventional Paps, and 10,694 ThinPrep specimens, collected concurrently in two patient populations, described only by age | No blind interpretation Pap and ThinPrep specimen with threshold of LSIL GS: histology with threshold of "positive" | Screening test: ThinPrep Prevalence (not specified)=42/54=78% Se (LSIL,NS)=40/42=95% Sp (LSIL,NS)=7/12=58% Screening test: Pap Prevalence (NS)=67/89=75% Se (LSIL,NS)=57/67=85% Sp (LSIL,NS)=8/22=36% | Quality Score=4 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Corkill, Knapp, and Hutchinson, 1997 | Diagnostic test evaluation Prospective, split sample, double-masked trial. Discrepancies and 5% of test-negatives verified by single independent pathologist only for second group. No histologic verification of test-positives | Conventional Pap vs. ThinPrep. Split sample collected with cytobrush/spatula | Colorado 5/95-6/95 and 3/96-4/96 11 planned parenthood clinics | 462 subjects in first group, 1,239 in following group All patients >18 years, premeno-pausal, and no history of abnormal Pap | Concordance between ThinPrep and conventional smear; discrepancies and 5% of test-negatives verified by single independent pathologist only for second group. | Unable to get estimate of specificity because no test positives verified with histology. ThinPrep more likely to identify slides as abnormal (LSIL+) than conventional smear | Quality Score=3.5 Ref. Std.: 0 blind: 2 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: .5
Inhorn, Wilbur, Zahniser et al., 1998 | Diagnostic test evaluation of ThinPrep vs. conventional Pap Cancer specimens from ThinPrep clinical trial, including results from ThinPrep beta and ThinPrep 2000 ThinPrep and conventional smear obtained from known cancer patients, split-sample No disease negatives studied | ThinPrep vs. conventional Pap. Split-sample, obtained with broom device | 5 institutions, gynecologic oncology clinics | 47 patients with known cervical cancer | No blind interpretation Ability of ThinPrep and conventional smear to identify cancerous cells as cancer | Independent reference pathologist only for samples from ThinPrep 2000 study only Study only evaluated cancer patients, therefore unable to estimate specificity ThinPrep identified 21/22 smears as cancer (1 was ASCUS) Conventional smear identified 19/22 as cancer (1 was ASCUS, 2 were unsatisfactory) | Quality Score=3.5 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Lee, Ashfaq, Birdsong et al., 1997 | Diagnostic test evaluation, conventional Pap vs. ThinPrep ThinPrep clinical trial: 6 centers, prospective, split sample, double-masked trial Discrepancies and 5% of test-negatives verified by single independent pathologist No histologic verification of test-positives | Conventional Pap vs. ThinPrep. Split sample collected with broom device. | US 1996 6 sites; 3 community clinics and 3 hospitals | 6,747 women, recruited from 6 centers. 3 hospital centers selected for high proportion of high-risk women. 58.9% white, 21.7% black, 13.9 % Hispanic, 2.2% other. | Concordance between ThinPrep and conventional smear; discrepancies and 5% of test-negatives verified by single independent pathologist | Unable to get estimate of specificity because no test positives verified with histology. ThinPrep more likely to identify slides as abnormal (ASCUS or LSIL) than conventional smear in screening centers, but not in hospitals | Quality Score=5.5 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: .5
Papillo, Zarka, and St. John, 1998 | Diagnostic test evaluation ThinPrep slides compared with historical cohort of conventional Pap slides for specimen adequacy and yield of abnormal diagnoses Histologic verification of most ThinPrep HSIL. No verification of test-negatives | ThinPrep vs. conventional smear ThinPrep Direct to vial | Vermont 3/97-9/97 12 practice sites that chose to offer ThinPrep | Uncertain sample collection. Spectrum not described | Specimen adequacy and yield of abnormal diagnoses Thresholds for ThinPrep and conventional smear of ASCUS/AGUS, LSIL, SIL NOS, HSIL | No reference standard; compared only with historical cohort of conventional smear samples. Prevalence of disease unknown Histologic verification of most ThinPrep HSIL ThinPrep resulted in more abnormal diagnoses (ASCUS+) than historical conventional smear, and less unsatisfactory or limited smears Positive Predictive Value of ThinPrep for HSIL=93.2% Historical Positive Predictive Value of conventional smear for HSIL=78.8% | Quality Score=1.5 Ref. Std.: 0 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Roberts, Gurley, Thurloe et al., 1997 | Diagnostic test evaluation. split sample, ThinPrep vs. conventional Pap Discrepant results reviewed Most of test-positives with HSIL verified. No test negatives verified with histology | Split sample technique with Cervex broom used to prepare both conventional Pap and ThinPrep 2000 | Australia 7/96 -5/97 | 35,560 pairs received from 500 practitioners who chose to offer ThinPrep along with conventional smear. 24% of women undergoing screening pap, and 35% of women needing referral pap had both samples taken | No blind interpretation Conventional smear and ThinPrep thresholds of minor changes/HPV, LSIL, inconclusive abnormality, HSIL, cytologic reference standard for test negatives. Histologic reference standard for those with HSIL or inconclusive results on either conventional smear or ThinPrep. | All discrepant results reviewed by independent cytopathologist Most of HSIL and inconclusive results on either ThinPrep or conventional smear had histologic confirmation No test negatives verified, or those with LSIL Relative True Positive rate (ThinPrep)=178/158=1.13 Relative False Positive rate(ThinPrep)=37/33=1.12 | Quality Score=1.5 Ref. Std.: 0 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Sherman, Mendoza, Lee et al., in press | Diagnostic test evaluation, conventional Pap vs. ThinPrep Data from ThinPrep clinical trial All abnormals, and random 5% of test-negatives verified by independent cytologists and pathologists. No histologic verification of test-positives. Diagnoses compared with HPV results | Conventional Pap vs. ThinPrep. Split sample collected with broom device | US 1996 6 sites; 3 community clinics and 3 hospitals | 1954 slides: 895 discrepant results, 759 concordant positives, and 300 random negatives from clinical trial. | Blind interpretation Sensitivity of ThinPrep and conventional smear as compared with most abnormal reference cytology diagnosis Positive Predictive Value estimated by comparison with HPV type | Unable to get estimate of specificity because no test positives verified with histology Se ThinPrep (HSIL)=88.6% Se conventional smear (HSIL)=81.2% No difference in HPV detection in smears called abnormal between conventional smear and ThinPrep More cancer-associated HPV types seen in ThinPrep+ patients. Very few HPV+ in 300 random test-negatives | Quality Score=4.5 Ref. Std.: 0 blind: 2 Verification: 1 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: .5
Weintraub and Morabia (submitted) | Diagnostic test evaluation, conventional Pap vs. ThinPrep ThinPrep slides compared with historical separate sample of women undergoing conventional smear Histologic verification of most of HSIL test-positives for ThinPrep No verification of test negatives, by either cytology or histology | Conventional Pap vs. ThinPrep. Conventional smear obtained with spatula/cytobrush ThinPrep obtained direct to vial with Cervex broom | Switzerland 12/96-12/97 | 39,865 consecutive ThinPrep slides compared with 151,588 consecutive conventionally prepared historical smears among similar populations undergoing routine screening | Detection rate of ThinPrep and conventional smear; Positive Predictive Value of ThinPrep | Historical controls, therefore no reference standard, and unknown prevalence. Only noncorrelating biopsy cases reviewed by independent pathologist ThinPrep more likely to identify slides as abnormal (ASCUS+) than historical conventional smear PPV ThinPrep (HSIL/CIN2-3)=86% | Quality Score=3.0 Ref. Std.: 0 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 0 Publication: 0 Industry: 1
Conventional Pap
Anderson, Flannelly, Kitchener et al., 1992 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (specimen collection not described) vs. colposcopy | England 10/89-10/91 | 228 women with history of mild / moderate dyskaryosis only Unspecified recruitment | No blind interpretation GS: colposcopy reported as Viral Change/CIN1 / 2 / 3 | Prevalence (CIN2/3)=159/228=70% Se (HSIL,CIN2/3)=60/159=38% Sp (HSIL,CIN2/3)=47/69=68% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Andrews, Hernandez, and Miyazawa, 1989 | Diagnostic test evaluation of paired Pap smears in follow-up of atypical cells | Conventional Pap (cotton-tipped applicator and wooden Ayre spatula) | Hawaii 2/85-4/88 | 360 women referred for atypical cells on Pap, excluded women with history of dysplasia Mean age: 36 | Blind interpretation Pap (negative, atypia, condyloma CIN) GS: histology or negative colposcopy (negative, condyloma, CIN) | Prevalence (CIN1)=118/353=33% Se (ASCUS,CIN1)=62/118=53% Sp (ASCUS,CIN1)=146/235=62% Se (LSIL,CIN1)=31/118=26% Sp (LSIL,CIN1)=206/235=88% Limitations: Referral population, all negatives had prior positive smear | Quality Score=9 Ref. Std.: 2 blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Baldauf, Dreyfus, Lehmann et al., 1995 | Diagnostic test evaluation of cervicography and Pap 10% random verification of test negative patients | Conventional Pap (cytobrush and Ayre spatula) | France 1/91-12/92 | 1,539 women undergoing routine prenatal or gynecology exam Mean age: 36 | Blind interpretation Pap (normal, reactive/inflamm, atypia, HPV, SIL, ICC or adenoCa) GS: colposcopy/ histology | Prevalence (CIN1)=62/324=19% Se (ASCUS,CIN1)=35/62=56% Sp (ASCUS,CIN1)=238/262= 91% Prevalence (CIN2/3)=23/323=7% Se (ASCUS,CIN2/3)=15/23=65% Sp (ASCUS,CIN2/3)=256/300= 85% | Quality Score=10 Ref. Std.: 2 blind: 2 Verification: 1 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Baldauf, Dreyfus, Ritter et al., 1995 | Diagnostic test evaluation comparing Pap, colposcopy and directed biopsy against final diagnosis | Conventional Pap (exocervical smear with Ayre spatula and endocervical smear with Ayre spatula or cytobrush), colposcopy and directed biopsy | France 1/85-12/92 | 117 pregnant women referred for colposcopy (98 because of abnormal Pap) Median age: 28 13 had prior cervical treatment | No blind interpretation Pap (m=normal, atypical, LSIL, HSIL, ICC, glandular abnormal) GS: either histologic analysis of surgical specimen or regular cytologic and colposcopic follow-up > 1 yr post delivery and 3 followup visits | GS type: colposcopy/histology Prevalence (CIN1)=85/117=73% Se (ASCUS,CIN1)=84/85=99% Sp (ASCUS,CIN1)=7/32=22% Prevalence (CIN2/3)=45/117= 38% Se (ASCUS,CIN2/3)=45/45= 100% Sp (ASCUS,CIN2/3)=8/72=11% Se (LSIL,CIN2/3)=42/45=93% Sp (LSIL,CIN2/3)=13/72=18% GS type: histology Prevalence (CIN1)=85/117=73% Se (LSIL/CIN1)=79/85=73% Sp (LSIL/CIN1)=10/32=31% Prevalence (CIN2/3)=45/117= 38% Se (HSIL,CIN2/3)=24/45=55% Sp (HSIL,CIN2/3)=69/72=96% Limitations: referred population, all test negatives on repeat Pap may be due to sampling error, no other verification of Pap negative women | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry:1
Beeby, Keating, Wagstaff et al., 1993 | Prospective randomized trial of Pap test sampling devices vs. colposcopic biopsy All subjects verified | Repeat conventional Pap (Ayre spatula, Aylesbury, Multi-Spatula, or Cervex and Rocket endo-cervical brush) at time of colposcopy | England 3/89-7/91 | 1,000 consecutive women referred for colposcopy for abnormal smears or appearance of cervix | Blind interpretation. Pap (borderline, mild, moderate, severe dyskaryosis) GS: colposcope-directed punch biopsy or loop diathermy biopsy (CIN classification) thresholds CINI+, CIN2+ | Prevalence (CIN1)=635/1000= 64% Se (LSIL,CIN1)=417/635=66% Sp (LSIL,CIN1)=285/365=78% Prevalence (CIN2/3)=471/1000= 47% Se (LSIL,CIN2/3)=420/471=89% Sp (LSIL,CIN2/3)=225/529=43% | Quality Score=11 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Bigrigg, Codling, Pearson et al., 1990 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (gauze swab) vs. colposcopy | UK 20 months around 1986 (?) | 981 women with history of abnormal Pap All referrals meeting above description in which entire transformation zone was visible on colposcopy | No blind interpretation GS: colposcopy reported as negative, mild / moderate / severe dyskaryosis or worse | Prevalence (CIN1)=934/981= 95% Se (LSIL,CIN1)=900/934=96% Sp (LSIL,CIN1)=16/47=34% Prevalence (CIN2/3)=707/981= 72% Se (LSIL,CIN2/3)=691/707=98% Sp (LSIL,CIN2/3)=34/274=12% Se (HSIL,CIN2/3)=567/707=80% Sp (HSIL,CIN2/3)=157/274=57% | Quality Score=6 Ref. Std.: 1 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Bolick and Hellman, 1998 | Diagnostic test evaluation Selection of negative smears uncertain | Conventional Pap (broom-type sampling device or a combination endocervical brush and plastic spatula) vs. ThinPrep | Utah 1996-97 | 39,408 conventional Paps, and 10,694 ThinPrep specimens, collected concurrently in two patient populations, described only by age | No blind interpretation Pap and ThinPrep specimen with threshold of LSIL GS: histology with threshold of "positive" | Screening test: ThinPrep Prevalence (not specified)= 42/54=78% Se (LSIL,NS)=40/42=95% Sp (LSIL,NS)=7/12=58% Screening test: Pap Prevalence (NS)=67/89=75% Se (LSIL,NS)=57/67=85% Sp (LSIL,NS)=8/22=36% | Quality Score=4 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Cecchini, Bonardi, Mazzotta et al., 1993 | Diagnostic test evaluation of cervicography, cerviscopy and Pap All women with atypia on Pap, suspicious cervicography or positive cervicoscopy underwent colposcopy No verification of test negatives | Conventional Pap (cytobrush and Ayre spatula) | Italy 5/91-1/92 | 2,105 consecutive women attending Pap smear clinic | Uncertain of blind interpretation Pap (threshold CIN2) GS: negative colposcopy or histology from colposcope-directed biopsy (threshold CIN2) | Prevalence (CIN2/3)=8/486=2% Se (ASCUS,CIN2/3)=5/8=63% Sp (ASCUS,CIN2/3)=409/478= 86% Se (LSIL,CIN2/3)=5/8=63% Sp (LSIL,CIN2/3)=463/478=97% Limitations: Data not presented for lower thresholds; no verification of test negative women | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Chomet, 1987 | Retrospective diagnostic test evaluation Only normal Paps verified were by those patients self-requesting colposcopy | Conventional Pap (standard Ayre spatula and cervical cytobrush) vs. colposcopy | UK 1972 - ? | 197 patients undergoing colposcopy for independent reasons | No blind interpretation GS: colposcopy reported as Inflam / CIN1 / 2 / 3 only | Women previously treated: Prevalence (CIN1)=9/14=64% Se (LSIL,CIN1)=3/9=33% Sp (LSIL,CIN1)=4/5=80% Prevalence (CIN2/3)=3/14=21% Se (LSIL,CIN2/3)=2/3=67% Sp (LSIL,CIN2/3)=9/11=82% Se (HSIL,CIN2/3)=2/3=67% Sp (HSIL,CIN2/3)=11/11=100% Women not previously treated: Prevalence (CIN1)=94/130=72% Se (LSIL,CIN1)=63/94=67% Sp (LSIL,CIN1)=22/36=61% Prevalence (CIN2/3)=58/130= 45% Se (LSIL,CIN2/3)=44/58=76% Sp (LSIL,CIN2/3)=39/72=54% Se (HSIL,CIN2/3)=14/58=24% Sp (HSIL,CIN2/3)=67/72=93% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Coibion, Autier, Vandam et al., 1994 | Diagnostic test evaluation of Pap and cervicography for premalignant lesions Test positives and women with positive cervicogram verified with histology | Conventional Pap, exo- and endo-cervical (sampling procedure not described), vs. cervicography | Belgium 1989-90 | 4,095 consecutive women presenting for screening Mean age: 53 | Blind interpretation Pap test with threshold of CIN1 or worse GS: histology with test threshold CIN1, 2, 3 | Prevalence (CIN1)=123/163= 75% Se (LSIL,CIN1)=27/123=22% Sp (LSIL,CIN1)=34/40=85% Prevalence (CIN2/3)=24/163= 15% Se (LSIL,CIN2/3)=14/24=58% Sp (LSIL,CIN2/3)=120/139=86% | Quality Score=9 Ref. Std.: 2 blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Cox, Lorincz, Schiffman et al., 1995 | Diagnostic test evaluation of Pap and HPV test | Conventional Pap (cytobrush and wooden Ayre spatula) | Santa Barbara, CA 5/91-5/92 Student health service | 217 young women initially referred for abnormal Pap (from 5,598 total Pap smears performed during the period) Mean age: 21 | Blind interpretation Repeat Pap (TBS) GS: colposcope-directed biopsy or negative colposcopy (no visible lesion, negative, CIN1-3) threshold koilocytotic atypia (CIN1) | Prevalence (CIN1)=50/217=23% Se (LSIL,CIN1)=19/50=38% Sp (LSIL,CIN1)=160/167=96% Prevalence (CIN1)=50/217=23% Se (ASCUS,CIN1)=30/50=60% Sp (ASCUS,CIN1)=129/167= 77% Limitations: Referred population; no verification of test negatives | Quality Score=9 Ref. Std.: 2 blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Cox, Schiffman, Winzelberg et al., 1992 | Diagnostic test evaluation of Pap and HPV test | Conventional Pap (cytobrush and wooden Ayre spatula) | Santa Barbara, CA 9/89-6/90 Student health service | 482 young women referred for abnormal Pap (from population of ~5,000 screened) | Blind interpretation Pap (neg, ASCUS, SIL) GS: colposcopic biopsy or negatiave colposcopy (no visible lesion, negative, low- or high-grade CIN) | Prevalence (CIN1)=137/482= 28% Se (ASCUS,CIN1)=113/137= 82% Sp (ASCUS,CIN1)=234/345= 68% Se (LSIL,CIN1)=60/137=44% Sp (LSIL,CIN1)=318/345=92% Limitations: Referred population; no verification of test negatives | Quality Score=9 Ref. Std.: 2 blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry:1
Davis, Hindman, Paplanus et al., 1981 | Diagnostic test evaluation of duplicate cervical smears for premalignant lesions All subjects verified with histology | Conventional Pap (Ayre spatula and endocervical aspirate or swab) | Arizona 1979 | 87 patients with history of prior abnormal Pap presenting to dysplasia clinic Population not characterized | No blind interpretation Pap test thresholds mild, moderate, severe dysplasia, CIS, cancer. GS: histology with thresholds of mild, moderate, severe dysplasia, CIS, and cancer. | Prevalence (CIN1)=82/87=94% Se (LSIL,CIN1)=57/82=70% Sp (LSIL,CIN1)=5/5=100% Prevalence (CIN2/3)=71/87=82% Se (HSIL,CIN2/3)=40/71=56% Sp (HSIL,CIN2/3)=13/16=81% Se (LSIL,CIN2/3)=51/71=72% Sp (LSIL,CIN2/3)=10/16=63% | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Davison and Marty, 1994 | Diagnostic test evaluation of screening Pap and colposcopy | Conventional Pap (cotton-tipped applicator and wooden Ayre spatula) | Rural mid-south US | 200 consecutive pre-menopausal women undergoing screening None had abnormal smear in previous two Pap tests | Blind interpretation Pap threshold mild dysplasia GS: normal, nonkoilocytic atypia, CIN1-3) | Prevalence (CIN1)=30/196=15% Se (LSIL,CIN1)=16/30=53% Sp (LSIL,CIN1)=166/166=100% Limitations: small size | Quality Score=11 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Del Priore, Maag, Bhattacharya et al., 1995 | Diagnostic test evaluation | Conventional Pap at colposcopy (wooden spatula, cervical brush) | Evanston, IL and Rochester, NY 7/91-11/93 | 52 HIV+ women 27 were referred for colposcopy because of abnormal Pap Control group: 57 HIV- women referred for colposcopy | No blind interpretation Conventional Pap smear (No SIL, LSIL, HSIL); threshold LSIL. GS: colposcope- directed punch biopsy (no dysplasia, HPV, CIN1, 2, 3) | Prevalence (CIN1)=20/52=38% Se (LSIL,CIN1)=16/20=80% Sp (LSIL,CIN1)=24/32=75% Prevalence (CIN2/3)=6/52=12% Se (LSIL,CIN2/3)=5/6=83% Sp (LSIL,CIN2/3)=27/46=59% Limitations: HIV(-) women included no test negatives | Quality Score=9 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
DiBonito, Falconieri, Tomasic et al., 1993 | Diagnostic test evaluation All subjects verified with histology | Conventional Pap (Ayre spatula and cytobrush) | Italy 1987-90 | 1,000 consecutive smears from women aged 14-80, (mean age: 34.6) undergoing colposcopy; of these, 918 had adequate cytologic and histologic samples | Blind interpretation Pap thresholds of atypical, CIN1, 2, 3, SCC GS: histology, with test threshold CIN1, 2, 3, SCC | Prevalence (CIN1)=249/918= 27% Se (ASCUS,CIN1)=190/249= 76% Sp (ASCUS,CIN1)=622/669= 93% Se (LSIL,CIN1)=152/249=61% Sp (LSIL,CIN1)=640/669=96% Prevalence (CIN2/3)=92/918= 10% Se (ASCUS,CIN2/3)=88/92=96% Sp (ASCUS,CIN2/3)=677/826= 82% Se (LSIL,CIN2/3)=88/92=96% Sp (LSIL,CIN2/3)=733/826=89% | Quality Score=11 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Fahim, Faris, Arab et al., 1991 | Diagnostic test evaluation comparing Pap with colposcopy-directed biopsy. Selection of negative smears uncertain | Conventional Pap (endo- and ecto-cervix sampling procedure not described) | Egypt 1981-89 | 757 women who had both cytology and directed biopsies from a population of 15,018 women screened, 1704 of whom underwent colposcopy | No blind interpretation Pap (normal, condyloma, CIN, Ca [CIN, adenoCa, ICC]) threshold condyloma. GS: cervix biopsy threshold condyloma. | Prevalence (CIN1)=323/757= 43% Se (LSIL,CIN1)=275/323=85% Sp (LSIL,CIN1)=269/434=62% Limitations: no verification of test negatives | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Ferenczy, Robitaille, Franco et al., 1996 | Diagnostic test evaluation All subjects verified | Conventional Pap (Accellon Combi cervical biosampler) vs. ThinPrep | Quebec, Canada and New York, NY | 365 patients referred for colposcopy for whom histology was available Population not characterized | Blind interpretation Cytology threshold ASCUS Histology, test thresholds were: LSIL or worse, and HSIL or worse | Screening test: ThinPrepPrevalence (CIN1)=186/364= 51% Se (ASCUS,CIN1)=145/186= 78% Sp (ASCUS,CIN1)=131/178= 74% Prevalence (CIN2/3)=81/364= 22% Se (ASCUS,CIN2/3)=71/81=88% Sp (ASCUS,CIN2/3)=162/283= 57% Screening test: Pap Prevalence (CIN1)=186/364= 51% Se (ASCUS,CIN1)=130/186= 70% Sp (ASCUS,CIN1)=133/178= 75% Prevalence (CIN2/3)=81/364= 22% Se (ASCUS,CIN2/3)=67/81=83% Sp (ASCUS,CIN2/3)=175/283= 62% | Quality Score=8 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 0 Spectrum: 0 Publication: Industry: 1
Ferris, Wright, Litaker et al., 1998 | Diagnostic test study of Pap test and HPV DNA test for detecting CIN2-3 All subjects verified | Conventional Pap (repeat smears collected with Ayre spatula and cytobrush or Accellon sampler) HPV DNA test (Hybrid Capture tube-based assay) | US (6 sites in GA, MA, KS, NY) | 279 women with either ASCUS (n=169) or LSIL (n= 110) in previous 4 months referred for colposcopy Average age 27.3 years | Blind interpretation Pap (TBS) GS: negative colposcopy or biopsy (CIN classification) thresholds CIN1, CIN2/3. | Prevalence (CIN1)=100/279= 36% Se (ASCUS,CIN1)=92/100=92% Sp (ASCUS,CIN1)=92/179=51% Se (LSIL,CIN1)=37/100=37% Sp (LSIL,CIN1)=153/179=85% Prevalence (CIN2/3)=23/279=8% Se (ASCUS,CIN2/3)=19/23=83% Sp (ASCUS,CIN2/3)=96/256= 38% Se (LSIL,CIN2/3)=5/23=22% Sp (LSIL,CIN2/3)=198/256=77% Limitations: Referred population with limited spectrum. All test negatives had prior positive smear. | Quality Score=11 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Frisch, Milner, and Ferris, 1994 | Diagnostic test evaluation Subjects verified if either abnormal Pap or naked eye inspection of cervix abnormal | Conventional Pap (cytobrush and spatula) along with naked eye inspection of cervix vs. histology | California and Georgia 1994 | 95 college students at student health center presenting for screening Pap, some with history of atypical smear 63% oral contraceptive users 33% with history of atypical smear | No blind interpretation Pap thresholds of atypia, CIN GS: histology with thresholds of HPV, CIN or both | Prevalence (CIN1)=40/51=78% Se (LSIL,CIN1)=14/40=35% Sp (LSIL,CIN1)=8/11=73% | Quality Score=5 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Fung, Senterman, Eid et al., 1997 | Diagnostic test evaluation All subjects verified with histology | Conventional Pap smear, (Ayre spatula and cytobrush) vs. FTIR spectroscopy | Canada 2/95-10/95 | 301 patients attending colposcopy clinic who were not pregnant and had no history of surgical treatment for dysplasia | No blind interpretation Pap with threshold of positive GS: biopsy with thresholds of LSIL, HGL | Prevalence (CIN1)=217/301= 72% Se (LSIL,CIN1)=188/217=87% Sp (LSIL,CIN1)=76/84=90% Prevalence (CIN2/3)=110/301= 37% Se (LSIL,CIN2/3)=96/110=87% Sp (LSIL,CIN2/3)=91/191=48% | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 0 Spectrum: 1 Publication: 1 Industry:1
Garutti, Immovill, Chiari et al., 1994 | Diagnostic test evaluation of Pap, cervicography and colposcopy for HPV detection All subjects verified with colposcopy plus histology | Conventional Pap (ectocervical smear with Ayre spatula and endocervical smear with endocervical loop) vs. cervicography and colposcopy/ histology | Italy 1/90-9/90 | 200 non-pregnant women referred to clinic for Pap. Mean age=41 | Blind interpretation Pap thresholds of HPV GS: histology with thresholds of HPV | Prevalence (CIN1)=72/200=36% Se (LSIL,CIN1)=30/72=42% Sp (LSIL,CIN1)=110/128=86% | Quality Score=8 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 0 Spectrum: 0 Publication: 1 Industry: 1
Germain, Heaton, Erickson et al., 1994 | Diagnostic test evaluation All subjects verified with histology | Conventional Pap (using one of three collection devices) vs. colposcopy and histology | Maryland Time period not described | 616 women referred for colposcopy for: ASCUS (240) LSIL (230) HSIL (116) Other (30) Prior surgical treatment in 161 | Pap reported as negative or CIN+ GS: histology reported as negative, CIN1, CIN2, CIN3 | Prevalence (CIN1)=120/430= 28% Se (LSIL,CIN1)=80/120=67% Sp (LSIL,CIN1)=245/310=79% | Quality Score=8.5 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: .5 Industry: 1
Giles, Hudson, Crow et al., 1988 | Diagnostic test evaluation Colposcopy given regardless of Pap status but results not given | Conventional Pap (spatula) vs. histology | London c. 1984 | 200 predominantly middle class, all over 21, some referrals for abnormal Paps but others not Offered to all patients in GP practice | Blind interpretation GS: histology reported as severe / moderate / mild / negative dyskaryosis | Prevalence (CIN1)=32/200=16% Se (LSIL,CIN1)=17/32=53% Sp (LSIL,CIN1)=143/168=85% | Quality Score=10 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Giles, Deery, Crow et al., 1989 | Diagnostic test evaluation All subjects verified with colposcopy +/- histology | Conventional Pap smear (Ayre spatula +/- cytobrush) | England 1989 | 215 consecutive women with mild cytologic abnormalities, 143 of whom had only 1 abnormal previous smear | No blind interpretation Pap with thresholds of mild dyskaryosis GS: colposcopy/ histology with thresholds of CIN1, 2, 3 | Prevalence (CIN1)=75/112=67% Se (LSIL,CIN1)=61/75=81% Sp (LSIL,CIN1)=37/37=100% Prevalence (CIN2/3)=41/112= 37% Se (LSIL,CIN2/3)=38/41=93% Sp (LSIL,CIN2/3)=48/71=68% | Quality Score=8 Ref. Std.: 1 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Glenthoj, Rank, Peen et al., 1988 | Diagnostic test evaluation All subjects verified | Conventional Pap (either 2 cotton swabs or cervical brush) | ?Sweden | 100 consecutive women referred to gynecology clinic for cone biopsy, with history of biopsy proven dysplasia Mean age of 32, range 20-69 | Blind interpretation GS: cytology threshold, CINI or worse; histology, test thresholds were CIN1 or worse | Prevalence (CIN1)=87/93=94% Se (LSIL,CIN1)=71/87=82% Sp (LSIL,CIN1)=6/6=100% Prevalence (CIN2/3)=85/93=91% Se (LSIL,CIN2/3)=70/85=82% Sp (LSIL,CIN2/3)=7/8=88% Se (HSIL,CIN2/3)=85/93=91% Sp (HSIL,CIN2/3)=7/8=88% | Quality Score=11 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication:1 Industry: 1
Gonzalez, Hernandez, Anderson et al., 1996 | Diagnostic test evaluation of Pap test | Conventional Pap (wooden Ayre spatula and endocervical brush) | Philadelphia, PA 8/92-2/94 | 118 consecutive women with ASCUS or LSIL referred for colposcopy | No blind interpretation Pap (TBS) GS: negative colposcopy or biopsy (negative, HPV, CIN1, CIN2 or 3) | Prevalence (CIN1)=21/62=34% Se (ASCUS,CIN1)=17/21=81% Sp (ASCUS,CIN1)=24/41=59% Se (LSIL,CIN1)=8/21=38% Sp (LSIL,CIN1)=36/41=88% Prevalence (CIN2/3)=1/62=2% Se (ASCUS,CIN2/3)=1/1=100% Sp (ASCUS,CIN2/3)=49/61=80% Se (LSIL,CIN2/3)=1/1=100% Sp (LSIL/CIN2/3)=49/61=80% Limitations: Referred population; no verification of test negatives. | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Gundersen, Schauberger, and Rowe, 1988 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (sampling procedure not described) vs. colposcopy | Wisconsin 1/86-3/86 | 56 women with no history of abnormal pathology Pap or cervigram positive patients in clinic received colposcopy | No blind interpretation GS: colposcopy reported as CIN3 / 2 / 1 / metaplasia / normal | Prevalence (CIN1)=26/56=46% Se (LSIL,CIN1)=4/26=15% Sp (LSIL,CIN1)=27/30=90% Prevalence (CIN2/3)=5/56=9% Se (LSIL,CIN2/3)=3/5=60% Sp (LSIL,CIN2/3)=47/51=92% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Haddad, Hussein, Livingstone et al., 1988 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (sampling procedure not described) vs. colposcopy | Scotland 1982-85 Colposcopy clinic | 118 women with positive / suspicious Pap or visible wart Unspecified recruitment among all referred females | Uncertain of blind interpretation GS: colposcopy reported as CIN3 / 2 / 1/ koilocytosis / koil and CIN / normal | Prevalence (CIN1)=105/121= 87% Se (LSIL,CIN1)=91/105=87% Sp (LSIL,CIN1)=7/16=44% Prevalence (CIN2/3)=74/121= 61% Se (LSIL,CIN2/3)=69/74=93% Sp (LSIL,CIN2/3)=16/47=34% Se (HSIL,CIN2/3)=4/74=5% Sp (HSIL,CIN2/3)=47/47=100% | Quality Score=5 Ref. Std.: 1 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 0 Publication: 1 Industry: 1
Hellberg, Axelsson, Gad et al., 1987 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (sampling procedure not described) vs. colposcopy | Sweden 6/77-12/81 Outpatient maternity clinic | 132 pregnant women w/ history > CIN2 Pap Population not characterized | Uncertain of blind interpretation GS: colposcopy reported as CIN3 / 2 / 1 / Normal | Prevalence (CIN1)=45/51=88% Se (LSIL,CIN1)=40/45=89% Sp (LSIL,CIN1)=4/6=67% Prevalence (CIN2/3)=41/51=80% Se (LSIL,CIN2/3)=37/41=90% Sp (LSIL, CIN2/3)=5/10=50% Se (HSIL,CIN2/3)=31/41=76% Sp (HSIL,CIN2/3)=8/10=80% | Quality Score=5 Ref. Std.: 1 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry:1
Helmerhorst, Dijkhuizen, Calame et al., 1987 | Diagnostic test evaluation No verification of test negatives | Conventional Pap vs. histology (method varied) | The Netherlands 3/84-12/84 | 132 females with history of abnormal Pap Unspecified recruitment | Uncertain of blind interpretation GS: histology reported as ICC / CIN3 / CIN1-2 / normal | Prevalence (CIN2/3)=102/132= 77% Se (HSIL,CIN2/3)=41/102=40% Sp (HSIL,CIN2/3)=29/30=97% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Herrington, Evans, Hallam et al., 1995 | Diagnostic test evaluation of Pap and HPV test | Conventional Pap (Aylesbury spatula) | UK | 167 women referred for colposcopy for borderline (99), wart virus detected (39),or mild dyskaryosis (29) smears | No blind interpretation Pap (normal, borderline, wart virus infection/mild dyskaryosis, moderate/severe dyskaryosis) GS: negative colposcopy or biopsy (negative, wart virus infection or CIN1, CIN2 or 3) | GS type: colposcopy/histology Prevalence (CIN1)=128/165= 78% Se (ASCUS,CIN1)=103/128= 80% Sp (ASCUS,CIN1)=22/37=59% Se (LSIL,CIN1)=88/128=69% Sp (LSIL,CIN1)=26/37=70% Prevalence (CIN2/3)=40/165= 24% Se (ASCUS,CIN2/3)=35/40=88% Sp (ASCUS,CIN2/3)=42/125= 34% Se (LSIL,CIN2/3)=35/40=88% Sp (LSIL,CIN2/3)=61/125=49% Se (HSIL,CIN2/3)=19/40=48% Sp (HSIL,CIN2/3)=125/125= 100% GS type: histology Prevalence (CIN1)=128/141= 91% Se (ASCUS,CIN1)=103/128= 80% Sp (ASCUS,CIN1)=7/13=54% Se (LSIL,CIN1)=88/128=69% Sp (LSIL,CIN1)=8/13=62% Prevalence (CIN2/3)=40/141= 28% Se (ASCUS,CIN2/3)=35/40=88% Sp (ASCUS,CIN2/3)=27/101= 27% Se (LSIL,CIN2/3)=35/40=88% Sp (LSIL,CIN2/3)=43/101=43% Se (HSIL,CIN2/3)=19/40=48% Sp (HSIL,CIN2/3)=101/101= 100% Limitations: Referred population; no verification of test negatives; cytology based upon repeat Pap. | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Hirschowitz, Raffle, Mackenzie et al., 1992 | Retrospective diagnostic test evaluation Patients with and without abnormal Pap smears followed, and had eventual diagnosis by various methods (histology used) | Conventional Pap | England 1981 | 874 women with history of borderline cytology changes with normal control All referrals meeting above description | No blind interpretation GS: histology reported as ICC / CIN3 / 2 / 1 / normal | Prevalence (CIN2/3)=87/111= 78% Se (HSIL,CIN2/3)=76/87=87% Sp (HSIL,CIN2/3)=12/24=50% | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Hockstad, 1992 | Diagnostic test evaluation All subjects verified with histology or colposcopy | Conventional Pap (cervical os aspirator and a circumferential cervical scraping with a wooden spatula) | Michigan 1988-89 | 73 consecutive women, aged 15-39, presenting, without previous abnormal Pap, pelvic symptoms, or hysterectomy All patients received Pap smear, HPV test, and colposcopy and biopsy of visible lesions. If patients had negative colposcopy but Pap or HPC was positive, they had second colposcopy with biopsy | No blind interpretation Pap considered positive if atypical, CIN, or condylomatous changes GS: negative colposcopy /histology with threshold of mild dysplasia | Prevalence (CIN1)=7/70=10% Se (ASCUS,CIN1)=2/7=29% Sp (ASCUS,CIN1)=61/63=97% | Quality Score=8 Ref. Std.: 1 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Johansen, Arffmann, and Pallesen, 1979 | Diagnostic test evaluation of Pap, endocervical swab and exocervical scrapings Selection of negative smears uncertain | Conventional Pap (cotton-tipped applicator and wooden Ayre spatula) | Denmark c. 1977 | 312 consecutive women referred or followed for abnormal Pap. 168 had a cervix biopsy within 3 months of interpretable cytology Mean age: 33 | Uncertain of blind interpretation GS: histology (no malignancy, mild, moderate or severe dysplasia, CIS, ICC) | Prevalence (CIN1)=122/182= 67% Se (ASCUS,CIN1)=111/122= 91% Sp (ASCUS,CIN1)=43/60=72% Se (LSIL,CIN1)=110/122=90% Sp (LSIL,CIN1)=43/60=72% Limitations: Referred population; no verification of test negatives | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Jones, Jenkins, Cuzick et al., 1992 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (brush and Aylesbury spatula) vs. colposcopy | UK 40-month study period around 1990 | 143 women with single smear history of mild dyskaryosis only Consecutive referrals meeting population description during study time period | No blind interpretation GS: colposcopy reported in CIN2 + 3 / 1 + 2, Borderline, Normal only | Prevalence (CIN1)=82/143=57% Se (LSIL,CIN1)=30/82=37% Sp (LSIL,CIN1)=53/61=87% Prevalence (CIN2/3)=25/143= 17% Se (HSIL,CIN2/3)=7/25=28%VSp (HSIL,CIN2/3)=118/118= 100% | QualityScore=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Jones, Creasman, Dombroski et al., 1987 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (wooden spatula and a saline moistened cotton swab) vs. histology | North Carolina c. 1986 | 236 referred patients with history of abnormal Pap (class II) Consecutively based on referral | Uncertain of blind interpretation GS: histology reported as CIN3/2/1/ Benign | Prevalence (CIN1)=58/236=25% Se (LSIL,CIN1)=10/58=17% Sp (LSIL,CIN1)=174/178=98% Prevalence (CIN2/3)=10/236=4% Se (LSIL,CIN2/3)=5/10=50% Sp (LSIL,CIN2/3)=217/226=96% Se (HSIL,CIN2/3)=3/10=30% Sp (HSIL,CIN2/3)=224/226=99% | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Jones and Novis, 1996 | Diagnostic test evaluation of Pap test Selection of negative smears uncertain | Conventional Pap (specimen collection not described) | 348 labs in the US, Canada, Australia, Belgium, UK, New Zealand, Hong Kong, Saudi Arabia (94.3% of participants were in the US) 10/94-3/95 | 22,439 paired Pap-cervical biopsy specimens from 348 laboratories | No blind interpretation Pap (TBS) threshold LSIL GS: cervical biopsy (WNL, Benign cellular changes, LSIL, HSIL, SCC) Re-examination of discrepant pairs. | Prevalence (CIN1)=16392/22412=73% Se(ASCUS/CIN1)=14948/16392= 91% Sp (ASCUS,CIN1)=2814/6020 =47% Se (LSIL,CIN1)=12210/16392 =74% Sp LSIL,CIN1)=4494/6020= 75% Limitations: No verification of test negatives; no description of collection procedures; no blind interpretation. | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Kaufman, Adam, Icenogle et al., 1997 | Diagnostic test evaluation of Pap and HPV test Only women with either persistent abnormal smear or any HSIL smear verified | Conventional Pap (specimen collection not described) | Texas | 462 women with ASCUS or LSIL referred for colposcopy who underwent colposcopy-directed biopsy and repeat Pap | No blind interpretation Repeat Pap (TBS) threshold ASCUS or HSIL GS: colposcope-directed biopsy or negative colposcopy (no visible lesion, negative, CIN1-3) threshold CIN2 | Prevalence (CIN1)=325/462= 70% Se (ASCUS,CIN1)=158/325= 49% Sp (ASCUS,CIN1)=101/137= 74% Prevalence (CIN2/3)=67/462= 15% Se (ASCUS,CIN2/3)=42/67=63% Sp (ASCUS,CIN2/3)=243/395= 62% Se (HSIL,CIN2/3)=17/67=25% Sp (HSIL,CIN2/3)=378/395=96% Limitations: Referred population; no verification of test negatives | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Kealy, 1986 | Diagnostic test evaluation comparing Pap and cervical biopsy. All biopsy and hysterectomy cases with Pap in preceding 3 mo. | Conventional Pap (specimen collection not described) | Ireland 1980-84 | 300 women with Paps within 3 months of cervical biopsy or hysterectomy (n=1,259) Mean age= 43.8 | No blind interpretation Pap smear threshold mild dysplasia GS: CIN1 (hysterectomy 149, non-colpo bx 84, colpo/cone bx 84). | Prevalence (CIN1)=93/300=31% Se (LSIL,CIN1)=80/93=86% Sp (LSIL,CIN1)=182/207=88% Prevalence (CIN2/3)=74/300= 25% Se (LSIL,CIN2/3)=70/74=95% Sp (LSIL,CIN2/3)=191/226=85% Se (HSIL,CIN2/3)=63/74=85% Sp (HSIL,CIN2/3)=216/226=96% | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Koonings, Dickinson, d'Ablaing et al., 1992 | Diagnostic test evaluation No verification of test negatives | Pap (cotton swab) vs. histology | Los Angeles 9/88-9/89 | 143 referrals for history of abnormal Pap Randomized sample of nonpregnant referrals | No blind interpretation GS: histology reported as Ca / CIN3 / 2 / 1 / No CIN only | Collection device: CytobrushPrevalence (CIN1)=78/147=53% Se (LSIL,CIN1)=62/78=79% Sp (LSIL,CIN1)=49/69=71% Prevalence (CIN2/3)=58/147= 39% Se (LSIL,CIN2/3)=49/58=84% Sp (LSIL,CIN2/3)=56/89=63% Se (HSIL,CIN2/3)=39/58=67% Sp (HSIL,CIN2/3)=78/89=88% Collection device: Cotton swabs Prevalence (CIN1)=88/143=62% Se (LSIL,CIN1)=61/88=69% Sp (LSIL,CIN1)=35/55=64% Prevalence (CIN2/3)=62/143= 43% Se (LSIL,CIN2/3)=48/62=77% Sp (LSIL, CIN2/3)=48/81=59% Se (HSIL,CIN2/3)=34/62=55% Sp (HSIL,CIN2/3)=70/81=86% | Quality Score=6.5 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: .5
Korach, Menczer, and Lusky, 1995 | Diagnostic test evaluation of Pap test Selection of negative smears uncertain | Conventional Pap (specimen collection not described) | Israel 1984-89 | 95 women referred for abnormal Pap, with repeat Pap within 3 months without treatment, 51 also had cervical biopsy | No blind interpretation Pap (normal, atypia, CIN1, CIN2, CIN3, carcinoma) threshold CIN1 GS: normal colposcopy or cervical biopsy (CIN) threshold not stated. | GS type: colposcopy/histology Prevalence (GS threshold not specified)=34/95 =36% Se (NS,NS)=31/34= 91% Sp (NS,NS)=41/61= 67% GS type: histology Prevalence (NS)=34/50=68% Se (NS,NS)=31/34= 91% Sp (NS,NS)=10/16= 63% Limitations: No verification of test negatives; no description of collection procedures; no blind interpretation. | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Korn, Autry, DeRemer et al., 1994 | Diagnostic test evaluation All subjects verified with histology reference standard | Conventional Pap (cervical brush and Ayre spatula) vs. screening colposcopy and biopsy | California | 52 HIV+ women and 85 women referred for colposcopy for abnormal Pap and known HIV- | GS: Pap and histology reported as normal, atypia/cervicitis LSIL, HSIL (TBS) | HIV+ women: Prevalence (CIN1)=35/73=48% Se (LSIL,CIN1)=22/35=63% Sp (LSIL,CIN1)=32/38=84% Prevalence (CIN2/3)=9/73=12% Se (LSIL,CIN2/3)=7/9=78% Sp (LSIL,CIN2/3)=43/64=67% Se (HSIL,CIN2/3)=4/9=44% Sp (HSIL,CIN2/3)=64/64=100% HIV- women: Prevalence (CIN1)=66/85=78% Se (LSIL,CIN1)=42/66=64% Sp (LSIL,CIN1)=14/19=74% Prevalence (CIN2/3)=27/85=32% Se (LSIL,CIN2/3)=19/27=70% Sp (LSIL,CIN2/3)=6/58=10% Se (HSIL,CIN2/3)=10/27=37% Sp (HSIL,CIN2/3)=55/58=95% | Quality Score=9 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Kwikkel, Quaak, and de With, 1986 | Diagnostic test evaluation comparing most recent Pap (up to 2 months) and histology (biopsy cone biopsy, hysterectomy) in patients with abnormal Pap Selection of negative smears uncertain | Conventional Pap (wooden Ayre spatula/cotton q-tip) | The Netherlands 1/1/65-6/1/83 | Patients with abnormal Pap except clinically obvious cancer Selection criteria unclear: all abnormals, including ?atypias, biopsied; not all with normal repeat biopsied | No blind interpretation GS: histology (cone biopsy or colposcope-directed biopsy) | Prevalence (CIN1)=147/184= 80% Se (LSIL,CIN1)=144/147=98% Sp (LSIL,CIN1)=3/37=8% Prevalence (CIN2/3)=100/184= 54% Se (LSIL,CIN2/3)=99/100=99% Sp (LSIL,CIN2/3)=5/84=6% Prevalence (CIN2/3)=100/184= 54% Se (HSIL,CIN2/3)=79/100=79% Sp (HSIL,CIN2/3)=58/84=69% Study results:; 1 Test characteristics as above Sensitivity related to prevalence; Study limitations: Few negative tests Pathologists not blind to cytology Variation in selection criteria | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Lederer and Lambourne, 1973 | Diagnostic test evaluation | Preoperative conventional Pap smear (specimen collection not described) vs. hysterectomy pathology | UK 1966-70 | 3,141 women with Paps 6 months before hysterectomy | Blind interpretation GS: histology (HSIL and invasive carcinoma) | Prevalence (CIN2/3)=366/3073= 12% Se (HSIL,CIN2/3)=267/366=73% Sp (HSIL,CIN2/3)=2670/2707= 99% | Quality Score=11 Ref. Std.: 2 blind: 2 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Lozowski, Mishriki, Talebian et al., 1982 | Diagnostic test evaluation of Pap and colposcopy for preclinical lesions Test negative patient selection not specified (not all had repeat Pap at time of colposcopy) | Conventional Pap (wooden Ayre spatula, cotton q-tip) | New York 7/78-10/79 | 157 consecutive colposcopy clinic patients; selection of test negative results uncertain Patients with abnormal Pap or other indication for colposcopy | Uncertain of blind interpretation GS: histology | Prevalence (CIN1)=115/155= 74% Se (LSIL,CIN1)=107/115=93% Sp (LSIL,CIN1)=20/40=50% Prevalence (CIN2/3)=86/155= 77% Se (LSIL,CIN2/3)=83/86=97% Sp (LSIL,CIN2/3)=25/69=36% Prevalence (CIN2/3)=86/155= 55% Se (HSIL,CIN2/3)=66/86=55% Sp (HSIL,CIN2/3)=44/69=64% Study limitations:; 1 Uncertain blinding of reference standard; 2 Uncertain timing between cytology, histology; 3 Uncertain selection criteria for test negatives; 4 High-prevalence population> | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
MacCormac, Lew, King et al., 1988 | Diagnostic test evaluation | Conventional Pap (specimen collection not described) smear vs. biopsy Question about timing majority of histology cases within 5 years of pap. | South Australia 1959-82 | 315,654 patients screened | Blind interpretation GS: histology | Prevalence (CIN1)=2237/6680= 33% Se (ASCUS,CIN1)=2016/2237= 90% Sp (ASCUS,CIN1)=4071/4443= 92% Se (LSIL,CIN1)=1893/2237=85% Sp (LSIL,CIN1)=4204/4443=95% | Quality Score=7 Ref. Std.: 2 blind: 2 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Maggi, Zannoni, Giorda et al., 1989 | Diagnostic test evaluation All patients received colposcopy biopsy despite Pap status | Conventional Pap (ectocervical smear with wooden spatula and endocervical smear with a cotton swab) vs. colposcopy | Italy 1/86-12/87 | 161 women with history of abnormal Pap (mild dysplasia) Unspecified recruitment among new referrals | Uncertain of blind interpretation GS: colposcopy reported as CIN3 / 2 / 1 / Negative only | Prevalence (CIN1)=52/142=37% Se (LSIL,CIN1)=40/52=77% Sp (LSIL,CIN1)=47/90=52% Prevalence (CIN2/3)=29/142= 20% Se (LSIL,CIN2/3)=24/29=83% Sp (LSIL,CIN2/3)=54/113=48%VSe (HSIL,CIN2/3)=12/29=41% Sp (HSIL,CIN2/3)=111/113=98% | Quality Score=8 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Mann, Lonky, Scotti et al., 1993 | Diagnostic test evaluation | Conventional Pap (specimen collection not described) vs. colposcopy/ biopsy | 10 locations across the US 1989-92 | 243 women with positive Pap smears Mean age: 28.7 (range, 14-60) | No blind interpretation Paps ASCUS or worse GS: histology= HPV, CIN, CIS, invasive carcinoma | Prevalence (CIN1)=29/243=12% Se (ASCUS,CIN1)=9/29=31% Sp (ASCUS,CIN1)=213/214= 100% | Quality Score=5 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Mayeaux, Harper, Abreo et al., 1995 | Diagnostic test evaluation | Conventional Pap (Unimar Cervex brush) vs. colposcopy/ biopsy | Louisiana 1989-93 | 428 consecutive series of patients presenting to colposcopy clinic after a positive Pap smear Most were less than 30 years of age (range, 15-73) | Uncertain of blind interpretation GS: histology | Prevalence (CIN1)=329/428= 77% Se (ASCUS,CIN1)=149/329= 45% Sp (ASCUS,CIN1)=79/99=80% Se (LSIL,CIN1)=144/329=44% Sp (LSIL,CIN1)=80/99=81% Prevalence (CIN2/3)=110/428= 26% Se (LSIL,CIN2/3)=65/110=59% Sp (LSIL,CIN2/3)=220/318=69% Se (HSIL,CIN2/3)=27/110=25% Sp (HSIL,CIN2/3)=300/318=94% | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Melnikow, Nuovo, Paliescheskey et al., 1997 | Diagnostic test evaluation Conventional Pap compared with colposcopy and biopsy | Conventional Pap (specimen collection not described) , colposcopy, and directed biopsies | California 1988-93 | 771 women in family planning clinics with Paps and cervical biopsies 93% of women <30 years | Blind interpretation Pap (LSIL, HSIL) GS: histology (normal, LSIL, HSIL, carcinoma) | Prevalence (CIN1)=658/771= 85% Se (LSIL,CIN1)=583/658=89% Sp (LSIL,CIN1)=13/113=12% Prevalence (CIN1)=5905/6018= 98% Se (LSIL,CIN1)=5830/5905=99% Sp (LSIL,CIN1)=13/113=12% Limitations: did not evaluate negative Pap smears | Quality Score=9 Ref. Std.: 2 blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Morrison, Goldberg, Hagan et al., 1992 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (specimen collection not described) vs. colposcopy | Bronx, NY c. 1990 | 15 inner city women with history of abnormal Pap All new patients in clinic meeting above description | Uncertain of blind interpretation GS: colposcopy reported as CIN3 / 2 / 1 / koilocytosis / cervicitis / squamous metaplasia only | Prevalence (CIN1)=12/15=80% Se (LSIL,CIN1)=10/12=83% Sp (LSIL,CIN1)=3/3=100% Prevalence (CIN2/3)=8/15=53% Se (LSIL,CIN2/3)=8/8=100% Sp (LSIL,CIN2/3)=5/7=71% Se (HSIL,CIN2/3)=5/8=63% Sp (HSIL,CIN2/3)=5/7=71% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Morrison, Erickson, Doshi et al., 1988 | Diagnostic test evaluation | Conventional Pap (specimen collection not described) vs. colposcopy/ biopsy | Pittsburgh 1979-87 | 139 women attending colposcopy clinic (?consecutive) Ages: 15-88 Mean age=28 Colposcopy within 6 weeks of Pap | No blind interpretation GS: histology CIN1-2 | Prevalence (CIN1)=21/115=18% Se (ASCUS,CIN1)=17/21=81% Sp (ASCUS,CIN1)=16/94=17% | Quality Score=8 Ref. Std.: 1 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Naslund, Auer, Pettersson, et al., 1986 | Diagnostic test evaluation comparing Pap and pulse wash technique in women referred for abnormal Pap All test negatives at repeat Pap verified | Conventional Pap (Ayre spatula, q-tip) | Sweden 9/82-11/84 | 36 women with Pap prior to pulse wash (other sequence for calculation because of possible effects of washing on collection) Selection of subjects uncertain-consecutive series? Referrals for Pap or other abnormality, some normals | Uncertain of blind interpretation GS: histology | Prevalence (CIN1)=23/36=64% Se (LSIL,CIN1)=23/23=100% Sp (LSIL,CIN1)=10/13=77% Prevalence (CIN2/3)=21/36=58% Se (LSIL,CIN2/3)=21/21=100% Sp (LSIL,CIN2/3)=10/15=67% Se (HSIL,CIN/2/3)=19/21=90% Sp (HSIL,CIN2/3)=11/15=73% Study limitations:; 1 Small sample size; 2 High prevalence of disease; 3 Uncertain blinding of reference standard | Quality Score=9 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Nyirjesy, 1972 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (specimen collection not described) vs. histology | Washington, DC 7/67-4/70 | 136 patients with suspicious or atypical smears only Unspecified recruitment | No blind interpretation GS: histology reported as Invasive / In Situ / AdenoCa / Dysplasia / Cervicitis | Prevalence (CIN1)=110/136= 81% Se (LSIL,CIN1)=66/110=60% Sp (LSIL,CIN1)=13/26=50% | Quality Score= Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Okagaki and Zelterman, 1991 | Review of cytology/ histology pairs Test negative subjects those with abnormality other than SIL or greater; reasons for biopsy not stated | Conventional Pap (Ayre spatula/ Cytobrush) | Minnesota 1984-87 | 3,545 Consecutive series of biopsies Abnormal Paps obtained through routine screening | Uncertain of blind interpretation GS: histology | Prevalence (CIN2/3)=611/3545= 17% Se (HSIL,CIN2/3)=340/611= 56% Sp HSIL,CIN2/3)=2568/2934= 88% Study limitations:; 1 Uncertain timing between cytology, histology; 2 Uncertain selection criteria for test negatives | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Oyer and Hanjani, 1986 | Diagnostic test evaluation No verification of test negatives | Incidental conventional Pap (specimen collection not described) vs. colposcopy in study of ECC biopsy | Philadelphia, PA 1/77-10/84 | 401 referrals with history of abnormal Pap Chart review of some (maybe all) referrals meeting population description during study time | Uncertain of blind interpretation GS: colposcopy reported as undefined positive or negative only | Prevalence (CIN1)=297/402= 74% Se (LSIL,CIN1)=223/297=75% Sp (LSIL,CIN1)=83/105=79% | Quality Score=5 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 0 Publication: 1 Industry: 1
Pang, Hsu, and Kwan-Chau, 1977 | Diagnostic test evaluation Consecutive series of patients referred to colposcopy clinic; repeat cytology, colposcopy, biopsy done; cone biopsy done in patients with colposcopy-directed biopsy, or abnormal Pap with negative colposcopy No Pap negative patients; all patients had colposcopy, biopsy and/or cone biopsy | Conventional Pap (specimen collection not described) Control group: conventional Pap | Hong Kong 8/75-7/76 | Consecutive series of 52 patients referred from University gynecology, family planning, STD clinics Age: 17-70 | Uncertain of blind interpretation Threshold for Pap: LSIL vs. HSIL GS: colposcope- directed biopsy, cone biopsy | Prevalence (CIN2/3)=43/52=83% Se (HSIL,CIN2/3)=40/43=93% Sp (HSIL,CIN2/3)=6/9=67% Study limitations:; 1 Uncertain blinding of pathologists; 2 Uncertain time between Pap and colposcopy; 3 Small series; 4 High prevalence of advanced disease; 5 Patients with negative colposcopy not biopsied | Quality Score=7 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Parham, Wiredu, and Hussein, 1991 | Diagnostic test evaluation | Conventional Pap (specimen collection not described) smear vs. biopsy | Scotland 1/88-12/89 | 1262 matched cases of cytology and histology | Blind interpretation Pap smears (Dyskaryosis-mild, moderate, severe) GS: biopsy CIN1-3, CIS and invasive carcinoma | Prevalence (CIN1)=1105/1262= 88% Se (LSIL,CIN1)=1088/1105=98% Sp (LSIL,CIN1)=28/157=18% Prevalence (CIN2/3)=790/1262= 63% Se (LSIL,CIN2/3)=782/790=99% Sp (LSIL,CIN2/3)=37/472=8% Se (HSIL,CIN2/3)=624/790=79% Sp (HSIL,CIN2/3)=341/472=72% | Quality Score=10 Ref. Std.: 2 blind: 2 Verification: 1 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Parker and Ueki, 1986 | Diagnostic test evaluation No verification of test negatives | Retrospective exfoliative cervical cytology Pap vs. histology (method varied) | New Zealand 3/84-6/84 | Retrospective look at all 441 cervix biopsies Unspecified recruitment | Uncertain of blind interpretation GS: histology reported as Invasive / In Situ / Dysplasia / Koilocytotic + Cervicitis | Prevalence (CIN1)=137/365= 38% Se (LSIL,CIN1)=102/137=74% Sp (LSIL,CIN1)=193/228=85% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Ramirez, Hernandez, Miyazawa, 1990 | Diagnostic test evaluation | Conventional Pap (specimen collection not described) vs. cone biopsy | Hawaii 1985-87 | 134 patients undergoing cone biopsy (consecutive) at gynecology clinic | Uncertain of blind interpretation GS: cone biopsy CIN1-3 cytology LSIL and HSIL | Prevalence (CIN2/3)=10/18=56% Se (HSIL,CIN2/3)=7/10=70% Sp (HSIL,CIN2/3)=4/8=50% | Quality Score=9 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Rasbridge, Nayagam, 1995 | All histological specimens for colposcopy, cone biopsy, or hysterectomy for dysplasia Selection of negative smears uncertain | Conventional Pap (specimen collection not described) | UK 4/90-3/91 | Consecutive series of 595 histology results Population not characterized | Uncertain of blind interpretation GS: histology; SIL | Prevalence (CIN1)=432/595= 73% Se (LSIL,CIN1)=374/432=87% Sp (LSIL,CIN1)=82/163=50% Prevalence (CIN2/3)=301/595= 51% Se (LSIL,CIN2/3)=269/301=89% Sp (LSIL,CIN2/3)=108/294=37% Se (HSIL,CIN2/3)=197/301=65% Sp (HSIL,CIN2/3)=218/294=74% Study limitations:; 1 Uncertain indications for biopsy or procedure; 2 Uncertain length of time between cytology, histology; 3 Pathologists not blind to cytology | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Ritter, Kadish, Vermund et al., 1988 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (cotton-tip swab and Ayre spatula) vs. colposcopy biopsy | New York, NY 6/84-10/85 | 191 women with history of abnormal Pap / visible lesion / cervical disease Unspecified recruitment | No blind interpretation GS: histology reported as normal or lesion (defined as koil, CIN1-3 or Ca) | Prevalence (CIN1)=150/191= 79% Se (ASCUS,CIN1)=111/150= 74% Sp (ASCUS,CIN1)=30/41=73% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Ronco, Montanari, Aimone et al., 1996 | Concomitant Paps at time of colposcopy Histology on all patients | Conventional Pap (specimen collection not specified) | Italy 9/90-8/91 | Consecutive series of patients referred for colposcopy, 50 with adequate Pap Population not characterized | Uncertain of blind interpretation GS: histology: Thresholds ASCUS, LSIL, HSIL | Prevalence (CIN2/3)=32/50=64% Se (HSIL,CIN2/3)=20/32=63% Sp (HSIL,CIN2/3)=14/18=78% Study limitations:; 1 Pathologists not blind to cytology; 2 High prevalence of disease | Quality Score=9 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Singh, Pang, and Ratnam, 1985 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (specimen collection not described) vs. cone biopsy histology | Singapore 3/79-2/83 | 427 females with history of abnormal Pap, suspicious cervix, or other Unspecified recruitment from above population | Uncertain of blind interpretation GS: cone biopsy histology reported as doubtful, suspicious or positive | Prevalence (CIN1)=101/107= 94% Se (ASCUS,CIN1)=99/101=98% Sp (ASCUS,CIN1)=1/6=17% Se (LSIL,CIN1)=76/101=75% Sp (LSIL,CIN1)=2/6=33% Prevalence (CIN2/3)=97/107= 91% Se (LSIL,CIN2/3)=73/97=75% Sp (LSIL,CIN2/3)=3/10=30% Se (HSIL,CIN2/3)=17/97=18% Sp(HSIL,CIN2/3)=9/10=90% | Quality Score=4 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 0 Publication: 1 Industry:0
Skehan, Soutter, Lim et al, 1990 | Series of women undergoing laser cone biopsy; colposcopy/ cytology results compared All Pap negatives had cone biopsy | Conventional Pap (specimen collection not described) | UK 11/87-2/89 | Consecutive series of 118 patients having cone biopsy for abnormal colposcopy and/or Pap Population not characterized | Uncertain of blind interpretation GS: histology | Prevalence (CIN1) = 68/97=70% Se (LSIL,CIN1)=56/68=82% Sp (LSIL,CIN1)=5/29=17% Prevalence (CIN2/3)=60/97=62% Se (LSIL,CIN2/3)=51/60=85% Sp (LSIL,CIN2/3)=8/37=22% Se (HSIL,CIN2/3)=40/60=67% Sp (HSIL,CIN2/3)=19/37=51% Study limitations:; 1 Pathologists not blind to cytology results; 2 High prevalence of disease | Quality Score=9 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Slawson, Bennett, Simon et al., 1994b | Diagnostic test evaluation | Conventional Pap (specimen collection not described) vs. colposcopy/ biopsy | Pennsylvania 8/89- 2/91 | 122 women with ASCUS in a family practice clinic under age 45. Waited 4-6 months before colposcopy and followup Pap | Blind interpretation Pap smear (ASCUS) GS: histology (condyloma, CIN1-3) | Prevalence (CIN1)=66/121=55% Se (ASCUS,CIN1)=28/66=42% Sp (ASCUS,CIN1)=38/55=69% | Quality Score=8 Ref. Std.: 1 blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Smith, Cowan, Hemstreet et al., 1987 | Diagnostic test evaluation Patients referred to colposcopy clinic for abnormal Pap; repeat Pap/QFIA compared to results from biopsy All negative Paps of patients referred to colposcopy clinic | Conventional Pap (plastic Ayre spatula) | Oklahoma 1984-85 | 122 patients referred for abnormal Pap Ages: not specified Selection of study subjects not specified | Only discordant results blindly reviewed GS: colposcopic biopsy; threshold: LSIL + | Prevalence (CIN1)=91/122=75% Se (LSIL,CIN1)=71/91=78% Sp (LSIL,CIN1)=18/31=58% Study limitations: High prevalence population Unblinded preliminary review Unspecified selection process: unclear if consecutive series, random selection, nonrandom selection | Quality Score=8 Ref. Std.: 2 blind: 0 Verification: 2 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Soost, Lange, Lehmacher et al., 1991 | Abnormal Paps with histology within 1 year Selection of negative smears uncertain | Conventional Pap (specimen collection not described) | Bavaria 1971-80 | 2,478 women with biopsy within 1 year of abnormal Pap; selection not specified Routine screening population | Uncertain of blind interpretation GS: histology; also assumed 2 negative smears within 3 years was true negative (data for cytology gold standard not included in this table) | Prevalence (CIN1)=1659/2086= 80% Se (ASCUS,CIN1)=1486/1659= 90% Sp (ASCUS,CIN1)=83/427=19% Prevalence (CIN1)=1391/2086= 67% Se (LSIL,CIN1)=1205/1391=87% Sp (LSIL,CIN1)=241/695=35% Study limitations:; 1 Uncertain time between biopsy, histology; 2 Uncertain selection criteria for test negatives | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Soutter, Wisdom, Brough et al., 1986 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (specimen collection not described) vs. colposcopy | England 7/83 | 172 women with history of abnormal Pap only All new referrals meeting description | Uncertain of blind interpretation GS: colposcopy reported as Invasive / CIN3/2/1 / Viral / Normal | Prevalence (CIN1)=107/172= 62% Se (LSIL,CIN1)=89/107=83% Sp (LSIL,CIN1)=28/65=43% Prevalence (CIN2/3)=103/172= 60% Se (LSIL,CIN2/3)=86/103=83% Sp (LSIl,CIN2/3)=29/69=42% Se (HSIL,CIN2/3)=61/103=59% Sp (HSIL,CIN2/3)=55/69=80% | Quality Score=6 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 2 Spectrum: 0 Publication: 1 Industry: 1
Spinillo, Capuzzo, Tenti et al., 1998 | Diagnostic test evaluation of Pap | Conventional Pap (endocervical brush and Ayre spatula) and standard colposcopic assessment | Italy 1/92-6/96 | 241 HIV seropositive and 991 control (404 HIV seronegative and 587 unknown HIV status) women attending a vaginitis clinic Mean age: HIV+=28.6; Controls=29.5 | No blind interpretation Pap (TBS) GS: colposcopy or colposcopy-directed biopsy | HIV+ Women: Prevalence (CIN1)=64/202=32% Se (ASCUS,CIN1)=47/64=73% Sp (ASCUS,CIN1)=134/138= 97% Prevalence (CIN2/3)=37/202= 18% Se (HSIL,CIN2/3)=18/37=49% Sp (HSIL,CIN2/3)=161/165=98% Control Group: Prevalence (CIN1)=99/932=11% Se (ASCUS, CIN1)=83/99=84% Sp (ASCUS,CIN1)=825/833= 99% Prevalence (CIN2/3)=55/932= 6% Se (HSIL,CIN2/3)=39/55=71% Sp (HSIL,CIN2/3)=874/877= 100% | Quality Score=8 Ref. Std.: 1 blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Spitzer, Krumholz, Chernys, 1987 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (endocervical smear with moistened Q-tip and ectocervical smear with moistened wooden spatula) vs. colposcopy | New York 1986 (?) | 97 women with history of abnormal Pap Unspecified recruitment | No blind interpretation GS: colposcopy reported as Invasive / 3 / 2 / 1 / HPV / Normal | Prevalence (CIN1)=55/97=57% Se (ASCUS,CIN1)=32/55=58% Sp (ASCUS,CIN1)=23/42=55% Se (LSIL,CIN1)=10/55=18% Sp (LSIL,CIN1)=40/42=95% | Quality Score=5 Ref. Std.: 2 blind: 0 Verification: 0 Consecutive: 1 Spectrum: 0 Publication: 1 Industry: 1
Stafl, 1981 | Diagnostic test evaluation No verification of test negatives | Cervigram vs. colposcopy | Wisconsin c. 1979 | 26 women with routine gynecology plus positive cervigram Unspecified recruitment | Blind interpretation GS: colposcopy reported as ICC / CIS / CIN3 / 2 / 1 / Normal but not in relation to Pap | Prevalence (CIN1)=16/26=62% Se (LSIL,CIN1)=7/16=44% Sp (LSIL,CIN1)=9/10=90% | Quality Score=6 Ref. Std.: 1 blind: 2 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Syrjanen, Mantyjarvi, Vayrynen et al., 1987 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (specimen collection not described) vs. colposcopy | Finland 1981 | 385 consecutive women with history of Pap consistent w/ HPV infection only | Uncertain of blind interpretation GS: colposcopy reported as HPV-No CIN / HPV-CIN1 / HPV-CIN2 / HPV-CIN3 | Prevalence (CIN1)=162/385= 42% Se (LSIL,CIN1)=118/162=73% Sp (LSIL,CIN1)=183/223=82% | Quality Score=7 Ref. Std.: 1 Blind: 0 Verification: 1 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Tait, Balawatte-gama, and Rees, 1988 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (Ayres spatula) vs. colposcopy | UK 3/85-8/86 | 65 women with history of genital warts, abnormal Pap, high-risk, or abnormal clinical exam All new cervicography referrals | Uncertain of blind interpretation GS: colposcopy reported as Ca / CIN3 / 2 / 1 / Negative | Prevalence (CIN1)=51/127=40% Se (LSIL,CIN1)=38/51=75% Sp (LSIL,CIN1)=62/76=82% Prevalence (CIN2/3)=41/127= 32% Se (LSIL,CIN2/3)=32/41=78% Sp (LSIL,CIN2/3)=66/86=77% Se (HSIL,CIN2/3)=20/41=49% Sp (HSIL,CIN2/3)=66/86=77% | Quality Score=6 Ref. Std.: 1 Blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Tawa, Forsythe, Cove et al., 1988 | Diagnostic test evaluation | Conventional Pap (specimen collection not described) vs. colposcopy/ biopsy | Louisiana Published 1988 | Routine gynecology patients Age: 18-50 | Uncertain of blind interpretation Paps= positive (defined as ASCUS or greater) GS: histology = CIN1-3 | Prevalence (CIN1)=81/397=20% Se (ASCUS, CIN1)=14/81=17% Sp (ASCUS,CIN1)=291/316=92% | Quality Score=5 Ref. Std.: 2 Blind: 0 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Tay, Jenkins, and Singer, 1987 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (Ayres spatula) vs. colposcopy | London 1/86-6/86 | 44 women with history of borderline nuclear abnormality Unspecified recruitment | No blind interpretation GS: colposcopy reported as Severe / Moderate / Mild Dyskaryosis / Borderline / Negative | Prevalence (CIN1)=36/44=82% Se (LSIL,CIN1)=12/36=33% Sp (LSIL,CIN1)=8/8=100% Prevalence (CIN2/3)=18/44=41% Se (LSIL,CIN2/3)=7/18=39% Sp (LSIL,CIN2/3)=21/26=81% Se (HSIL,CIN2/3)=3/18=17% Sp (HSIL,CIN2/3)=26/26=100% | Quality Score=6 Ref. Std.: 2 Blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1
Upadhyay, Jha, Sinha et al., 1984 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (wooden Ayres spatula) vs. histology | India c. 1984 | 308 women attending outpatient clinic for gynecology complaints All females in clinic | Blind interpretation GS: histology reported as Invasive / CIN3 / 2 / 1 / Cervicitis / No Pathology | Prevalence (CIN1)=240/308= 78% Se (LSIL,CIN1)=239/240=100% Sp (LSIL,CIN1)=15/68=22% Prevalence (CIN2/3)=222/308= 72% Se (LSIL,CIN2/3)=222/222=100% Sp (LSIL,CIN2/3)=16/86=19% Se (HSIL,CIN2/3)=222/222= 100% Sp (HSIL,CIN2/3)=18/86=21% | Quality Score=9 Ref. Std.: 2 Blind: 2 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Walker, Dodgson, and Duncan, 1986 | Diagnostic test evaluation No verification of test negatives | Conventional Pap (specimen collection not described) vs. colposcopy | Scotland 1/76-12/85 | 214 women with history of mildly atypical Pap All new patients meeting the above description | Uncertain of blind interpretation GS: colposcopy reported as CIN3 / 2 / 1 / No CIN | Prevalence (CIN1)=182/214= 85% Se (LSIL,CIN1)=140/182=77% Sp (LSIL,CIN1)=17/32=53% | Quality Score=7 Ref. Std.: 2 Blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry:1
Wetrich,1986 | Review of 2,194 patients referred for abnormal Paps; all had colposcopy Uncertain criteria for selecting patients for histology | Conventional Pap (specimen collection not specified) | Iowa 1971-83 | Consecutive series of abnormal Pap referrals; uncertain who did/didn't get histology 1607 had biopsy, 500 cone or hysterectomy Population not characterized | Uncertain of blind interpretation GS: histology | Prevalence (CIN1)=1175/1607= 73% Se (LSIL,CIN1)=954/1175=81% Sp (LSIL,CIN1)=289/432=67% Prevalence (CIN2/3)=741/1607= 46% Se (LSIL,CIN2/3)=657/741=89% Sp (LSIL,CIN2/3)=426/866=49% Se (HSIL,CIN2/3)=491/741=66% Sp (HSIL,CIN2/3)=702/866=81% Study results: Pap sensitivity higher, specificity lower with hysterectomy or cone specimen than colposcope-directed biopsy Study limitations:; 1 High prevalence of disease; 2 Uncertain criteria for selection of test negatives for biopsy; 3 Reference standard not blind; 4 Not all negative Paps had histology | Quality Score=9 Ref. Std.: 2 Blind: 0 Verification: 2 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Wheelock and Kaminski, 1989 | Diagnostic test evaluation | Conventional Pap (endo- and ectocervical scraping not described) vs. colposcopy/ biopsy | Mississippi 1984-86 | Consecutive 273 women with LSIL Underwent repeat Pap and colposcopy/biopsy | Uncertain of blind interpretation GS: histology CIN1-3 | Prevalence (CIN1)=133/273= 49% Se (ASCUS,CIN1)=101/133= 76% Sp (ASCUS,CIN1)=67/140=48% Se (LSIL,CIN1)=64/133=48% Sp (LSIL,CIN1)=114/140=81% Prevalence (CIN2/3)=86/273= 32% Se (LSIL,CIN2/3)=48/86=56% Sp (LSIL,CIN2/3)=145/187=78% Se (HSIL,CIN2/3)=17/86=20% Sp (HSIL,CIN2/3)=178/187=95% | Quality Score=7 Ref. Std.: 2 Blind: 0 Verification: 0 Consecutive: 2 Spectrum: 1 Publication: 1 Industry: 1
Wright, Sun, and Koulos, 1995 | Diagnostic test evaluation | Conventional Pap (Ayres-type spatula and a cytobrush) vs. colposcopy/biopsy | Quebec, Canada or New York, NY 4/92-5/93 | 398 women referred to colposcopy clinic with ASCUS or LSIL Median age in ASCUS group: 31; Median age in LSIL group: 29 | No blind interpretation Pap=ASCUS or LSIL GS: biopsy =CIN yes/no | Prevalence (CIN1)=15/353=4% Se (ASCUS,CIN1)=8/15=53% Sp (ASCUS,CIN1)=316/338= 93% Prevalence (CIN1)=15/353=4% Se (LSIL,CIN1)=4/15=27% Sp (LSIL,CIN1)=333/338=99% | Quality Score=4 Ref. Std.: 1 Blind: 0 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Wright, Ellerbrock, Chaisson et al., 1994 | Diagnostic test evaluation of HIV+ and HIV- women | Conventional Pap (specimen collection not described) vs. colposcopy/ biopsy | New York Published 1994 | 398 HIV+ and 357 HIV- women, Median age: 34 40% black | Blind interpretation GS: biopsy=LSIL and HSIL | Prevalence (CIN1)=179/398= 45% Se (ASCUS,CIN1)=123/179= 69% Sp (ASCUS,CIN1)=125/219= 57% Limitations: needed to exclude those cases with biopsies reported as indeterminate for CIN and this could inflate specificity. | Quality Score=6 Ref. Std.: 1 Blind: 2 Verification: 0 Consecutive: 0 Spectrum: 1 Publication: 1 Industry: 1
Young, Naryshkin, And Bowman, 1993 | Review of 414 concomitant Pap/biopsy pairs from 644 Paps done at time of biopsy (total pool 15,706 Paps); only those with positive colposcopy included | Conventional Pap (Ayre's spatula) | US 1988-91 | 414 patients referred for abnormal Paps, only those with Pap and biopsy at same time selected Population not characterized | Uncertain of blind interpretation GS: histology | Prevalence (CIN1)=328/412= 80% Se (ASCUS,CIN1)=276/328= 84% Sp (ASCUS,CIN1)=42/84=50% Prevalence (CIN1)=328/412= 80% Se (LSIL,CIN1)=236/328=72% Sp (LSIL,CIN1)=61/84=73% Prevalence (CIN2/3)=99/412= 24% Se (LSIL,CIN2/3)=91/99=92% Sp (LSIL,CIN2/3)=145/313=46% Se (HSIL,CIN2/3)=56/99=57% Sp (HSIL,CIN2/3)=302/313=96% Study results: 41% of repeats did not agree with referral Pap 3 months earlier, 69% of these lower grade than referral Pap Study limitations:; 1 Test negatives under-represented; 2 Negative colposcopies not included; 3 Histology results not blinded to cytology results | Quality Score=6 Ref. Std.: 2 Blind: 0 Verification: 0 Consecutive: 1 Spectrum: 1 Publication: 1 Industry: 1

1 Format for display of results of conventional Pap test: Prevalence (GS threshold)=diseased/total=% Sensitivity (Pap threshold/GS threshold)=true positives/diseased=% Specificity (Pap threshold/GS threshold)=true negatives/non-diseased=%

2 Description of summary score for assessing the quality of studies: scores are shown in parentheses. Ref. Std.: Was the test compared with a valid reference standard? Histology (2); Histology or negative colposcopy (1); Cytology (0) Blind: Were the test and reference standard measured independently (blind) of each other? Yes (2); No (0) Verification: Was the choice of patients who were assessed by the reference standard independent of the test's results? All test positives and test negatives verified (2); Test positives and random fraction of test negatives verified (1); Test positives and selected sample or none of test negatives verified (0) Consecutive: How was the study sample collected? Consecutive or random (2); Other (0) Spectrum: Was the spectrum of disease/non-disease defined? Yes (1); No (0) Publication: How was the study published? Paper (1); Abstract (0) Industry: What was the industry relationship to the study? Neither done nor supported by a manufacturer (1); Supported by a manufacturer (.5); Done by a manufacturer (0)

Evidence Table 2. Studies of Health Outcomes and Costs Associated with Screening Cervical Cytology

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Barnes, 1981 | Estimates the cost per death averted from carcinoma of the cervix by a screening program with annual Pap smears. Assumptions for cost estimate (from published literature):; 1 incidence of treatment of dysplasia and carcinoma in situ in screened population is 0.3%;; 2 total risk of death from carcinoma of the cervix in lifetime experience of women through 58 YOA is less than 0.3%.; Sources of data for cost estimates not given. | Annual conventional Pap for 40 years (from 18-58 years of age) Sensitivity = 79%; specificity = 95%; predictive value positive=5%; predictive value negative 99%; incidence=0.4% Values for Paps are based on representative values derived from the medical literature. | US Hypothetical data | Hypothetical population of healthy, asymptomatic women. | Health costs: cost of the screening program per death averted from carcinoma of the cervix. | Cost per death averted by screening program = $501,000. | G, H, K, L, M, N, O

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Barnes and Barnes, 1977 | Cost-benefit analysis: flow diagram of patient pool sizes and costs provided. Population and other estimates are taken from the current gynecological literature, but informed guesses are also made. Cite "assumed charges and professional fees for gynecological exams and therapy and estimates of transportation costs and foregone earnings." Discount rate = 6% | Conventional Pap Data for true- and false-negative smears not stated directly Clinical strategy provided in flow diagram | US 1977 | Hypothetical population over 20 years of age, not pregnant and with no hysterectomy: estimate of 75% participation of the appropriate female population. | Health outcomes and costs: cost-benefit analysis of screening program; life years gained. | Costs and benefits per year per beneficiary of the screening program is $565,000 ($685,000-$120,000). On average, each beneficiary would gain 22 years of life at an average cost/year of $26,000. | H, M

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Bergstrom, Adami, Gustafsson et al., 1993 | Used multivariate regression models to test whether the benefit of screening can be predicted by histopathologic criteria as reflected in the reported incidence of cancer in situ. Comparison of pre- and post-screening invasive cervical cancer rates. Each county (n=24) was a unit of measurement, adjustment was made for the incidence of invasive cancer before screening. Data source is the Swedish National Cancer Registry. Main part of analyses based on directly standardized incidence rates with Swedish census population in 1970 as a reference. Simplest model assumes that without treatment, a certain proportion of the detected and removed in situ cancers would have progressed to invasive cancer t_1_ years later. | Conventional Pap with histopathology Screening test characteristics not provided | Sweden 1958-1987 | National Registry totals for all age groups by age at diagnosis and period of diagnosis: 21,330 patients diagnosed with an invasive cervical cancer between 1958-87, and 75,892 patients with a diagnosis of cancer in situ or severe dysplasia between 1958-84. Invasive cervical cancer incidence decreased from 19.6 to 11.2 cases per 100,000 between 1960 and 1985. | Health outcomes: incidence of invasive cervical cancer. | No statistically significant (P<.05) associations were found between the incidence of cancer in situ in 1965, 1970, or 1975 and the reduction of invasive cancer 5, 10, or 15 years later. The best-fitting model showed the detection of 100 extra cases of cancer in situ per 100,000 women per year in 1975 resulted in a reduction of 1.0 (95% CI = -1.6-3.7) cases of invasive cancer 10 years later. The corresponding best model estimate implied a reduction of 4.6 cases (95%CI = 1.5-7.7) in a model restricted to cancer in situ in patients aged 20-50 years (when organized screening took place), invasive cancer in patients aged 30-60 years, and cancer in situ measured in 1970. Limitations: statistical power may be too small (limited by small number of observational units, use of age-standardized incidence figures, absence of exact knowledge of the mean and variability in the latency time from discovery of in situ cancer to diagnosis of invasive cancer); presence of measurement errors in the in situ variable caused by the inclusion of false positives among the in situ cases. | C, Q, R, S

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Bethwaite, Rayner, and Bethwaite, 1986 | Markov cost-effectiveness model. Disease transition probabilities are those used by the US Congress OTA report (1981) which are based on published sources and include an overall false-negative rate of 20%. "In the absence of reliable figures private sector costs for specific procedures have been used as proxies." Assumptions of treatment model:; 1 women are initially screened during a visit to a general practitioner for an unrelated consultation;; 2 there are no complications associated with treatment;; 3 treatment of dysplasia is assumed to be curative; the treatment of invasive carcinoma of the cervix has a 50% 5-year death rate. | Conventional Pap at varying intervals, from annually to every 8 years. Diagram of treatment model presented. | New Zealand Price data: 1984 | Hypothetical cohort of 100,000 women, initially clear of all abnormalities. | Health outcomes and costs: average and marginal costs per life saved per 100,000 women. | Screening Interval -- Avg Cost per life saved/100,000 women -- Marginal cost per life saved/100,000 women: Annual -- 79,871 -- -- 2 yr -- 42,104 -- 419,778 3 yr -- 29,552 -- 190,939 4 yr -- 24,400 -- 85,487 5 yr -- 22,495 -- 43,177 6 yr -- 22,543 -- 22,070 7 yr -- 23,867 -- 12,134 8 yr -- 26,789 -- 3, 830 No screening -- Marginal cost =26,789. Note: Costs are presented in New Zealand $. Deaths/100,000 women/yr by screening interval: Annual screening: 5.0 2 yr -- 6.0 3 yr -- 6.7 4 yr -- 7.4 5 yr -- 8.1 6 yr -- 8.8 7 yr -- 9.5 8 yr -- 10.2 No screening (symptomatic treatment) -- 15.0 | H, L, M, N, O

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Age | TS | CIN1 | CIN3+CA
Age | TS | CIN1 | CIN3+CA

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Screening Strategy | Days of Life^a^ | Cost 96$^a^ | Marginal Cost per YLS^b^

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Carter, Coburn, and Lusczak, 1993 | Cost-effectiveness of performing routine cervical cytologic examination during pregnancy; modeling done using single-step Markov process. Assumptions:; 1 all suboptimal and inadequate Pap smears were repeated;; 2 all patients with squamous atypia or CIN had colposcopy during pregnancy;; 3 90% of invasive cervical cancers are curable if treated immediately, and 60% curable if allowed to progress without treatment until the post partum period;; 4 of all women with initial prenatal Pap smears showing dysplasia or carcinoma in situ (CIN1 to 3), one-third will be willing to undergo definitive treatment during the pregnancy and two-thirds will receive definitive treatment after delivery;; 5 of all women with invasive carcinoma diagnosed at the time of the initial prenatal Pap smear, 80% will receive early definitive treatment and 20% will choose to receive treatment after delivery;; 6 average cost of definitive treatment for curable ICC is $10,000, and the average cost of incurable ICC is $100,000.; Cost and resource utilization data were obtained from Hays Army Community Hospital and two private practices. The prevalence of CIN and cancer of the cervix obtained from Planned Parenthood study; Markov transition probabilities obtained from Schweitzer and Luce (1988). Discount rate=5% | Prenatal Pap, and repeat Pap smear and colposcopy as needed. 63% of smears were adequate, 34% were suboptimal, and 13% were inadequate. | US 1990 | Chart review of a consecutive sample of 423 pregnant women for resource utilization data; a hypothetical cohort of 100,000 pregnant women used in the Markov process. Prevalence of initial disease states: CIN1-2 = 0.0215; CIN3 = 0.0018; Invasive cancer = 0.00001 Transition rate to Invasive cancer per year: CIN1-2 = 0.004; CIN3 = 0.05; Invasive cancer = 1.0 | Health outcomes and costs: number of smears done; number of cases diagnosed at each disease stage; average cost per patient; total cost; well-years saved. | 394 (95%) smears showed no evidence of abnormality; 16 (4%) showed squamous atypia without apparent cause; 3 (0.7%) showed inflammatory atypia; and 3 (0.7%) showed CIN. Total costs generated by the prenatal Pap smear in the sample were $24,205, representing an average cost of $57.20 per patient. The total savings resulting from early diagnosis of invasive cervical cancer was $180,000 for a population of 100,000. Undiscounted well-years saved was 93.32 years, 37.7 years when discounted at 5%. Baseline cost/life-year gained was $146,600; C/E was higher for younger age groups, lower for women over 30. Even under conditions most favorable to screening (high prevalence, high transition rate to cancer, low proportion of curable cancers, high acceptance of treatment), C/E ratios were in the range of $49,400-$75,600. Stratified by age group: Extensive sensitivity analysis was performed. Limitations: ignores false positive and false negative Pap tests; no source for treatment costs; workup costs probably underestimate; cost data limited. Conclusion: Prenatal Pap smears in reliable population at low risk for invasion not cost-effective. | K, L, N
  Age | Cost/Yr. of Life Saved
  15-19 | $321,600
  20-24 | $144,200
  25-29 | $83,200
  30-34 | $73,100
  35-39 | $48,800

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Scenario 1 2
Scenario 3 4

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Chesebro and Everett, 1996 | Cost-benefit analysis of protocol for studying patients with SIL on Pap smears. Analytical model for triage of patients. Assumptions:; 1 48% of untreated severe dysplasias would progress to ICC 10-31 years in the future;; 2 on average, a woman would be diagnosed as having CIS at 29 years of age and that having developed ICC, 47.2% would die 10-31 years later if untreated;; 3 average female life expectancy is 79 years of age; Assumed the rate of Pap smears with SIL in the screened population at 1.8%, 5.1%, and 11.5%. Discount rate=5% Itemization of costs "available from authors." | Colposcopic evaluation and treatment of Pap smears with low-grade SIL, high-grade SIL (moderate), and high-grade SIL (severe) | US 1990-93 | Data collected from medical charts of 424 patients who received colposcopy and biopsy. Mostly indigent women; high-risk population. Average age=27.1 (range, 15.8-68.1) Estimated 6.2% rate of SIL. | Health outcomes and costs: number of invasive cervical cancer cases prevented; cost per life saved; marginal cost of performing colposcopy on all LSIL and HSIL Pap smears. | Treating the 61 patients with severe dysplasia on biopsy specimens may have prevented 29.3 (range, 18.3-48.8) cases of ICC, of which 47.2% would have resulted in death. Marginal cost of performing colposcopy on all LSIL , HSIL (moderate) and HSIL (high grade) PAP smears ranged from $406-$5,746; $160-$2,263, and $85-$1,197 per year of life saved, respectively. Previous evidence suggests that as many as 48% of the patients with CIS might develop and die of ICC. Sensitivity analysis in this study used 30% and 80% as the lower and higher estimates of this proportion. Depending on the rate of SIL in the screened population (which in this study was 1.8%, 5.1%, and 11.5%), the cost of screening and treating the referral base was $1.3 million, $538,126, and $307,037, respectively. The average cost per year of life saved to screen and treat LSIL was $1105-$68,909, HSIL (moderate) was $375-$21,673, and HSIL (high) was $177-$8,831. Colposcopy for SIL is a cost-effective strategy. | K, L, N

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Dickinson, 1972 | Cost-benefit analysis of cytologic screening for cervical cancer. Source of 1968 cost data for the screening program is Mayo Clinic. Costs of confirming the diagnosis and treatment of screened patients is the Mayo Clinic and are based on 1961 estimated prices. Source of costs of treating the unscreened patients was based on 1961 prices and the source is not explicitly stated. Mean annual earnings estimated based on 1963 data from the Bureau of Labor Statistics. Assumptions include:; 1 proportion screened=29.5% annually; Incidence among the screened=0.00356 based on 184 screened cases diagnosed, an estimate from a 1% sample of the Mayo cytology records, and an actual count from Olmsted Medical Group (184/51,677);; 2 all women with positive cytology were biopsied, and all women with positive biopsy were treated;; 3 proportion not cured and proportion cured=0.9 and 0.91, respectively for the well-screened women;; 4 expectation of life after diagnosis for the not-cured and cured=3.52 and 39.92 years, respectively;; 5 expectation of life after diagnosis for the untreated=unknown, but assumed to be 3.52 years.; No discount rate was used because the return here is computed on a relatively short 3-year period. | Conventional Pap Sensitivity=96.7%; specificity=99.8% Compared expectation of life for two treated groups, one screened and one unscreened. | US 1960-67 | 184 screened women between 1960-67, 5 had diagnosis without screening; 92 unscreened women from 1935-51, with 23 receiving a Pap prior to diagnosis. | Health outcomes and costs: cervical cancer incidence, mortality, and survival; costs of additional year of life saved. | Between 1935-67, average annual incidence increased from 19.3/100,000 to 53.4/100,000. Mortality decreased from 5 to 7/100,000 before 1960 to 3/100,000 after 1960. Of the well-screened group of women in whom the diagnosis was made between 1960 and 1965, 91% were cured (i.e., had a normal life expectancy) and had an expectation of life after diagnosis that was 3.23 years greater than the relatively unscreened group whose diagnosis was made between 1935 and 1951. In the latter group, only 74% were cured. Excluding Federal tax returns, each dollar spent yields an additional 1.3 days of life, with each additional year costing $291. If federal income tax returns are included, each additional year of life costs about $14. | B, C, M, N, O

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Age

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Discounted Life-Screening Years (in 1,000s)
Schedule | Total | Incremental
Screening Cost (in millions)
Schedule | Total | Incremental
Screening Cost-Effect. Ratio
Schedule | * | Incremental

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Johnson, Sutton, Thornton et al., 1993 | Decision tree | Immediate colposcopy and biopsy versus repeat Pap in 6 months for CINI | UK 1993 | Hypothetical population of 1,000 women with CIN1 on Pap. | Health outcomes: cases of cancer; lives saved. | Immediate colposcopy/bx and treatment results in 1.6 cases of cancer/1000 women with CIN1 on Pap, assuming every 5-year screening, whereas repeat Pap results in 2 cases/1,000 women. The results are equivalent under every 3-year screening. The number of repeat smears needed to prevent one colposcopy is 6 (from 4 women). Results are sensitive to test characteristics, regression/progression rates, and the frequency of screening Paps. Limitations:; 1 no formal cost analysis;; 2 time frame/ analytic horizon unclear;; 3 annual screening (de facto U.S. standard) not considered;; 4 no modeling of effects of compliance.; Conclusion: At routine screening intervals longer than every 3 years, immediate colposcopy results in fewer cases of cancer. | B, C, G

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Koopmans-chap, Van Oortmarssen, van Agt et al., 1990 | Cost-effectiveness analysis of screening programs by level of attendance (i.e., the percentage of woman invited to undergo screening who respond to the invitation). Computer simulation program, MISCAN, used for the calculations. Discount rate=5% | Organized screening program (7 invitations between 37 and 73) compared with spontaneous screening (i.e., screening only when requested by the woman) | The Netherlands Computer simulation: 1988-2015 | Computer-simulated population based on data from Canada and The Netherlands | Health outcomes and costs: incremental cost per life-year gained | Organized screening (7 invitations between ages 37 and 73) versus spontaneous screening: Incremental costs: $163 million versus $178 million; Life-years gained: 68,000 versus 43,000; Incremental cost/life-years gained: $12,400 versus $26,900. Limitation: Starting age and screening interval not consistent with US standard. | K, L

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Luce, 1981 (OTA) | Cost-effectiveness analysis model,13-state Markov Discount rate = 10% | Alternate Pap test screening intervals versus no Pap screening | US 1979 | Hypothetical cohort aged 30-39 | Health outcomes and costs: lives saved, life-years saved, costs | Under base case assumptions (including a 10% discount rate), annual screening had a cost/life-year saved of $97,600. Cost-effectiveness increased as the screening interval, to $14,300 for every 10-year screening. C/E estimates were most sensitive to the perspective of the analysis, the discount rate used, the costs of screening, and the use of a joint production effects model. C/E ratios were relatively insensitive to Pap test characteristics. A "mixed" model, using low screening cost assumptions for low-risk populations and more aggressive policies for high-risk populations, was almost as cost-effective as a policy using low-cost assumptions for all subjects. Limitations:; 1 10% discount rate;; 2 older data;; 3 assumptions about treatment and diagnostic evaluation of test positives may not be current.; Conclusions: The cost-effectiveness of cervical cancer screening is dependent on the interval of screening, the perspective of the analysis, the costs of screening, and technical aspects of the economic model. | M

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Mandelblatt and Fahs, 1988 | Cost-effectiveness analysis model, Markov | Program of routine Pap screening versus no program | US 1985 | Infrequently screened elderly women at an urban municipal hospital outpatient clinic | Health outcomes and costs: total health care costs; life-years saved | The results of Pap testing were abnormal (malignant or premalignant) in 11 of 816 women screened. Screening saved $5,907 and 3.7 years of life per 100 Pap tests. When average medical costs per year of life extended by screening were included, the program cost $2,874 per year of life saved. Comprehensive sensitivity analyses performed on competing medical and economic points of view did not change the conclusion of a favorable cost-effectiveness ratio for screening. Limitations: Considers one-time costs and benefits (not ongoing program); ignores false negatives Conclusion: Pap screening targeted at high risk groups who have not had previous screening can be cost saving. | L, M

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
| Total | Marginal
| Total | Marginal

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Outcome | No Pap | Pap

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Costs: | Conservative | Aggressive
| Conservative | Aggressive

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Age | Interval
| Every 5 yr | Every 10 yr | Lifetime
Age | Interval
| Every 5 yr | Every 10 yr | Lifetime
Age | Interval
| Every 5 yr | Every 10 yr | Lifetime
Age | Interval
| Every 5 yr | Every 10 yr | Lifetime
Age | Interval
| Every 5 yr | Every 10 yr | Lifetime
Age | Interval
| Every 5 yr | Every 10 yr | Lifetime

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Raab, 1997 | Comparison of:; 1 rescreening at 10% and 100% rates,; 2 no rescreening, repeat Pap in 1 year,; 3 no rescreening or repeat Pap (7 total possible strategies); Assumptions:; 1 colposcopy for LSIL and higher, or ASCUS on initial and repeat smears;; 2 100% rescreening detects all FNs due to interpretation;; 3 high rates of progression to cancer in 1 year, no regression;; 4 100% sensitivity/specificity for colposcopy/biopsy;; 5 microinvasive cancer included with Stage 1;; 6 false negative rate, proportion of cancers missed by misinterpretation = those due to sampling error; 7 All assumptions biased toward rescreening; Probability data source: comprehensive literature review Cost data: N/A (C/E analysis threshold analysis only) Discount rate: 3% | Conventional Pap with "rescreening" (technique not specified) Sensitivity and specificity not reported; reports false negative rate by TBS stage, 5X5 table of cytology versus colposcopy. Strategy: colposcopy all LSIL and higher, repeat Pap for ASCUS, colposcopy for ASCUS and higher on repeat. Control: Pap with no rescreen and no 1-year repeat | Iowa 1997 | Base case: 30-year-old white woman with normal risk. Prevalence and incidence rates not given. Progression: LSIL to Ca: 0.01 HSIL to Ca: 0.1 Progression in 1 year: LSIL to Ca: 0.25 HSIL to Ca: 0.50 Regression rate:assumed to be 0%. | Health outcomes; threshold analysis on health costs: false negatives, false positives, cancer cases, discounted life expectancy, cost/life year gained. | All results per 10,000 except gain in life expectancy (days); 1 no rescreen/repeat: FN: 568; FP: 0; Ca : 30.75 Gain in life expectancy: Base (days); 2 100% rescreen: FN: 284; FP: 196; Ca: 17.78 Gain in life expectancy: 0.66; 3 10% rescreen: FN: 540; FP: 20; Ca: 29.45 Gain in life expectancy: 0.07; 4 100% rescreen, repeat 1 year: FN: 16; FP: 381; Ca: 11.59 Gain in life expectancy: 1.08; 5 100% automated rescreen, repeat 1 year: FN: 8; FP: 387; Ca: 11.08 Gain in life expectancy: 1.09; 6 repeat 1 year, no rescreen: FN: 32; FP: 370; Ca: 17.24 Gain in life expectancy: 0.84; 7 10% rescreen, repeat 1 year: FN: 31; FP: 371; Ca: 17.08 Gain in life expectancy: 0.84; Cost-effectiveness: Rescreening cost thresholds at which cost-effectiveness favors 100% rescreening at the following 1-year HSIL[image]CA progression rates:; 1 0.0625 $7.55; 2 0.125 $12.50; 3 0.25 $14.80; Limitations:; 1 cost of false positives, false negatives not evaluated;; 2 total health-care costs not included;; 3 actual costs not used. | K, L, N

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Radensky and Mango, 1998 | Cost-effectiveness analysis; adapted Eddy (1990) model by applying a range of accuracy data (synthesized from the literature) and costs for interactive neural network- assisted (INNA) rescreening. All assumptions in the Eddy model concerning natural history, screening procedures, and treatment of cervical cancer were maintained. Discount rate for costs and health outcomes=3% | Cervical cancer screening with unassisted manual examination of cervical smears versus INNA rescreening of negative smears on a triennial schedule through age 75. Sensitivity: Pap, 85%; INNA, 89-100%. Specificity: Pap, 99.5%; INNA, 99.5%. Rate of unnecessary procedures: 0.00022. | US 1997 | Hypothetical cohort of women starting screening at age 20 and screened | Health outcomes outcomes and costs: sensitivity of INNA (based on different biopsy standards); costs; life-days; and cost per life year saved. | The different sensitivities for INNA and different biopsy standards (CIN1+, CIN2-3 or ICC) led to cost-effectiveness ratios ranging from $39,087 to $79,440, with a preponderance of ratios at or below $50,000. Sensitivity analysis:; 1 The CE ratios were very sensitive to the sensitivity of unassisted Pap smear exams. Ranging the sensitivity of unassisted Pap smear exams from 60% to 95% resulted in cost-effectiveness ratios that ranged from $8,045 to over $266,151.; 2 CE ratios were not sensitive to cost of treatment of cervical cancer. Halving these costs results in a 2% change in the CE ratio.; 3 The CE ratios were sensitive to changes in specificity of INNA rescreening. If false positive rate is doubled, CE ratios rise by approximately 30%. | A, G, I, L

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Int | CIS | Inv

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
| Pap only | Papnet^®^

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Schweitzer, 1974 | Cost-benefit analysis using decision tree model, one time conventional Pap screen; abnormal Pap followed by repeat Pap; if second abnormal, then biopsy; if biopsy abnormal, cone biopsy Assumptions:; 1 radical hysterectomy for cancer;; 2 clinical strategy as above; Comprehensive lit review: No Probablility estimates: literature Costs: MediCal, Mayo Clinic Inflation adjustment: Medical CPI Discount rates=0, 4, 10% | Conventional Pap Pap: sensitivity 91.3% (midpoint of 86%-96.7%); specificity: 97.4% (midpoint of 95-99.8%) Punch biopsy (not colposcopically directed): sensitivity 96.7%; Specificity 90% Cone biopsy:sensitivity 98%;specificity 96% Clinical Strategy:; 1 one time Pap; 2 if Pap abnormal, repeat; 3 if repeat abnormal, punch biopsy; 4 if punch biopsy abnormal, cone biopsy; 5 control: no Pap | US Sensitivity and specificity data: 1962, 1972; Incidence data: 1962; Cost data: adjusted to 1970 | US women Description of study population not given. Incidence: 35/100,000 Pap data from Mayo Clinic, textbook. | Health outcomes and costs: cost/case treated; ?cost/life saved (denominator not explicitly defined);cost/benefit ($ value given to lost life from cervical cancer). | $36,667/life saved $44,421/case treated Cost/benefit: $72,000 at 4% discount rate $50,000 at 10% discount rate Limitations:; 1 no sensitivity analyses;; 2 outdated clinical strategy;; 3 clinical outcomes not explicit;; 4 limited number of data sources. | C, E, G, H, J, K, L, M

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Screening every: | Add'l Cost per Add'l life saved
Screening every: | Add'l Cost per Add'l life saved

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Sherlaw-Johnson, Gallivan, Jenkins et al., 1994 | Computer simulation model | Immediate colposcopy and treatment versus repeat Pap test at 6-month intervals with colposcopy for persistent abnormalities | UK Year of data: unspecified, referenced elsewhere | Hypothetical population of women over age 18 with dyskaryosis. | Health outcomes: incidence of invasive cancer | All incidence rates for ICC below are per 10,000 per year. Unscreened population: 5.9 With 50% of women screened: Colposcopy: 3.11 Repeat Pap: 3.18 With 70% of women screened: Colposcopy: 2.0 Repeat Pap: 2.10 With 90% of women screened: Colposcopy: 0.90 Repeat Pap: 1.02 Screening intervals 1 yr to 10 yr: Colposcopy: 1.85-2.53 Repeat Pap: 1.91-2.64 Limitations: Does not look at costs but provides utilization data of smear tests & colposcopies; Model's main goal is to measure effects of changing screening program parameters, not estimate incidence Conclusion: Better participation in cervical cytologic screening rather than greater frequency of testing is needed. | A, C, G

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
| Spontaneous | Efficient

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
van Bollegooijen,van den Akker-van Marle, Warmerdam et al., 1997 | Cytology only versus HPV testing only versus cytology+HPV testing; States: Healthy, HPV, CIN, Cancer; Transitions: HPV [image]Healthy, HPV [image]CIN, CIN [image]Cancer, CIN [image]Healthy Assumptions:; 1 95% Ca preceded by HPV [image]CIN;; 2 high-risk HPV types only;; 3 duration of HPV that will develop into CIN: 10 yrs, 1 year (2 models);; 4 duration of HPV that will regress: 1 year, 10 yrs;; 5 duration of CIN: 11.8 yrs;; 6 asymptomatic Ca: 3.9 yrs;; 7 efficacy of CIN treatment 85%;; 8 followup for +HPV, - Pap: Pap/HPV q 6 months until HPV- or Pap+;; 9 CIN+: 4 years for Dx, Rx, f/u;; 10 ASCUS/LSIL managed by repeat Pap;; 11 5% of screening smears generated 2 repeats in CIN- women 1.5/10,000 women without CIN had colposcopy/ biopsy; Comprehensive lit review: No Probability estimates: literature, prior models Costs: Source unclear: "true resource costs" for Pap, HPV, colposcopy, radiation therapy, "charges" for others; given in 1995 Dutch guilders (1.61/$) Inflation adjustment: Not specified Discount rate=not specified | Conventional Pap, HPV testing Pap: Sensitivity: 80% CIN, 87.5% Ca. HPV: Sens:100% for HPV Specificities not explicitly given Clinical strategy:; 1 CIN+ on Pap: colposcopy/ biopsy, and treat if biopsy positive;; 2 HPV+, CIN-: Repeat both every 6 months until HPV- or Pap+; 3 HPV-, CIN-: repeat at specified interval; Control group: conventional Pap | The Netherlands Incidence data: 1965-92 | Dutch women Prevalence of HPV: 4% CIN-, 67% CIN+ Incidence of CIN: age-specific Progression rate not given. Regression:<35=72%;35-54=40%;>55="very low" | Health outcomes and costs: Mortality reduction; life-years gained; years in followup; costs; average cost/life year gained. | All figures per 1,000 women screened 2 models: A: 10-year duration HPV[image]CIN 1-year duration HPV[image]well B: 1-year duration HPV[image]CIN 10-year duration HPV[image]well Sensitivity analysis: Costs -- results given in terms of % difference from Pap only screening; varying costs of HPV testing did not effect relative C/E ratios Limitations:; 1 management not standard in US;; 2 no separation of CIN into LSIL, HSIL;; 3 no discounting. | C, L, N, O
  (a) Life-years gained:
  Pap only q 3 yrs | 65
  Model A:
  Pap+HPV q 10 yrs | 68
  HPV only q 10 yrs | 66
  Model B:
  Pap+HPV q 5 yrs | 66
  HPV only q 3 yrs | 62
  (b) Years in followup:
  Pap only q 3 yrs | 700
  Model A:
  Pap+HPV q 10 yrs | 520
  HPV only q 10 yrs | 290
  Model B:
  Pap+HPV q 5 yrs | 1760
  HPV only q 3 yrs | 1790
  Costs (converted to US$):
  Pap only q 3 yrs | $460K
  Model A:
  Pap+HPV q 10 yrs | $286K
  HPV only q 10 yrs | $143K
  Model B:
  Pap+HPV q 5 yrs | $745K
  HPV only q 3 yrs | $776K
  Average cost/life-year gained:
  Pap only q 3 yrs | $7071
  Model A:
  Pap+HPV q 10 yrs | $4201
  HPV only q 10 yrs | $2165
  Model B:
  Pap+HPV q 5 yrs | $11,293
  HPV only q 3 yrs | $12,522
  Incremental cost/life-year gained (calculated; not given in paper):
  Pap only q 3 yrs | Reference
  Model A:
  Pap+HPV q 10 yrs | Cost-saving
  HPV only q 10 yrs | Cost-saving
  Model B:
  Pap+HPV q 5 yrs | $285,714
  HPV only q 3 yrs | Dominated

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
van Nagell, Dudik, Frank et al., 1987 | Calculations based on estimated incidence of cervical cancer, death rate, hospital charges Assumptions: false negative rate 10%, implied 100% compliance with screening, treatment Comprehensive lit review: No Probability estimates: CDC for incidence, mortality, others not specified Cost estimates: University of Kentucky charges for 1 patient No adjustment for inflation Discount rate=none | Conventional Pap Pap: 90% sensitivity, specificity not addressed (assumed to be 100%?) Description of clinical strategy: unclear Control group: no Pap | Kentucky 1981 | ?Poor women, ages not specified. Prevalence rate not specified. Incidence: 30/85,000, 13.1 deaths/85,000 Progression and regression rates not given. | Health outcomes and costs: cases prevented; cost/life saved. | Screening 85,000 women: 27 cases detected, 12 deaths prevented Costs:; 1 screening: $2,386,750; 2 cancer: $675,000; 3 cost/life saved: $142,646; Sensitivity analysis: None | A, B, C, D, G. H, I, J, K, L, M, N, O

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Van Oortmarssen, and Habbema, van Ballegooijen, 1992. | Mathematical model of cost-effectiveness. No comprehensive literature review. Data for the probability estimates are taken from the cohort study of cervical cancer screening in British Columbia. Cost data is taken from the literature. There is no adjustment for inflation Discount rate=none | Conventional Pap at 1-, 2-, 3-, 4-, 5-, and 10- year screening intervals. Sensitivity:80%specificity: not given. | British Columbia Year of data: not stated | Data taken from a cohort study of cervical cancer screening in British Columbia. Details of the selection criteria and population description are given elsewhere. Prevalence and incidence rates not given. Progression and regression rates not given. | Health outcomes and cost:incidence of invasive cancer and mortality; cost per life-year gained. | % Reduction in incidence and mortality of cervical cancer by screening interval: Marginal cost per life gained from switching from 5- to 3-year screening interval: £25,000. Sensitivity analysis: none | A, B, C, J, L, N, O
  Screen Interval | Cum. incidence | Cum mortality
  1 y | 95.4 | 96.9
  2 y | 93.3 | 95.3
  3 y | 91.0 | 93.7
  4 y | 88.3 | 91.8
  5 y | 85.2 | 89.7
  10 y | 68.1 | 80.0

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
van Oortmarssen and Habbema, 1995 | Mathematical model Assumptions:; 1 regression rates vary by age: 84% for "younger" women, 40% "older";; 2 risk of other cause death or hysterectomy independent of cervical cancer risk;; 3 screening participants have lower risk of cervical Ca (RR 0.74);; Comprehensive lit review: No Sources of probabilities: British Columbia cohort (referenced) Sources of costs: N/A | Conventional Pap Sensitivity: 80% SIL; 90% invasive cancer Specificity: not addressed Clinical strategy not specified Control Group: No Pap, Pap at various intervals (3 versus 5 years) | British Columbia 1949-69 | Cohort study, description of population not given. Prevalence and incidence not given but referenced. Progression rate not given but referenced Regression rate:"younger"=84%; "older"=40% | Health outcomes: relative risk reduction in invasive cancer after 1 or 2 negative smears. | Incidence depends on whether screen-detected cancers are included in calculations; RR 0.4 or less up to 5 years after one negative smear if screen-detected cases included, lower if only clinically detected cases included Sensitivity analysis: Key variables include duration of preinvasive and invasive disease, screening frequency -- all can be altered to fit data (longer duration/less frequent screening and vice versa) Limitations:; 1 outcome (RR) not intuitive or comparable to other studies;; 2 assumptions about other cause mortality/hysterectomy risk may be wrong (e.g., cervical cancer patients more likely to smoke, have PID) | B, C, G, H

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Waugh and Robertson, 1996a | Marginal cost-effectiveness analysis; retrospective data | 3-yr versus 5-yr cervical screening | UK Incidence data: 1991; Cost data: 1995 | 105,000 women ages 20-59. | Health outcomes: additional cancers diagnosed; mortality avoided. | Two additional women may have been diagnosed, with one women cured by treatment; this would lead to CE ratios of £250,000 per life saved and £8,000 per life year saved. Sensitivity analysis: £1,538 to £15,286. Takes into consideration hysterectomies (17%) and non-compliance (17%). Limitations: Outcomes and costs are imputed, rather than based on observed data. | B, C, L, N

Study | Study Design & Characteristics | Intervention | Location & Time Period | Patients & Methods | Outcomes Measured | Study Results & Limitations | Quality Scoring ^1^
Waugh, Smith, Robertson et al., 1996b | Cost/benefit analysis of program issuing invitations for screening to women with no previous smear, compared with no screening. Assumes all micro-invasive cancers progress to cancer. 50% of cancer curable, rest fatal. No literature review. Probability estimates taken from literature, primary data collection. Cost data taken from literature. No adjustment for inflation reported. Discount rate=7% | Conventional Pap No estimates of sensitivity or specificity reported. Strategy: repeat smears of unsatisfactory and abnormal smears, colposcopy of second abnormal smears. Control: no screening. | UK 1991 | Population not described but cited elsewhere. Prevalence and incidence rates not given. Progression rates: CIN3 -- 50% and 100% to cancer; CIN1-2 -- 12% or 24% to CIN3. Regression rate not given. | Health outcomes and costs: total costs; life-years gained. | Total life years gained by screening : 327 (or 522 at different progression rate). 9 (or 16) lives saved. Costs of program: £51,019, net costs (including future savings) £29,081. Cost per life saved: £5,780 (£3,251 at higher progression). Cost per life-year saved: £159 (£100) | B, D, L, N

## [Quality Scoring Key]

^1^ Code appears when article fails to meet criterion.

For articles that model health outcomes:
  A | There was a description or diagram of decision model.
  B | The clinical strategies were described in detail.
  C | A comprehensive literature review was conducted.
  D | The control group was described
  E | Sources of data for probability estimates were identified.
  F | The source of the utility scale or measurement method was given.
  G | Clinically relevant outcomes of interest were described in detail.
  H | Results of a sensitivity analysis were presented.
For articles that model costs:
  I | There was a description of the framework for the cost analysis.
  J | Modeling assumptions were stated explicitly.
  K | There was sufficient description of estimates of types of resources used, amount of resource use, and unit costs, and their sources.
  L | There was a critique of data quality.
  M | The cost data were current, i.e., 1988 or more recent.
  N | There was a description of a method to adjust costs for inflation.
  O | There was a statement of discount rates used (for multiperiod or longitudinal studies).
For articles that compare health outcomes with and without Pap smear screening, or with and without use of new Pap technology:
  P | Study population was representative or clearly defined.
  Q | Screened and unscreened populations were concurrent (e.g. before-after design).
  R | Screened and unscreened populations were randomly allocated.
  S | The method of ascertainment of health outcomes was the same in the screened and unscreened groups.
  T | The ascertainment of health outcomes was complete (loss to followup >5%).