# Acronyms and Abbreviations

ACHPR: Agency for Health Care Policy and Research

ACOG: American Collage of Obstetricians and Gynecologists

AGUS: atypical glandular cells of uncertain significance

AHA: American Hospital Association

AJCC: American Joint Committee on Cancer

ASCUS: atypical squamous cells of uncertain significance

CAP: College of American Pathologists

CAT: computerized axial tomography

CDC: Centers for Disease Control

CE: cost-effectiveness

CER: cost-effectiveness ratio

CI: confidence interval

CIN: cervical intraepithelial neoplasia

CINAHL: Cumulative Index to Nursing & Allied Health

CIS: carcinoma in situ

CLIA: Clinical Laboratory Improvement Amendments

COBRA: Consolidated Omnibus Budget Reconciliation Act

CPS: Consumer Price Survey

CPT: Current Procedures Terminology

DRG: diagnosis-related group

EPC: Evidence-based Practice Center

FDA: Food and Drug Administration

FIGO: Federation Internationale de Gynecologie et Obstetriques

FN: false negative

FNR: false negative rate

FPR: false positive rate

HCFA: Health Care Financing Administration

HPV: human papilloma virus

HSIL: high-grade squamous intraepithelial lesion

IARC: International Agency for Research on Cancer

ICD: International Classification of Diseases

INNA: interactive neural network-assisted

LEEP: loop electrosurgical excision procedure

LSIL: low-grade squamous intraepithelial lesion

Med.: median

MEI: Medicare Economic Index

MRI: magnetic resonance imaging

NAMCS: National Ambulatory Medical Care Survey

NSI: Neuromedical Systems Inc.

Obs.: observations

OTA: Office of Technology Assessment

Pap: Papanicolaou

PCE: patient care evaluation

Q1: quartile 1

Q3: quartile 3

RBRVS: resource-based relative value scale

ROC: receiver operating characteristic

SBLB: Satisfactory but limited by

SEER: Surveillance, Epidemiology, and End Results

SIL: squamous intraepithelial lesion

STD: sexually transmitted disease

TNM: Tumor, Nodes and Metastases

TPR: true positive rate

WHO: World Health Organization