# References

American Academy of Pediatrics. Guidelines for health supervision II. Elk Grove Village, IL: The Academy; 1988.
American Cancer Society. Guidelines for the cancer-related checkup: An update. New York: The Society; 1993.
American College of Obstetricians and Gynecologists. ACOG Committee Opinion: Recommendations on frequency of Pap test screening. Washington, DC: American College of Obstetricians and Gynecologists; 1995. Publication No. 152.
American College of Physicians. Screening for cervical cancer. In: Eddy DM, editor. Common screening tests. Philadelphia: American College of Physicians; 1991, p. 413-4.
American Joint Committee on Cancer. Cervix uteri. In: AJCC cancer staging manual. Philadelphia: Lippincott-Raven Publishers, 5th edition; 1997. P. 189-94.
American Medical Association. AMA guidelines for adolescent preventive services (GAPS): Recommendations and rationale. Chicago: American Medical Association; 1994.
Anderson DJ, Flannelly GM, Kitchener HC, Fisher PM, Mann EM, Campbell MK, Templeton A. Mild and moderate dyskaryosis: Can women be selected for colposcopy on the basis of social criteria?. BMJ. 1992;305:84-7. [pmid: 1638252]. [pmcid: 1882624].
Andrews S, Hernandez E, Miyazawa K. Paired Papanicolaou smears in the evaluation of atypical squamous cells. Obstet Gynecol. 1989;73(5 Pt 1):747-50. [pmid: 2704501].
Ashfaq R, Liang Y, Saboorian MH. Evaluation of PAPNET system for rescreening of negative cervical smears. Diagn Cytopathol. 1995;13:31-6. [pmid: 7587873].
Ashfaq R, Solares B, Saboorian MH. Detection of endocervical component by PAPNET system on negative cervical smears. Diagn Cytopathol. 1996;15:121-3. [pmid: 8872433].
Baldauf JJ, Dreyfus M, Ritter J, Philippe E. Colposcopy and directed biopsy reliability during pregnancy: A cohort study. Eur J Obstet Gynecol Reprod Biol. 1995;62:31-6. [pmid: 7493705].
Baldauf JJ, Dreyfus M, Lehmann M, Ritter J, Philippe E. Cervical cancer screening with cervicography and cytology. Eur J Obstet Gynecol Reprod Biol. 1995 Jan;58:33-9. [pmid: 7758643].
Barnes BA. Papanicolaou cervical smears for screening in asymptomatic women. Prim Care. 1981;8:131-40. [pmid: 6911755].
Barnes BA, Barnes AB. Evaluation of surgical therapy by cost-benefit analysis. Surgery. 1977;82:21-33. [pmid: 406685].
Bauer HM, Hildesheim A, Schiffman MH, Glass AG, Rush BB, Scott DR, Cadell DM, Kurman RJ, Manos MM. Determinants of genital human papillomavirus infection in low-risk women in Portland, Oregon. Sex Transm Dis. 1993;20:274-8. [pmid: 8235925].
Bearman DM, MacMillan JP, Creasman WT. Papanicolaou smear history of patients developing cervical cancer: An assessment of screening protocols. Obstet Gynecol. 1987;69:151-5. [pmid: 3808501].
Beeby AR, Keating PJ, Wagstaff TI, Wilson EMJ, Sims PF, Manning PJ, Wadehra V. The quality and accuracy of cervical cytology: A study of five sampling devices in a colposcopy clinic. J Obstet Gynaecol. 1993;13:276-81.
Bergstrom R, Adami HO, Gustafsson L, Ponten J, Sparen P. Detection of preinvasive cancer of the cervix and the subsequent reduction in invasive cancer. J Natl Cancer Inst. 1993;85:1050-7. [pmid: 8515491].
Bethwaite J, Rayner T, Bethwaite P. Economic aspects of screening for cervical cancer in New Zealand. N Z Med J. 1986;99:747-51. [pmid: 3464889].
Bigrigg MA, Codling BW, Pearson P, Read MD, Swingler GR. Colposcopic diagnosis and treatment of cervical dysplasia at a single clinic visit. Experience of low-voltage diathermy loop in 1000 patients. Lancet. 1990;336:229-31. [pmid: 1973781].
Bolick DR, Hellman DJ. Laboratory implementation and efficacy assessment of the ThinPrep cervical cancer screening system. Acta Cytol. 1998;42:209-13. [pmid: 9479342].
Boon ME, de Graaff Guilloud JC. Cost effectiveness of population screening and rescreening for cervical cancer in the Netherlands. Acta Cytol. 1981;25:539-42. [pmid: 6792845].
Boyko EJ. Meta-analysis of Pap test accuracy. Am J Epidemiol. 1996;143:406-7. [pmid: 8633625].
Brown AD, Garber AM. The cost-effectiveness of three new technologies to enhance Pap testing. Chicago, IL: Blue Cross Blue Shield Association Technical Evaluation Center Assessment Program Special Assessment; 1998 April.
Bureau of Labor Statistics. CPI-U. Medicare Services Average Annual Index, Base Period, 1982-84.
Canadian Task Force on the Periodic Health Examination. Canadian guide to clinical preventive health care. Ottawa: Health Canada; 1994.
Cannistra SA, Niloff JM. Cancer of the uterine cervix. N Engl J Med. 1996;334:1030-8. [pmid: 8598842].
Carson HJ, DeMay RM. The mode ages of women with cervical dysplasia. Obstet Gynecol. 1993;82:430-4. [pmid: 8355947].
Carter PM, Coburn TC, Luszczak M. Cost-effectiveness of cervical cytologic examination during pregnancy. J Am Board Fam Pract. 1993;6:537-45. [pmid: 8285092].
Cecchini S, Bonardi R, Mazzotta A, Grazzini G, Iossa A, Ciatto S. Testing cervicography and cervicoscopy as screening tests for cervical cancer. Tumori. 1993;79:22-5. [pmid: 8497916].
Cecchini S, Bonardi R, Iossa A, Zappa M, Ciatto S. Colposcopy as a primary screening test for cervical cancer. Tumori. 1997;83:810-3. [pmid: 9428912].
Centers for Disease Control and Prevention. Premarital sexual experience among adolescent women -- United States, 1970-1988. MMWR. 1991;39:929-32. [pmid: 1898527].
Chesebro MJ, Everett WD. A cost-benefit analysis of colposcopy for cervical squamous intraepithelial lesions found on Papanicolaou smear. Arch Fam Med. 1996;5:576-81. [pmid: 8930229].
Chock C, Irwig I, Berry G, Glasziou P. Comparing dichotomous screening tests when individuals negative on both tests are not verified. J Clin Epidemiol. 1997;50:1211-7. [pmid: 9393377].
Chomet J. Screening for cervical cancer: A new scope for general practitioners? Results of the first year of colposcopy in general practice. BMJ. 1987;294:1326-8. [pmid: 3109641]. [pmcid: 1246491].
Coibion M, Autier P, Vandam P, Delobelle A, Huet F, Hertens D, Vosse M, Andry M, De Sutter P, Heimann R, et al. Is there a role for cervicography in the detection of premalignant lesions of the cervix uteri?. Br J Cancer. 1994;70:125-8. [pmid: 8018522].
Coker AL, Jenkins GR, Busnardo MS, Chambers JC, Levine LZ, Pirisi L. Human papillomaviruses and cervical neoplasia in South Carolina. Cancer Epidemiol Biomarkers Prev. 1993;2:207-12. [pmid: 8391355].
Colgan TJ, Patten SF Jr, Lee JS. A clinical trial of the AutoPap 300 QC system for quality control of cervicovaginal cytology in the clinical laboratory. Acta Cytol. 1995;39:1191-8. [pmid: 7483997].
Cox JT, Schiffman MH, Winzelberg AJ, Patterson JM. An evaluation of human papillomavirus testing as part of referral to colposcopy clinics. Obstet Gynecol. 1992;80(3 Pt 1):389-95. [pmid: 1323087].
Cox JT, Lorincz AT, Schiffman MH, Sherman ME, Cullen A, Kurman RJ. Human papillomavirus testing by hybrid capture appears to be useful in triaging women with a cytologic diagnosis of atypical squamous cells of undetermined significance. Am J Obstet Gynecol. 1995;172:946-54. [pmid: 7892889].
Davis JR, Hindman WM, Paplanus SH, Trego DC, Wiens JL, Suciu TN. Value of duplicate smears in cervical cytology. Acta Cytol. 1981;25:533-8. [pmid: 6945018].
Davison JM, Marty JJ. Detecting premalignant cervical lesions. Contribution of screening colposcopy to cytology. J Reprod Med. 1994;39:388-92. [pmid: 8064706].
Del Priore G, Maag T, Bhattacharya M, Garcia PM, Till M, Lurain JR. The value of cervical cytology in HIV-infected women. Gynecol Oncol. 1995;56:395-8. [pmid: 7705674].
de Villiers EM, Wagner D, Schneider A, Wesch H, Munz F, Miklaw H, zur Hausen H. Human papillomavirus DNA in women without and with cytological abnormalities: Results of a 5-year follow-up study. Gynecol Oncol. 1992;44:33-9. [pmid: 1309717].
DiBonito L, Falconieri G, Tomasic G, Colautti I, Bonifacio D, Dudine S. Cervical cytopathology. An evaluation of its accuracy based on cytohistologic comparison. Cancer. 1993;72:3002-6. [pmid: 8221568].
Dickinson L. Evaluation of the effectiveness of cytologic screening for cervical cancer. 3. Cost-benefit analysis. Mayo Clin Proc. 1972;47:550-5. [pmid: 5049159].
DiSaia P, Creasman W. Clinical gynecologic oncology. St. Louis: Mosby; 1997.
Drummond MF, Richardson WS, O'Brien BJ, Levine M, Heyland D. Users' guides to the medical literature. XIII. How to use an article on economic analysis of clinical practice. A. Are the results of the study valid? For the Evidence-Based Medicine Working Group. JAMA. 1997;277(19):1552-7. [pmid: 9153371].
Duggan MA, Brasher P. Paired comparison of manual and automated Pap test screening using the PAPNET system. Diagn Cytopathol. 1997;17:248-54. [pmid: 9316778].
Eddy DM. Screening for cervical cancer. Ann Intern Med. 1990;113:214-26. [pmid: 2115753].
Eisenberg JN. Clinical economics. A guide to the economic analysis of clinical practices. JAMA. 1989;262:2879-86. [pmid: 2509745].
Fahey MT, Irwig L, Macaskill P. Meta-analysis of Pap test accuracy. Am J Epidemiol. 1995;141:680-9. [pmid: 7702044].
Fahim HI, Faris R, Arab SE, Sammour MB. An epidemiologic study of Papanicolaou smear data at Ain-Shams University hospitals. J Egypt Public Health Assoc. 1991;66:97-111. [pmid: 1800628].
Fahs MC, Mandelblatt J, Schechter C, Muller C. Cost effectiveness of cervical cancer screening for the elderly. Ann Intern Med. 1992;117:520-7. [pmid: 1503355].
Farnsworth A, Chambers FM, Goldschmidt CS. Evaluation of the PAPNET system in a general pathology service. Med J Aust. 1996;165:429-31. [pmid: 8913244].
Feinstein AR. Clinical epidemiology: The architecture of clinical research. Philadelphia: Pennsylvania:W.B. Saunders Company; 1985. p. 434.
Ferenczy A, Robitaille J, Franco E, Arseneau J, Richart RM, Wright TC. Conventional cervical cytologic smears vs. ThinPrep smears. A paired comparison study on cervical cytology. Acta Cytol. 1996;40:1136-42. [pmid: 8960019].
Ferenczy A, Gelfand MM, Franco E, Mansour N. Human papillomavirus infection in postmenopausal women with and without hormone therapy. Obstet Gynecol. 1997;90:7-11. [pmid: 9207803].
Ferris DG, Wright TC, Litaker MS, Richart RM, Lorincz AT, Sun X, Borgatta L, Buck H, Kramer L, Rubin R. Triage of women with ASCUS and LSIL on Pap smear reports: Management by repeat Pap smear, HPV DNA testing, or colposcopy?. J Fam Pract. 1998;46:125-34. [pmid: 9487318].
Fetters MD, Fischer G, Reed BD. Effectiveness of vaginal Papanicolaou smear screening after total hysterectomy for benign disease. JAMA. 1996;275:940-7. [pmid: 8598623].
Figueroa JP, Ward E, Luthi TE, Vermund SH, Brathwaite AR, Burk RD. Prevalence of human papillomavirus among STD clinic attenders in Jamaica: Association of younger age and increased sexual activity. Sex Transm Dis. 1995;22:114-8. [pmid: 7624812].
Food and Drug Administration. Points to consider for cervical cytology devices, Version 7/25/94. Washington, DC: FDA Center for Devices and Radiological Health, Document No. 968; 1994.
Frisch LE, Milner FH, Ferris DG. Naked-eye inspection of the cervix after acetic acid application may improve the predictive value of negative cytologic screening. J Fam Pract. 1994;39:457-60. [pmid: 7755697].
Fung Kee Fung M, Senterman M, Eid P, Faught W, Mikhael NZ, Wong PT. Comparison of Fourier-transform infrared spectroscopic screening of exfoliated cervical cells with standard Papanicolaou screening. Gynecol Oncol. 1997;66:10-5. [pmid: 9234913].
Garutti P, Immovilli S, Chiari U, Segala V, Mollica G. Cervical screening for detection of cervical HPV. Cervix Lower Female Genital Tract. 1994;12:31-4.
Germain M, Heaton R, Erickson D, Henry M, Nash J, O'Connor D. A comparison of the three most common Papanicolaou smear collection techniques. Obstet Gynecol. 1994;84:168-73. [pmid: 8041524].
Giles JA, Hudson E, Crow J, Williams D, Walker P. Colposcopic assessment of the accuracy of cervical cytology screening. BMJ. 1988;296:1099-102. [pmid: 3132225].
Giles JA, Deery A, Crow J, Walker P. The accuracy of repeat cytology in women with mildly dyskaryotic smears. Br J Obstet Gynaecol. 1989;96:1067-70. [pmid: 2804009].
Glenthoj A, Rank F, Peen U, Bostofte E. Diagnostic efficiency of brush cytology from the uterine cervix. In: Gierttler K, Fuchter G, Witte S, editors. New frontiers in cytology. Berlin: Springer; 1988. p. 421-4.
Gold MR, Siegel JE, Russell LB, Weinstein MC, editors. Cost-effectiveness in health and medicine. New York: Oxford University Press; 1996.
Gonzalez D, Hernandez E, Anderson L, Heller P, Atkinson BF. Clinical significance of a cervical cytologic diagnosis of atypical squamous cells of undetermined significance. Favoring a reactive process or low grade squamous intraepithelial lesion. J Reprod Med. 1996;41:719-23. [pmid: 9026557].
Green M, editor. Bright futures: Guidelines for health supervision of infants, children and adolescents. Arlington, VA: National Center for Education in Maternal and Child Health; 1994.
Gundersen JH, Schauberger CW, Rowe NR. The Papanicolaou smear and the cervigram. A preliminary report. J Reprod Med. 1988;33:46-8.
Gustafsson L, Adami HO. Optimization of cervical cancer screening. Cancer Causes Control. 1992;3:125-36. [pmid: 1562702].
Gustafsson L, Ponten J, Bergstrom R, Adami HO. International incidence rates of invasive cervical cancer before cytological screening. Int J Cancer. 1997;71:159-65. [pmid: 9139836].
Gustafsson L, Ponten J, Zack M, Adami HO. International incidence rates of invasive cervical cancer after introduction of cytological screening. Cancer Causes Control. 1997;8:755-63. [pmid: 9328198].
Haddad NG, Hussein I, Livingstone JR, Smart GE. Colposcopy in teenagers. BMJ. 1988;297.
Halford JA, Wright RG, Ditchmen EJ. Quality assurance in cervical cytology screening. Comparison of rapid rescreening and the PAPNET Testing System. Acta Cytol. 1997;41:79-81. [pmid: 9022730].
Hasselblad V, Hedges L. Meta-analysis of diagnostic tests. Psychometric Bull. 1995;11:167-78.
Hellberg D, Axelsson O, Gad A, Nilsson S. Conservative management of the abnormal smear during pregnancy. A long-term follow-up. Acta Obstet Gynecol Scand. 1987;66(3):195-9. [pmid: 3661125].
Helmerhorst TJ, Dijkhuizen GH, Calame JJ, Kwikkel HJ, Stolk JG. The accuracy of colposcopically directed biopsy in diagnosis of CIN. Eur J Obstet Gynecol Reprod Biol. 1987;24:221-9. [pmid: 3493927].
Herrero R. Epidemiology of cervical cancer. J Natl Cancer Inst Monogr. 1996;21:1-6. [pmid: 9023822].
Herrington CS, Evans MF, Hallam NF, Charnock FM, Gray W, McGee JD. Human Papillomavirus status in the prediction of high-grade cervical intraepithelial neoplasia in patients with persistent low-grade cervical cytological abnormalities. Br J Cancer. 1995;71:206-9. [pmid: 7819041].
Hildesheim A, Gravitt P, Schiffman MH, Kurman RJ, Barnes W, Jones S, Tchabo JG, Brinton LA, Copeland C, Epp J, et al. Determinants of genital human papillomavirus infection in low-income women in Washington, DC. Sex Transm Dis. 1993;20:279-85. [pmid: 8235926].
Hildesheim A, Schiffman MH, Gravitt PE, Glass AG, Greer CE, Zhang T, Scott DR, Rush BB, Lawler P, Sherman ME, et al. Persistence of type-specific human papillomavirus infection among cytologically normal women. J Infect Dis. 1994;169:235-40. [pmid: 8106758].
Hirschowitz L, Raffle AE, Mackenzie EF, Hughes AO. Long term follow up of women with borderline cervical smear test results: Effects of age and viral infection on progression to high grade dyskaryosis. BMJ. 1992;304:1209-12. [pmid: 1325232]. [pmcid: 1881787].
Ho GYF, Bierman R, Beardsley L, Chang CJ, Burk RD. Natural history of cervicovaginal papillomavirus infection in young women. N Engl J Med. 1998;338:423-8. [pmid: 9459645].
Hockstad RL. A comparison of simultaneous cervical cytology, HPV testing, and colposcopy. Fam Pract Res J. 1992;12:53-60. [pmid: 1312758].
IARC Working Group on Evaluation of Cervical Cytology Cancer Screening Programmes. Screening for squamous cervical cancer: Duration of low risk after negative results of cervical cytology and its implication for screening policies. BMJ. 1986;293:659-64. [pmid: 3092971]. [pmcid: 1341512].
Inhorn SL, Wilbur D, Zahniser D, Linder J. Validation of the ThinPrep Pap test for cervical cancer diagnosis. J. Lower Genital Tract Dis 1998; in press.
Intersociety Working Group for Cytology Technologies. Proposed guidelines for secondary screening (rescreening) instruments for gynecologic cytology. Acta Cytol. 1998;42:273-6. [pmid: 9479352].
Janerich DT, Hadjimichael O, Schwartz PE, Lowell DM, Meigs JW, Merino MJ, Flannery JT, Polednak AP. The screening histories of women with invasive cervical cancer, Connecticut. Am J Public Health. 1995;85:791-4. [pmid: 7762711]. [pmcid: 1615485].
Jenny J, Isenegger I, Boon ME, Husain OA. Consistency of a double PAPNET scan of cervical smears. Acta Cytol. 1997;41:82-7. [pmid: 9022731].
Johansen P, Arffmann E, Pallesen G. Evaluation of smears obtained by cervical scraping and an endocervical swab in the diagnosis of neoplastic disease of the uterine cervix. Acta Obstet Gynecol Scand. 1979;58:265-70. [pmid: 484218].
Johnson N, Sutton J, Thornton JG, Lilford RJ, Johnson VA, Peel KR. Decision analysis for best management of mildly dyskaryotic smear. Lancet. 1993;342(8863):91-6. [pmid: 8100917].
Jones BA, Novis DA. Cervical biopsy-cytology correlation: A College of American Pathologists Q-Probes study of 22,439 correlations in 348 laboratories. Arch Pathol Lab Med. 1996;120:523-31. [pmid: 8651852].
Jones DE, Creasman WT, Dombroski RA, Lentz SS, Waeltz JL. Evaluation of the atypical Pap smear. Am J Obstet Gynecol. 1987;157:544-9. [pmid: 3631155].
Jones MH, Jenkins D, Cuzick J, Wolfendale MR, Jones JJ, Balogun-Lynch C, Usherwood MM, Singer A. Mild cervical dyskaryosis: Safety of cytological surveillance. Lancet. 1992;339:1440-3. [pmid: 1351129].
Jones WB, Shingleton HM, Russell A, Chmiel JS, Fremgen AM, Clive RE, Zuber-Ocwieja KE, Winchester DP. Patterns of care for invasive cervical cancer: Results of a national survey of 1984 and 1990. Cancer. 1995;(suppl);76:1934-47. [pmid: 8634985].
Kataja V, Syrjanen K, Mantyjarvi R, Vayrynen M, Syrjanen S, Saarikoski S, Parkkinen S, Yliskoski M, Salonen JT, Castren O. Prospective follow-up of cervical HPV infections: Life table analysis of histopathological, cytological, and colposcopic data. Eur J Epidemiol. 1989;5:1-7. [pmid: 2540024].
Kataja V, Syrjanen K, Syrjanen S, Mantyjarvi R, Yliskoski M, Saarkoski S, Salonen JT. Prospective follow-up of genital HPV infections:survival analysis of the HPV typing data. Eur J Epidemiol. 1990;6:9-14. [pmid: 2160892].
Kaufman RH, Adam E, Icenogle J, Reeves WC. Human papillomavirus testing as triage for atypical squamous cells of undetermined significance and low-grade squamous intraepithelial lesions: Sensitivity, specificity, and cost-effectiveness. Am J Obstet Gynecol. 1997;177:930-6. [pmid: 9369847].
Kaufman RH, Schreiber K, Carter T. Analysis of atypical squamous (glandular) cells of undetermined significance smears by neural network-directed review. Obstet Gynecol. 1998;91:556-60. [pmid: 9540940].
Kealy WF. Correlation of cervical cytodiagnosis and histopathology -- an exercise in quality control. Ir J Med Sci. 1986;155:381-8. [pmid: 3804671].
Kiviat N. Natural history of cervical neoplasia: Overview and update. Am J Obstet Gynecol. 1996;175:1099-104. [pmid: 8885793].
Kjerulff KH, Guzinski GM, Langenberg PW, Stolley PD, Moye NEA, Kazandjian VA. Hysterectomy and race. Obstet Gynecol. 1993;82:757-64. [pmid: 8414322].
Koonings PP, Dickinson K, d'Ablaing G 3d, Schlaerth JB. A randomized clinical trial comparing the Cytobrush and cotton swab for Papanicolaou smears. Obstet Gynecol. 1992;80:241-5. [pmid: 1635737].
Koopmanschap MA, van Oortmarssen GJ, van Agt HM, van Ballegooijen M, Habbema JD, Lubbe KT. Cervical-cancer screening: Attendance and cost-effectiveness. Int J Cancer. 1990;45:410-5. [pmid: 2106499].
Korach J, Menczer J, Lusky A. A comparison between referral and hospital cervical cytology laboratory reports. Isr J Med Sci. 1995;31:352-5. [pmid: 7607854].
Korn AP, Autry M, DeRemer PA, Tan W. Sensitivity of the Papanicolaou smear in human immunodeficiency virus-infected women. Obstet Gynecol. 1994;83:401-4. [pmid: 8127533].
Koutsky L. Epidemiology of genital human papillomavirus infection. Am J Med. 1997;102(5A):3-8. [pmid: 9217656].
Koutsky LA, Holmes KK, Critchlow CW, Stevens CE, Paavonen J, Beckmann AM, DeRouen TA, Galloway DA, Vernon D, Kiviat NB. A cohort study of the risk of cervical intraepithelial neoplasia grade 2 or 3 in relation to papillomavirus infection. N Engl J Med. 1992;327:1272-8. [pmid: 1328880].
Kwikkel HJ, Quaak MJ, de With C. Predictive value of the abnormal Pap smear: A retrospective analysis of error rates. Eur J Obstet Gynecol Reprod Biol. 1986;21:101-12. [pmid: 3956830].
Landis SH, Murray T, Bolden S, Wingo PA. Cancer statistics, 1998. CA Cancer J Clin. 1998;48:6-29. [pmid: 9449931].
Landoni F, Maneo A, Columbo A, Placa F, Milani R, Perego P, Favini P, Fern L, Mangioni C. Randomised study of radical surgery versus radiotherapy for stage Ib-IIa cervical cancer. Lancet. 1997;350:532-40.
Lederer H, Lambourne A. The results of screening by cervical cytology and of histological examination of gynaecological operation specimens. J Obstet Gynaecol Br Commonw. 1973;80:67-71. [pmid: 4696563].
Lee JSJ, Kuan L, Oh S, Patten FW, Wilbur DC. A feasibility study of the AutoPap System location-guided screening. Acta Cytol. 1998;42:221-6. [pmid: 9479344].
Lee KR, Ashfaq R, Birdsong GG, Corkill ME, McIntosh KM, Inhorn SL. Comparison of conventional Papanicolaou smears and a fluid-based, thin-layer system for cervical cancer screening. Obstet Gynecol. 1997;90:278-84. [pmid: 9241308].
Lepine LA, Hillis SD, Marchbanks PA, Koonin LM, Morrow B, Kieke BA, Wilcox LS. Hysterectomy surveillance -- United States, 1980-1993. CDC Surveillance Summaries, August 8, 1997. MMWR. 1997;46(No. SS-4):1-14.
Lozowski MS, Mishriki Y, Talebian F, Solitare G. The combined use of cytology and colposcopy in enhancing diagnostic accuracy in preclinical lesions of the uterine cervix. Acta Cytol. 1982;26:285-91. [pmid: 6954809].
Luce BR. The implications of cost-effectiveness analysis of medical technology. Background paper No. 2: Case studies of medical technologies. case study No. 7: Allocating costs and benefits in disease prevention programs: an application to cervical cancer screening. U.S. Congress, Office of Technology Assessment; 1981 Jun. 43 p.
MacCormac L, Lew W, King G, Allen PW. Gynaecological cytology screening in South Australia: A 23-year experience. Med J Aust. 1988;149:530-6. [pmid: 3185322].
Maggi R, Zannoni E, Giorda G, Biraghi P, Sideri M. Comparison of repeat smear, colposcopy, and colposcopically directed biopsy in the evaluation of the mildly abnormal smear. Gynecol Oncol. 1989;35:294-6. [pmid: 2599462].
Mandelblatt JS, Fahs MC. The cost-effectiveness of cervical cancer screening for low-income elderly women. JAMA. 1988;259:2409-13. [pmid: 3127608].
Mandelblatt J, Freeman H, Winczewski D, Cagney K, Williams S, Trowers R, Tang J, Gold K, Lin TH, Kerner J. The costs and effects of cervical and breast cancer screening in a public hospital emergency room. The Cancer Control Center of Harlem. Am J Public Health. 1997;87(7):1182-9. [pmid: 9240110].
Mango LJ, Radensky PW. Interactive neural network-assisted screening. A clinical assessment. Acta Cytol. 1998;42:233-45. [pmid: 9479346].
Mango LJ, Valente PT. Neural network-assisted analysis and microscopic rescreening in presumed negative cervical cytologic smears. A comparison. Acta Cytol. 1998;42:227-32. [pmid: 9479345].
Mann W, Lonky N, Massad S, Scotti R, Blanco J, Vasilev S. Papanicolaou smear screening augmented by a magnified chemiluminescent exam. Int J Gynaecol Obstet. 1993;43:289-96. [pmid: 7907040].
Martin L, Calle E, Wingo P, Heath C. Comparison of mammography and Pap test use from the 1987 and 1992 National Health Interview Surveys: Are we closing the gaps?. Am J Prev Med. 1996;12:82-90.
Matsunaga G, Tsuji I, Sato S, Fukao A, Hisamichi S, Yajima A. Cost-effectiveness analysis of mass screening for cervical cancer in Japan. J Epidemiol. 1997;7:135-41. [pmid: 9337511].
Mayeaux EJ Jr, Harper MB, Abreo F, Pope JB, Phillips GS. A comparison of the reliability of repeat cervical smears and colposcopy in patients with abnormal cervical cytology. J Fam Pract. 1995;40:57-62. [pmid: 7807039].
Melnikow J, Nuovo J, Paliescheskey M. Management choices for patients with squamous atypia on Papanicolaou smear. A toss up?. Med Care. 1996;34:336-47. [pmid: 8606558].
Melnikow J, Nuovo J, Paliescheskey M, Stewart GK, Howell L, Green W. Detection of high-grade cervical dysplasia: Impact of age and Bethesda System terminology. Diagn Cytopathol. 1997;17:321-5. [pmid: 9360043].
Miller BA, Kolonel LN, Bernstein L, Young JL, Swanson GM, West D, Key CR, Liff JM, Glover CS, Alexander GA et al. Racial/ethnic patterns of cancer in the United States 1988-1992. Bethesda, MD: U.S. Department of Health and Human Services, National Institutes of Health; 1998.
Miller DK, Homan SM. Determining transition probabilities: Confusion and suggestions. Med Decis Making. 1994;14:52-8. [pmid: 8152357].
Miller WC. Bias in discrepant analysis: When two wrongs don't make a right. J Clin Epidemiol. 1998;51:219-31. [pmid: 9495687].
Mitchell H, Medley G. Detection of unsuspected abnormalities by PAPNET-assisted review. Acta Cytol. 1998;42:260-4. [pmid: 9479349].
Mitchell M, Tortolero-Luna G, Wright T, Sarkar A, Richards-Kortum R, Hong WK, Schottenfeld D. Cervical human papillomavirus infection and intraepithelial neoplasia: A review. J Natl Cancer Inst Mongr. 1996;21:17-25.
Morrison BW, Erickson ER, Doshi N, Russo JF. The significance of atypical cervical smears. J Reprod Med. 1988;33:809-12. [pmid: 3193410].
Morrison EA, Goldberg GL, Hagan RJ, Kadish AS, Burk RD. Self-administered home cervicovaginal lavage: A novel tool for the clinical-epidemiologic investigation of genital human Papillomavirus infections. Am J Obstet Gynecol. 1992;167:104-7. [pmid: 1332474].
Moscicki AB, Shiboski S, Broering J, Powell K, Clayton L, Jay N, Darragh TM, Brescia R, Kanowitz S, Miller SB, et al. The natural history of human papillomavirus infection as measured by repeated DNA testing in adolescent and young women. J Pediatr. 1998;132:277-84. [pmid: 9506641].
Muller C, Mandelblatt J, Schechter CB, Power EJ, Duffy BM, Wagner JL. Costs and effectiveness of cervical cancer screening in elderly women. Washington, DC: US Congress, Office of Technology Assessment; 1990.
Munoz N, Kato I, Bosch FX, Eluf-Neto J, SanJose SD, Ascunce N, Gili M, Izarzugaza I, Viladiu P, Tormo M-J, et al. Risk factors for HPV DNA detection in middle-aged women. Sex Transm Dis 1996:504-10.
Myers ER, Thompson JW, Simpson K. Cost-effectiveness of mandatory compared with voluntary screening for human immunodeficiency virus in pregnancy. Obstet Gynecol. 1998;91:174-81. [pmid: 9469271].
Naslund I, Auer G, Pettersson F, Sjovall K. Evaluation of the pulse wash sampling technique for screening of uterine cervical carcinoma. Acta Radiol Oncol. 1986;25:131-6. [pmid: 3012957].
National Cancer Institute Workshop. The Bethesda System for reporting cervical/vaginal cytologic diagnoses: Revised after the second National Cancer Institute Workshop, April 29-30, 1991. Acta Cytol. 1993;37:115-24. [pmid: 8465628].
National Center for Health Statistics. http://www.cdc.gov/nchswww/daa/gm291_1.pdf.
Noller KL. Incident and demographic trends in cervical neoplasia. Am J Obstet Gynecol. 1996;175(4 Pt 2):1088-90. [pmid: 8885791].
Nyirjesy I. Atypical or suspicious cervical smears. An aggressive diagnostic approach. JAMA. 1972;222:691-3. [pmid: 4677898].
O'Brien BJ, Heyland D, Richardson WS, Levine M; Drummond MF. Users' guides to the medical literature. XIII. How to use an article on economic analysis of clinical practice. B. What are the results and will they help me in caring for my patients? For the Evidence-Based Medicine Working Group. JAMA. 1997;277:1802-6. [pmid: 9178794].
Okagaki T, Zelterman D. Information, discrimination and divergence in cytology. II. Total discrimination as a measure of performance. Acta Cytol. 1991;35:25-9. [pmid: 1994629].
O'Leary TJ, Tellado M, Buckner SB, Ali IS, Stevens A, Ollayos CW. PAPNET-assisted rescreening of cervical smears. Cost and accuracy compared with a 100% manual rescreening strategy. JAMA. 1998;279:235-7. [pmid: 9438746].
Oyer R, Hanjani P. Endocervical curettage: Does it contribute to the management of patients with abnormal cervical cytology?. Gynecol Oncol. 1986;25:204-11. [pmid: 3758830].
Pang JC, Hsu C, Kwan-Chau KM. Cytology and colposcopy in the diagnosis of cervical neoplasia. Gynecol Oncol. 1977;5:134-41. [pmid: 881125].
Parham DM, Wiredu EK, Hussein KA. The cytological prediction of cervical intraepithelial neoplasia in colposcopically directed biopsies. Cytopathology. 1991;2:285-90. [pmid: 1801949].
Parker A, Ueki M. A comparison of preoperative exfoliative cervical cytology with subsequent histology. N Z Med J. 1986;99:414-6. [pmid: 3461355].
Parkin DM. The epidemiological basis for evaluating screening policies. New developments in cervical cancer screening and prevention. Franco E and Monsonego J, editors. Oxford, England: Blackwell Science; 1997.
Paskett ED, Rimer BK. Psychosocial effects of abnormal Pap tests and mammograms: A review. J Women's Health. 1995;4:73-81.
Paskett ED, Carter WB, Chu J, White E. Compliance behavior in women with abnormal Pap smears. Developing and testing a decision model. Med Care. 1990;28:643-56. [pmid: 2366603].
Patten SF Jr, Lee JSJ, Wilbur DC, Bonfiglio TA, Colgan TJ, Richart RM, Cramer H, Moinuddin S. The AutoPap 300 QC System multicenter clinical trials for use in quality control rescreening of cervical smears. I. A prospetive intended use study. Cancer. 1997a;81:337-42. [pmid: 9438458].
Patten SF Jr, Lee JSJ, Wilbur DC, Bonfiglio TA, Colgan TJ, Richart RM, Cramer H, Moinuddin S. The AutoPap 300 QC System multicenter clinical trials for use in quality control rescreening of cervical smears. II. Prospective and archival sensitivity studies. Cancer. 1997b;81:343-7. [pmid: 9438459].
Prabhakar AK. Cervical cancer in India -- strategy for control. Indian J Cancer. 1992;29:104-13. [pmid: 1292993].
Pretorius R, Semrad N, Watring W, Fotheringham N. Presentation of cervical cancer. Gynecol Oncol. 1991;2:48-53.
Prorok PC. Mathematical models and natural history in cervical cancer screening. Screening for cancer of the uterine cervix. Hakama M, Miller AB, Day NE, editors. Lyon (France): International Agency for Research on Cancer 1986;76:185-98.
Raab SS. The cost-effectiveness of cervical-vaginal rescreening. Am J Clin Pathol. 1997;108:525-36. [pmid: 9353091].
Radensky PW, Mango LJ. Interactive neural network-assisted screening. An economic assessment. Acta Cytol. 1998;42:246-52. [pmid: 9479347].
Ramirez EJ, Hernandez E, Miyazawa K. Cervical conization findings in women with dysplastic cervical cytology and normal colposcopy. J Reprod Med. 1990;35:359-61. [pmid: 2352226].
Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299:926-30. [pmid: 692598].
Rasbridge SA, Nayagam M. Discordance between cytologic and histologic reports in cervical intraepithelial neoplasia. Results of a one-year audit. Acta Cytol. 1995;39:648-53. [pmid: 7631537].
Reagan JW, Fu YS. Histologic types and prognosis of cancers of the uterine cervix. Int J Radiat Oncol Biol Phys. 1979;5:1015-20. [pmid: 229090].
Richart RM. Cervical intraepithelial neoplasia. In: Pathology Annual. East Norwalk, CT: Appleton-Century-Crofts; 1973. p. 301-23.
Richart RM, Barron BA. Screening strategies for cervical cancer and cervical intraepithelial neoplasia. Cancer. 1981;47(5 Suppl):1176-81. [pmid: 7237375].
Ries LAG, Kosary CL, Hankey BF, Miller BA, Harras A, Edwards BK. SEER cancer statistics review, 1973-1994. Bethesda, MD: National Cancer Institute; 1997. NIH Pub No. 97-2789.
Ries LAG, Kosary CL, Hankey BF, Miller BA, Edwards BK, editors. SEER cancer statistics review, 1973-1995. Bethesda, MD: National Cancer Institute; 1998.
Ritter DB, Kadish AS, Vermund SH, Romney SL, Villari D, Burk RD. Detection of human papillomavirus deoxyribonucleic acid in exfoliated cervicovaginal cells as a predictor of cervical neoplasia in a high-risk population. Am J Obstet Gynecol. 1988;159:1517-25. [pmid: 2849881].
Roberts JM, Gurley AM, Thurloe JK, Bowditch R, Laverty CRA. Evaluation of the ThinPrep Pap test as an adjunct to the conventional Pap smear. Med J Aust. 1997;167:466-9. [pmid: 9397059].
Ronco G, Montanari G, Aimone V, Parisio F, Segnan N, Valle A, Volante R. Estimating the sensitivity of cervical cytology: Errors of interpretation and test limitations. Cytopathology. 1996;7:151-8. [pmid: 8782987].
Russell AH, Shingleton HM, Jones WB, Fremgen A, Winchester DP, Clive R, Chmiel JS. Diagnostic assessements in patients with invasive cancer of the cervix: A national patterns of care study of the American College of Surgeons. Gynecol Oncol. 1996;63:159-65. [pmid: 8910621].
Schechter CB. Cost-effectiveness of rescreening conventionally prepared cervical smears by PAPNET testing. Acta Cytol. 1996;40:1272-82. [pmid: 8960040].
Schiffman MH, Bauer HM, Hoover RN, Glass AG, Cadell DM, Rush BB, Scott DR, Sherman ME, Kurman RJ, Wacholder S, et al. Epidemiologic evidence showing that human papillomavirus infection causes most cervical intraepithelial neoplasia. J Natl Cancer Inst. 1993;85:958-64. [pmid: 8388478].
Schwartz PE, Hadjimichael O, Lowell DM, Merino MJ, Janerich D. Rapidly progressive cervical cancer: The Connecticut experience. Am J Obstet Gynecol. 1996;175:1105-9. [pmid: 8885794].
Schweitzer SO. Cost effectiveness of early detection of disease. Health Serv Res. 1974;9:22-32. [pmid: 4829491]. [pmcid: 1071777].
Schweitzer SO, Luce BR. A cost-effective approach to cervical cancer detection: Final report and executive summary. Rockville, MD: Agency for Health Care Policy and Research (formerly the National Center for Health Services Research); 1978 Apr. National Center for Health Services Research Publication 79-82. 86 p. Available from: NTIS, Springfield, VA; PB292685.
Sherlaw-Johnson C, Gallivan S, Jenkins D, Jones MH. Cytological screening and management of abnormalities in prevention of cervical cancer: An overview with stochastic modelling. J Clin Pathol. 1994;47:430-5. [pmid: 8027396]. [pmcid: 502020].
Sherman ME, Kelly D. High-grade squamous intraepithelial lesions and invasive carcinoma following the report of three negative Papanicolaou smears: Screening failures or rapid progression?. Mod Pathol. 1992;5:337-42. [pmid: 1495939].
Sherman ME, Mendoza M, Lee KR, Ashfaq R, Birdsong, Corkill ME, McIntosh KM, Inhorn SL, Baber G, Barber C, Stoler M. Peformance of liquid-based, thin-layer cervical cytology: Correlation with reference diagnosis and HPC testing. Mod Pathol, in press.
Shingleton HM, Patrick RL, Johnston WW, Smith RA. The current status of the Papanicolaou smear. CA Cancer J Clin. 1995;45:305-20. [pmid: 7656133].
Siegel JE, Weinstein MC, Russell LB, Gold MR. For the Panel on Cost-Effectiveness in Health and Medicine. Recommendations for reporting cost-effectiveness analyses. JAMA. 1996;276:1339-41. [pmid: 8861994].
Singh P, Pang M, Ratnam SS. Selective cervical conization following colposcopy: A critical evaluation of 107 cases. Singapore Med J. 1985;26:289-94. [pmid: 4048991].
Skehan M, Soutter WP, Lim K, Krausz T, Pryse-Davies J. Reliability of colposcopy and directed punch biopsy. Br J Obstet Gynaecol. 1990;97:811-6. [pmid: 2242366].
Slawson DC, Bennett JH, Herman JM. Are Papanicolaou smears enough? Acetic acid washes of the cervix as adjunctive therapy: A HARNET study. Harrisburg Area Research Network. J Fam Pract. 1992;35:271-7. [pmid: 1517723].
Slawson DC, Bennett JH, Simon LJ, Herman JM. Should all women with cervical atypia be referred for colposcopy: A HARNET study. J Fam Pract. 1994;38:387-92. [pmid: 8163964].
Smith EM, Johnson SR, Figuerres EJ, Mendoza M, Fedderson D, Haugen TH, Tureck LP. The frequency of human papillomavirus detection in postmenopausal women on hormone replacement therapy. Gynecol Oncol. 1997;65:441-6. [pmid: 9190973].
Smith JJ, Cowan L, Hemstreet G 3d, Smith ML, Pippitt CH Jr, Doggett R, McGill L. Automated quantitative fluorescent image analysis of cervical cytology. Gynecol Oncol. 1987;28:241-54. [pmid: 3678975].
Sonnenberg FA, Beck JR. Markov models in medical decision making: A practical guide. Med Decis Making. 1993;13:322-38. [pmid: 8246705].
Soost HJ, Lange HJ, Lehmacher W, Ruffing-Kullmann B. The validation of cervical cytology. Sensitivity, specificity and predictive values. Acta Cytol. 1991;35:8-14. [pmid: 1994641].
Soutter WP, Wisdom S, Brough AK, Monaghan JM. Should patients with mild atypia in a cervical smear be referred for colposcopy?. Br J Obstet Gynaecol. 1986;93:70-4. [pmid: 3942709].
Spinillo A, Capuzzo E, Tenti P, De Santolo A, Piazzi G, Iasci A. Adequacy of screening cervical cytology among human immunodeficiency virus-seropositive women. Gynecol Oncol. 1998;69:109-13. [pmid: 9600816].
Spitzer M, Krumholz BA, Chernys AE, Seltzer V, Lightman AR. Comparative utility of repeat Papanicolaou smears, cervicography, and colposcopy in the evaluation of atypical Papanicolaou smears. Obstet Gynecol. 1987;69:731-5. [pmid: 3106869].
Stafl A. Cervicography: A new method for cervical cancer detection. Am J Obstet Gynecol. 1981;139(7):815-25. [pmid: 7211987].
Stevens MW, Milne AJ, James KA, Brancheau D, Ellison D, Kuan L. Effectiveness of automated cervical cytology rescreening using the AutoPap 300 QC System. Diagn Cytopathol. 1997;16:505-12. [pmid: 9181316].
Swets, JA. Measuring the accuracy of diagnostic systems. Science. 1988;240:1285-93. [pmid: 3287615].
Syrjanen KJ, Mantyjarvi R, Vayrynen M, Yliskoski M, Syrjanen SM, Saarikoski S, Nurmi T, Parkkinen S, Castren O. Cervical smears in assessment of the natural history of human papillomavirus infections in prospectively followed women. Acta Cytol. 1987;31:855-65. [pmid: 2827414].
Syrjanen K, Kataja V, Ykliskoski M, Chang F, Syrjanen S, Saarikoski S. Natural history of cervical human papillomavirus lesions does not substantiate the biologic relevance of the Bethesda System. Obstet Gynecol. 1992;79:675-82. [pmid: 1314359].
Tait IA, Alawattegama AB, Rees E. Screening for cervical dysplasia in department of genitourinary medicine. Genitourin Med. 1988;64:255-8. [pmid: 3169756].
Tawa K, Forsythe A, Cove JK, Saltz A, Peters HW, Watring WG. A comparison of the Papanicolaou smear and the cervigram: Sensitivity, specificity, and cost analysis. Obstet Gynecol. 1988;71:229-35. [pmid: 3336558].
Tay SK, Jenkins D, Singer A. Management of squamous atypia (borderline nuclear abnormalities): Repeat cytology or colposcopy?. Aust N Z J Obstet Gynaecol. 1987;27:140-1. [pmid: 2823785].
U.S. Congress Office of Technology Assessment. Allocating costs and benefits in disease prevention programs: An application to cervical cancer screening. Washington, DC: U.S. Government Printing Office; 1981.
U.S. Congress Office of Technology Assessment. The costs and effectiveness of cervical cancer screening in elderly women. OTA-BP-H-65. Washington, DC: U.S. Government Printing Office; 1990 Feb.
U.S. Preventive Services Task Force. Guide to clinical preventive services. Baltimore: Williams & Wilkins; 1996.
Upadhyay SN, Jha RS, Sinha TK, Mishra NK. Accuracy of cytology in screening for cervical cancer. Indian J Med Res. 1984;80:457-62. [pmid: 6532957].
van Ballegooijen M, Habbema JD, van Oortmarssen GJ, Koopmanschap MA, Lubbe JT, van Agt HM. Preventive Pap-smears: Balancing costs, risks and benefits. Br J Cancer. 1992;65:930-3. [pmid: 1616867].
van Ballegooijen M, van den Akker-van Marle ME, Warmerdam PG, Meijer CJ, Walboomers JM, Habbema JD. Present evidence on the value of HPV testing for cervical cancer screening: A model-based exploration of the (cost-)effectiveness. Br J Cancer. 1997;76:651-7. [pmid: 9303366].
van Nagell JR Jr, Dudik LM, Frank AL, Allen DT, Leigh JP, Engelberg J. Cervical cancer. South Med J. 1987;80:75-81. [pmid: 3099398].
van Oortmarssen G, Habbema J. Epidemiological evidence for age-dependent regression of pre-invasive cervical cancer. Br J Cancer. 1991;64:559-65. [pmid: 1911199].
van Oortmarssen GJ, Habbema JDF. Duration of preclinical cervical cancer and reduction in incidence of invasive cancer following negative pap smears. Int J Epidemiol. 1995;24:300-7. [pmid: 7635589].
van Oortmarssen GJ, Habbema JD, van Ballegooijen M. Predicting mortality from cervical cancer after negative smear test results. BMJ. 1992;305:449-51. [pmid: 1392957]. [pmcid: 1882551].
Veljovich DS, Stoler MH, Anderson WA, Covell JL, Rice LW. Atypical glandular cells of undetermined significance: A five-year retrospective histopathological study. Am J Obstet Gynecol. 1998;179(2):382-90. [pmid: 9731842].
Walker EM, Dodgson J, Duncan ID. Does mild atypia on a cervical smear warrant further investigation?. Lancet. 1986;2:672-3. [pmid: 2876144].
Waugh N, Robertson A. Costs and benefits of cervical screening. II. Is it worthwhile reducing the screening interval from 5 to 3 years?. Cytopathology. 1996;7:241-8. [pmid: 8853970].
Waugh N, Smith I, Robertson A, Reid GS, Halkerston R, Grant A. Costs and benefits of cervical screening. I. The costs of the cervical screening programme. Cytopathology. 1996a;7:231-40. [pmid: 8853969].
Waugh N, Smith I, Robertson A, Reid GS, Halkerston R, Grant A. Costs and benefits of cervical screening. III. Cost/benefit analysis of a call of previously unscreened women. Cytopathology. 1996b;7:249-55. [pmid: 8853971].
Weintraub J, Morabia A. Efficacy of the ThinPrep Pap test for the cytological detection of cervical cancer precursors in a low risk outpatient population: A large-scale investigator sponsored prospective study. Unpublished manuscript.
Wetrich DW. An analysis of the factors involved in the colposcopic evaluation of 2194 patients with abnormal Papanicolaou smears. Am J Obstet Gynecol. 1986;154:1339-49. [pmid: 3717244].
Wheeler CM, Parmenter CA, Hunt WC, Becker TM, Greer CE, Hildesheim A, Manos M. Determinants of genital human papillomavirus infection among cytologically normal women attending the University of New Mexico Student Health Center. Sex Transm Dis. 1993;20:286-9. [pmid: 8235927].
Wheelock JB, Kaminski PF. Value of repeat cytology at the time of colposcopy for the evaluation of cervical intraepithelial neoplasia on Papanicolaou smears. J Reprod Med. 1989;34:815-7. [pmid: 2795564].
Wilbur DC, Bonfiglio TA, Rutkowski MA, Atkison KM, Richart RM, Lee JS, Patten SF Jr. Sensitivity of the AutoPap 300 QC System for cervical cytologic abnormalities. Biopsy data confirmation. Acta Cytol. 1996;40:127-32. [pmid: 8604565].
Wilbur DC, Prey MU, Miller WM, Pawlick GF, Colgan TJ. The AutoPap System for primary screening in cervical cytology. Comparing the results of a prospective, intended-use study with routine manual practice. Acta Cytol. 1998;42:214-20. [pmid: 9479343].
Wilson S, Woodman C. Assessing the effectiveness of cervical screening. Clin Obset Gynecol. 1995;38:577-84.
Woolf SH. An organized analytic framework for practice guideline development: Using the analytic logic as a guide for reviewing evidence, developing recommendations, and explaining the rationale. In: McCormick KA, Moore SR, Siegel RA, editors. Clinical practice guideline development: methodology perspectives. Rockville, MD: Agency for Health Care Policy and Research; 1994 Nov. AHCPR Pub. No. 95-0009.
Womeodu RJ, Bailey JE. Barriers to cancer screening. Med Clin North Am. 1996;80:115-33. [pmid: 8569291].
Wright TC Jr, Ellerbrock TV, Chiasson MA, Van Devanter N, Sun XW. Cervical intraepithelial neoplasia in women infected with human immunodeficiency virus: Prevalence, risk factors, and validity of Papanicolaou smears. New York Cervical Disease Study. Obstet Gynecol. 1994b;84:591-7. [pmid: 8090399].
Wright TC, Richart RM. Pathogenesis and diagnosis of preinvasive lesions of the lower genital tract. Hoskins WJ, Perez CA, Young RC, editors. In: Principles and practice of gynecologic oncology. Philadelphia: Lippincott; 1992.
Wright TC, Kurman RJ, Ferenczy A. Precancerous lesions of the cervix. Kurman RJ, editor. In: Blaustein's pathology of the female genital tract, 4 ^ th ^ edition. New York: Springer-Verlag; 1994a. p. 229-78.
Wright TC, Sun XW, Koulos J. Comparison of management algorithms for the evaluation of women with low-grade cytologic abnormalities. Obstet Gynecol. 1995;85:202-10. [pmid: 7824231].
Young NA, Naryshkin S, Bowman RL. Value of repeat cervical smears at the time of colposcopic biopsy. Diagn Cytopathol. 1993;9(6):646-9. [pmid: 8143537].