# Conclusions

## Accuracy of Cervical Cytological Screening Tests

Recent studies provide important new evidence with which to estimate the accuracy of cervical cytological screening. Despite the demonstrated capability of such screening to reduce cervical cancer mortality, conventional Pap smear screening has a poorer capability of discriminating between diseased and nondiseased patients than has generally been believed to be true. Pap smear screening is more accurate when a higher cytological threshold (HSIL) is used to detect a high-grade lesion. Lower test thresholds, or use of the Pap smear to detect low-grade dysplasia, result in poorer discrimination.

The accuracy of Pap smear screening is strongly dependent on study characteristics. In the studies reviewed for this report, prevalence of disease was the strongest and most consistent factor associated with between-study variation in effectiveness scores. Higher disease prevalence was associated with higher estimates of sensitivity and lower estimates of specificity (with a greater effect on specificity). These findings are consistent with prevalence as a surrogate for "workup" bias and perhaps also reflect an imperfect reference standard that is more specific than sensitive.

The quality of the studies reviewed in this report varied widely; however, quality scores did not explain a statistically significant amount of the between-study variation in effectiveness scores, sensitivity, or specificity. It is possible that the separate components of the quality score affected the test effectiveness scores in different directions, leading to an overall lack of significance. However, when controlling for prevalence of disease, because of small numbers and collinearity, we were unable to separately assess the effects of verification of test-negative subjects and type of reference standard on between-study variation in sensitivity and specificity.

Few studies of initial screening were unaffected by workup bias, but the few that were provided estimates of the specificity of Pap smear screening of 97 to 100 percent and sensitivity of 29 to 56 percent, indicating sensitivity estimates much lower than those generally believed to be true.

Most of the studies reviewed were conducted on women referred for evaluation of a cytological abnormality. The cervical cytological test repeated at the time of colposcopy was often the cytological result reported, and that result was then compared with colposcopy or histology results. The fact that cytology-"negative" women in many of these studies had often had a recent positive Pap smear suggested that they may have been systematically different from women who had received a negative Pap test on initial screening.

Based on studies using a cytological or histological reference standard, ThinPrep^®^ demonstrated improved sensitivity compared with conventional Pap smears. The only study allowing estimation of the relative FPR suggested that ThinPrep^®^ had slightly lower specificity than did conventional smear; however, this difference was not statistically significant.

Both computer rescreening technologies (AutoPap^®^, Papnet^®^) have been shown to be capable of improving the diagnostic yield of false negatives, although the magnitude of the false negative reduction under different circumstances is difficult to estimate precisely. Similarly, estimates of the effect of rescreening on specificity are unreliable.

The evidence regarding the accuracy of the newer technologies on cervical cytological screening is insufficient for several reasons. First, little evidence is available with which to assess the effects of thin-layer cytology or computer rescreening on specificity. Second, most estimates of effect on sensitivity (or reducing the false negative rate) are based on a surrogate reference standard: cytology. Standards for cytological reference standards put forth by the FDA and the Intersociety Working Group for Cytology Technologies improve the validity of the cytological reference standard by requiring consensus among an independent panel of cytology professionals; however, this standard is often applied only to discrepant cases, and histological verification of high-grade lesions is also often lacking. Both of these deficiencies lead to overestimation of diagnostic performance.

## Costs of Cervical Cytological Screening

Our analysis provides cost estimates in 1997 dollars for procedures associated with screening, diagnosis, and treatment of cervical cancer for women ages 20-64 years and those 65 and older. Previous cost-effectiveness analyses of cervical cancer diagnosis and treatment in the United States have relied on cost estimates derived from 1988 data (U.S. Congress Office of Technology Assessment, 1990). The present analysis adds substantially to the existing cost literature on cervical cancer because it is the first to estimate costs associated with younger (20-64 years) and older women (65 years and older) separately.

The cost of Pap smear screening was somewhat higher in older women than in younger women, chiefly because physician and total time spent in obtaining Pap smears during office visits was greater for older women. For costs associated with cervical cancer treatment, estimates were substantially lower for older women because the cost estimates for the under-65 age group were derived from primary analysis of claims data, whereas cost estimates for the 65-and-older age group were obtained from Medicare payments. Although the same time period was used to enhance comparability between the costs provided for the two groups, the use of different data sources likely affected the estimates derived. The claims data analyses reflect more comprehensive costs of providing the services than do Medicare payments, since costs for related services were not always added to the cost of the primary service.

Cost estimates for diagnosis and treatment of cervical dysplasia or cancer calculated from episodes of care are substantially higher than are estimates based on average procedure-specific costs because of both the provision of related services and the effect of complicated cases with unusually high costs. Estimates based on procedure-related costs alone will underestimate the true direct medical costs.

## Cost-Effectiveness of New Technologies

### Literature Review

Published models examining the cost and effectiveness of Pap smear screening have consistently found Pap screening to have a significant impact on the incidence and mortality of cervical cancer and to have an acceptable range of cost-effectiveness ratios when compared with no screening. Existing models were all consistent in this finding despite different modeling techniques, parameters, and assumptions.

Estimates of Pap test accuracy used in these models generally overestimated Pap test performance, as determined by recent unbiased studies and previous meta-analyses. Pap test performance was not found to be a key determinant of cost-effectiveness in studies that included sensitivity analyses of Pap test accuracy; however, our best estimates of Pap test performance fall outside the range used in sensitivity analyses in some models.

The studies suggest that screening programs become less cost-effective when the age of onset for Pap screening is lowered (e.g., to 17 years), when applied to low-risk subpopulations (e.g., previously screened pregnant women), or when the screening interval is more frequent (e.g., annual). Screening programs were found to be more cost-effective when applied to higher risk subpopulations (e.g., previously unscreened women, older women) or at less frequent screening intervals (e.g., every 3-5 years).

The several high-quality existing models of effectiveness and costs associated with Pap testing for cervical cancer screening provided a valuable resource for this project. These models provided a conceptual framework for the assumptions, modeling techniques, and literature evidence. The number of similar models and their degree of detail were sufficient to support a significant effort to describe and critique them. These models indicated that high-quality cost-effectiveness analysis is possible, and they not only provided resources to support the creation of such a model, but also indicated areas for improvement (e.g., better cost parameters).

### Cost-Effectiveness Model

We found that under favorable assumptions, the use of technologies that improve initial screening sensitivity or rescreening sensitivity can have acceptable cost-effectiveness compared with conventional Pap smear screening at a frequency of every 3 years. However, the cost-effectiveness of these new technologies (and of conventional Pap smear screening) is directly related to the frequency of screening, with longer intervals resulting in lower cost-effectiveness estimates. Our findings were relatively insensitive to assumptions about cervical cancer incidence, the cost of technologies, diagnostic strategies for abnormal screening results, age at onset of screening, or most other variables tested. However, there is substantial uncertainty about the estimates of sensitivity and specificity of the new technologies compared with each other and with conventional Pap testing. It is clear from our sensitivity analysis that both sensitivity and specificity are important in determining cost-effectiveness. Although it is clear that both types of technology provide an improvement in effectiveness at higher cost, the imprecision in estimates of their effectiveness makes drawing conclusions about the relative cost-effectiveness of thin-layer cytology and computerized rescreening technologies problematic.

Although a societal perspective would be preferable, the inherent difficulties in estimating nondirect costs such as lost productivity led us to choose the simpler health care perspective. Invasive cervical cancer affects mostly women in midlife and older, whereas the much more common HPV infection and SIL (most of which do not progress to cervical cancer) are primarily seen in younger women. It therefore seems likely that the nonhealth care costs associated with screening and treatment of SIL may be greater than those associated with the diagnosis and treatment of invasive cervical cancer. If this is true, then the cost-effectiveness of screening, and of new technologies to improve screening performance, will be more favorable from a health care system perspective than from a societal perspective, especially if new technologies increase sensitivity at the expense of specificity.

### Natural History of Cervical Cancer

Our model predicts an age-specific incidence of cervical cancer similar to that reported in unscreened populations. Our peak incidence, 81/100,000 at age 50, is higher and comes at an earlier age than that reported in an unscreened population in the United States in the 1930s (60/100,000 at age 60); is similar to that seen in India in the 1960s, Canada in the 1960s, or Singapore in the 1970s; and is somewhat lower than in Germany in the 1960s (peak 110/100,000) (Gustafsson, Ponten, Bergstrom et al., 1997). Our estimates of age-specific prevalence of HPV, LSIL, and HSIL are also within reported ranges. We are therefore confident that our model represents a reasonable approximation of the natural history of cervical cancer. Clearly, further refinements can be made, especially in the modeling of transitions between states. Further development of this model could be useful for analyzing the natural history of cervical cancer in greater detail, even at the molecular level. The model could also be used for future technology assessments of HPV testing or HPV vaccination programs.

### Effects of Screening Programs on Outcomes

Our findings that the incremental gain in life expectancy decreases dramatically when the screening interval is lengthened are consistent with those of other previously published models. We found a similar pattern for cervical cancer deaths, cervical cancer cases, and morbidity associated with cervical cancer. Although further research on quality-of-life issues associated with cervical cancer screening and treatment is clearly needed, it seems unlikely that data on quality-of-life issues would significantly change our findings. Given the rarity of cervical cancer relative to HPV infection and SIL, the inconvenience, potential discomfort, and psychological distress (Paskett and Rimer, 1995) associated with screening and treatment of cancer precursors (many of which will never progress to become cancer) might well outweigh the negative impact of cancer itself on women's quality of life at the population level.

Our model also predicts that, even with the most sensitive screening program, there will continue to be cervical cancer cases and that the bulk of these cases will be in younger women. There are clearly differences in biological behavior of different tumors. The occurrence of tumors in women under 30 is itself evidence that there are some rapidly growing tumors. Since one would expect screening to preferentially detect slower growing tumors, the proportion of younger women among cervical cancer cases should increase as screening sensitivity increases.

Several authors have discussed the difficulties involved in modeling cervical cancer (Prorok, 1986; Wilson and Woodman, 1995). In addition to the uncertainty surrounding almost all of the parameter estimates, which are discussed in detail elsewhere, and given our assumptions about natural history, diagnosis, and treatment, there are limitations inherent in the underlying choice of a Markov model for our cost-effectiveness analysis.

First, we assumed that the probabilities of regression and progression of HPV and SIL, although varying with age, are constant within specified age ranges. Because the progression from HPV to SIL to invasive cancer appears to be dependent on a series of specific mutations in the HPV genome (Mitchell, Tortolero-Luna, Wright et al., 1996), it is likely that the true transition probabilities are not constant, but a function of the specific HPV viral type and host co-factors. A different model structure, using either stochastic modeling or Monte Carlo simulation, might result in a closer approximation of the true natural history. We chose a Markov cohort simulation because (1) it allowed faster computation of results, an advantage given the large number of variables, clinical strategies, and sensitivity analyses to be evaluated; (2) the interpretation of the model and its results may be more intuitive to readers with less experience in decision-analytic techniques; and (3) we lack data that would allow more precise estimation of the distribution of regression and progression probabilities.

Given the robustness of our findings to variation over a wide range of possible parameter values, it seems unlikely that a different model structure would have resulted in substantially different conclusions.

Second, like all Markov models, our model also assumes that transitions occur only at the beginning of each cycle. For life expectancy, we applied the half-cycle correction (Sonnenberg and Beck, 1993); however, this assumption may affect some of the results with certain diagnostic strategies. For example, if a Pap test with a cytological result of ASCUS or LSIL is followed by a repeat Pap test in 6 months rather than by immediate colposcopy, the underlying histological state may progress, regress, or persist during that time period, whereas our model assumes that, in the absence of treatment, a given state persists for at least 1 year. However, because regression or persistence is more likely than progression for LSIL or HSIL within a given year, this assumption results in an overestimation of the likelihood of finding SIL on the subsequent Pap. This, in turn, is a bias in favor of screening and in favor of any strategy that improves the sensitivity of screening.

Our validation technique does not account for the fact that age-specific incidence data collected at any one point in time may be dependent on the distribution in the population of different cohorts, each with its own age-specific incidence (Gustafsson, Ponten, Bergstrom et al., 1997). Our choice of an earlier onset of sexual activity and HPV infection is consistent with current demographic trends, and, again, is biased in favor of screening.

## Clinical Implications

Many issues have been raised to justify the use of improved technologies for cervical cytological screening. This report does not address them all. Attention has been focused on quality control in cytopathology laboratories in an attempt to reduce the problem of false negative Pap smear tests; in fact, this has been one of the primary motivations for the development of computerized rescreening technologies. Variability in sensitivity and specificity between laboratories could be expected to have a profound effect on the cost-effectiveness, yet our model assumed uniform performance among the simulated cohort. In theory, the 10 percent manual rescreening mandated by CLIA could be a useful tool to assure uniform quality among cytopathology laboratories; however, it is an ineffective strategy alone for solving the problem of false negative Pap smear screening tests. Computerized rescreening technologies offer, in addition to improvements in performance, the advantage of greater uniformity across laboratories.

The shortage of cytotechnologists and the difficulties in implementing screening recommendations in medically underserved areas are additional factors that may provide incentives for using computerized rescreening or initial screening technologies. These issues were not considered in this analysis because many of these factors are difficult to quantify and model.

Another set of issues not included in the model relate to compliance with Pap smear screening recommendations. We assumed uniform compliance by patients and providers; however, increased costs of screening from implementation of these new technologies could result in worse compliance with cervical cytological screening and, on a national level, result in no reductions in cervical cancer incidence.

Our model suggests that improving the sensitivity of screening, even at no additional cost, might actually increase the cost-effectiveness of a cervical cancer screening program. Most of the abnormalities found are low-grade, a finding that leads to costs for diagnosis and treatment, but yields little benefit in terms of reduced cervical cancer incidence or life-years saved. Along these lines, there may not be a price at which improved initial or rescreening technologies can be cost-effective according to years of life saved or cervical cancer incidence. Only if one places a high value on detecting and treating low-grade cytological abnormalities can improvements in Pap smear screening be justified. No analyses, including this one, have taken such factors as psychological distress, quality of life, or costs of litigation for failure to diagnose cervical lesions into account; it may be factors such as these that are needed to justify the implementation of these technologies that hover near the threshold of acceptable cost-effectiveness.

## Summary

The currently available data on the accuracy of thin-layer cytology and computerized rescreening technologies used for cervical cytological screening fail to describe reliable estimates for test specificity. The increased sensitivity permitted by both types of technologies has implications for the cost-effectiveness of screening that, according to our model, would result in moderate improvements in life expectancy at much higher cost than conventional Pap screening alone. The level of precision in estimates of their accuracy precludes determining the relative cost-effectiveness of thin-layer cytology and computer rescreening. However, our assumptions about their diagnostic performance do allow us to use the model to provide estimates of the cost-effectiveness of these new technologies relative to conventional Pap screening or no screening. Especially when considered as part of a strategy with screening intervals of 3 years, the new technologies have incremental cost-effectiveness ratios that are within the range of accepted health care practices.