# Methodology

This section documents explicitly the methods and procedures used to develop the evidence report, emphasizing the comprehensive evaluation of the evidence and the analytic framework used. The section begins with a description of the research questions and evidence model that guided our work and proceeds to a detailed description of the techniques and approaches used in the literature review, including descriptions of the literature search and review parameters, MeSH terms used, types of study design included, number and identity of databases searched, and years included in the search. The methodologies used to produce cost estimates and carry out the meta-analysis and cost-effectiveness analysis are then described. Finally, the role of the report partner (American College of Obstetricians and Gynecologists) and quality control methods are described.

## Evidence Report Questions and Evidence Model

The report addresses three main questions:

1 What is the accuracy of cervical cytology using conventional Pap smears and new technologies (thin-layer cytology, computerized rescreening using neural network or algorithm-based technology) for detecting cervical cancer and its precursors?
2 What are the direct medical costs associated with cervical cancer screening, evaluation, treatment, and followup of cervical cytological abnormalities and treatment and followup of cervical cancer?
3 What are the effects on total health care cost, morbidity, and mortality of regular cervical cytological screening using thin-layer cytology, computerized rescreening using neural network technology, and computerized rescreening using algorithm-based technology compared with conventional Pap smear in women participating in a screening program

The evidence model or "causal pathway" used, which is illustrated in Figure 1 , identifies the population, critical interventions, and outcomes (intermediate, surrogate, beneficial health outcomes, and harms) considered and also indicates explicitly the relationships among these factors (Woolf, 1994). Arrows link the intervention to outcomes either directly or through intermediate steps. Different linkages may have different levels of evidence supporting whether an association is present. In some cases, linkages may be indirectly supported by studies in slightly different populations.

Figure 1. Evidence model

We drafted and revised the evidence model, soliciting input from the study's Advisory Panel of Technical Experts regarding the outcomes and harms of interest, and identified the type of evidence that exists to support each linkage. The specific linkages identified as key questions were the subject of a systematic literature review.

The project focused on several linkages that are crucial to the question of the cost an effectiveness of several new technologies for cervical cytological screening. The overall question of the effectiveness of cervical cytological screening on morbidity and mortality is described by the overarching linkages between cervical cytological screening and reductions in mortality and morbidity, as well as influences on cost and other health outcomes such as quality of life. Strong but indirect evidence supports the effectiveness of cervical cytological screening in reducing cervical cancer morbidity and mortality. This evidence includes quasi-experimental observational studies describing cervical cancer incidence before and after implementation of screening programs. Additional indirect evidence comes from decision- and simulation-modeling of cervical cancer screening.

Current costs associated with cervical cytological screening are not well described in the literature, and in this project an empirical investigation of health care claims and other databases was undertaken to address this linkage in the evidence model.

The link between cervical cytological screening and detection of abnormalities is investigated in a literature review on the diagnostic accuracy of conventional Pap smear screening and the new technologies. Discrimination, sensitivity, and specificity are the most relevant data for the assessment of the new technologies.

We did not specifically address the well-established linkages between detection of abnormal cytology or early cervical cancer and reductions in cervical cancer morbidity and mortality through early treatment of cervical lesions.

The evidence model also functioned as a conceptual basis for the construction of a working mathematical model of the cost and effectiveness of cervical cytological screening that synthesizes all the linkages depicted regarding cervical cancer screening. Our approach thus extends the idea of the evidence model to a mathematical model that allows us to examine the impact of various cervical cancer screening strategies on the health and economic outcomes depicted in the evidence model. Both models provide an inventory of the inputs relevant to a screening decision and give a sense of which screening questions are tractable and for which questions reasonable scientific data exist. The models thus also guided the design of our literature search to focus on those inputs that most strongly influence the relative desirability of alternative decision strategies to various clinical decisionmakers.

## Methodology: Literature Review

The comprehensive review of the literature, from identification of databases through abstraction of individual articles into the evidence tables, was a multistep, sequential process. This process is detailed below.

### Literature Sources Used

Primary sources of literature for the two key research questions that were the subject of literature reviews were six of the most widely used online bibliographic databases: MEDLINE, CancerLit, HealthSTAR, CINAHL, EMBASE, and EconLit. Although there is considerable overlap among these databases, each contains unique information.

Produced by the U.S. National Library of Medicine, the MEDLINE database is widely recognized as the premier source for bibliographic and abstract coverage of biomedical literature. MEDLINE coverage began in 1966. More than 8.7 million records from more than 3,600 journals are indexed, plus selected monographs of congresses and symposia. Abstracts are included for about 67 percent of the records.

Produced by the U.S. National Cancer Institute, CancerLit is an important source of bibliographic records (most with abstracts) beginning in 1983 and pertaining to all aspects of cancer therapy, including experimental and clinical cancer therapy; chemical, viral, and other cancer-causing agents; mechanisms of carcinogenesis; biochemistry, immunology, and physiology of cancer; and mutagen and growth factor studies. Approximately 200 core journals contribute a large percentage of the records. Other entries are drawn from proceedings of meetings, government reports, symposia reports, theses, and selected monographs. Indexed materials include articles from journals, abstracts of papers presented at professional meetings, government and technical reports, dissertations, and monographs.

HealthSTAR, produced cooperatively by the U.S. National Library of Medicine and the American Hospital Association, contains citations to the published literature on health services, technology, administration, and research from 1975 to the present. Topics included that were of particular interest to us are evaluation of patient outcomes; effectiveness of procedures, programs, products, services, and processes; health economics and financial management; and quality assurance. This database contains citations and abstracts (when available) to journal articles, monographs, technical reports, meeting abstracts and papers, book chapters, government documents, and newspaper articles.

The Cumulative Index to Nursing & Allied Health (CINAHL) provides authoritative coverage of the literature related to nursing and allied health from 1983 to the present. CINAHL was chosen for the literature searches on cervical cytology primarily because it indexes several medical laboratory journals.

EMBASE is a comprehensive pharmacological and biomedical database containing over 3 million records from 1980 to the present, indexed from 3,500 journals published in 70 countries. More than 65 percent of the records contain abstracts.

EconLit contains abstracts of journal articles, books, and working papers, book reviews, and citations to articles in collective volumes. It covers economic literature broadly, from 1969 to the present.

Computerized searches of these online databases were supplemented by secondary searches, including the manual scanning of newly published journal issues that had not yet been indexed in the online databases. This scanning was accomplished through online searches of journal websites as well as searches of printed journals obtained through subscriptions and the Duke University Medical Center Library. In addition, the World Wide Web of the manufacturers of the automated cytology devices reviewed in this report were checked several times a week, along with those of relevant professional societies.

### Search Strategies for Computerized Databases

The two strategies used to search the above computerized databases were developed in consultation with a Duke University Medical Center librarian who specializes in evidence-based medicine research. There were several iterations of each search strategy before the final strategies were agreed upon. The final strategy for articles on diagnostic testing for cervical cancer was:

1 Vaginal smears/
2 ((pap or papan$) and (smear$ or test$)).tw
3 (papnet or autopap or thinprep).tw.
4 1 or 2 or 3
5 exp Cervix neoplasms/
6 Cervix dysplasia/
7 Cervical Intraepithelial Neoplasia/
8 dyskaryo$.tw.
9 5 or 6 or 7 or 8
10 exp "Sensitivity and Specificity"/
11 (sensitivity or specificity).tw.
12 exp Diagnostic errors/
13 4 and (10 or 11 or 12)
14 13 and 9
15 limit 14 to (human and english language)
16 Papillomavirus, Human/
17 15 not 16

The final search strategy for articles on the costs and health outcomes associated with cervical cancer screening was as follows:

1 Vaginal smears/
2 ((pap or papan$) and (smear$ or test$)).tw
3 (papnet or autopap or thinprep).tw.
4 1 or 2 or 3
5 exp "costs and cost analysis"/
6 (cost$ or expenditure$).tw.
7 ec.fs.
8 5 or 6 or 7
9 4 and 8
10 limit 9 to (human and english language)
11 exp Decision Support Techniques/
12 exp Models, Statistical/
13 Technology assessment, biomedical/
14 Monte carlo method/ or Survival Analysis/
15 11 or 12 or 13 or 14
16 4 and 15
17 limit 16 to (human and english language)
18 10 or 17

These strategies were initially developed using the National Library of Medicine MeSH key word nomenclature developed for MEDLINE. The Duke University Medical Center librarians assisted with the translation of these search strategies to the key word structures used by other databases. The basic search terms remained the same. Each online search began with the first year of the database (see individual database descriptions above).

After the initial runs in January 1998, the computerized searches were updated twice, in February and March. The final yield of the two searches was 1,538 unduplicated articles--939 articles were identified by the diagnostic testing searches and 671 by the cost and health outcomes searches, including articles identified through manual searches. Approximately 67 percent of all articles were identified through MEDLINE, 23 percent through EMBASE, and 5 percent through manual searches, with the remaining 5 percent divided among CancerLit, HealthSTAR, and CINAHL. EconLit did not identify any relevant or unique articles.

### Development of a Bibliographic Database

As online literature searches were conducted, results were imported into Pro-Cite Version 2.0, a database software program for storing, managing, and retrieving bibliographic information. Each article was given a unique identifier within the Pro-Cite database. An ongoing search for duplicates was conducted. Initially, each article was coded to indicate its source and key question(s). As screening and data abstraction progressed, each article was coded for the stage at which it was excluded from the evidence report.

### Screening of Articles

Separate sets of criteria for including articles in the evidence report were developed for the two topics that were the subject of literature reviews (diagnostic testing and cost and health outcomes). In each case, final screening criteria were developed through an iterative process. Each iteration of criteria was pilot-tested by each reviewer/abstractor on a subset of randomly chosen articles.

#### Articles on Diagnostic Testing

These articles were clinically and methodologically complex and thus required a two-step screening process. In Step 1, articles were screened on the basis of the basic information available through the online databases (primarily title, authors, and abstract when available). Articles at this step were eliminated from further consideration based on answers to three questions:

1 Was cervical cytology evaluated as a screening test? If no, then article excluded.
2 Was the screening test for primary screening only, rescreening only, or primary screening with rescreening? If none of these, then article excluded.
3 Was the reference standard histology, histology or negative colposcopy, or cytology? If none of these, then article excluded.

At this stage, the following information was also recorded:

4 Type of rescreening included: none, manual, interactive, or independent.
5 Description of target population.

Bibliographic records were screened by three pairs of clinicians, two pairs consisting of a general internist and obstetrician/gynecologist and one pair consisting of a medical student and obstetrician/gynecologist. The decisions of the two partners in each pair were compared, and a kappa statistic was calculated to estimate the strength of the agreement between them. Differences of opinion were then reconciled. Only when both clinician-reviewers agreed to include or exclude an article was the decision entered into the Pro-Cite database. Copies of the full text of all articles passing the initial screening were obtained. Each included article was subjected to a further screening (Step 2) by the same pair of reviewers who had performed the initial screening of the corresponding bibliographic record (Step 1).

As in Step 1, the criteria used in Step 2 went through several iterations to assure that the most salient articles would be included. The four questions used for excluding articles at Step 2 were:

1 Did the study use a reference standard? If not, then article excluded.
2 Was the reference standard histology or colposcopy? Histology and colposcopy qualified the article for inclusion; articles with cytology reference standard were excluded.
3 For studies comparing histology or colposcopy with cytology as a screening test: were these tests reasonably concurrent, i.e., up to 3 months apart? If not, then article excluded.
4 Can all cells of a 2-by-2 table be completed? If not, then article excluded. The 2-by-2 table is defined as a tabulation of the number of subjects with normal and abnormal screening test results according to the specified screening test threshold versus the number of subjects with normal or abnormal reference standard results according to the reference standard threshold.

The review process was the same as in the first step, with the two clinicians in each team comparing their decisions and reaching agreement to include or exclude the article. The decision to exclude at Step 2 was then entered into the Pro-Cite database. The two major reasons for excluding an article at this stage were lack of histology/colposcopy as a reference standard and the lack of sufficient data to complete a 2-by-2 table.

Of the 939 bibliographic references reviewed, 561, or approximately 60 percent, were excluded during Step 1 screening, and another 293, or 31 percent, during Step 2 screening. Eighty-six articles passed both screens.

Few articles pertaining to the new technologies were included among the 86 articles passing both screens. In most cases, this was due to the lack of a histology/colposcopy reference standard. We sought guidance from cytology society guidelines (Intersociety Working Group for Cytology Technologies, 1998 ) and FDA documents (Food and Drug Administration, 1994) about acceptable reference standards other than histology or colposcopy. These resources suggested that cytology would be an acceptable surrogate reference standard, but only when an independent panel of cytology professionals was used to arrive at a consensus diagnosis. Furthermore, the Intersociety Working Group guidelines called for histological validation of a significant proportion of high-grade cytological findings.

We also explored the methodological literature on diagnostic tests to determine techniques for dealing with lack of verification of test negative subjects. Information about the incremental test performance characteristics can be obtained from a direct comparison of independently applied conventional and new tests, in which case it is not necessary to obtain reference standard results for subjects who are negative on both tests (Chock, Irwig, Berry et al.,1997). Using this method, one cannot calculate sensitivity and specificity directly, but a relative true positive rate (TPR) and a relative false positive rate (FPR) can be calculated. These statistics can be used to modify estimates of the conventional test performance to yield estimates of the performance of the new test relative to the reference standard. These methods apply only when the tests being compared are used independently. For example, studies that applied initial manual screening followed by computerized rescreening could not be evaluated with these methods because the use of rescreening was conditional on a negative initial screen and thus the two tests were not applied independently. These methods would apply primarily to studies of alternatives to conventional Pap when used as primary screeners or studies that use independent comparisons of computerized versus manual rescreening.

This review of methodological issues led to the development of a separate set of screening criteria for studies of the new technologies (Step 3 screen). We reevaluated articles on monolayer slide preparation and neural-network or algorithm-based screening technologies that had been excluded in Step 2 either because they used a cytology reference standard or because they failed to allow estimates of both sensitivity and specificity. Again, two clinicians in each team compared their decisions and reached agreement on whether to include or exclude an article. The Step 3 screening criteria were as follows:

1 Did the study use a two-armed prospective design? If not, then article excluded. (A two-arm design implies that the tests being compared are applied to the same set of subjects or slides.)
2 Were discordant results from the two study arms adjudicated by an independent panel of experienced cytology professionals? If not, then article excluded.
3 Were the majority of those testing positive for HSIL verified with histology or colposcopy?Studies which did not verify at least half of those with screening tests positive for HSIL were excluded.
4 Did the study design allow for separate analyses of sensitivity (or relative TPR) and specificity (or relative FPR)? If not, then article excluded.

A total of 59 articles were considered at this stage (12 on AutoPap, 27 on Papnet^®^, and 20 on ThinPrep ^®^). Forty-three of these fit the description provided above (excluded during Stage 2 screen because of cytology reference standard or failure to allow estimates of sensitivity and specificity). Sixteen new articles were also brought to our attention by reviewers or manufacturers. Of these 16 articles, 7 were unpublished manuscripts and 2 were published only in abstract form.

Applying Step 3 screening criteria to these 59 articles led to the inclusion of only one study of the new technologies: an evaluation of ThinPrep^®^ (Roberts, Gurley, Thurloe et al.,1997). To provide some description of the available literature on the effectiveness of the new technologies, we have included in Evidence Table 1 and described in the text of this report all those studies considered for Step 3 that also met the criterion of a concurrent reference standard (histology, coposcopy, or cytology), even though they did not permit estimates of specificity or relative FPR. The net result was the inclusion of 6 studies of AutoPap^®^, 11 of Papnet ^®^, and 8 of ThinPrep^®^.

#### Articles on Cost and Health Outcomes

Articles were excluded on the basis of responses to two questions:

1 Was the screening test AutoPap ^®^, Papnet ^®^ , ThinPrep ^®^ , or conventional Pap? If none of these, then article excluded.
2 Does the article assess the effect of screening on life expectancy or quality, number of cervical cancer cases avoided, or total health care costs? If none of these, then article excluded. Note: Studies that reported costs of screening test alone, without subsequent evaluation- and management-related costs, were excluded.

Bibliographic records (title, author, and abstract, when available) from the Pro-Cite database were screened by two pairs of reviewers, each including a doctoral-level economics graduate student and either a clinician or health policy analyst. Decisions by the partners were recorded, a kappa statistic was calculated, and agreement was reached where discrepancies existed. If the abstract satisfied the screen, then the full article was reviewed with respect to the same two criteria. The decision to exclude an article was entered into the computer database after the abstract and/or the full article had been screened.

Of the 672 articles identified, 638, or 95 percent, were eliminated during the screening process. Thirty-four articles were included in the review.

### Study Design of Included Articles

At the time the literature searches were conducted, there were no completed randomized clinical trials comparing conventional Pap tests with new technologies to detect cervical cancer and its precursors. Study designs included in the diagnostic testing review were diagnostic test evaluations, meta-analyses, and review articles. Cost and health outcomes articles included were cost studies, typically cost-effectiveness and cost-benefit analyses.

### Data Abstraction Process

The review team responsible for including a given article was also responsible for abstracting data and other key information from that article. The goal of the data abstraction process was to abstract essential information directly into the template of the evidence table in the format required by the Agency for Health Care and Research (AHCPR).

The evidence table entries were created by one member of each review team, over-read by the other team member, and then revised. For the cost and health outcomes articles, each evidence table entry was again over-read by a clinician.

For the diagnostic testing articles, both members of each paired clinician-reviewer team also independently completed 2-by-2 tables for each study, extracting the key data permitting calculation of sensitivity, specificity, prevalence, and other data to be used in the meta-analysis. The main outcome measures considered were the sensitivity and specificity of cytologic abnormality on Pap test for detecting cases, where "cytologic abnormality" was defined by one of three thresholds ranging from atypical squamous cells of uncertain significance (ASCUS) (threshold 1) to LSIL (threshold 2) to HSIL (threshold 3), and where a "case" was defined as a histologicdiagnosis of dysplasia or carcinoma. Equivalent categories in other classification schemes were also used according to a mapping of cervical cytology classification schemes (Figure 2). Data were abstracted according to four different combinations of cytological versus histological thresholds: ASCUS/CIN1, LSIL/CIN1, LSIL/CIN2-3, and HSIL/CIN2-3. Indeterminant cases (e.g., due to uninterpretable cytology or lack of reference standard confirmation) were noted in the data abstraction process but excluded from the calculation of sensitivity and specificity. Where more than one study population was included in a single report with data provided separately, they were treated as individual studies. All the 2-by-2 table data were entered into a computer database, and data from the two members of each reviewing team were compared and reconciled.

Figure 2. Map of cervical cytology classification schemes

Classification System | Within Normal Limits | Benign Cellular Changes | Epithelial Abnormalities
The Bethesda System (National Cancer Institute Workshop, 1993) | Normal | Infection reactive repair | ASCUS | Squamous intraepithelial lesion (SIL) | | | | | Invasive carcinoma
The Bethesda System (National Cancer Institute Workshop, 1993) | Normal | Infection reactive repair | ASCUS | Low grade (LSIL) | | High grade (HSIL) | | | Invasive carcinoma
Richart (1973) | Normal | | | Condylom a | Cervical intraepithelial neoplasia (CIN) | | | | Invasive carcinoma
Richart (1973) | Normal | | | Condylom a | Grade 1 | Grade 2 | Grade 3 | | Invasive carcinoma
Reagan (1979) (WHO) | Normal | Atypia | | Mild dysplasia | | Moderate dysplasia | Severe dysplasia | In situ carcinoma | Invasive carcinoma
Papanicolaou (Nyirjesy, 1972) | I | II | | III | | | IV | | V

ASCUS = atypical squamous cell of uncertain significance.

Some studies that failed to permit calculation of sensitivity and specificity directly nonetheless allowed calculation of relative TPR and relative FNR (false negative rate) according to the method of Chock, Irwig, Berry et al. (1997). This method was applied to studies comparing two independently applied screening tests in which verification was obtained on any patient testing positive on either test (but not those testing negative on both tests).

### Criteria for Evaluating the Quality of Articles

Given the two very distinct sets of articles reviewed for the evidence report, two separate sets of criteria to judge their quality were needed.

#### Articles on Diagnostic Testing

The goal was to develop a single numeric or alphabetic summary of the methodological quality of individual studies. A systematic approach was used to reach consensus on rigorous, predetermined methodological criteria and the relative numeric weights to be assigned to each. The participants were nine members of the study's work group (six clinicians, two economists, one health policy analyst). Each member of the group was familiar with the diagnostic testing articles. The group initially identified more than a dozen evaluation criteria; the consensus process narrowed the list to seven. The weight given to each criterion was determined by each participant writing his/her numerical assessment of the value of that criterion (blinded to the rest of the group). The means of these "votes" were calculated. Each participant received a copy of his/her own responses, graphically depicted in relation to the mean of all responses, and was requested to confirm or reconsider his/her responses. The revised responses were then calculated and the means affirmed by the group as the weight. The quality review criteria and their weights (in parentheses) are:

1 Were the test and reference standard measured independently (blind) of each other?yes (2); no (0)
2 Was the test compared with a valid reference standard?histology (2); histology or negative colposcopy (1); cytology (0)
3 Was the choice of patients who were assessed by the reference standard independent of the test's results? all test positives and test negatives verified (2); test positives and random fraction of test negatives verified (1); test positives and selected sample or none of test negatives verified (0)
4 How was the study sample collected?consecutive or random (2); other (0)
5 Was the spectrum of disease/nondisease defined? yes (1); no (0)
6 How was the study published? paper (1); abstract (0)
7 What was the industry relationship to the study? neither done nor supported by a manufacturer (1); supported by a manufacturer (1/2); done by a manufacturer (0)

#### Articles on Cost and Health Outcomes

The major difficulty with this set of articles was that the two types of studies (health outcomes and costs), sometimes distinct and sometimes overlapping, generated many criteria. There were several expert sources of quality criteria by which to judge these articles that were readily affirmed by the work group and reaffirmed by the study's Advisory Panel of Technical Experts (Drummond, Richardson, O'Brien et al., 1997 ; Gold, Siegel, Russell et al., 1996 ; O'Brien, Heyland, Richardson et al., 1997 ; Siegel, Weinstein, Russell et al., 1996).

Letters representing the criteria that were not satisfied by a given article are shown in the last column of the evidence table. The criteria were:

For articles that modeled health outcomes:

1 There was a description or diagram of a decision model.
2 The clinical strategies were described in detail.
3 A comprehensive literature review was conducted.
4 The control group was described.
5 Sources of data for probability estimates were identified.
6 The source of the utility scale or measurement method was given.
7 Clinically relevant outcomes of interest were described in detail.
8 Results of a sensitivity analysis were presented.

For articles that modeled costs:

9 There was a description of the framework for the cost analysis.
10 Modeling assumptions were stated explicitly.
11 There was sufficient description of estimates of types of resources used, amount of resource use, and unit costs, and their sources.
12 There was a critique of data quality.
13 The cost data were current, i.e., 1988 or more recent.
14 There was a description of a method to adjust costs for inflation.
15 There was a statement of discount rates used (for multiperiod or longitudinal studies).

For articles that compared health outcomes with and without Pap smear screening or with and without use of new Pap technology:

16 Study population was representative or clearly defined.
17 Screened and unscreened populations were concurrent (e.g., before-after design).
18 Screened and unscreened populations were randomly allocated.
19 The method of ascertainment of health outcomes was the same in the screened and unscreened groups.
20 The ascertainment of health outcomes was complete (loss to followup <5 percent ).

## Methodology: Cost Estimates

The costs of screening, diagnosing, and treating cervical cancer were estimated by Health Economics Research, Inc., utilizing both claims and secondary data sources. A comprehensive approach was used to incorporate costs associated with all medical services provided. For instance, the costs associated with both physician and pathology services were included in the total cost of screening for cervical cancer. In the case of diagnosis and treatment, all costs of providing outpatient and inpatient services were estimated. However, societal costs or indirect costs, such as those associated with lost wages or with waiting time at the physician's office, were not included. The methodology employed is discussed in detail below.

Separate estimates are provided for those 20-64 years of age, and those 65 years and older (eligible for Medicare). The costs for the under-65 population were estimated from MEDSTAT data, and for the older subgroup Medicare's resource-based relative value scale (RBRVS) fee schedule, clinical laboratory fee schedule, diagnosis-related group payment rates, and ambulatory surgery center payment rates were utilized. Charges and payment information obtained from these sources were then converted to reflect costs associated with the services provided. Finally, all costs were inflated to 1997 dollars. The methodology used to estimate the cost for each group is discussed separately, starting with the estimates for women 20-64 years.

### Cost Estimates for Women 20-64 Years

To obtain cost estimates for this age group, Health Economics Research, Inc., analyzed the MarketScan database created by the MEDSTAT Group and previously used in cost analyses of AHCPR practice guidelines. The MEDSTAT MarketScan database provides claims information for a large sample of privately insured individuals employed at large private companies across the country. The claims data are collected from over 100 different insurance companies, Blue Cross and Blue Shield plans, and third-party administrators (for self-insured employers). The data represent the medical experiences of insured active employees, early retirees, Consolidated Omnibus Budget Reconciliation Act (COBRA) participants, and their dependents. These data were used to estimate screening and treatment costs for the population under the age of 65. For our analyses, we used four types of claims files: inpatient claims, physician claims, outpatient department claims, and pharmaceutical claims. Information on service dates, procedures, diagnoses, and payments was abstracted. We analyzed data for a 3-year period, 1991-93, which represented the medical experience for roughly 2.5 million privately insured beneficiaries with more than 500,000 inpatient admissions and over 76 million outpatient claims.

Although the MarketScan database is a rich source of medical utilization information for the under-65 population, a number of issues arise when these data are used that may or may not affect our analyses. First, our ability to track treatment costs over time due to individuals' dropping in and out of the MarketScan database because of employment changes is limited. Thus, the data were used to estimate average costs of treatment and screening at an aggregated level. It is also important to note that the MarketScan data represent a nonrandom sample of the under-65 population. The MarketScan database includes a disproportionate number of persons employed in large firms, especially in California, Michigan, Ohio, and Texas. To the extent that large employers generally offer more generous insurance benefits than do smaller firms, utilization estimates derived from the MarketScan database are likely to overstate the general under-65 utilization experience. This bias would most directly affect cost estimates for cancer treatment, rather than cost estimates for specific diagnostic procedures or therapeutic services, as episode of care estimates are most affected by differential utilization patterns. Better insured women may use more services as well as more expensive services than less well-insured women. Last, the MarketScan database reflects the mix of fee-for-service and managed care arrangements present in the early 1990s. To the extent that the risk sharing and payment arrangements for the set of large firms in the MarketScan database differ systematically from those observed for the general under-65 population, there might be biases in the derived cost estimates. However, the direction of the bias is not readily known.

We used the MEDSTAT data to estimate the unit cost of screening, diagnosis, and treatment of cervical cancer. Since 3 years of data (1992, 1993, and 1994) were analyzed, all 1992 and 1993 charges were inflated to reflect 1994 charges. The national medical care services (includes hospital and physician services) inflation rate of 12.02 percent for 1992 charges and 5.17 percent for 1993 charges were utilized (CPI-U, U.S. Bureau of Labor Statistics, 1982-84).

The costs associated with hospital and physician services were derived from the MEDSTAT data estimates by utilizing appropriate adjustments. In the case of services provided in a hospital setting, the total covered charge for each service submitted by the hospital was identified from the MEDSTAT data. The inpatient hospital charges include room and board and ancillary charges. To convert these charges to costs, 1994 cost-to-charge ratios published by the American Hospital Association (AHA) (obtained by AHA through its Annual Survey of Hospitals) were utilized. The 1994 cost-to-charge ratio was 0.58. That is, on average across the Nation, the cost associated with the inpatient services provided was 58 percent of the charge.

Since no similar cost-to-charge ratio was available for physician charges, it was assumed that the payments made by the health care plans closely reflected the costs associated with providing these services. Thus, payments were used as a proxy for costs. This approach provides a "total" cost estimate for a given procedure or set of procedures. It not only includes the amount reimbursed by the insurance plan but also any copayments made by the patient. These payments differ from charges because they include only the amount eligible for payment under the benefit plan after pricing guidelines such as discounts and fee schedules are applied.

### Cost Estimates for Women 65 Years and Older

Medicare's RBRVS fee schedule for physician services, Medicare's Clinical Laboratory fee schedule for laboratory services, national average diagnosis-related group (DRG) payments for hospital admissions, and ambulatory surgery center payment rates for outpatient procedures were used to identify the payments associated with services received for cervical cancer screening, diagnosis, and treatment. The 1994 Medicare payments were used to allow for comparability in the estimates between the over-65 and the under-65 age groups (MEDSTAT data estimates). The Medicare payments were assumed to closely approximate the national average cost of providing the service, and therefore no conversion factors were employed (Eisenberg, 1989).

Cost estimates for both the under-65 and the over-65 age groups were updated to reflect 1997 dollars. Separate inflators were employed for services provided at institutional and noninstitutional settings. Services received at institutions were updated to 1997 dollars using the DRI-Prospective Payment System (PPS) Hospital Market Index and Health Care Financing Administration (HCFA) Capital Index. A rate of 9.85 percent was utilized. The rate was calculated using DRI-PPS Hospital Consumer Price Survey (CPS) Market Index (DRI/McGraw Hill) for operating costs, and HCFA Capital Index (Federal Register) for capital cost. A rate combining the operating and capital inflator was obtained by assuming that 90 percent of costs were related to operations and 10 percent to capital. The Medicare Economic Index (MEI) was used to inflate 1994 costs of all noninstitutional services to 1997 dollars. The MEI of 8.40 percent was utilized.

## Methodology: Meta-Analysis of Pap Test Accuracy

To combine data from multiple studies describing the performance of the conventional Pap test in discriminating between patients with and without cervical lesions, we used the effectiveness score, a measure described by Hasselblad and Hedges (1995) and Fahey, Irwig, and Macaskill (1995). The effectiveness score takes account of both sensitivity and specificity. As is well known, sensitivity and specificity are interdependent; both vary according to the test threshold used, but in opposite directions. The effectiveness score allows us to consider both measures by fitting a receiver operating characteristic (ROC) curve (Swets, 1988) through a logistic odds transformation of sensitivity and specificity, thus accounting for the interdependence of the two.

The classifications used to describe the results of cervical cytology in the clinical research literature have an ordered categorical response instead of a dichotomous one. Such a response permits the use of multiple discrete cut-points for defining an abnormal Pap test. In addition to these explicit thresholds, there may be differences in the implicit thresholds used by cytologists in labeling a slide as abnormal. One of the main advantages of using the effectiveness score is that it is often independent of the cut-points used for the test.

The effectiveness score is more normally distributed than either sensitivity or specificity and can be thought of as a gauge of the overall discriminatory ability of the test. To standardize the effectiveness score, we adjusted the standard deviation of the logistic normal distribution curve by the square root (3)/pi to get the following measure:

delta = (square root [3]/pi) * (log(sensitivity/[1-sensitivity]) + log(specificity/[1-specificity]))

Because it is standardized, the effectiveness score can be interpreted across different diagnostic tests. In general, a score of 3 reflects a test with good discrimination, whereas a score of 1 reflects a test that does not discriminate between disease positives and disease negatives.

Another measure, the log odds ratio, may be more familiar to some readers:

log odds ratio = log(sensitivity/[1-sensitivity]) + log(specificity/[1-specificity]).

This measure differs from the effectiveness score by multiplication by a constant, square root (3)/pi.

We calculated summary measures of effectiveness at each of the four explicit diagnostic thresholds (ASCUS/CIN1, LSIL/CIN1, LSIL/CIN2-3, HSIL/CIN2-3), using maximum likelihood estimation techniques and a random effects model. We chose a random effects model because of the wide variation in reported sensitivity and specificity among the included studies. We also evaluated the effect of differences in implicit threshold on effectiveness scores by including the following variable, S, in the model:

S = log(sensitivity/[1-sensitivity]) - l og(specificity/[1-specificity])

Because the model results were not changed by including this value, we used the parameter estimates from the simpler one-parameter (intercept only) logistic equations to generate summary estimates of sensitivity and specificity and to produce ROC curves.

Our data included studies with different reference standards, primarily histology (cone biopsy, hysterectomy, or punch biopsy) and negative colposcopy. These reference standards are themselves subject to inaccuracy, and one problem that may occur when a diagnostic test is compared with an imperfect independent reference standard is underestimation of sensitivity and specificity (Boyko, 1996). In such a case, the sensitivity and specificity of the test may vary with prevalence of disease. To address the possible imperfect nature of histology/colposcopy, we evaluated the effect of disease prevalence on our summary estimates of effectiveness. Multiple logistic regression was used to estimate the variation in overall effectiveness due to variations in prevalence. We also evaluated the effect of study quality on summary effectiveness scores, initially using individual components of the score, then using the total score both as a continuous and a dichotomous (quality score <7, >7) variable.

## Methodology: Cost-Effectiveness Analysis

### Introduction

This section describes our response to the question, "What are the effects on total health care costs, morbidity, and mortality of regular cervical cytological screening using thin-layer cytology or computer rescreening compared with conventional Pap smear in women participating in a screening program?"

Our basic approach to this question was to create a decision analytic model to simulate the health and economic impact of various cervical cancer screening strategies based on the results of our literature review and meta-analysis. The model, borrowing from previous similar efforts, was created to generate a wide variety of health and cost outcome projections, including survival, cumulative cost, and incremental cost-effectiveness. However, because limited data were available regarding the natural history of cervical cancer and the costs and effectiveness of cervical cancer screening and treatment, we concluded that the sort of precise projections that would be of use to decisionmakers would not be possible. In particular, we determined that the aggregate effect of uncertainty in the model inputs (see below) led to substantial uncertainty in the outputs, such that a point estimate of incremental cost-effectiveness could not be taken as a reliable representation of the value of many of the screening strategies under investigation. As a consequence, we focused the model on the general question, "What characteristics would a cervical cancer screening strategy need to have in order to be cost-effective?"The results of this investigation are intended to guide future research regarding cervical cancer screening strategies.

Two model inputs that are crucial to the precise estimation of the cost-effectiveness of new screening technologies are particularly uncertain, namely, test operating characteristics (sensitivity and specificity) and test costs. Evaluation of the sensitivity and specificity of new screening technologies is particularly problematic given the discrepancy in reference standards. As previously stated, because the clinical management of the patient depends on cytology, colposcopy, and histology taken together (and certainly not cytology alone), histologic diagnosis, or at least colposcopic diagnosis, is the most appropriate reference standard. However, given the practical and methodological difficulties in applying this reference standard, and the paucity of studies available that used such a standard, we attempted to identify other studies that met alternative criteria, as outlined above. Unfortunately, there were few studies that met even these alternative criteria, and the resulting estimates of relative true positive rates and false positive rates had very wide confidence intervals.

Our estimates for the costs associated with implementation of ThinPrep ^®^, AutoPap^®^, and Papnet^®^ are based on a variety of sources, including the manufacturers. There is a wide range of estimates, and issues such as training costs, amortization of equipment, and labor costs are contestable. Our original estimate for one technology, based primarily on information from the manufacturer, was thought to be unacceptably low by every reviewer of the draft report except that manufacturer.

Because of the difficulty in estimating operating characteristics and costs that have face validity for all readers, we decided that presenting cost-effectiveness estimates for generic technologies across the range reported would ultimately prove more useful to readers than selecting base case estimates that were uncertain and lacked face validity. Our alternative approach is to provide cost-effectiveness estimates across a range of test characteristics and incremental costs and to identify ranges of these parameters (thresholds) that lead to cost-effective cervical cancer screening. This allows readers to use their own judgment about which costs and effectiveness measures are most appropriate. The thresholds also provide a "target" for future studies -- convincing evidence of either cost or effectiveness that meets these threshold values will be evidence for acceptable cost-effectiveness. To perform this analysis, we considered two generic strategies for improving Pap sensitivity -- 3/4improving the sensitivity of the initial screening test, or allowing 100 percent rescreening with improved sensitivity. By varying sensitivity, specificity, incremental cost, and screening frequency, we sought to identify threshold values where the incremental cost per life-year saved was within generally acceptable limits (in this case, we used a threshold value of $50,000/life-year).

To address the general question of what would constitute a substantially valuable improvement in Pap technology, we reframed the specific question to be addressed by the cost-effectiveness modeling to: "What are the ranges of incremental cost, sensitivity, specificity, and screening frequency that meet conventional levels of cost per life-year saved for technologies that improve Pap test performance by (1) improving the sensitivity of the initial screening step, or (2) allowing 100 percent rescreening at improved sensitivity?"

Also, since some decisionmakers prefer presentation of specific outcomes rather than an aggregate outcome, the incremental cost-effectiveness ratio, we pursued a secondary question: "What are the expected number of cervical cancer cases, deaths, and treatments prevented at different levels of test sensitivity and screening frequency?"

### Structure of the Model

For the cost-effectiveness analysis, we constructed a model with two major components. The first component is a 20-state Markov model (Sonnenberg and Beck, 1993) intended to simulate the natural history of cervical cancer in the absence of screening. The second component is an intervention model that represents possible screening strategies. The model was developed in DATA 3.0 software (Boston, MA: TreeAge Software, Inc).

#### Natural History

The model follows a cohort of women from age 15 to 85 and assumes that, at the beginning of the simulation, the prevalence of HPV infection is 10 percent and the prevalence of LSIL is 1 percent. Cycle lengths are 1 year long. Women infected with HPV can undergo regression, no change, or progression. Although most progress from HPV to LSIL, a proportion progresses directly to HSIL. Women with LSIL can undergo regression (to either "Well" or the HPV-infected state), no change, or progression to HSIL. Women with HSIL can regress, stay in the same state, or progress to Stage I cancer. Women with cancer either become symptomatic or progress through Stages II-IV. Once a cancer diagnosis is made, the probability of survival is stage-specific. Women without cancer are at risk for hysterectomy for other causes, and all women are at risk for death from other causes. The states and transitions of the natural history model are shown in Table 1.

Table 1. Markov Model Description

State | Definition | Allowable Transitions
Well | Never infected with HPV, no history of SIL | Well, benign hysterectomy, death from other cause, undetected HPV
Benign hysterectomy | Hysterectomy for cause other than cervical cancer or SIL | Benign hysterectomy, death from other cause
Death from other cause | Death from cause other than cervical cancer | Absorbing state
Death from cervical cancer | Death from cervical cancer | Absorbing state
Undetected HPV | Undiagnosed cervical HPV infection | Well, death from other cause, benign hysterectomy, undetected HPV, LSIL
Detected HPV | Diagnosed cervical HPV infection or posttreatment for SIL | Well, detected HPV, death from other cause, benign hysterectomy LSIL, HSIL
LSIL | Low-grade squamous intraepithelial lesion | LSIL, death from other cause, benign hysterectomy, undetected HPV, detected HPV, well, HSIL
HSIL | High-grade squamous intraepithelial lesion | HSIL, death from other cause, benign hysterectomy, detected HPV, undetected HPV, LSIL, well
Unknown Stage I | Undiagnosed Stage I cervical cancer | Unknown Stage I, detected Stage I, death from other cause, unknown Stage II
Detected Stage I | Stage I cancer diagnosed by Pap or symptoms | Detected Stage I, death from cervical cancer (over 5 years), death from other cause
Stage I survivor | 5 years after initial diagnosis of Stage I | Stage I survivor, death from other cause
Unknown Stage II | Undiagnosed Stage II cervical cancer | Unknown Stage II, detected Stage II, death from other cause, unknown Stage III
Detected Stage II | Stage II cancer diagnosed by Pap or symptoms | Detected Stage II, death from cervical cancer (over 5 years), death from other cause
Stage II survivor | 5 years after initial diagnosis of Stage II | Stage II Survivor, death from other cause
Unknown Stage III | Undiagnosed Stage III cervical cancer | Unknown Stage III, detected Stage III, death from other cause, Unknown Stage IV
Detected Stage III | Stage III cancer diagnosed by Pap or symptoms | Detected Stage III, death from cervical cancer (over 5 years)
Stage III survivor | 5 years after initial diagnosis of Stage III | Stage III Survivor, death from other cause
Unknown Stage IV | Undiagnosed Stage IV cervical cancer | Unknown Stage IV, detected Stage IV, death from other cause
Detected Stage IV | Stage IV cancer diagnosed by Pap or symptoms | Detected Stage IV, death from cervical cancer (over 5 years)
Stage IV survivor | 5 years after initial diagnosis of Stage IV | Stage IV survivor, death from other cause

Cervical cancer is staged clinically. The two most commonly used staging systems are the Federation Internationale de Gynecologie et Obstetriques (FIGO) staging system and the Tumor, Nodes and Metastases (TNM) staging system of the American Joint Committee on Cancer (AJCC). The two systems are compatible as described in the AJCC Manual (American Joint Committee on Cancer, 1997). The FIGO staging system is described in Table 2.

Table 2. FIGO Staging of Cervical Cancer

Stage | Definition
| 0 Carcinoma in situ (corresponds to CIN III or HSIL) Ia Confined to the cervix, detectable by microscopy only, depth of invasion not greater than 3 mm in depth or 7 mm in width Ib Confined to the cervix, larger than Ia IIa Involvement of upper 2/3 of vagina, no parametrial involvement IIb Involvement of parametria but not to pelvic sidewall IIIaInvolvement of lower 1/3 of vagina but not to pelvic sidewall if parametria involved
IIIb | Extension to pelvic sidewall and/or hydronephrosis or nonfunctioning kidney
IVa | Involvement of mucosa of bladder or rectum
IVb | Distant metastasis or disease outside of pelvis

Because cervical cancer is clinically staged, findings at exploratory surgery or during subsequent treatment do not change the stage. Progression of disease also does not change the stage. In addition, imaging modalities such as computerized axial tomography (CAT) scanning or magnetic resonance imaging (MRI), while useful in determining the extent of the disease, are not permitted to be used in assigning stage.

The FIGO staging system is not used by the Surveillance, Epidemiology, and End Results (SEER) Program of the National Cancer Institute, the source of the most reliable estimates of cervical cancer incidence and mortality. SEER reports cancer stages as "Local," "Regional," and "Distant." This classification is also used in the MEDSTAT data we used to generate cost estimates associated with cervical cancer. Although cervical cancer staging does not create as many difficulties in synthesizing data for the purposes of constructing a model as does the variety of classification systems for preinvasive cervical changes, there are still some issues that must be addressed.

First, the definition of Stage 0 has changed with time. Initially, this referred only to carcinoma in situ (CIS). Subsequently, when carcinoma in situ was included as CIN3, lesions that previously would not have been included as cervical cancer cases were classified as such at some SEER sites. Adaptation of The Bethesda System further increases the potential number of cases, since lesions previously classified as CIN2 are included along with CIN3 and CIS in the HSIL classification. Because of this, cases that would not meet FIGO criteria for invasive cancer may be included in SEER data (Noller, 1996).

Second, it is unclear whether the Local/Regional/Distant classification is based on clinical, radiological, or surgical findings. Cervical cancer spreads most commonly by local extension and/or by lymphatic spread. The likelihood of pelvic lymph node metastases increases with advancing FIGO stage (DiSaia and Creasman, 1997), but if the diagnosis of nodal metastases is made on the basis of surgery or imaging modalities such as CAT or MRI, the initial FIGO stage should not change.

### Interventions

#### Screening strategies

We compared no Pap smear screening to the following screening strategies: (a) conventional Pap smears at 1-, 2-, and 3-year intervals; (b) a technology that improves the initial screening step, increasing overall test sensitivity by 40, 60, or 90 percent at 1-, 2-, and 3-year intervals; and (c) a technology that allows 100 percent rescreening, again increasing overall test sensitivity by 40, 60, or 90 percent at the same screening intervals. Strategies for the evaluation of abnormal cytological results are discussed below. The intervention strategies are illustrated in Figures 3 - 9 . We compared screening with the different technologies at intervals of 1, 2, and 3 years, since this reflects current recommended maximum screening intervals in the United State (U.S. Preventive Services Task Force, 1996). Although several European countries recommend screening at 5-year intervals (Koopmanschap, van Oortmarssen, van Agt et al., 1990), no American organization recommends a screening interval of longer than 3 years.

Figure 3. Distribution of Pap results based on primary and rescreening steps. The model assumes that the sensitivity of cytological screening using an ASCUS threshold is identical for all histological states

Figure 9. Distribution of cytological results for women with the cancer. For a sensitivity of 51 percent, 49 percent of results after the primary screening step will be normal, 6.2 percent ASCUS, 3.7 percent LSIL, 10.6 percent HSIL, and 30.6 percent cancer

We did not model combinations of screening intervals--for example, every 3 years after three consecutive negative annual Pap tests as recommended by the American Cancer Society (U.S. Preventive Services Task Force, 1996). Modeling such strategies significantly increases the complexity of the model. A model derived from age-specific incidence rates in unscreened populations suggests that the age at which screening occurs, rather than the interval between screens or the number of preceding negative smears, is the most important determinant of screening efficiency (Gustafsson and Adami, 1992). This is consistent with the natural history of the disease, where the incidence and prevalence of low-grade lesions that are unlikely to progress are high in younger ages, and high-grade lesions have peak incidence and prevalence between ages 30 and 45. Thus, three negative annual smears at age 18 or 20, just when HPV incidence is peaking, might have a low predictive value for the development of lesions 15-20 years later and would not significantly improve screening efficiency.

#### Diagnostic Strategies for Abnormal Pap Tests

We assumed that any cytologic result of HSIL or cancer will result in immediate referral for colposcopy and biopsy if warranted and that endocervical curettage is performed routinely as part of the colposcopic evaluation. Because not every patient will undergo endocervical curettage, this assumption may overestimate the sensitivity of colposcopy and overestimate the average cost of colposcopy. However, because we use the global estimate for the evaluation of LSIL and HSIL in the base case and vary these costs in sensitivity analysis, this assumption should not have a major impact on the cost-effectiveness estimates. We also assumed that a colposcopic or histologic diagnosis that is significantly less advanced than the cytologic result (for example, a biopsy result of LSIL in the setting of a cytologic diagnosis of cancer, or a biopsy result of normal in the setting of cytologic HSIL) would result in either a cone biopsy or a loop electrosurgical excision procedure (LEEP) (DiSaia and Creasman, 1997) after the exclusion ofdisease elsewhere in the lower genital tract.

We compared two possible strategies for the management of ASCUS and LSIL. In the base case, we assumed that all patients with LSIL or higher will receive colposcopy, whereas those with ASCUS will receive a repeat smear within 6 months, followed by a colposcopy if abnormal. Because this strategy depends on a Pap of high sensitivity (since colposcopy depends on the persistence of an abnormality), we used this in the base case. We also evaluated an "aggressive" strategy where any Pap with a result of ASCUS or higher is referred for colposcopy as the base case, since this should result in the highest detection rate. Both of these strategies are within current American College of Obstetricians and Gynecologists (ACOG) recommendations

### Measures of Effectiveness

We estimated the cost-effectiveness of cervical cytology using several outcomes. First, we calculated the cost per year of life saved. This allows comparison with other health interventions and with other cost-effectiveness analyses of cervical cancer screening. However, use of life expectancy, or life-years saved, may underestimate some of the benefits of screening. Early-stage cervical cancer is slow-growing and has a very high cure rate (approximate 85-90 percent 5-year survival for Stage I tumors). Thus, failure to detect preinvasive lesions that are then detected as Stage I tumors will not result in much decrement in life expectancy. However, the therapeutic options for all but the most minimally invasive Stage I tumors are radical hysterectomy or radiation therapy, both of which have substantial short- and long-term morbidity that may have significant impact on quality of life.

We were unable to identify any data that would allow calculation of quality-adjusted life years. We therefore calculated other outcomes that can be used to draw some inferences about morbidity. We produced estimates of cost per cervical cancer death prevented and per cervical cancer case prevented. In addition, by estimating the number of cases presenting in each stage and using data on the probability of specific treatments by stage, we also estimated the number of morbid therapies avoided using different screening strategies.

### Assumptions of the Model

#### Perspective

We used a U.S. health system perspective and evaluated the direct health care specific costs associated with screening, diagnosis, and treatment of cervical cancer and its precursors. We did not consider other societal costs such as direct nonmedical costs (e.g., costs attributable to work lost by patients or caregivers due to screening, diagnosis, treatment, or premature mortality). A societal perspective that included these costs would be preferable (Gold, Siegel, Russell et al., 1996); however, estimating these costs (for example, wage/wage equivalent costs, transportation time, and time lost while waiting for an appointment) would be extremely difficult. Invasive cervical cancer is a disease affecting mostly midlife and older women, whereas the much more common HPV infection and SIL, most of which do not progress to cervical cancer, are seen primarily in younger women; therefore, it seems likely that the nonhealth care costs associated with screening and treatment of SIL are greater than those associated with the diagnosis and treatment of invasive cervical cancer. If this is true, then the cost-effectiveness of screening, and of new technologies to improve screening performance, will be more favorable from a health care system perspective than from a societal perspective, especially if new technologies increase sensitivity at the expense of specificity.

#### Discount Rate

We discounted costs and years of life at 3 percent annually in the base case and varied the discount rate from 0 to 5 percent in sensitivity analysis (Gold, Siegel, Russell et al., 1996).

#### Population

Our model follows a cohort of U.S. women from age 15 through 85. We calculated screening strategies as described above beginning at age 15, at age 18 (as recommended by ACOG), at age 20 (Eddy, 1990), at age 35 (Gustaffson and Adami, 1992), at age 50, and at age 65 (Fahs, Mandelblatt, Schechter et al., 1992). We also varied the incidence and progression rates of HPV and SIL to reflect higher risk populations. However, it is likely that other parameters in the model would also be affected in these populations (for example, smoking, which is associated with higher rates of preinvasive and invasive cervical cancer, is also associated with a higher risk of mortality from other causes).

#### Histological Subtypes of Invasive Cervical Cancer

Squamous cancer of the cervix accounts for approximately 80-85 percent of invasive cervical cancer cases. Adenocarcinoma, which accounts for another 10-15 percent, may be increasing in incidence (DiSaia and Creasman, 1997). Cervical cytology may also be less sensitive for adenocarcinoma. However, we did not distinguish between histologic subtypes in any of our estimates for screening or treatment. This is consistent with other models.

Similarly, the clinical implications of a cytological diagnosis of ASCUS (atypical SQUAMOUS cells of uncertain significance) and AGUS (atypical GLANDULAR cells of uncertain significance) appear to be quite different. A cytological diagnosis of AGUS may be associated with premalignant or malignant changes of the cervix or uterus in as many as 30-35 percent of cases (Veljovoich, Slater, Anderson et al., 1998). The diagnostic evaluation of AGUS usually involves endometrial biopsy as well as colposcopy and endocervical curettage. When ASCUS and AGUS are combined for purposes of conditional probabilities, the proportion of true histological lesions with cytologic diagnoses of atypia is increased. Using ASCUS as our threshold has the overall effect of increasing the sensitivity of screening. Given the relatively low proportion of AGUS as a diagnosis (0.3%), this is unlikely to have a significant impact on our cost-effectiveness estimates.

#### Patient and Provider Behavior

Our model assumes that all women in the cohort receive the screening test at the appropriate interval and that all patients receive appropriate diagnostic and therapeutic interventions based on the results of the screening tests. Lack of appropriate followup on the part of the patient or provider accounts for a significant proportion of cervical cancer cases (Janerich, Hadjimichael, Schwartz et al., 1995), and lack of patient compliance with treatment has been shown to increase the marginal cost-effectiveness of other screening tests (Myers, Thompson, and Simpson, 1998). Between 30 and 75 percent of women with abnormal Pap smears results do not return for followup (Paskett and Rimer, 1995; Paskett, Carter, Chu et al., 1990). We did not directly test the impact of postscreening behavior on cost-effectiveness estimates. However, patient failure to return for followup visits, or inappropriate management by providers, clearly decreases the effectiveness of a screening program. The actual cost-effectiveness of any screening program will vary depending on patient and provider behavior.

We also did not test the impact of complete lack of screening on the overall cost-effectiveness of different screening strategies. A model based on Dutch data showed that increasing participation was significantly more cost-effective than decreasing screening intervals (Koopmanschap, van Oortmarssen, van Agt et al., 1990). The proportion of women with no prior screening in series of women with invasive cervical cancer is between 30 and 40 percent (Bearman, MacMillan, and Creasman 1987; Janerich, Hadjimichael, Schwartz et al., 1995; Pretorius, Semrad, Watring et al., 1991; Schwartz, Hadjimichael, Lowell et al., 1996). Current Public Health Service estimates are that 5-10 percent of women have never had a Pap smear (Martin, Calle, Wingo et al., 1996). Clearly, the issue of the appropriate allocation of resources for improving the sensitivity of current screening tests versus improving the utilization of any screening test in women who are unscreened or underscreened is important for policymakers to consider. Given reliable estimates of the costs and effectiveness of interventions designed to improve screening rates, this model could be further developed to explore this issue. However, estimating the effectiveness of programs to improve participation in screening is difficult and is beyond the scope of the current report.

#### Further Assumptions

Specific assumptions associated with individual model parameters are discussed in detail in the appropriate sections. Our overall aim in selecting base case estimates was to bias the model in favor of more sensitive screening strategies. In addition to the use of a health system perspective (likely creating a bias in favor of more sensitive screening strategies as mentioned above), the following assumptions were incorporated into the cost-effectiveness model:

1 We chose an age-specific incidence rate for cervical cancer 30 percent higher than that reported in the unscreened U.S. population of the 1930s.
2 We chose estimates for progression rates from HPV to LSIL, from LSIL to HSIL, and from HSIL to cancer at the higher end of the reported ranges.
3 We used a base case estimate of conventional Pap sensitivity that is considerably lower than that used in most previous models of cervical cancer screening.
4 Our cost estimates for the diagnosis and treatment of cervical cancer are based on average global diagnosis and treatment charges. Because these incorporate the full range of outcomes, including complications, they are considerably higher than estimates based on average charges for the components of care, the technique used in previous models. The higher the estimated cost of treating cancer, the greater the potential savings from etection and treatment of premalignant lesions.
5 We assumed that the diagnostic evaluation of abnormal cervical cytology would detect all true histological abnormalities. Failure of colposcopy and biopsy to detect true premalignant or malignant lesions would decrease the clinical effectiveness of screening, therefore increasing the cost-effectiveness ratio.
6 We assumed that all patients with abnormalities on cervical cytology would receive appropriate followup and treatment. Failure of the patient to return for appropriate followup, or of the provider to institute appropriate followup, decreases the clinical effectiveness of screening, again increasing the cost-effectiveness ratio.
7 We assumed in the base case that new technologies would increase sensitivity without any decrement in specificity.
8 Although Pap smears can detect vaginal or cervical infections with organisms such as Candida, Trichomonas, or Chlamydia, we did not consider the impact of detection of these diseases. Other tests are available for the detection of these organisms that are more sensitive and specific than Pap screening.

These assumptions favor strategies that increase the detection of premalignant and early malignant changes; therefore, our assumptions tend to favor more sensitive screening strategies.

### Parameter Estimates from Available Data: Natural History

The sources and rationale for specific transition probability estimates and ranges for sensitivity analysis are discussed in detail below. Some transition probabilities are based on large datasets using standard reporting methods (e.g., age-specific death or hysterectomy rates, or stage-specific mortality for cervical cancer); in such cases, estimation was relatively straightforward. However, some transition probabilities had to be estimated from smaller datasets that used nonstandard reporting; in these cases, it was difficult to estimate transition probabilities related to HPV and SIL from reports of incidence, regression, persistence, and progression rates probabilities (Miller and Homan, 1994). Regression and progression are usually reported as percentages of either prevalent or incident infections, with followup time varying widely among studies. In addition, very few data are available that allow calculation of transition probabilities for untreated cervical cancer, such as the annual stage-specific probability of symptom development or the annual probability of progression between stages. Estimates for these probabilities were derived from the literature and prior published models of cervical cancer screening, especially those of Eddy (1990) and Muller, Mandelblatt, Schechter et al. (1990), which have served as the basis for several subsequent models (Brown and Garber, 1998; Radensky and Mango, 1998; Schechter, 1996).

#### Hysterectomy for Benign Disease

Age-specific hysterectomy rates from the National Hospital Discharge Survey (Lepine, Hillis, Marchbanks et al., 1997) and Maryland discharge data (Kjerluff, Guzinski, Langenberg et al., 1993) were used to estimate age-specific hysterectomy rates. We did not correct these rates for procedures performed for cervical cancer or preinvasive disease for two reasons. First, because the rates do not include radical hysterectomies for invasive cervical cancer, which have a separate International Classification of Diseases, ninth revision (ICD-9) code. Second, the proportion of procedures performed for preinvasive diseases is relatively small, less than 2 percent of all procedures over a 6-year period in North Carolina (E. Myers, unpublished data, 1998).

We did not correct for hysterectomy prevalence in our natural history model, since most population-based cancer incidence rates do not do so. However, since the relative likelihood of hysterectomy with removal of the cervix clearly affects an individual's risk for developing cervical cancer, we included this factor in the cost-effectiveness model and tested the impact of doing so on cost-effectiveness estimates. We did not specifically address continued cytological screening after hysterectomy because of questions about its effectiveness (Fetters, Fischer, and Reed, 1996) and because posthysterectomy Pap smears are screening tests for vaginal cancer, not cervical cancer.

We also did not consider the effectiveness of conventional Pap smears or the new technologies in the followup of treatment for invasive cervical cancer. Our analysis is limited to the use of cervical cytology in screening for previously undetected disease, not the detection of persistent or recurrent cancer after treatment. Costs for followup smears are included in the global estimates of treatment and followup costs.

#### Human Papillomavirus (HPV) Infection

Although not essential for the current analysis, HPV is included in the model. In this section, we document this component of our cervical cancer screening model is documented.

##### Incidence of HPV infection

The model assumes that all cases of cervical cancer begin with infection with human papillomavirus. We have incorporated HPV status into the model for two reasons. First, although a small percentage of cervical cancers do not have detectable HPV DNA, even with sensitive assays, there is consensus that HPV infection is the causative agent for the vast majority of cervical cancers (Herrero, 1996; Kiviat, 1996; Koutsky, 1997; Schiffman, Bauer, Hoover et al., 1993). Second, certain HPV types are clearly more likely to progress to cancer than others, and identification of these types in cervical cells may have a role in determining optimal diagnostic and treatment strategies for patients with abnormal Pap smears (Cox, Lorincz, Schiffman et al., 1995). Although this role is still unclear, the current model can be adapted in the future to allow consideration of technologies such as HPV testing in screening for cervical cancer and its precursors. In addition, incorporating HPV data also allows our model to be used for assessing the cost-effectiveness of vaccines against HPV.

The natural history of HPV infection is complex, with clearance and persistence of viral DNA, along with progression to SIL, varying depending on the viral type, patient characteristics such as age and immune status, and study design and assay methods (Herrero, 1996; Kiviat, 1996; Koutsky, 1997; Mitchell, Tortolero-Luna, Wright et al., 1996; Schiffman, Bauer, Hoover et al., 1993). We do not distinguish between different types of HPV. Our incidence, progression, and regression estimates are averages for all viral types. The risk of developing cervical cancer after infection is clearly related to HPV type. With further data on the test characteristics of screening tests incorporating HPV typing, this model can be adapted for estimating the utility and cost-effectiveness of such tests.

We used the following baseline age-specific estimates for HPV incidence in the model and varied them over ranges that, combined with our estimates of regression and progression, resulted in age-specific prevalence of HPV infection and age-specific incidence of cervical cancer within the ranges reported in the literature (Table 3). We varied the incidence rates by factors of 0.5-2 to examine the effects of changing HPV incidence on cervical cancer incidence in unscreened populations. We also varied the age of peak incidence from 20 to 30 in order to examine the effects of a later onset of sexual activity on age-specific cervical cancer incidence.

Table 3. Age-specific Annual Incidence of HPV Infection

Age | Incidence (percent per year)
15 | 0.1
16 | 0.1
17 | 0.12
18 | 0.15
19 | 0.17
20 | 0.15
21 | 0.12
22 | 0.1
23 | 0.1
24-29 | 0.05
30-49 | 0.01
50+ | 0.005

##### Regression, persistence, and progression of HPV infection

Estimates of regression and progression rates of HPV infection are subject to variability in study design, patient population, and viral assay techniques and are complicated by the mathematical difficulty of converting rates to probabilities. Reported regression rates for prevalent cases include 70 percent after 2 years in a cohort of adolescents and college-age women (Moscicki, Shiboski, Broering et al., 1998), 68 percent over 14 months for women under 25, and 35 percent for women over 30 (Hildesheim, Schiffman, Gravitt et al., 1994). Ho, Bierman, Beardsley et al. (1998) reported a 1-year regression rate of 70 percent. All of these results were in women with normal cytology. The overall regression rate in a large Finnish cohort was 42.8 percent over 50 months (Kataja, Syrjanen, Mantyjarvi et al., 1989; Kataja, Syrjanen, Syrjanen et al., 1990). However, determination of disease status in this group was made on the basis of cytological evidence of HPV infection. Under the Bethesda System, these would be classified as LSIL.

As with incidence, regression rates and possibly progression rates appear to vary with age. Whether this is truly related to age or is a function of duration of infection (the longer HPV persists, the less likely it is to regress) is unclear. Again, this question can be further explored with the current model. For the purposes of a cohort simulation, there is not much difference between an age-based or duration-based progression rate as long as the age-specific incidence is constant.

Progression rates are equally difficult to determine. Moscicki, Shiboski, Broering et al.(1998) reported progression to SIL in 15.7 percent over 40 months, and 7.6 percent of these progressed directly to HSIL. Ho, Bierman, Beardsley et al. (1998) reported a cumulative 36-month incidence of SIL of approximately 25 percent, and 6.5 percent of these were high-grade lesions. Koutsky, Holmes, Critchlow et al. (1992) found a 2-year cumulative incidence of HSIL of 28 percent in women with HPV DNA, and only 36 percent of these had had a prior LSIL smear. Consistent with our other estimates, our base case estimates (Table 4) are derived from the higher end of the reported ranges. Cases that progress directly to HSIL are similar to the "rapidly progressive" cases of the Eddy (1990) model. Again, we varied age-specific regression rates in order to achieve an age-specific cancer incidence curve similar to that seen in unscreened populations.

Table 4. Regression and Progression Rates of HPV Infection

Rate | Estimate | Range
Regression:
Age 15-24 | 0.7/18 months | 0.60-0.9
Age 25-29 | 0.50/18 months | 0.45-0.6
Age 30-39 | 0.25/18 months | 0.10-0.2
40-49 | 0.15/18 months | 0.10-0.2
Age 50 + | 0.05/18 months | 0.05-0.2
Progression: | 0.2/36 months | 0.15-0.3
Proportion progressing to HSIL directly | 0.1 | 0.05-0.5

Because there is some uncertainty in the literature about whether treatment of SIL results in total eradication of HPV, we created a Diagnosed HPV state to represent women who have been treated for SIL. We assumed that the probability of progression was 5 percent of the age-specific progression rates. This is equivalent to a 95 percent cure rate for SIL treatment used in other models (Eddy, 1990; Fahs, Mandelblatt, Schechter et al., 1992; Schechter, 1996).

#### Low-grade and High-grade Squamous Intraepithelial Neoplasia

Determining transition probabilities from the literature that accurately reflect natural history is as problematic for SIL as it is for HPV infection. The difficulties in converting rates collected over varying, often unspecified times and in heterogeneous populations are further magnified by differences in terminology. For example, many studies report transitions from HPV-associated cytologic changes to CIN 1 to CIN 2 to CIN 3 to CIS, which may be difficult to translate into the Bethesda System terminology of LSIL and HSIL. For our base case, we use the estimates of Syrjanen, Kataja, Yliskoski et al. (1992), the largest cohort that reports results using the Bethesda System. We assume an age dependence in regression and progression rates (Hildesheim, Schiffman, Gravitt et al., 1994; Munoz, Kato, Bosch et al., 1996; van Oortmarssen and Habbema, 1991). The length of time for HSIL progression is more difficult to estimate from these data than the other parameters; in this cohort, all patients who progressed to carcinoma in situ under an older classification system were treated. Prior models have estimated the duration from severe dysplasia/CIS to invasive cancer of 10-15 years. We use 12 years for the base case (Table 5), since this interval resulted in an age-specific incidence of cervical cancer most consistent with observed data.

Table 5. Progression and Regression Estimates for LSIL and HSIL

| Estimate | Range
LSIL
Regression
Age 15-34 | 0.65/72 months | 0.6-0.8
Age 35 + | 0.4/72 months | 0.3-0.6
Progression
Age 15-34 | 0.1/72 months | 0.1-0.3
Age 35 + | 0.35/72 months | 0.3-0.5
HSIL
Regression | 0.35/72 months | 0.3-0.5
Progression | 0.4/120 months | 0.3-0.5

#### Conditional Probabilities of Cytologic Results for Given Histologic States

Because the model is based on transitions from true histological states of LSIL, HSIL, and invasive cancer and Pap smear results are categorical, the probability of a particular cytological diagnosis for a given histological state requires estimates beyond "sensitivity" and "specificity" for cytology.

In the model, any Pap smear result of ASCUS or above is considered abnormal. For patients without histological changes (Well, Unknown HPV Infection, and Detected HPV Infection), the probability of a normal smear will be the specificity of the Pap smear or other test for a cytological threshold of ASCUS or above, since specificity is defined as the probability of a normal test result given no pathology, whereas the probability of an abnormal result, or false positive, is 1.0 minus the specificity.

For patients with histological changes (LSIL and higher), our base case estimate of the overall probability of an abnormal result is equal to our sensitivity estimate, using an ASCUS threshold, from the three studies by Baldauf, Dreyfus, Lehmann et al. (1995); Davison and Marty (1994); and Hockstad (1992). This estimate was 51 percent. We varied the sensitivity up to 78 percent, the mean estimate of the meta-analysis.

For the base case for conventional Pap smears, we used an estimate of specificity based on the three studies of the use of conventional Pap smear in primary screening that were unaffected by verification bias (Baldauf, Dreyfus, Lehmann et al., 1995; Davison and Marty, 1994; Hockstad, 1992). This estimate is 97 percent, which we varied down to 0.88 percent, the mean specificity estimate for all of the studies included in the meta-analysis. For the base case, we assumed that new technologies would have no impact on specificity. We varied the relative specificity of the new technologies from a 50 percent increase in specificity to a 50 percent decrease in specificity.

Abnormal results on Pap testing include ASCUS, LSIL, HSIL, and cancer. For each histological state, we calculated the proportion of all abnormal results represented by each possible cytological diagnosis using data from a large data set of biopsy-cytology pairs (Jones and Novis, 1996). For our model, we collapsed the categories as follows: ASCUS and AGUS = ASCUS (this is not meant to imply comparability in the relative clinical significance of these two diagnoses, but rather only to simplify the calculations, as discussed below), indeterminate SIL and LSIL = LSIL, any malignancy or glandular carcinoma-in-situ = cancer. Because data correlating ThinPrep^®^, AutoPap^®^, or Papnet^®^ results with histological results were limited, we assumed that these proportions are similar for new technologies. We present these proportions graphically in Figures 3 - 9

Figure 4. Effect of a new technology that improves the sensitivity of the primary screening step on the distribution of normal and abnormal Pap results. The model assumes that 10 percent of slides intially read as normal are rescreened at the sensitivity and specificity of the new technology.

Figure 6. Distribution of Pap results when underlying histology is normal(including patients with HPV infection but no cytological or histological change) (Jones and Novis, 1996). If specificity of conventional Pap is 97 percent, then 97 percent of cytology results will be normal, 3 percent X 52.5 percent = 1.6 percent will be ASCUS, 1.2 percent LSIL, 0.3 percent HSIL, and 0.01 percent cancer after the primary screening step

Figure 7. Distribution of specific abnormal Pap results when underlying pathology is LSIL. If sensitivity is 51 percent, then 49 percent of patients with LSIL will have initially Paps, 51% X 23.5% = 12.0 percent will have ASCUS, 34.8 percent LSIL, 4.1 percent HSIL, and 0.08 percent cancer as the cytological diagnosis.

Figure 8. Distribution of cytological resutls for underlying histological diagnosis of HSIL. At sensitivity of 51 percent, 49 percent of Paps will be normal, 5.3 percent will be ASCUS, 15.3 percent LSIL, 29.9 percent HSIL, and 0.56 percent cancer.

We assumed that the sensitivity of the screening test is independent of the underlying histology. In other words, the sensitivity using an ASCUS threshold is identical for LSIL, HSIL, or cancer. This assumption may not be true. This is a complex issue that would be difficult to model in a useful way. In keeping with other models, we have assumed constant sensitivity and specificity across histological states. Misclassification of cases, whether to a higher or lower stage, could significantly alter procedure or cost parameters.

#### Natural History of Invasive Cancer

As stated above, there are almost no data for estimating the rates of progression from Stage I through Stage IV cervical carcinoma. There is also no way to determine the likelihood of developing symptoms. Since the distribution of cases by stage in an unscreened population should be a function of the progression rate and the likelihood of symptoms (since cases would only be detected upon presentation with symptoms), we have adopted the approach taken by others (Eddy, 1990; Fahs, Mandelblatt, Schechter et al., 1992) and adjusted these estimates so that the proportion of cases represented by each stage is similar to that seen in cervical cancer patients who have never been screened (Bearman, MacMillan, and Creasman, 1987; Janerich, Hadjimichael, Schwartz et al., 1995; Pretorius, Semrad, Watring et al., 1991; Schwartz, Hadjimichael, Lowell et al., 1996). Our base case estimates are described in Table 6.

Table 6. Progression Rates for Cervical Cancer Stages I through IV

Cancer Stage | Progression Rate | Annual Probability of Symptoms | Proportion of Cases in Unscreened Population Predicted by Model | Proportion Reported in Literature
I | 0.9/4 years | 0.15 | 0.463 | 0.34-0.55
II | 0.9/3 years | 0.225 | 0.270 | 0.13-0.28
III | 0.9/1.25 years | 0.6 | 0.181 | 0.12-0.19
IV | N/A | 0.9 | 0.085 | 0.06-0.10

#### Stage-Specific Treatment Probabilities

The proportion of women in each stage of cervical cancer who received a specific treatment was estimated using 1990 data from the American College of Surgeons' Patient Care Evaluation (PCE) study for cervical cancer (A. Fremgen, personal communication to E. Myers, 1998; Jones, Shingleton, Russell et al., 1995; Russell, Shingleton, Jones et al., 1996). Table 7 shows the stage-specific data. Of note, 21.8 percent of the patients in this dataset had an unknown stage. Of those, almost one-half were treated with either a simple or radical hysterectomy, suggesting that most were earlier stage disease.

Table 7. Stage-specific Treatment Probabilities

Treatment | Stage I | Stage II | Stage III | Stage IV
Simple hysterectomy | 0.146 | 0.006 | 0.004 | 0.003
Radical hysterectomy | 0.355 | 0.043 | 0.013 | 0.009
Radiation therapy | 0.204 | 0.647 | 0.537 | 0.398
Radiation therapy and surgery | 0.146 | 0.072 | 0.046 | 0.017
Radiation therapy and chemotherapy | 0.022 | 0.161 | 0.320 | 0.307
Chemotherapy only | 0.002 | 0.004 | 0.004 | 0.103
Other therapy | 0.038 | 0.028 | 0.027 | 0.020
No Therapy | 0.087 | 0.039 | 0.049 | 0.143

These proportions were used to calculate the number of specified procedures resulting from each diagnosed case of a specific stage of cervical cancer predicted by the model. These proportions were also used to generate estimates of stage-specific treatment costs (see below).

#### Stage-Specific Survival

Survival probabilities at 1, 2, 3, 4, and 5 years postdiagnosis for each stage were obtained from PCE data (Fremgen, personal communication; Jones, Shingleton, Russell et al., 1995). These values were chosen because they represent data from a wide range of facilities treating women with cervical cancer. Five-year survival rates based on these data were Stage I, 86.0 percent; Stage II, 62.5 percent; Stage III, 37.9 percent; and Stage IV, 11.3 percent.

We assumed that there was no cancer-related mortality after 5 years. Although the PCE data show some deaths after 5 years in all stages, they are relatively rare compared with those in the first 5 years. Other models have also used 5-year survivals. The PCE data are disease-specific; patients are also at risk for other causes of death during the 5-year postdiagnosis period.

#### Non-Cervical Cancer Mortality

Mortality from causes other than cervical cancer was estimated by subtracting age-specific cervical cancer mortality rates from age-specific all-cause mortality rates using U.S. life tables for 1995 (obtained from the National Center for Health Statistics World Wide Web page: http://www.cdc.gov/nchswww/daa/gm291_1.pdf).

### Parameter Estimates from Available Data: Test Characteristics

We derived our estimates for conventional Pap sensitivity and specificity from the systematic literature review and meta-analysis. For sensitivity and specificity of the new technologies, we used articles reviewed under the revised criteria, the review of Brown and Garber (1998), and estimates provided by the manufacturers. The derivation of these estimates is described in greater detail below.

#### Conventional Pap Smear Test Characteristics

For conventional Pap smears, we used estimates of sensitivity and specificity from the meta-analysis for a cytological threshold of ASCUS and a histological diagnosis of LSIL or higher. For the base case, we used an estimate derived from the three studies not affected by verification bias (Baldauf, Dreyfus, Lehmann et al., 1995; Davison and Marty, 1994; Hockstad, 1992). These values have a sensitivity of 51 percent and a specificity of 97 percent. We varied this level up to the mean values of the test characteristics from the meta-analysis, 78.8 percent for sensitivity and 88.8 percent for specificity. However, these estimates, like those used in all previous models, assume that there are no joint effects for sensitivity and specificity, an assumption that is not confirmed by the meta-analysis.

The prevalence of underlying cervical neoplasia was a significant predictor of test sensitivity in both the meta-analysis of Fahey, Irwig, and Macaskill (1995) and in ours. We used sensitivity estimates based on fairly low prevalence estimates for the base case. We also did not account for the effect of increasing the screening interval on Pap sensitivity: Because prolonging the screening interval should increase the prevalence of the disease, Pap test performance should be better at longer screening intervals compared with shorter. We made no adjustment for this bias against longer screening intervals.

We assumed in the base case that the combination of history, pelvic examination, and Pap have a sensitivity of 100 percent in the diagnosis of Stage II, III, or IV cervical cancer (cancer that has spread beyond the cervix). Because, by definition, these tumors involve the vagina and/or parametrial tissues, the combination of a speculum and bimanual examination and cervical cytology should, in theory, detect all disease. This is especially true because cervical cancer is clinically staged. Therefore, the failure to detect malignancy cannot be attributed solely or, arguably, even primarily to a failure of cytology. We used a sensitivity of 85 percent as the lower bound.

#### Adequacy of Specimens

The adequacy of a cervical slide for interpretation can be affected by the presence of inflammatory cells, bloods, vaginal or cervical secretions, the number or type of cells collected, and other factors. The Bethesda System requires a statement of adequacy by the pathologist, along with the reason for any inadequacy. One category used is "Satisfactory but limited by" (SBLB)," which states the reason the interpretation of the slide may be compromised. The American College of Obstetricians and Gynecologists recommends that the decision to repeat a smear in such cases be made at the discretion of the individual practitioner.

A technology that improves the adequacy of the specimen may be superior to conventional techniques in two ways. First, the sensitivity of the smear may be enhanced because the slide may be easier to read and interpret. Second, the number of inadequate slides, and subsequent need for repeating the smear, may be reduced. New thin-layer technologies may produce both types of improvement. For example, in a large study of ThinPrep^®^, the number of "Satisfactory but limited by" smears was reduced from 27.8 percent with conventional smears to 19.8 percent (Lee, Ashfaq, Birdsong et al., 1997). However, of note, the number of smears that were inadequate because of a lack of endocervical cells was higher in the ThinPrep^®^ group in this same study (15.8 percent versus 9.4 percent for conventional smears). Many clinicians would argue that the absence of endocervical cells is of potentially greater significance than "Satisfactory but limited by" smears, since it may indicate that sampling of the transformation zone was inadequate or that lesions were missed in the endocervical canal. Although this finding may be a result of technical factors in the design of the study, the main issue is that the clinical significance of an "unsatisfactory" slide is widely variable.

Although we do not specifically address the issue of specimen adequacy in our model, we do address its consequences. First, we assume that the primary screening technology has improved sensitivity compared with conventional Pap. Second, reducing the number of "Satisfactory but limited by" smears may reduce costs by reducing the number of repeat smears. However, we are unaware of any data on the actual proportion of "Satisfactory but limited by" smears that are repeated in clinical practice. This will probably vary widely, depending on patient populations, perception of malpractice risk, reimbursement issues, etc. Previously published models of cervical cancer screening suggest that the risk of an undetected premalignant or malignant lesion in a patient with a history of regular normal smears is very small. It is likely that the number of repeat smears actually saved by reducing the "Satisfactory but limited by" category is less than the full 10 percent reported by Lee, Asfaq, Birdsong et al. (1997). There are several reasons for this. First, the compliance rate with followup for Pap smears that are truly abnormal is only 30-70 percent (Paskett and Rimer, 1995). Second, the most compliant patients are likely to be those at lowest risk. Third, ACOG has left the decision to repeat the smear up to the individual practitioner. A small pilot study by Paskett, Carter, Chu et al (1990) found that patient perception of the accuracy and severity of an abnormal report was a significant predictor of the likelihood of returning for followup. Even in the best case scenario, where 100 percent of providers would order a repeat smear for a "Satisfactory but limited by" result, the actual reduction in repeat smears would not be 0.08 (0.278-0.198) but instead would be between 0.027 (0.3 X 0.08) and 0.063 (0.7 X 0.08). In any event, the effect on the need for repeat specimens is primarily a cost issue, which we address by decreasing the extra cost of the new technology in sensitivity analysis.

#### New Screening Technologies

Because our estimates of conventional Pap smear sensitivity and specificity are based on a histological gold standard, there are limited data that allow direct comparison of the new technologies with conventional Pap smears. We have modeled the potential impact of these technologies on the cost-effectiveness of various screening strategies by assigning two separate sensitivity and specificity estimates, one for initial screening and one for rescreening. We assumed that 10 percent of all slides initially read as normal using either a conventional Pap or a hypothetical new technology will be rescreened. We also assumed that the new technology improves the sensitivity of the initial screening step with no decrement in specificity. We incorporated the cost of rescreening 10 percent of slides into the global cost estimate for Pap tests and further assumed that, with either of these procedures, the sensitivity and specificity of the rescreening step is identical to the initial step. We also tested the impact of 100 percent rescreening using an automated rescreening device, again with improved sensitivity and no decrement in specificity. Because of significant uncertainty about the actual changes in sensitivity and specificity of the new technologies, we have modeled their test characteristics as functions of the sensitivity and specificity of the conventional Pap smear.

#### Calculating Improvement in Test Characteristics

We approached the problem of calculating improvement in test characteristics in two ways:

1 As part of the reevaluation of new technology studies, we calculated relative true positive rates for studies where relative performance could be estimated. The relative TPR is the ratio of the true positive rate of a new technology to the true positive rate of the conventional test (TPRnt/TPRpap). For the studies of Roberts, Gurley, Thurloe et al. (1997) and Bolick and Hellman (1998), we calculated a relative TPR for ThinPrep^®^ of 1.16, with confidence limits from 0.9 to 1.4.
2 From the review of Brown and Garber (1998), we calculated the reduction in false negative rate based on their base case estimates of sensitivity and specificity for conventional Pap smears and the new technologies. Sensitivity of the new technology was related to the sensitivity of conventional Pap smear as a function of the parameter x using the following formula:

Sensitivity of New Technology = Sensitivity of Conventional Pap + [x * (1-Sensitivity of Conventional Pap)] (equation a).

This variable, x, is useful for modeling probabilities. We refer to this variable in the Results section as the reduction in false negative rate. For example, if x = 0.4, then there is a 40 percent reduction in false negative rate.

Note that since TPR is the same as test sensitivity, x is algebraically related to relative TPR and sensitivity of conventional Pap smear. That is,

x = [Sensitivity of Conventional Pap * (relative TPR -1)] / (1-Sensitivity of Conventional Pap) (equation b).

For example, Bolick and Hellman (1998) calculated a sensitivity of 0.94 for ThinPrep^®^ and 0.85 for conventional Pap. The relative true positive rate would be 1.11 (0.94/0.85). On the basis of equation a, these numbers correspond to a reduction in FNR (x) of 0.6, since

0.94 = 0.85 + [x * (1- 0.85)],

so,

x = (0.94 - 0.85) / 0.15 = 0.6.

From equation b, the reduction in FNR would also be 0.6, since

[0.85 * (1.11-1)]/(1 - 0.85) = 0.6.

#### Sensitivity Estimates for Initial Screening Step

One way to improve Pap test sensitivity is to improve the sensitivity of the initial screening step, either through reducing potential sampling errors and interpretive errors, such as monolayer preparations, or through interpretive errors only, such as computerized technologies. We modeled an improvement in sensitivity by using the reduction in false negative rate (see Figures 3 - 5). As mentioned previously, we assumed that 10 percent of normal smears would be rescreened at the same sensitivity and specificity as primary screening. As a starting point, we used data from studies of ThinPrep^®^ included in our meta-analysis as well as estimates of reduction in FNR used by Brown and Garber (1998) (Table 8).

Table 8. Calculations of Reduction in False Negative Rate for Initial Screening Technologies

Source | Thin Prep^®^ Sensitivity | Conventional Pap Sensitivity | Calculated Reduction in False Negative Rate
Roberts, Gurley, Thurloe et al (1997) | Relative TPR 1.13 | NA | 0.91 (assumes same sensitivity and specificity as Bolick and Hellman, 1998)
Bolick and Hellman, (1998) | 0.94 | 0.85 | 0.6
Brown and Garber (1998) | 0.91 | 0.8 | 0.55

Figure 5. Effect of a new technology that improves the sensitivity of the rescreening step on the distribution of Pap results. 100 percent of slides that are read as normal by conventional Pap are re-read at the sensitivity and specificity of the new technology

We therefore use 0.6 as our base case reduction in FNR for the initial primary step. For sensitivity analysis, we varied the estimate of reduction in FNR from 0.4 to 0.9. This range is consistent with the "50 percent increase in detection of disease" cited by the manufacturer (R.Silverman, personal communication to D.C. McCrory, 1998 ).

Because these values are calculated relative to the sensitivity of the conventional Pap testing using adjudicated review, they should, in theory, be independent of the actual sensitivity of the conventional Pap testing. In fact, this argument is the justification for not requiring histological confirmation studies for FDA approval of these technologies. Therefore, in our model, the base case sensitivity of the initial screening technology will be

0.51 + (0.6 * 0.49) = 0.804.

We assume that 10 percent of slides will be rescreened at the same improved sensitivity, for an overall sensitivity of

0.51 + (0.6 * 0.49) + (0.1 * 0.6 * 0.49) = 0.833.

It is important to note that these estimates do not distinguish test sensitivity for screening and rescreening, nor do they differentiate sampling error and interpretive error. Test performance is likely to be different in a rescreening application, since the population subjected to rescreening is different from the primary screening population. For practical purposes, if sensitivity is improved sufficiently to make a new screening technology cost-effective, then it should not matter if that differential is due to technological superiority or difference in the type of error that is reduced. However, to examine the impact of this difference, we model differential sensitivities between initial and rescreening testing. Regarding different types of test errors, sampling errors may result from either poor technique on the part of the person obtaining the smear, or placement of cells on the slide which may not be representative of the potential areas of abnormality. Determining the relative effect of errors in technique (inadequate visualization of the cervix, inadequate sampling of the transformation zone, failure to clear off blood and mucous prior to obtaining the smear) versus errors in cell sampling from the collection device itself would require more histological confirmation than is currently available. Again, to permit examination of this issue, we model the effect of changes in differential sensitivities between initial and rescreening technologies.

#### Sensitivity Estimates for Rescreening Step

We also examined the potential impact of technologies that improve the sensitivity of the rescreening step. We assumed that the sensitivity of the primary screening step was that of the conventional Pap and that 100 percent of smears read as normal would be rescreened at the improved sensitivity and specificity (see Figure 5). We used a similar approach to the one described above.

For rescreening technologies, the overall improvement in sensitivity can be calculated as either

Sensitivity Conventional Pap + {1.0 * [Sensitivity Conventional Pap +x (1-Sensitivity Conventional Pap)] * (1-Sensitivity Conventional Pap)}

or as

Sensitivity Conventional Pap + [1.0 * Sensitivity Rescreening Device * (1-Sensitivity Conventional Pap)].

Table 9 shows the sources and calculated reduction in false negative rate used to derive our estimated range for rescreening technologies.

Table 9. Calculation of Reduction in False Negative Rate for Rescreening Technologies

Source | Rescreening Sensitivity | Calculated Reduction in False Negative Rate
AutoPap^®^ (Rescreening Only)
Stevens, Milne, James et al. (1997) | 0.43 | 0.43
Patten, Lee, Wilbur et al. (1997a) | 0.51 | 0.51
Colgan, Patten, and Lee (1995) | 0.663 | 0.663
Brown and Garber (1998) | 0.77 | 0.77
Papnet^®^
Kaufman, Schreiber, and Carter (1998) | 0.38-0.41 | 0.38-0.41
Jenny, Isenegger, Boon et al. (1997) | 0.89 | 0.89
Brown and Garber (1998) | 0.88 | 0.88

Again, we chose 0.6 as the base case for the rescreening technology and varied it between 0.4 and 0.9. The base case estimate was chosen because it was in the mid-range of estimates. By beginning at identical values, identification of thresholds between the two types of technologies was simplified.

#### Specificity of New Technologies

Our base case assumes that the new technologies do not affect the specificity of Pap screening. We varied the relative specificity of the technologies from 0.9 to 1.0. However, since these are relative sensitivities and specificity, one would expect that the actual test characteristics of the new technologies will vary depending on the "true" sensitivity and specificity of conventional Pap testing when a histological gold standard is used. Thus, the lower the "true" conventional sensitivity, the lower the "true" sensitivity of the new technology.

Another issue is the relative contribution of sampling errors (failure to adequately collect abnormal cells) and interpretation errors (overlooking or falsely classifying abnormal cells on a smear) to the overall sensitivity of the test. There are several considerations. First, a certain unknown percentage of sampling errors will be attributable to the provider obtaining the smear; changes in Pap technology will not improve the ability of a provider to adequately visualize, clean, and sample the cervix. Second, although sampling errors may be more common, the relative impact on overall test sensitivity of different technologies would need to be demonstrated by direct comparison of smears obtained from conventional Paps, monolayers, and selected by rescreening devices, preferably with histological confirmation. It is difficult to see how the reduction in sampling error for a given technology can be determined without histological, or at least colposcopic, confirmation. We therefore did not consider sampling versus interpretive errors in the base case analysis. However, because it is possible that a differential impact on false negatives due to sampling or interpretation could have an impact on the relative cost-effectiveness of different technologies, we tested this in sensitivity analysis. We divided the false negative rate, 1-Sensitivity Conventional Pap, into two components as follows:

False Negative Rate = [Relative Contribution Sampling Error * (1-Sensitivity)] + [Relative Contribution Interpretive Error * (1-Sensitivity)].

We assumed in this sensitivity analysis that a rescreening technology would not affect false negatives attributable to sampling, but that a primary screening technology such as ThinPrep^®^ could potentially reduce both types of errors. Again, the relative contributions of sampling and interpretive errors on the relative sensitivities of different technologies can ultimately only be answered by direct comparison of the technologies, preferably with colposcopic and histological confirmation.

### Parameter Estimates from Available Data: Cost

Cost estimates for cervical cancer screening and for the diagnosis and treatment of LSIL, HSIL, and invasive cervical cancer were derived primarily from the review of MEDSTAT data conducted by Health Economics Research, Inc.

#### Costs of Screening

Estimates for the incremental cost per slide for conventional Pap smears, Paps smears obtained using ThinPrep^®^ media, and Paps with 100 percent rescreening with AutoPap^®^ or Papnet^®^ were assigned on the basis of data from Health Economics Research, Inc., and estimates made by Brown and Garber (1998), Schechter (1996), Radensky and Mango (1998), peer reviewers of the draft evidence report, and the manufacturers. These costs are summarized in Table 10.

Table 10. Costs of Screening Tests

Test | Base Case | Range | Medicare Cost
Conventional Pap, 20-64 | $38.68 | $35.32-43.7
Conventional Pap, 65+ | $47.73 | $44.24-56.98 | $35.01 (range: $34.55-36.92)
New technology which improves primary screening sensitivity | Incremental cost: $10.00 | $5.00-15.00 | Not available
New technology which improves rescreening sensitivity | Incremental cost: $10.00 | $5.00-15.00 | Not available

#### Costs of Diagnostic Evaluation for LSIL, HSIL, and Invasive Cancer

Diagnostic costs were estimated in two ways. First, the mean cost for diagnosis and treatment of LSIL, HSIL, and Stages I, II, III, and IV cervical cancer from MEDSTAT data was used to assign a global diagnosis and treatment cost to each level of pathology. Sensitivity analyses were run using the 25^th^ and 75^th^ percentiles as the minimum and maximum values. The MEDSTAT dataset did not contain information specific to FIGO stage, only World Health Organization (WHO) stage (Local, Regional, Distant). We assumed that "local" disease equaled Stage I, "regional" equaled Stage II or III, and "distant" equaled Stage IV.

The model was also evaluated using procedure-specific costs for diagnostic and treatment procedures. Means and 25^th^ and 75^th^ percentiles from the MEDSTAT data were used to establish base estimates and ranges for colposcopy and biopsy, LEEP, and cone biopsy (Table 11).

Table 11. Procedure-specific Costs for Diagnostic and Treatment Procedures

Diagnostic Procedure | Base Case | Range | Medicare Cost
Colposcopy + biopsy + endocervical curettage | $375 | $244-477 | $244
Colposcopy + biopsy only | $276.57 | $195-351 | $172.63
LEEP | $564 | $352-710 | $205
Cone biopsy | $919 | $623-1114 | $409

The diagnostic costs associated with each stage of cervical cancer were estimated by calculating a weighted average cost using the proportion of patients within each stage who underwent a given diagnostic procedure in 1990 (Russell, Shingleton, Jones et al., 1996) and procedure-specific MEDSTAT costs (Table 12).

Table 12. Proportion of Patients in Each Stage Undergoing Specified Diagnostic Procedures

Procedure | Average Cost | Stage I | Stage II | Stage III | Stage IV
Examination under anesthesia | $201 | 0.414 | 0.458 | 0.462 | 0.462
Cystoscopy | $982 | 0.201 | 0.388 | 0.454 | 0.454
Proctoscopy | $774 | 0.152 | 0.281 | 0.316 | 0.316
Chest X-ray | $43 | 0.727 | 0.781 | 0.779 | 0.779
Intravenous pyelogram | $339 | 0.313 | 0.327 | 0.311 | 0.311
Barium enema | $108 | 0.136 | 0.199 | 0.213 | 0.213
Bone scan | $236 | 0.045 | 0.112 | 0.136 | 0.136
CT scan | $312 | 0.408 | 0.696 | 0.768 | 0.768
MRI scan | $563 | 0.046 | 0.067 | 0.071 | 0.071
Lymphangiogram | NA | 0.013 | 0.032 | 0.039 | 0.039
Fine needle biopsy | NA | 0.017 | 0.035 | 0.042 | 0.042

NA = not available.

Source: Russell, Shingleton, Jones et al., 1996

The base case estimates (Table 13) were derived using the average MEDSTAT costs, with lower and upper estimates calculated using the 25^th^ and 75^th^ percentiles. Similar estimates were made based on Medicare costs.

Table 13. Stage-specific Cost Estimates of a Diagnostic Workup

Cervical Cancer Stage | Base Case | Range | Medicare Costs
I | $714 | $274-1042 | $348
II | $1138 | $429-1642 | $520
III | $1257 | $470-1837 | $563
IV | $1257 | $470-1837 | $563

Because MEDSTAT data did not include professional charges for anesthesia for pelvic examination under anesthesia, or charges for lymphangiography or fine needle biopsy, the diagnostic costs are likely to underestimate the true average costs of diagnosis of cervical cancer to some extent.

#### Costs of Treatment

Like diagnostic costs, treatment costs were estimated in two ways. Global diagnostic and treatment costs estimated from MEDSTAT data (Table 14) were one source.

Table 14. Global Costs of Diagnosis and Treatment

Pathological Findings | Base Case | Range
LSIL | $1728 | $675-2274
HSIL | $3049 | $1384-4203
Stage I | $17,645 | $9,439-21,946
Stage II-III | $27,069 | $11,734-29,089
Stage IV | $40,280 | $12,670-46,509

Procedure-specific costs were also calculated and used to generate a second set of estimates (Table 15). Costs for procedures used in the treatment of SIL were obtained directly from MEDSTAT and Medicare data.

Table 15. Procedure-specific Costs

Therapeutic Procedure | Base Case | Range | Medicare Costs
LEEP | $564 | $352-710 | $205
Cryotherapy | $156 | $108-184 | $111
Laser ablation | $730 | $390-976 | $205

As noted elsewhere in the report, mean costs for cervical cancer treatment were often substantially higher than median costs, especially for more advanced procedures. This probably represents the effects of varying severity of disease within stages or of complications of treatment, which substantially increase costs. We have chosen to use mean costs for our base case estimate in order to include the economic impact of varying disease severity, comorbidities, and complications. Because of the extremely wide standard deviations resulting from the effect of outliers, we use the 25^th^ and 75^th^ percentiles as endpoints in sensitivity analysis.

Estimates of the proportion of patients undergoing a specified treatment in each stage were calculated from the American College of Surgeons data (see section on Stage-specific Treatment Probabilities above). Because the data were not specific about the exact radiation therapy or chemotherapy regimens used, we assumed that patients received standard regimens of each, which are described in Table 16 (A. Berchuk and D.L. Clarke-Pearson, personal communication to E. Myers, 1998; DiSaia and Creasman, 1997).

Table 16. Number of Inpatient and Outpatient Treatment Procedures

Treatment | Number of Inpatient Procedures | Number of Outpatient Procedures
Simple hysterectomy only | 1 | 0
Radical hysterectomy only | 1 | 0
Surgery + radiation | 1 Radical hysterectomy or 1 Simple hysterectomy + 2 radiation treatments | 20 outpatient
Radiation + chemotherapy | 2 radiation treatments and 0 inpatient chemotherapy, or 6 inpatient chemotherapy | 6 outpatient (if no inpatient)
Chemotherapy | 6 | 6 (if no inpatient)
Radiation therapy | 2 | 20

The cost estimates resulting from these assumptions about treatment regimens for each stage were then multiplied by the proportion of patients in each stage receiving each treatment in the American College of Surgeons PCE dataset to arrive at the following weighted averages for treatment of cervical cancer (Tables 17 and 18):

The mean MEDSTAT global estimates (see Table 18) are substantially higher than the estimates derived by applying procedure-specific MEDSTAT costs to the distribution of treatments reported in the American College of Cancer data set (see Table 17). This may reflect differences in patient populations, professional charges, changes in practice patterns between 1990 and 1994, or additional costs, such as antiemetic treatment for chemotherapy patients, or followup outpatient clinic visits, not captured using procedure-specific costs. Again, to bias the model in favor of more sensitive screening strategies, we used the global costs for the base case estimate. In the base case, we also did not use the lower Medicare estimates for patients over 65, again to deliberately bias the results in favor of more sensitive screening strategies.

Table 17. Stage-specific Costs for Treatment (based on MEDSTAT procedure-specific cost data, standard treatment regimens, and distribution of treatments in American College of Surgeons dataset)

Stage | Base Case | Range | Medicare
I | $12,243 | $7320-15185 | $7724
II | $15,244 | $7196-21,660 | $10,105
III | $15,244 | $7526-25,144 | $10,159
IV | $17,431 | $9296-34,365 | $8,001

Table 18. Procedure-specific Costs for Diagnosis and Treatment Compared with MEDSTAT Global Estimates

Stage | Procedure-Specific Estimates | | | MEDSTAT Global Estimate
| Diagnosis | Treatment | Total
I | $714 | $12,243 | $12,957 | $17,645
II | $1138 | $15,244 | $16,382 | $27,069
III | $1257 | $15,244 | $16,501 | $27,069
IV | $1257 | $17,431 | $18,688 | $40,280

#### Costs of Terminal Care

The MEDSTAT data do not allow direct attribution of a cost associated with terminal care for cervical cancer patients. Eddy (1990) estimated a cost of $22,150 in 1989 dollars, based on 1987 Medicare data. The MEDSTAT data do report a category of "All stages (final diagnosis Stage 4)," with an average incremental cost of $16,530 above the average cost for Stage IV cancers. It is unclear whether these represent terminal care, recurrent cases, or progressive cases, since stage, once assigned, should not change.

Eddy's cost, inflated to 1997 dollars, is $34,805. This figure represents charges. Since we use a 0.5 cost/charge ratio, the MEDSTAT costs above represent charges of $33,060. Because of the similarity of these figures, we assume that the cost of terminal care for cervical cancer is $16,530 and assign this cost to all patients dying of cervical cancer.

### Calibration Against Epidemiological Data

Epidemiological data on the incidence and prevalence of cervical cancer and its precursors (LSIL, HSIL, and HPV infection) were used to calibrate the cost-effectiveness model.

Converting reported incidence, regression, persistence, and progression rates for HPV and SIL to reliable transition probabilities for the model was difficult because of the way most of these values are reported in the literature. Regression and progression rates are usually reported as percentages of either prevalent or incident infections, but followup time varied widely among studies. Data are rarely provided in a way that easily allows conversion of these rates to yearly transition probabilities (Miller and Homan, 1994). In addition, very few data are available that allow calculation of transition probabilities for untreated cervical cancer, such as the annual stage-specific probability of symptom development or the annual probability of progression between stages. Estimates for these probabilities were derived from the epidemiological literature and prior published models of cervical cancer screening, especially those of Eddy (1990) and Muller, Mandelblatt, Schechter et al. (1990).

The model was calibrated by adjusting natural history parameters to recreate the age-specific incidence of cervical cancer in an unscreened population (Figure 10) (Gustafsson, Ponten, Bergstrom et al., 1997). Data from several unscreened populations show a striking similarity in the pattern of age-specific incidence (Gustafsson and Adami, 1992 ; Gustafsson, Ponten, Bergstrom et al., 1997; Gustafsson, Ponten, Zack et al., 1997; Parkin, 1997)

Figure 10. Predicted age-specific incidence of cervical cancer

Gustafsson, Ponten, Bergstrom et al. (1997) described two separate curves, one with a peak between ages 40 and 50 with a more rapid decline, and one similar to the U.S. data with a peak between ages 50 and 65 and a more gradual decline. Their modeling suggests that some of the difference results from increased incidence in successive birth cohorts. The early peak curves primarily were observed in western European countries with data collected predominantly between 1950 and 1975. Conversely, the U.S. data comes from Connecticut between 1935 and 1949. It is likely that early sexual activity, and therefore exposure to HPV, was more frequent in western Europe and Scandinavia during the 1950s and 1960s than in 1940s Connecticut. In addition, there are likely to be differences in access to care, or willingness to seek care for symptoms, across time and cultures.

We tested the impact of a later age of onset of sexual activity, and thus a later age of peak HPV incidence, on the age-specific incidence of cervical cancer, holding all other variables constant. Figure 11 shows the differences in age-specific HPV incidence between the base case model and one in which peak HPV incidence is shifted forward to ages 25-30, and Figure 12 shows the resulting age-specific cervical cancer incidences. Later onset of HPV shifts the cervical cancer curve to the right, as expected, although the age of peak incidence is similar. We then decreased the annual probability of presenting with symptoms for Stage I from 15 percent to 1 percent, and for Stage II from 22.5 percent to 10 percent, with the resulting later age of peak incidence (Figure 13). The later peak incidence of cervical cancer seen in older unscreened cohorts is consistent with both later onset of sexual activity (and HPV infection) and delay in seeking medical attention for symptoms (or in access to care). Other combinations of variables, such as regression and progression rates for HPV and SIL, are also likely to affect the shape of the cancer incidence curve.

Figure 11. Change in peak HPV prevalence

Figure 12. Effect of peak age of HPV on cervical cancer incidence

Figure 13. Effect of age of peak HPV incidence and delay in seeking medical attention on cancer incidence

We elected to use values resulting in an earlier onset for the base case scenario. Prevention of fatal disease occurring at younger ages results in greater increases in life expectancy compared with prevention of disease at older ages; thus, our base case model is biased in favor of screening strategies that have increased sensitivity.

The peak incidence of cervical cancer used in the model (81/100,000) is somewhat higher than that observed in an unscreened U.S. population in the 1930s (approximately 60/100,000) but lower than that seen in developing nations (Gustafsson, Ponten, Bergstrom et al., 1997). Because there have been significant increases in sexual activity in adolescents over time (Centers for Disease Control and Prevention, 1991), it seems likely that the actual expected rate in an unscreened population would be higher than the rate observed 60 years ago, especially since mortality from other causes, particularly in younger women, has declined. This higher incidence estimate is consistent with our choice of other base case estimates for the model, in that we have tried to bias the model in favor of screening strategies with increased sensitivity compared with conventional Pap smears at longer screening intervals.

In an unscreened population, age-specific incidence of cervical cancer will be dependent both on the rate of progression of the disease and the stage-specific probability of developing symptoms that lead to diagnosis. Very few data are available to validate parameter estimates for rates of progression between stages of cancer or the probability of developing symptoms in any given stage. Therefore, these parameters were adjusted to result in a distribution of cases by stage that approximates that seen in patients without Pap smear screening (Bearman, MacMillan, and Creasman, 1987; Eddy, 1990). These proportions are also similar to those observed in larger series of cervical cancer patients (Jones, Shingleton, Russell et al., 1995; Pretorius, Semrad, Watring et al., 1991), presumably because at least 30-40 percent of cervical cancer patients have never been screened or have not been screened within the past 5 years.

## Role of Report Partner

The American College of Obstetricians and Gynecologists formed the "private" half of the "public-private partnership" fostered by AHCPR through the Evidence-based Practice Centers initiative. ACOG played a significant role in this study by nominating evaluation of cervical cytology as a task order topic for funding through the EPC program. Dr. Stanley Zinberg, ACOG's Vice President of Practice Activities, is a member of the study's Advisory Panel of Technical Experts and Peer Review Panel. Through Dr. Zinberg's participation on these panels, ACOG was involved at key decision stages of the study, providing consultation on the key literature search questions and reviewing the first drafts of the evidence tables, the plans for the cost-effectiveness analysis and meta-analysis, and the draft evidence report. ACOG also assisted in writing a dissemination plan for this evidence report for AHCPR.

## Quality Control

Internal and external quality control mechanisms were incorporated into each phase of the development of the evidence report.

### Internal Quality Control Mechanisms

Quality control procedures were integrated into each step of the literature review. The search strategies used were checked and finalized by two professional medical librarians. For additional checks on completeness, the articles cited in reference lists of reviewed articles, particularly meta-analyses, were compared with those in the Pro-Cite literature database developed for this evidence report, and when appropriate, articles were copied, reviewed, and added to the Pro-Cite database. Further, the manufacturers of AutoPap^®^, Papnet^®^, and ThinPrep^®^ were asked to submit articles and other documents that met the specified inclusion criteria for the evidence report.

With regard to the content of the evidence tables and data analyses, quality control procedures included: screening of all articles by at least two clinicians, abstracting of information into the evidence report by two clinicians, and independent construction of each 2-by-2 table by two clinicians and over-reading by a third. No data or other information was inserted into the evidence table or data analyses without absolute agreement by two, and often three, clinicians. Further, once the content was agreed upon by the clinicians, the information for the evidence table and data for the meta-analysis and cost-effectiveness analysis were double-entered and compared, and any discrepancies reconciled. Where appropriate, kappa statistics were calculated to show the strength of agreement between clinician-reviewers, particularly in the article screening stage and the construction of the 2X2 tables. When the strength of agreement was low, all reviewers met to discuss the nature of the discrepancies and to come to common agreement on the interpretation of the criteria and their application to the articles as well as agreeing on responses to articles that were in a "gray" area. In the latter case, the decision was to err on the side of including the article, recognizing that the data abstraction process and the development of the 2X2 tables would further illuminate the inclusion/exclusion status of the article.

Quality control in the cost-effectiveness analysis was provided by extensive sensitivity analyses, by validation with epidemiological data, and by comparisons with previously published cost-effectiveness models.

### External Quality Control Mechanisms

Two external oversight and review panels were established. The Advisory Panel of Technical Experts was initiated early in the 11-month time frame for the study. The Advisory Panel of Technical Experts reviewed progress on the evidence report at four key stages of its development: the identification of the key literature search questions, the first drafts of the evidence tables, the plans for the cost-effectiveness analysis and meta-analysis, and the draft of the evidence report. The Technical Experts were sent draft documents that were discussed as a group in two conference calls and also in individual phone calls and written communications. The eight-member Panel consisted of clinical and methodological experts in relevant specialty areas, including clinical and laboratory pathology, obstetrics/gynecology, family practice, oncology, women's health, meta-analysis, cost-effectiveness analysis, and epidemiology. Consumers were represented on the Advisory Board of Technical Experts by Family Health International, a not-for-profit organization committed to improving the health of women and children; helping women and men have access to safe, effective, acceptable, and affordable family planning methods; and preventing the spread of AIDS and other sexually transmitted diseases (STDs).

The primary function of the second group, the Peer Review Panel, was to review and comment on the complete draft of the evidence report. The 23-member panel, which included AHCPR staff and the Advisory Panel of Technical Experts, consisted of clinical and methodological experts in relevant specialty areas, including clinical and laboratory pathology, obstetrics/gynecology, family practice, oncology, women's health, meta-analysis, cost-effectiveness analysis, and epidemiology, as well as the manufacturers of the Pap screening devices reviewed. The report was modified on the basis of their comments, with close attention to relevant studies not included in the draft report, misinterpretation of findings, and other issues deserving revision within the constraints of the methodology, time frame, and budget. The format for the report was designed by AHCPR.