# Evidence Tables

Evidence Table 1. Prevalence of Lesions Detected by Transthoracic Echocardiography in Patients with Stroke or TIA

AuthorYear | Population/setting | Major exclusions | Mean age (range) | Female (%) | TIA (%) | Lacunar stroke (%) | Posterior circulation stroke (%) | Heart disease (%) | Carotid stenosis (%) | Sample described | LAT | LVT | ASA | AoAth | LVA | SEC | PFO | MVP | MAC | RHD/ MS | Veg | Myxoma | Quality/Comments
Nishide 1983 | 350 consecutive patients with stroke/TIA at a hospital in Japan | | 69.5 (20-96) | 44% | 9% | Not reported | Not reported | 37% | Not reported | 235 without AF | 2.1% | | | | | | | 2.6% | 6.0% | 2.1% | 0.9% | 0.4% | GOOD.
Bogousslavsky 1986 | 215 consecutive patients with anterior circulation TIA and no known carotid disease at a university hospital in Ontario | 1) Completed stroke 2) Posterior circulation event | 63 (25-83) | 36% | 100% | 0% | 0% | 32% (excluded in this table) | 30% (>75% stenosis) | 140 without AF or other heart disease | | 0% | | | 0% | | | 3.6% | 2.1% | 0% | 0% | 0% | FAIR. Criteria for echocardiographic diagnoses were not described. Echocardiographic methods were not well described.
Good 1986 | 65 consecutive patients undergoing cerebral angiography for recent stroke/TIA at two community teaching hospitals in Illinois | 1) Angiographic cerebrovascular disease 2) Lacunar stroke | 63 (21-88) | 52% | 51% | None (excluded) | 9% | 40% | None (excluded) | 62 without AF 23 with heart disease, no AF | 0% 0% | 0% 0% | | | 0% 0% | | | 2% 4% | | 0% 0% | 0% 0% | 0% 0% | FAIR. Moderate sample size.
Greenland 1981 | 95 consecutive patients with stroke/TIA on the neurology service of a public hospital in Minnesota | | 69.6 (95% over 45) | 47% | 24% | 6% | 19% | 48% (excluded in this table) | Not reported | 47 without AF or other heart disease | 0% | 0% | | | | | 0% | | 4.3% | 0% | 0% | 0% | FAIR. Criteria for echocardiographic diagnoses were not described. Moderate sample size.
Pop 1990 | 72 consecutive patients with minor stroke or TIA at a university hospital in the Netherlands | | 60 (24-73) | 33% | 28% | Not reported | 13% | 26% (excluded in this table) | 0% (among 27 patients imaged) | 53 without AF or other heart disease | 0% | 0% | | | | 0% | | 0% | | 0% | 0% | 0% | FAIR. Criteria for echocardiographic diagnoses were not described. Moderate sample size.
Toyoda 1993 | 62 patients with clinically defined cardioembolic stroke in the stroke unit of a referral hospital in Japan | 1) Atherosclerotic cerebrovascular disease 2) TIA 3) Lacunar stroke | 65 (39-87) | 36% | None (excluded) | None (excluded) | Not reported | 100% | None (excluded) | 20 without AF | 0% | 0% | | | | | | | | | 5.0% | 0% | FAIR. Moderate sample size.
Voyce 1992 | 68 consecutive patients with anterior circulation stroke or TIA at a university hospital in Massachussetts | 1) Posterior circulation event | 68.5 (47-95) | 54% | 26% | Not reported | None (excluded) | 37% | 27% (>50% stenosis) | 68 (none with AF) 25 with heart disease, no AF 50 without carotid stenosis | 0% 0% 0.0% | 13.2% 36.0% 18.0% | 0% 0% 0.0% | | | | 0% 0% 0.0% | 2.9% | 19.1% | | 2.9% 0% | 0% 0% | FAIR. Criteria for echocardiographic diagnoses were not described. Moderate sample size.
Joubert 1989 | 102 consecutive black patients with stroke at a university hospital in S. Africa (24% of strokes were hemorrhagic) | | 58 (18-100) | 56% | 0% | Not reported | Not reported | Not reported | Not reported | 96 without AF | 3.1% | 8.2% | | | | | 1.0% | 4.9% | 4.1% | 13.5% | 3.1% | 0% | POOR. Spectrum of patients was not adequately described. Criteria for echocardiographic diagnoses were not described. Moderate sample size.

LAT: left atrial thrombus; LVT: left ventricular thrombus; ASA: atrial septal aneurysm; AoAth: aortic atheroma; veg: valvular vegetation; LVA: left ventricular aneurysm; SEC: spontaneous echocardiographic contrast; PFO: patent foramen ovale; MVP: mitral valve prolape; MAC: mitral annular calcium; RHD: rheumatic heart disease; MS: mitral stenosis; veg: valvular vegetation

Evidence Table 2. Prevalence of Lesions Detected by Transesophageal Echocardiography in Patients with Stroke or TIA

Author Year | Population/setting | Major exclusions | Mean age (range) | Female (%) | TIA (%) | Lacunar stroke (%) | Posterior circulation stroke (%) | Heart disease (%) | Carotid stenosis (%) | Sample described | LAT | LVT | ASA | AoAth | LVA | SEC | PFO | MVP | MAC | RHD/MS | Veg | Myxoma | Quality/Comments
Albers 1994 | 145 consecutive patients with stroke/TIA at a community and VA hospital in California | | 61 (17-85) | 41% | Not reported | 18% | 16% | 64% | 11% (> 50% stenosis) | 125 without AF | 0.8% | 1.6% | 21.6% | | 1.6% | 11.2% | 20.8% | 1.6% | | | 0.8% | 0% | GOOD. Data were also abstracted from Comess, 1994.
Mendel 1998 | 104 consecutive patients with mild-moderate stroke at a hospital in Poland | 1) "Significant" carotid stenosis | 55 | 51% | None | None | 19% | Not reported | None (excluded) | 70 without AF | 4.3% | | | | | 7.1% | | | | 0% | 0% | 0% | GOOD.
Nighoghossian 1996 | 118 consecutive patients admitted to a neurology referral center in France for management of stroke | 1) Age > 60 2) AF 3) Potential sources of embolism on TTE | 47 (23-59) | 36 | 14% | 5% | 36% | Not reported | 15% | 118 (none with AF) | | | 28.0% | 3.4% | | | 25.4% | 11.0% | | | | | GOOD.
Roijer 1997 | 121 consecutive patients with stroke living in the catchment area of a university hospital in Sweden | | 70 (38-93) | 35% | None | Not reported | Not reported | 51% | 26% (> 50% stenosis) | 99 without AF 67 without AF, carotid stenosis, LAT, LVT, myxoma | 7.1% | | 25.4% | 6.0% | | 1.0% | 25.4% | 1.5% | 20.9% | | | 0.8% | GOOD.
Censori 1998 | 65 consecutive patients with lacunar or cryptogenic stroke/TIA at primary care hospital in Italy | 1) > 50% carotid stenosis 2) High-risk for cardioembolism by TOAST criteria | 64.5 (40-80) | 32% | 15% | 34% | 20% | Not reported | None (excluded) | 65 (none with AF) 43 non-lacunar 22 lacunar | 1.5% 2.3% 0% | 0% 0% 0% | 3.1% 4.7% 0% | 4.6% 4.7% 4.5% | | 7.7% 7.0% 9.1% | 35.4% 39.5% 27.3% | 0% 0% 0% | 0% 0% 0% | | 0% 0% 0% | 0% 0% 0% | FAIR. Moderate sample size.
Jones 1993 | 135 consecutive patients with first stroke or witnessed TIA admitted to a stroke unit in Australia | | 67 (24-88) | 44% | Not reported | 13% | 13% | Not reported | 10% (> 70% stenosis) | 105 without AF | 0% | 1.9% | 3.8% | 1.9% | | 10.5% | 9.5% | 7.6% | 14.3% | 0% | 1.9% | 0% | FAIR. Criteria for echocardiographic diagnoses not described.
Labovitz 1993 | 270 consecutive patients with stroke/TIA at a university hospital in Missouri | 1) > 50% carotid stenosis 2) Potential sources of embolism on TTE | 55 (17-83) | 48% | Not reported | Not reported | Not reported | Not reported | None (excluded) | 208 without AF | 18.0% | | 15.0% | | | 11.0% | 17.0% | | | | | 0% | FAIR. Spectrum of patients not adequately described. Criteria for echocardiographic diagnoses not described.
Omran 2000 | 869 consecutive patients with stroke or TIA at a university hospital in Germany | | 49 | 33% | Not reported | Not reported | Not reported | 32% | Not reported | 583 without AF | 1.0% | | | | | | | | | 1.2% | | | FAIR. Spectrum of patients not well described. Echo cardiographic methods not well described.
Pop 1990 | 72 consecutive patients with minor stroke or TIA at a university hospital in the Netherlands | | 60 (24-73) | 33% | 28% | Not reported | 13% | 26% | 0% (among 27 patients imaged) | 67 without AF 14 with heart disease, no AF | 1.5% 0% | 0% 0% | | | | 0% 0% | | 1.5% 0% | | 0% 0% | 1.5% 0% | 0% 0% | FAIR. Criteria for echocardiographic diagnoses not described. Moderate sample size.
Rauh 1996 | 30 consecutive patients with stroke at a hospital in Germany | 1) > 50% carotid stenosis 2) AF 3) Potential sources of embolism on TTE | 62 (28-83) | 50% | Not reported | Not reported | Not reported | 53% | None (excluded) | 30 (none with AF) | 10.0% | | 6.7% | 0% | | | 23.3% | | | | | | FAIR. Small sample size.
Shyu 1994 | 94 consecutive patients with stroke/TIA at a university hospital in Taiwan | | 60 (22-82) | 53% | 3% | Not reported | 7% | 36% (excluded in this table) | 32% (> 50% stenosis) | 60 without AF or other heart disease | 3.3% | 0% | 11.7% | 6.7% | 0% | 1.7% | | 8.3% | 1.7% | | 0% | 0% | FAIR. Criteria for echocardiographic diagnoses not described. Moderate sample size.

LAT: left atrial thrombus; LVT: left ventricular thrombus; ASA: atrial septal aneurysm; AoAth: aortic atheroma; veg: valvular vegetation; LVA: left ventricular aneurysm; SEC: spontaneous echocardiographic contrast; PFO: patent foramen ovale; MVP: mitral valve prolapse; MAC: mitral annular calcium; RHD: rheumatic heart disease; MS: mitral stenosis; veg: valvular vegetation

Evidence Table 3. Accuracy of Transesophageal Echocardiography for Detecting Left Atrial Thrombus

Author year | Population/setting | Mean age (range) | Female (%) | Lesion prevalence | Reference standard | Indeterminate results | Sensitivity | Specificity | Positive LR | Negative LR | Quality | Comments
Hwang 1993 | 213 consecutive patients scheduled for surgery for rheumatic mitral valve disease at a university hospital in Taiwan | 45 | 77% | 14% | Surgical inspection | None | 93% | 100% | Infinite | 0.07 | GOOD. | 28 of 30 patients with thrombus had AF, all had mitral stenosis.
Manning 1995 | 231 consecutive patients undergoing intraoperative TEE prior to elective mitral valve surgery or excision of a left atrial tumor at a university hospital in Massachussetts | 64 | 55% | 5% | Surgical inspection | None | 100% | 99% | 100 | 0 | GOOD. | Intraoperative TEE with patient under anesthesia may have allowed better exams than in awake patients. All patients with thrombus had a history of AF and were on warfarin.
Acar 1991 | 101 patients who had undergone mitral valve replacement or repair for mitral stenosis at a hospital in France | Not described | Not described | 12% | Surgical inspection | None | 83% | 97% | 27.7 | 0.18 | FAIR. Potential verification bias. Inter-rater reliability was not assessed. | Retrospective study.
Fatkin 1996 | 60 patients scheduled for surgery for rheumatic mitral valve disease or prosthetic valve dysfunction at 3 tertiary care hospitals in Australia | 60 (38-78) | 77% | 8% | Surgical inspection | None | 100% | 93% | 14.3 | 0 | FAIR. Moderate sample size. Selection process was not described. | All patients with thrombus were in AF.
Koca, 1999 | 262 patients undergoing surgery for rheumatic mitral valve disease at a university hospital in Turkey | 42 | 60% | 13% | Surgical inspection | None | 97% | 100% | Infinite | 0.03 | FAIR. Inter-rater reliability was not assessed.
Olson, 1992 | 21 consecutive patients with valve disease undergoing surgery or autopsy at a university hospital in Minnesota | 62 (32-81) | 67% | 10% | Autopsy, surgical inspection | None | 100% | 100% | Infinite | 0 | FAIR. Small sample size. Inter-rater reliability was not assessed. | 20 of 21 TEE studies were done intraoperatively, which may have allowed better exams than in awake patients.
Aschenberg 1986 | 21 consecutive patients with symptomatic mitral stenosis scheduled for elective mitral valve replacement at a university hospital in Germany | 51 | 43% | 29% | Surgical inspection | None | 100% | 100% | Infinite | 0 | POOR. Small sample size. Criteria for echocardiographic diagnosis of LAT were not described. Inter-rater reliability was not assessed.

LR: likelihood ratio; LAT: left atrial thrombus; LVT: left ventricular thrombus; TTE: transthoracic echocardiography; TEE: transesophageal echocardiography; AF:atrial fibrillation; LV: left ventricle; VA: Veterans Affairs

Evidence Table 4. Accuracy of Transthoracic Echocardiography for Detecting Left Atrial Thrombus

Author year | Population/setting | Mean age (range) | Female (%) | Lesion prevalence | Reference standard | Indeterminate results | Sensitivity | Specificity | Positive LR | Negative LR | Quality
Hwang 1993 | 213 consecutive patients scheduled for surgery for rheumatic mitral valve disease at a university hospital in Taiwan | 45 | 77% | 14% | Surgical inspection | None | 53% | 100% | Infinite | 0.47 | GOOD. Inter-rater reliability was not assessed.
Acar 1991 | 581 patients who had undergone mitral valve replacement or repair for mitral stenosis at a hospital in France | 59 (14-77) | 73% | 7% | Surgical inspection | None | 28% | 99% | 28 | 0.73 | FAIR. Potential verification bias. Inter-rater reliability was not assessed.
Bansal 1989 | 148 patients with mitral valve disease who had undergone TTE and mitral valve replacement at a university hospital in California | 61 | 61% | 9% | Surgical inspection | None | 46% | 99% | 46 | 0.55 | FAIR. Potential verification bias. Inter-rater reliability was not assessed.
Fatkin 1996 | 60 patients scheduled for surgery for rheumatic mitral valve disease or prosthetic valve dysfunction at 3 tertiary care hospitals in Australia | 60 (38-78) | 77% | 8% | Surgical inspection | None | 40% | 100% | Infinite | 0.6 | FAIR. Moderate sample size. Selection process was not described. Inter-rater reliability was not assessed.
Olson 1992 | 21 consecutive patients with valve disease undergoing surgery or autopsy at a university hospital in Minnesota | 62 (32-81) | 67% | 10% | Autopsy, surgical inspection | None | 0% | 100% | Infinite | 1 | FAIR. Small sample size. Inter-rater reliability was not assessed.
Shrestha 1983 | 293 patients undergoing surgery for rheumatic mitral valve disease at a cardiac care center in the Phillipines | 37 (17-55) | 51% | 17% | Surgical and pathological inspection | None | 59% | 99% | 59 | 0.41 | FAIR. Potential verification bias. Inter-rater reliability was not assessed.
Aschenberg 1986 | 21 consecutive patients with symptomatic mitral stenosis scheduled for elective mitral valve replacement at a university hospital in Germany | 51 | 43% | 29% | Surgical inspection | None | 0% | 100% | Infinite | 1 | POOR. Small sample size. Criteria for echocardiographic diagnosis of LAT were not described. Inter-rater reliability was not assessed.
Schweizer 1981 | 92 patients undergoing surgery for mitral valve disease at a hospital in Germany | 53 (29-72) | 70% | 9% | Surgical inspection | None | 33% | 100% | Infinite | 0.67 | POOR. Moderate sample size. Potential verification bias. Criteria for echocardiographic diagnosis of LAT were not described. Inter-rater reliability was not assessed.

LR: likelihood ratio; LAT: left atrial thrombus; LVT: left ventricular thrombus; TTE: transthoracic echocardiography; TEE: transesophageal echocardiography; AF: atrial fibrillation; LV: left ventricle; VA: Veterans Affairs

Evidence Table 5. Accuracy of Transthoracic Echocardiography for Detecting Left Ventricular Thrombus

Author year | Population/setting | Mean age (range) | Female (%) | Lesion prevalence | Reference standard | Indeterminate results | Sensitivity | Specificity | Positive LR | Negative LR | Quality | Comments
Ezekowitz, 1982 | 40 patients with LV aneurysm or mitral valve disease at a university hospital in Oklahoma | 52 | 21% | 33% | Autopsy, surgical inspection | 13 | 77% (38%) | 96% (65%) | 19.2 (2.20) | 0.24 (0.65) | FAIR. Small sample size. Potential spectrum bias. 13 indeterminate tests were excluded. | Figures in parentheses are operating characteristics when indeterminate results are included as all + or all - for LVT.
Starling, 1983 | 21 consecutive patients being evaluated for LV aneurysm at a VA hospital in Texas | 53 (38-64) | 0% | 62% | Autopsy, surgical inspection | None | 77% | 100% | Infinite | 0.23 | FAIR. Small sample size. Potential spectrum bias.
Visser 1983 | 67 consecutive patients who experienced a fatal myocardial infarction or were scheduled for LV aneurysectomy at a university hospital in the Netherlands | 57 (36-81) | 24% | 39% | Autopsy, surgical inspection | 15 | 92% (59%) | 88% (64%) | 7.67 (2.56) | 0.09 (0.64) | FAIR. Moderate sample size. Potential spectrum bias. 15 indeterminate tests were excluded. | Figures in parentheses are operating characteristics when indeterminate results are included as all + or all - for LVT.
Sechtem 1989 | 26 consecutive patients undergoing partial LV aneurysmectomy at a university hospital in Germany | 55 (35-72) | 15% | 54% | Surgical inspection | 6 | 86% (57%) | 70% (58%) | 2.86 (1.36) | 0.20 (0.74) | POOR. Small sample size. Potential spectrum bias. Potential verification bias. Inter-rater reliability was not reported. | Figures in parentheses are operating characteristics when results from indeterminate tests are classified as + or - for LVT according to findings at surgery.
Stratton 1982 | 78 patients who had undergone TTE and subsequent autopsy, surgery, or indium-111 platelet scan at a VA hospital in Washington state | 57 | 24% | 28% | Autopsy, surgical inspection, or indium-111 platelet scan | 10 | 86% (59%) | 95% (80%) | 17.2 (4.3) | 0.15 (0.43) | POOR. Moderate sample size. Potential verification bias. 10 indeterminate tests were excluded. | Figures in parentheses are operating characteristics when indeterminate results are included as all + or all - for LVT. Retrospective study.
Takamoto, 1985 | 37 patients who had undergone TTE prior to aneurysmectomy or heart transplantation at a university hospital in California | 41 | 13% | 30% | Surgical and pathological inspection | Up to 5 | 83% (59%) | 88% (73%) | 6.92 (3.07) | 0.19 (0.47) | POOR. Small sample size. Potential spectrum bias. Potential verification bias. Up to 5 indeterminate tests were excluded. | Figures in parentheses are operating characteristics when indeterminate results are included as all + or all - for LVT. Retrospective study.

LR: likelihood ratio; LAT: left atrial thrombus; LVT: left ventricular thrombus; TTE: transthoracic echocardiography; TEE: transesophageal echocardiography; AF: atrial fibrillation; LV: left ventricle; VA: Veterans Affairs

Evidence Table 6. Complications of transesophageal echocardiography

Study Year | Setting Study Type Duration | Author Affiliation | Sample Size and Selection | Major peri-TEE Complications | Quality | Comments
Chee 1995 | Singapore, single center Prospective 1989-1993 | Cardiology | 901 TEE in patients with suboptimal TTE | 0/901 (0%) deaths; 5/901 (0.6%) major complications | FAIR. Complications not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear. | 248/901 (28%) TEE to detect possible cardiac source of embolus. 10/901 (1.1%) attempted unsuccessfully.
Geibel 1988 | Germany, single center Prospective Duration not clear | Affiliation not clear | 54 TEE in patients with cardiac disease, not clear if consecutive | 0/54 (0%) deaths; 0/54 (0%) sustained or serious arrhythmia or hemodynamic instability | FAIR. Selection not clear. Complications not specified or defined. Unclear if ascertainment independent. | 3/54 (5.6%) patients underwent TEE for evaluation of possible cardiac thrombus.
Melendez 1991 | Canada, single center Prospective Duration not clear | Cardiology | 140 consecutive ambulatory TEE | 0/140 (0%) bacteremia or endocarditis at 12 wks | FAIR. Complications (endocarditis) not specified or defined. Inadequate description of ascertainment technique for endocarditis. Unclear if ascertainment independent. | 33/140 (24%) TEE for evaluation for source of emboli.
Ofili 1990 | US, single center Retrospective 1989-1990 | Cardiology | 35 consecutive TEE in patients >=70 years old | 0/35 (0%) deaths; 0/35 (0%) major complications (1/35 transient hypotension; 1/35 transient hypoxemia) | FAIR. Complications not specified or defined. Inadequate description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear. | 3/35 (8.6%) patients underwent TEE for evaluation of stroke. Complications not reported by indication.
Scriven 1994 | UK, single center Prospective Duration not clear | Cardiology | 150 consecutive TEE | 0/150 (0%) deaths; 2/150 (1.3%) profound hypoxemia; 27/150 (18.0%) significant hypoxemia (<90% saturation); no deaths reported | FAIR. Unclear if ascertainment independent. Duration of followup unclear. | Indication not reported. 22 (15%) patients underwent TEE for evaluation of embolus. Hypoxemia associated with NYHA classes III and IV and mitral valve disease.
Seward 1992 | US, single center Retrospective 1987-1991 | Cardiology | 3927 consecutive TEE | 1/3827 (0.03%) death; 9/3827 (0.2%) major complications (5 serious laryngospasm, 1 sustained VT 1, 2 CHF, 1 death) | FAIR. Unclear if followup complete. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear. | 1263/3827 (33%) patients underwent TEE for evaluation of cardiac embolus. Unable to separate complications by indication. Appears to include some data reported by Khandheria (1994).
Shyu 1992 | Taiwan, single center Prospective 1990-1991 | Medicine | 135 consecutive TEE meeting inclusion criteria (afebrile, no leukocytosis, no antibiotics prior to procedure) | 0/135 (0%) endocarditis | FAIR. Complications (endocarditis) not specified or defined. Inadequate description of ascertainment technique for endocarditis. Unclear if ascertainment independent. Duration of followup unclear. | 3/135 (2.2%) patients underwent TEE because of inadequate TTE.
Stoddard 1993 | US, single center Retrospective 1989-1991 | Cardiology | 283 consecutive TEE in patients >70 years old; random sample of 283/1200 TEE in patients <=50 years old | 0/566 (0%) deaths; 3/566 (0.5%) major complications (2/566 (0.4%) severe hypotension or arrhythmia; 1/566 (0.2%) hypertension or angina) | FAIR. Complications not specified or defined. Inadequate description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear. | 2/283 (0.7%) major complications in older group and 1/283 (0.4%) in younger group. Transient hypotension (14/283 (4.9%) elderly, 4/283 (1.4%) non-elderly) more common in older group. 65/283 (23%) of elderly group receiving TEE for evaluation of embolus.
Tam 1997 | Canada, single center Retrospective 1992-1996 | Cardiology | 2947 consecutive TEE | 1/2947 (0.03%) death; 26/2947 (0.9%) major complications (including death) | FAIR. Inadequate description of ascertainment technique. Not clear if ascertainment independent. Inadequate statistical analysis of confounders. Duration of followup unclear. | Indication not reported. 40/2947 (1.4%) TEE attempted unsuccessfully.
Voller 1991 | Germany, single center Prospective Duration not clear | Cardiology | 144 consecutive TEE in patients with neurologic disorders (presumed cerebral ischemia) | 0/144 (0%) endocarditis or bacterial infection | FAIR. Inadequate description of study population. Complications not specified or defined. Unclear if ascertainment independent. | All patients underwent TEE for evaluation of neurologic disorders.
Zabalgoitia 1990 | US, two centers Retrospective 1989 | Cardiology | 210 consecutive TEE; 88 in patients >65 years old; 122 <65 years old | 0/210 (0%) deaths; 1/210 (0.5%) severe vasovagal reaction | FAIR. Complications not specified or defined. Inadequate description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear | Indication not reported. 0/88 (0%) major complications in patients >65 yo; 1/122 (0.8%) major complications (severe vasovagal reaction) in patients <65 years old. Other complications included transient ectopy, nausea and vomiting.
Black 1990 | Australia, single center Retrospective Duration not clear | Cardiology | 100 consecutive TEE | 0/100 (0%) deaths; 0/100 (0%) major complications | POOR. Unclear if followup complete. Complications not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup not clear. | 27/100 (27%) TEE to detect possible cardiac source of embolus.
Daniel 1991 | Europe, multicenter Retrospective 1988-1989 | Cardiology | 10419 TEE, in centers performing TEE for at least 1 year, and with records available | 1/10218 (0.01%) death; 18/10218 (0.18%) major pulmonary, cardiac, or bleeding complications (including death) | POOR. Inadequate description of study population. Complications not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear. | Indication not reported. Largest study on TEE complications. 201/10419 (1.9%) of TEE unsuccessfully attempted; 90/10218 (0.88%) of TEE with successful insertion of probe interrupted due to complication (18 major)
deBelder 1989 | UK, single center Prospective Duration not clear | Cardiology | 207 consecutive TEE in unsedated patients | 0/207 (0%) deaths; 0/207 (0%) major complications | POOR. Inadequate description of study population. Complications not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear. | Indication not reported.
Gorge 1990 | Germany, single center Prospective 1989 | Medicine | 24 TEE, patients who gave informed consent | 0/24 (0%) systemic infection or endocarditis | POOR. Selection not clear. Inadequate description of study population. Unclear if followup complete. Complications not specified or defined. No description of ascertainment technique for systemic infection or endocarditis. Unclear if ascertainment independent. | Indication not reported. 4/24 (16.7%) patients had positive blood cultures; no evidence of bacteremia-induced illness at long-term followup.
Hwang 1993 | Taiwan, single center Retrospective 1990-1992 | Emergency medicine, cardiology, internal medicine | 80 TEE in patients in ICU or ED, all of whom also received TTE | 0/80 (0%) deaths; 0/80 (0%) major complications | POOR. Not clear if consecutive. Complications not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup 15 minutes. | 11/80 (14%) patients underwent TEE for evaluation of possible cardiac thrombus.
Khandheria 1994 | US, single center Retrospective 1988-1993 | Cardiology | 7134 TEE, not clear if consecutive | 2/7134 (.03%) deaths; 20/7134 (0.3%) major complications (14 laryngspasm, 2 sustained ventricular tachycardia, 2 CHF, 2 deaths) | POOR. Selection not clear. Inadequate description of study population. Completeness of followup not clear. Complications not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. No statistical analysis of confounders. Duration of followup unclear. | Indication not reported. Complications reported as part of non-systematic review on TEE. Appears to include some data published by Seward (1992).
Khoury 1994 | US, single center Retrospective 1989-1992 | Cardiology | 77 TEE in patients in ICU | 0/77 (0%) deaths; 2/77(2.6%) major complications (1/77 (1.3%) hypotension requiring pressors, 1/77 (1.3%) hypoxemia requiring temporary manual ventilation) | POOR. Not clear if consecutive. Complications not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup unclear. | 16/77 (21%) patioents underwent TEE for evaluation of possible cardiac thrombus.
Nikutta 1992 | Germany, single center Prospective Duration not clear | Cardiology | 100 consecutive TEE in patients without signs of infection or antibiotics prior to procedure | 0/100 (0%) clinical bacteremia or endocarditis at 6 days | POOR. Followup of 26 inpatients and 2 patients with positive cultures. Complications (clinical bacteremia or endocarditis) not specified or defined. No description of ascertainment technique. Unclear if ascertainment independent. Duration of followup insufficient in outpatients without positive cultures. | 43/100 (43%) underwent TEE for evaluation of source of emboli.
Pearson 1990 | US, single center Retrospective Duration not clear | Cardiology | 62 TEE in ICU pts, not clear if consecutive | 0/62 (0%) deaths; 0/62 major complications | POOR. Selection not clear. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. Duration of followup unclear. | 16/62 (26%) of TEE for evaluation of cardiac embolus. All patients in ICU.
Pongratz 1993 | Germany, single center Not clear if prospective Duration not clear | Cardiology | 101 TEE, not clear if consecutive; excluded if pre-procedure clinical or lab evidence of infection or use of antibiotics | 0/101 (0%) endocarditis | POOR. Selection not clear. Inadequate description of study population. Complications (endocarditis) not specified or defined. Inadequate description of ascertainment technique for endocarditis. Unclear if ascertainment independent. | Indication not reported.
Roudaut 1993 | France, single center Prospective Duration not clear | Cardiology | 82 consecutive TEE | 0/82 (0%) endocarditis | POOR. Inadequate description of study population. Only 1/3 of population seen in long-term followup. Complications not specified or defined. Unclear if ascertainment independent. Duration of followup 6 days. | 18/82 (22%) of TEE for evaluation of cerebral ischemia. Unable to separate complications by indication. No cases of infective endocarditis seen after TEE, but only 1/3 of patients seen in long-term followup.
Steckelberg 1991 | US, single center Prospective Duration not clear | Infectious disease and cardiology | 49 consenting patients undergoing TEE without evidence of infection, antibiotics, or anemia prior to procedure | 0/49 (0%) endocarditis or bacteremic infection | POOR. Inadequate description of study population. Not clear if followup complete. Complications (endocarditis or bacteremic infection) not specified or defined. Inadequate description of ascertainment technique. Unclear if ascertainment independent. Duration of followup not clear. | 34/49 (69%) underwent TEE for evaluation of cardiac source of embolus.

TTE: transthoracic echocardiography; TEE: transesophageal echocardiography; NYHA: New York Heart Association; CHF: congestive heart failure; VT: venticular tachycardia; ICU: intensive care unit; ED: emergency department

Evidence Table 7. Efficacy and safety of anticoagulation in unselected patients with stroke

Author Year | Study Design | Population/setting | Exclusions | CT imaging | Interventions | Treatment allocation | Outcomes
Author Year | Study Design | Population/setting | Exclusions | CT imaging | Interventions | Treatment allocation | Follow-up | Stroke | Hemorrhage | Death | Quality/Comments
Acute Anticoagulation
IST Group 1997 | Randomized, open trial | 19435 patients within 48 hours of acute stroke. Multiple centers in 36 countries. AF included (16%). | TIA, anticoagulation contraindications, ICH, current anticoagulation. | Performed in 96% of patients. | 1) Subcutaneous heparin (5000u BID, 12,500u BID) 2) Aspirin (300 mg) 3) Heparin+aspirin 4) Placebo Treatment duration 2-10 days. (Results for heparin in this table apply only to 5000u BID dose; higher dose was associated with worse outcomes) | Computer-generated randomization. Allocation concealed. | 14 days (100%). Outcome assessment not masked. | Any ischemic stroke: Heparin alone: 3.2 % Aspirin alone: 3.2% Combined: 2.1% Neither: 4.4% | Major hemorrhage (ICH, fatal, or requiring transfusion): Heparin alone: 1.1 % Aspirin alone: 1.0% Combined: 1.6% Neither: 0.6% ICH: Heparin alone: 0.7 % Aspirin alone: 0.5% Combined: 0.8% Neither: 0.3% | Heparin: 8.9% No heparin: 9.3% Aspirin alone: 9.3% Combined: 8.0% (Mortality results for heparin alone were not presented) | FAIR. Outcome assessment not masked.
Chronic Anticoagulation
WARSS, 2001 | Randomized, double-blind trial | 2206 "acceptable candidates for anticoagulation" with ischemic stroke in prior 30 days. Forty-eight academic medical centers in U.S. | INR>1.4, AF, procedure-related stroke, severe carotid stenosis requiring surgery. | Required to determine eligibility. | 1) Warfarin (INR 1.4-2.8) 2) Aspirin (325 mg) | Randomization method, allocation concealment not described (baseline characteristics evenly distributed). | 2 years (98.5%). | Nonfatal ischemic stroke: Warfarin: 13.5% Aspirin: 11.2% | Major hemorrhage (ICH or other central nervous system, or requiring transfusion) Warfarin: 3.4% Aspirin: 2.7% | Warfarin: 4.3% Aspirin: 4.8% | GOOD.
SPIRIT 1997 | Randomized, open trial | 1316 patients with TIA or minor ischemic stroke in prior 6 months. Multiple centers (mainly in the Netherlands). | Severe carotid stenosis requiring surgery, AF, valve disease, recent MI, coagulopathy, contraindication to anticoagulants or aspirin. | Performed in 88% of patients. | 1) Warfarin (INR 3.0-4.5) 2) Aspirin (30 mg) | Computer-generated block randomization. Allocation concealed. | Mean 14 months (completeness of follow-up not indicated). | Nonfatal ischemic stroke: Warfarin: 3.7% Aspirin: 2.7% | Major hemorrhage (ICH, fatal, or requiring hospitalization) Warfarin: 8.1% Aspirin: 0.9% | Warfarin: 5.4% Aspirin: 2.3% | GOOD. Trial terminated early due to excess adverse outcomes in warfarin group.
Garde 1983 | Randomized, open trial | 241 patients with anterior circulation TIA in prior 2 weeks. Two hospitals in Sweden. | "Advanced age," gastritis, peptic ulcer, severe systemic disease, clear indications for anticoagulant or aspirin (e.g., AF, rheumatic disease) | Not performed. | 1) Warfarin (monitored with thrombotest) 2) Aspirin (2 gm) | Randomization method, allocation concealment not described. | 20 months (completeness of follow-up not indicated). Outcome assessment not masked. | Any cerebral infarction: Warfarin: 3.5% Aspirin: 3.1% | Any hemorrhage Warfarin: 7.0% Aspirin: 3.1% ICH Warfarin: 0% Aspirin: 0.8% | Warfarin: 2.6% Aspirin: 2.4% | POOR. Groups not comparable. Treatment not blinded. Outcome assessment not masked.
Buren 1981 | Quasi-randomized, open trial | 125 patients with acute TIA. Single hospital in Sweden. | Noncompliance (including due to adverse effects), non-atherosclerotic stroke etiology, cancer, collagen disease. | Not performed. | 1) Anticoagulants (agents not specified, monitored with thrombotest) 2) Aspirin + dipyridamole | Allocation by patient's birthdate. | 2 years (completeness of follow-up not indicated). Outcome assessment not masked. | Any cerebral infarction: Anticoagulant: 3.3% Antiplatelet: 6.2% | ICH Anticoagulant: 0% Antiplatelet: 3.1% | Anticoagulant: 5.0% Antiplatelet: 12.3% | POOR. Interventions not well described. Treatment not randomized or blinded. Outcome assessment not masked.
Olsson 1980 | Randomized, open trial | 135 patients with TIA/RIND, treated for 2 months with anticoagulants prior to randomization. Five hospitals in Sweden. | Bleeding complications from anticoagulant, intercurrent illness, inability to manage treatment during first 2 months. | Performed in 13%. | 1) Warfarin (monitored with thrombotest) 2) Aspirin + dipyridamole | Randomization method, allocation concealment not described. | 12-13 months (completeness of follow-up not indicated). Outcome assessment not masked. | Any cerebral infarction: Warfarin: 1.5% Antiplatelet: 4.5% | Major hemorrhage (requiring hospitalization) Warfarin: 10.3% Antiplatelet: 4.5% ICH Warfarin: 1.5% Antiplatelet: 0% | Warfarin: 8.8% Antiplatelet: 3.0% | POOR. Groups not comparable. Treatment not blinded. Outcome assessment not masked.
Eriksson 1985 | Quasi-randomized, open trial | 188 patients with TIA in prior 3 months. Single center in Sweden. | Contraindications to anticoagulation; taking antithrombotic or anti-inflammatory drugs or estrogen at entry; AF; severe valvular stenosis; carotid occlusion or surgery; angiographic complications. | Not performed. | 1) Warfarin (monitored with thrombotest) 2) Aspirin + dipyridamole | Allocation by month of admission. | 3 years for warfarin group, 2 years for antiplatelet group (completeness of follow-up not indicated). Outcome assessment not masked. | Any stroke: Warfarin: 6.5% Antiplatelet: 16.7% | Major hemorrhage(not defined) Warfarin: 2.2% Antiplatelet: 1.0% ICH Warfarin: 1.1% Antiplatelet: 1.0% | Warfarin: 6.5% Antiplatelet: 6.3% | POOR. Groups not comparable. Treatment not randomized or blinded. Outcome assessment not masked.

Evidence Table 8. Accuracy of carotid ultrasound for detecting internal carotid artery stenosis

Author year | Population/setting | Mean/median age (range) | Female (%) | Symptomatic patients (%) | TIA(%) | Stroke subtypes | Reference standard | Method for measuring degree of stenosis | Stenosis defined as positive on reference standard | Prevalence of positive stenosis | Prevalence of occlusion | CUS method | CUS criteria | Cutoff for positive test by NASCET criteria | Number arteries/patients | Indeterminate results | Sensitivity | Specificity | Positive LR | Negative LR | Quality | Comments
Eliasziw 1995 | 1011 patients with stroke/TIA from 50 academic medical centers participating in NASCET | 66 | 31% | 100% | 68% | Hemispheric or retinal | Selective carotid angiography | NASCET | 70-99% | 48% (patients) | Not reported | Duplex | Combinations of PSV, PSF, ICA/CCA PSV ratio | 70% | 1011 patients (ipsilateral arteries studied) | Not reported | 69% | 68% | 2.16 | 0.46 | GOOD. | Exclusion of patients with < 30% stenosis may have inflated sensitivity and decreased specificity.
Dippel 1999 | 152 consecutive patients with minor stroke/TIA at a university hospital in the Netherlands | 56 (19-80) | 35% | 100% | 47% | Not reported | Selective carotid angiography | ECST | 70-99% | 16% (patients) | 8% (patients) | Duplex/color flow | PSV>150, ICA/CCA PSV ratio >2, EDV>50, 1+ turbulence | 50% | 321 patients (ipsilateral arteries studied) | 2 uninterpretable duplex exams excluded | 58% | 92% | 7.25 | 0.46 | FAIR. No inter-rater reliability assessment. Discretionary subject selection. Two indeterminate arteries excluded. | Sensitivity and specificity were adjusted for verification bias.
Golledge 1999 | 50 patients with recent stroke/TIA at an academic medical center in the UK | 71 (47-84) | 48% | 100% | Not reported | Not reported | Selective carotid DSA | NASCET | 70-99% | 33% (arteries) | 9% (arteries) | Duplex/color flow | EDV > 90 | 70% | 100 arteries | None | 88% | 84% | 5.50 | 0.14 | FAIR. CUS criteria were derived from this sample, not validated. No inter-rater reliability assessment.
Russell 1985 | 66 patients with symptoms suggestive of carotid occlusion at a hospital in Norway | Not reported | Not reported | 100% | Not reported | Not reported | Selective carotid angiography | NASCET | 51-99% 76-99% | 23% (arteries) 10% (arteries) | 9% (arteries) | Doppler spectral analysis | Ratio of spectral spreading at stenosis site vs. distal ICA | 51% 76% | 132 arteries | None None | 86% 72% | 99% 93% | 86.00 9.63 | 0.14 0.30 | FAIR. No inter-rater reliability assessment. Discretionary subject selection. Sample was not well described.
Torvaldsen 1985 | 52 patients undergoing Doppler scanning who had had angiography in the prior month at a hospital in Australia | 59 | 33% | 27% | 23% | Not reported | Carotid angiography | NASCET | 50-99% 75-99% | 29% (arteries) 12% (arteries) | 6% (arteries) | Doppler/color Echoflow | Color codes indicating degree of stenosis | 50% 75% | 101 arteries | None None | 83% 61% | 78% 93% | 3.72 8.17 | 0.22 0.42 | FAIR. No inter-rater reliability assessment. Discretionary subject selection.
Vanninen 1995 | 45 consecutive patients with carotid territory ischemic symptoms at a university hospital in Finland | 58 (34-72) | 16% | 100% | Not reported | Carotid territory only | Carotid DSA | NASCET | 70-99% | 14% (arteries) | Not reported | Duplex/color flow | PSV > 230 | 70% | 90 arteries | None | 93% | 93% | 13.29 | 0.08 | FAIR. No inter-rater reliability assessment. Discretionary subject selection.
Worthy 1997 | 73 consecutive patients with symptomatic carotid territory ischemia at a hospital in the UK | 62 (47-84) | 47% | 100% | 68% | Carotid territory only | Selective carotid DSA | ECST | 70-99% | 31% (arteries) | 16% (arteries) | Duplex/color flow | PSV>300 and EDV>120 | 50% | 143 arteries | 3 arteries excluded due to atypical findings on CUS | 76% (73%) | 95% (91%) | 15.20 (8.44) | 0.25 (0.28) | FAIR. No inter-rater reliability assessment. Three indeterminate arteries excluded. | Figures in parentheses represent sensitivity, specificity, and LRs when 3 indeterminate results are assumed to be all false + or all false -
Sillesen 1988 | 68 consecutive patients referred for carotid evaluation to the vascular surgery department of a university hospital in Denmark | 61 (37-78) | Not reported | 79% | Not reported | Not reported | Cerebral angiography | NASCET | 50-99% | 23% (arteries) | 8% (arteries) | Doppler spectral analysis | Systolic spectral broadening index > 0.37 | 50% | 128 arteries | 3 uninterpretable Doppler exams excluded | 92% (86%) | 83% (80%) | 5.41 (4.60) | 0.10 (0.17) | POOR. CUS criteria were derived from this sample, not validated. No inter-rater reliability assessment. Three indeterminate arteries. | Figures in parentheses represent sensitivity, specificity, and LRs when 3 indeterminate results are assumed to be all false + or all false -

TIA: transient ischemic attack; CUS: carotid ultrasound; LR: likelihood ratio; NASCET: North American Symptomatic Carotid Endarterectomy Trial; ECST: European Carotid Surgery Trial; PSV: peak systolic velocity; PSF:peak systolic frequency; ICA: internal carotid artery; CCA: common carotid artery; EDV: end-diastolic velocity; DSA: digital subtraction angiography

Evidence Table 9. Accuracy of magnetic resonance angiography for detecting internal carotid artery stenosis

Author Year | Population/setting | Mean/median age (range) | Female (%) | Symptomatic patients (%) | TIA(%) | Stroke subtypes | Reference standard | Method for measuring degree of stenosis | Stenosis defined as positive on reference standard | Prevalence of positive stenosis | Prevalence of occlusion | MRA method | Categorization of flow void | Cutoff for positive test by NASCET criteria | Number of arteries/patients | Indeterminate results | Sensitivity | Specificity | Positive LR | Negative LR | Quality | Comments
Young 1994 | 70 consecutive patients with non-disabling stroke/TIA, > 30% stenosis on duplex ultrasound at a hospital in the UK | 62 (37-76) | 30% | 100% | 51% | Carotid territory only | Selective carotid DSA | Common carotid denominator | 70-99% | 41% (arteries) | 11% (arteries) | 2D & 3D TOF | 90% stenosis | 50% | 137 arteries | 1 | 90% (89%) | 95% (94%) | 19.83 (15.10) | 0.10 (0.12) | GOOD. One indeterminate result was excluded. | Figures in parentheses represent sensitivity, specificity, and LRs when indeterminate result is assumed to be false + or false -
Huston 1998 | 50 consecutive patients scheduled for angiography after CUS at a referral hospital in Minnesota | 70 (42-87) | 32% | Not reported | Not reported | Not reported | Selective carotid angiography | NASCET | 70-99% | 25% (arteries) | 10% (arteries) | 2D & 3D TOF | 98% stenosis | 70% | 100 arteries | Reported results indicate 3 arteries missing from analysis | 94% (86%) | 84% (78%) | 5.93 (4.27) | 0.07 (0.16) | FAIR. Discretionary subject selection. 3 arteries were missing from reported results. | Figures in parentheses represent sensitivity, specificity, and LRs when 3 missing results are assumed to be all false + or all false -
Sardanelli 1999 | 30 consecutive patients with symptoms of cerebrovascular disease, who had undergone DSA | 64.5 | 41% | 100% | Not reported | Not reported | Cerebral DSA | NASCET | 70-99% | 23% (arteries) | 10% (arteries) | 3D TOF Gadolinium-enhanced | 99% stenosis | 70% | 60 arteries | None | 100% 100% | 85% 100% | 6.67 Infinite | 0.00 0.00 | FAIR. Moderate sample size. Discretionary subject selection. No inter-rater reliability testing.
Vanninen 1995 | 45 consecutive patients with carotid territory TIA or non-disabling stroke, referred for angiography | 58 (34-72) | 16% | 100% | Not reported | Not reported | Selective carotid DSA | NASCET | 70-99% | 14% (arteries) | Not reported | 3D TOF | 85% stenosis | 70% | 90 arteries | None | 93% | 95% | 17.64 | 0.08 | FAIR. Moderate sample size. Discretionary subject selection.
Jackson 1998 | 50 consecutive patients referred for carotid angiography after CUS at a military hospital in Washington, DC | 69.5 | 28% | 76% | Not reported | Not reported | Conventional cerebral angiography and DSA | NASCET | 60-99% | 36% (arteries) | 6% (arteries) | 2D TOF | > 80% stenosis | 60% | 99 arteries | 1 indeterminate 5 missing from analysis | 85% (74%) | 70% (63%) | 2.87 (2.32) | 0.21 (0.37) | POOR. Moderate sample size. Discretionary subject selection. No inter-rater reliability testing. One indeterminate result was excluded. 5 arteries were missing from reported results. | Figures in parentheses represent sensitivity, specificity, and LRs when 6 missing results are assumed to be all false + or all false -
Riles 1992 | 41 patients referred for angiography due to symptoms or asymptomatic stenosis > 80% on CUS | 68 (44-87) | 48% | Not reported | Not reported | Not reported | Conventional selective carotid angiography or DSA | NASCET | 50-99% 80-99% | 60% (arteries) 27% (arteries) | 7% (arteries) | 2D TOF | Not reported Not reported | 50% 80% | 75 arteries 75 arteries | None None | 100% 88% | 64% 88% | 2.78 7.33 | 0.00 0.14 | POOR. Moderate sample size. Discretionary subject selection. No inter-rater reliability testing. Testing methods were not well described. Potential unblinding in some cases.

TIA: transient ischemic attack; DSA; digital subtraction angiography; NASCET; North American Symptomatic Carotid ENdarterectomy Tial; CUS; carotid ultrasound; TOF; time-of-flight; 2D; two-dimensional; 3D; three dimensional; LR; likelihood ratio

Evidence Table 10. Accuracy of combined carotid ultrasound and magnetic resonance angiography for detecting internal carotid artery stenosis

Author, year | Population/setting | Mean/median age (range) | Female (%) | Symptomatic patients (%) | TIA(%) | Stroke subtypes | Reference standard | Method for measuring degree of stenosis | Stenosis defined as positive on reference standard | Prevalence of positive stenosis | Prevalence of occlusion | CUS method | CUS degree of stenosis | CUS criteria | MRA method | Categorization of MRA flow void | Cutoff for positive test by NASCET criteria | Number arteries/patients | Indeterminate results | Non-concordant CUS and MRA | Concordant MRI and CUS | | | | Quality
Author, year | Population/setting | Mean/median age (range) | Female (%) | Symptomatic patients (%) | TIA(%) | Stroke subtypes | Reference standard | Method for measuring degree of stenosis | Stenosis defined as positive on reference standard | Prevalence of positive stenosis | Prevalence of occlusion | CUS method | CUS degree of stenosis | CUS criteria | MRA method | Categorization of MRA flow void | Cutoff for positive test by NASCET criteria | Number arteries/patients | Indeterminate results | Non-concordant CUS and MRA | Sensitivity | Specificity | Positive LR | Negative LR | Quality
Huston 1998 | 50 consecutive patients scheduled for angiography after CUS at an academic medical center in Minnesota | 70 (42-87) | 32% | Not reported | Not reported | Not reported | Selective cerebral angiography | NASCET | 70-99% | 25% (arteries) | 10% (arteries) | Duplex/color flow | > 70% | PSV> 230 + EDV>70 | 2D & 3D TOF | 98% stenosis | 70% | 100 arteries | Reported results indicate 3 arteries missing from MRA analysis | 14 (14%) (includes 3 missing results) | 97% | 85% | 6.42 | 0.04 | FAIR. Discretionary subject selection. Potential verification bias for CUS. No inter-rater reliability testing of CUS.
Mittl 1994 | 35 patients who had undergone CUS, MRA and angio for suspected carotid disease at a university hospital in Pennsylvania | 66 (48-80) | 47% | 74% | 52% | Not reported | Selective conventional carotid angiography or DSA | NASCET | 70-99% | 30% (arteries) | 10% (arteries) | Duplex/color flow | > 70% | ICA/CCA PSV ratio > 4.0 | 2D TOF | 70-99% stenosis | 70% | 66 arteries | None | 11 (17%) | 100% | 80% | 5.00 | 0.00 | FAIR. Moderate sample size. Discretionary subject selection. Potential verification bias for CUS. No inter-rater reliability testing of CUS.
Patel et al. 1995 | 81 patients referred for angiography after CUS at 2 university hospitals in Massachussetts | 70 (48-87) | 34% | 91% | 65% | Not reported | DSA | NASCET | 70-99% | 32% (arteries) | 10% (arteries) | Duplex | 70-99% | PSV > 230 ICA/CCA PSV >4.0 | 2D & 3D TOF | 90-99% stenosis | 70% | 158 arteries | 8 indeterminate MRA 2 indeterminate CUS | 34 (22%) (includes 10 indeterminate results) | 100% | 90% | 10.50 | 0.00 | FAIR. Discretionary subject selection. Potential verification bias. No inter-rater reliability testing of CUS.
Serfaty 2000 | 23 consecutive patients with middle cerebral artery ischemia or amaurosis, and asymptomatic patients with >30% stenosis on CUS prior to coronary bypass surgery | 68 (34-85) | 25% | 50% | Not reported | Not reported | Selective carotid DSA | NASCET | 70-99% | 27% (arteries) | 3% (arteries) | Duplex/color flow | 70-99% | PSV>250 | 3D TOF Gadolinium-enhanced | >70% stenosis Not relevant | 70% 70% | 46 arteries | None | 7 (15%) 10 (22%) | 100% 100% | 100% 100% | Infinite Infinite | 0.00 0.00 | FAIR. Small sample size. Potential verification bias. No inter-rater reliability testing of CUS.
Young 1994 | 70 consecutive patients with non-disabling stroke/TIA, > 30% stenosis on duplex ultrasound at a hospital in the UK | 62 (37-76) | 30% | 100% | 51% | Carotid territory only | Selective carotid DSA | Common carotid denominator | 70-99% | 41% (arteries) | 11% (arteries) | Duplex | > 70% | Mathematical model derived in a prior study | 2D & 3D TOF | 90% stenosis | 50% | 138 arteries | 1 MRA | 7 (5%) (includes 1 indeterminate MRA) | 94% | 95% | 18.80 | 0.06 | FAIR. Potential verification bias for CUS. No inter-rater reliability testing of CUS.
Back 2000 | 40 consecutive patients undergoing CEA, who had undergone pre-operative CUS, MRA, and angiography at a VA hospital in Florida | 63 (46-82) | 2% | 56% | Not reported | Hemispheric or retinal | Conventional cerebral angiography and DSA | NASCET | 75-99% | 36% (arteries) | 5% (arteries) | Duplex/color flow | > 75% | PSV, EDV, ICA-CCA ratio (combinations determined from prior study) | 2D & 3D TOF (intracranial and extracranial) | 75-99% stenosis | 75% | 75 arteries | 1 inadequate CUS | 5 (7%) (includes 1 inadequate CUS) | 100% | 76% | 4.20 | 0.00 | POOR. Narrow spectrum (only patients undergoing CEA). Moderate sample size. Discretionary subject selection. Potential verification bias. No inter-rater reliability testing of CUS or MRA.
Jackson 1998 | 50 consecutive patients referred for carotid angiography after CUS at a military hospital in Washington, DC | 69.5 | 28% | 76% | Not reported | Not reported | Conventional cerebral angiography and DSA | NASCET | 60-99% | 36% (arteries) | 6% (arteries) | Duplex/color flow | | PSV>245 + EDV>65 | 2D TOF | > 80% stenosis | 60% | 100 arteries | 1 indeterminate MRA 9 missing from CUS analysis | 36 (36%) (includes 10 missing or indeterminate results) | 100% | 95% | 20.00 | 0.00 | POOR. Moderate sample size. Discretionary subject selection. Potential verification bias. No inter-rater reliability testing of CUS or MRA.
Mattle 1991 | 20 patients who had undergone CUS, MRA, and angiography at a university hospital in Massachussetts | 61 | 20% | 65% | 55% | Not reported | Conventional cerebral angiography or DSA | NASCET | 70-99% | 26% (arteries) | 10% (arteries) | Duplex (with color flow imaging later in study) | > 70% | Not reported | 2D & 3D TOF | Not reported | 70% | 39 arteries | None | 8 (21%) | 100% | 100% | Infinite | 0.00 | Poor. Small sample size. Discretionary subject selection. Potential verification bias. No inter-rater reliability testing of CUS or MRA. Testing methods were not well described. Reading of reference standard was not clearly blinded.
Nicholas 1995 | 40 patients who had undergone CUS, MRA, and angiography at a community hospital in Pennsylvania | 69 (49-85) | 28% | 62.5% (additional 17.5% w/ non-hemispheric symptoms) | Not reported | Hemispheric and non-hemispheric | Conventional cerebral angiography or DSA | NASCET | 70-99% | 23% (arteries) | 12% (arteries) | Duplex/color flow | > 60% | PSV>185 + EDV>40 | 2D & 3D TOF | Subjective assignment | 70% | 78 arteries | 4 "technically unsatisfactory" MRA or CUS studies | 12 (15%) (includes 4 unsatisfactory studies) | 100% | 98% | 45.00 | 0.00 | Poor. Moderate sample size. Discretionary subject selection. Potential verification bias. No inter-rater reliability testing of CUS or MRA. Testing methods were not well described. Reading of reference standard was not clearly blinded.
Riles 1992 | 41 patients referred for angio due to symptoms or asymptomatic stenosis > 80% on CUS at a university hospital in New York | 68 (44-87) | 48% | Not reported | Not reported | Not reported | Selective conventional carotid angiography or DSA | NASCET | 50-99% 80-99% | 60% (arteries) 27% (arteries) | 7% (arteries) | Duplex | > 50% | PSV, diastolic velocity, spectral analysis (criteria not defined) | 2D TOF | Not reported | 50% 80% | 75 arteries | None | 10 (13%) 21 (28%) | 100% 100% | 72% 69% | 3.60 3.18 | 0.00 0.00 | Poor. Moderate sample size. Discretionary subject selection. Potential verification bias for CUS. No inter-rater reliability testing of CUS or MRA. Testing methods were not well described. Potential unblinding in some cases.
Spartera 1993 | 51 patients who had undergone MRA, CUS, and angio at a university hospital in Italy | Not reported | Not reported | Not reported | Not reported | Not reported | Cerebral DSA | NASCET | 60-99% | 37% (arteries) | 11% (arteries) | Duplex/color flow | 60-99% | Not described | 2D TOF | Not described | 60% | 102 arteries | 1 indeterminate MRA | 33 (32%) (includes 1 indeterminate MRA) | 100% | 87% | 7.69 | 0.00 | Poor. Patient population was not described. Discretionary subject selection. Potential verification bias. No inter-rater reliability testing of CUS or MRA. Testing methods were not well described.

Evidence Table 11. Complications of cerebral angiography

Study Year | Setting Duration | Author Affiliation | Sample Size and Selection | Major peri-angiography (72 hours) Complications | Quality | Comments
Davies 1993 | UK, single center 1989-1992 | Neurology and neurosurgery | 200 consecutive patients selected for angiography based on ultrasound and considered fit for CEA | 8/200 (4%) stroke or death; 0/200 (0% death) | GOOD. Not clear if ascertainment independent | Ultrasound used to exclude patients without suggestive findings.
Earnest 1984 | US, single center 1980-1982 | Radiology, neurology, and neurosurgery | 1517 consecutive angiography, 637 in symptomatic patients | 4/637 (0.6%) stroke or death; 0/637(0%) death | GOOD. Not clear if duration of followup 72 hours. | Relatively detailed univariate analysis of potential risk factors/confounders; multivariate analysis not performed. Tabulated results exclude asymptomatic patients
Hankey 1990 | UK, single center 1977-1986 | Neurology | 382 consecutive patients undergoing angiography for symptomatic cerebrovascular disease | 5/382 (1.3%) stroke or death; 0/382 (0%) death | GOOD. | Complication rate reported separately according to presenting cerebral ischemic syndrome.
Dion 1987 | Canada, single center 1983-1984 | Radiology and neurology | 1002 consecutive angiography, 284 in symptomatic patients | 2/284 stroke or death (0.7%); 0/284 (0%) death | FAIR. Inadequate description of study population. Inadequate description of ascertainment technique. | Tabulated results exclude asymptomatic patients.
Gasparini 1986 | Italy, single center Duration not clear | Neurology | 218 consecutive angiography, 86 in symptomatic patients | 0/86 (0%) stroke or death; 0/86 death | FAIR. Complications not specified or defined. Inadequate description of ascertainment technique. Not clear if ascertainment independent. Not clear if duration of followup 72 hours. | Multivariate analysis of multiple clinical characteristics, procedure variables, and presenting symptoms performed. Tabulated results exclude asymptomatic patients.
Heiserman 1994 | US, single center 1992-1993 | Radiology | 688 consecutive angiography, 322 in symptomatic patients | 5/322 (1.6%) stroke or death; death not reported separately | FAIR. Not clear if ascertainment independent. Inadequate statistical analysis of confounders. Not clear if duration of followup 72 hours. | Many patients had more than one angiographic procedure done; experience of angiographer reported by level of training. Tabulated results exclude asymptomatic patients.
McIvor 1987 | UK, single center 1981-1984 | Radiology and neurology | 230 consecutive angiography in patients considered fit for CEA | 13/230 (5.7%) stroke or death; 0/230 (0%) death | FAIR. Complications not specified or defined. Inadequate statistical analysis of confounders. Not clear if duration of followup 72 hours. | Contrast medium had no effect on complication rates. Reported 1 month followup: 5 patients with major neurologic deficits and 6 with minor deficits.
Ball 1985 | US, single center 1982-1983 | Radiology | 650 consecutive patients received IV DSA (n=500) or conventional angiography (n=150) at discretion of radiologist, for evaluation of cerebrovascular disease | 0/150 (0%) stroke or death; 0/150 (0%) death | POOR. Unclear how patients selected for conventional angiography or IV DSA. Inadequate description of study population. Complications not specified or defined. Inadequate description of ascertainment technique. No statistical analysis of confounders. Unclear if duration of followup 72 hours. | Tabulated results do not include 500 patients who underwent IV DSA (intravenous digital subtraction angiography).
Jeans 1986 | UK, single center Duration 3 years | Radiology | 135 angiography, not clear how selected, 130 in symptomatic patients | 5/135 (3.7%) stroke or death; 1/135 (0.7%) death | POOR. Complications not specified or defined. Inadequate description of ascertainment technique. Not clear if ascertainment independent. No statistical analysis of confounders. Not clear if duration of followup 72 hours. | 32% of patients went on to CEA. Unable to separate out asymptomatic patients, though they only comprised 4% of population.
Kerber 1978 | US, single center Duration 4.5 years | Radiology | 662 consecutive angiography in patients suspected of having cerebrovascular disease | 3/662 (0.5%) stroke or death; 0/662 (0%) death | POOR. Inadequate description of study population. Complications not specified or defined. Ascertainment not independent. No statistical analysis of confounders. Not clear if duration of followup 72 hours.
Skalpe 1980 | Norway, single center 1977-1978 | Radiology and neurology | 308 patients, not consecutive, excluded patients examined outside regular working hours | Combined stroke or death not clear; 1/308 (0.3%) death | POOR. Excluded patients who underwent angiography outside ordinary working hours. Inadequate description of study population. Complications not specified or defined. No statistical analysis of confounders. Not clear if duration of followup 72 hours. | Clinical trial of different types of contrast agents.

CUS: carotid ultrasoiund; MRA: magnetioc resonance angiography; CEA: carotid endarterectomy; IV DSA: intravenous digital subtraction angiography

Evidence Table 12. Complications of carotid endarterectomy

Study Year | Setting Study Type Duration | Author Affiliation | Selection | Major peri-operative (30-day) Complications | Quality | Comments
Barnett 1998 (NASCET) | North America, multicenter RCT 1987-1997 | Multi-disciplinary | Symptomatic patients with <70% stenosis randomized to CEA | 13/1087 (1.2%) death; 73/1087 (6.7%) stroke or death (30/1087 disabling stroke or death); 13/1087 (1.2% death) | GOOD. Ascertainment independent but not clear if blinded to treatment. | Study does not report outcomes of 200 subjects allocated to medical rx who crossed over to CEA. 30-day post-randomization event rates in medical subjects were 27/1188 (2.3%) all stroke or death; 17/1188 (1.4%) disabling stroke or death. Male gender associated.
Barnett 1991 (NASCET) | North America, multicenter RCT 1987-1991 | Multi-disciplinary | Symptomatic patients with 70-99% stenosis randomized to CEA | 19/237 (8.0%) stroke or death (7/327 disabling stroke/death); 2/327 (0.6%) death; 3/327 (0.9%) MI | GOOD. Ascertainment independent but not clear if blinded to treatment. | Study does not report outcomes of 21 subjects allocated to medical rx who crossed over to CEA. 30-day post-randomization event rates in medical subjects were 10/331 (3.3%) stroke; 11/331 (3.3%) stroke or death. Male gender and increased age (>70 yo) associated.
Brott 1986 | US, multicenter Population-based, retrospective 1980, 1983-1984 | Neurology and surgery | All patients undergoing CEA in Cincinatti | 55/585 (9.4%) stroke or death; 16/585 (2.7%) death | GOOD. Inadequate statistical analysis of confounders. Followup not 30 days. | Tabulated results exclude asymptomatic patients. Complication rates not significantly different between 1980 and 1983-1984 samples. Paper by Kempczinski (1986) analyzed same population.
Cebul 1998 | US, multicenter Population-based, retrospective 1993-1994 | Medicine and public health | Random sample of 700/4120 Medicare patients | 24/356 (6.7%) stroke or death; death alone not reported | GOOD. Database abstraction validated by inter-rater agreement. | Tabulated results exclude asymptomatic patients and those with "nonspecific" symptoms. In detailed multivariate analysis, higher-volume hospital, TIA as indication, angina, and renal insufficiency associated with higher complication rates.
ECST 1998 | Europe, multicenter RCT 1981-1994 | Multi-disciplinary | Symptomatic patients randomized to CEA | 124/1787 (7.0%) stroke or death; 22/1787 (1.3%) death | GOOD. Ascertainment independent but not clear if blinded to treatment. | Tabulated results include 42 patients randomized to medical treatment who crossed over to CEA (2/42 stroke or death; 0/42 death). Multivariate Cox proportional-hazards model showed female gender, age, and degree of stenosis (in a complex function) assocociated with increased complications.
Karp 1998 | US, multicenter Population-based, retrospective 1993 | Medicine and public health | All Medicare patients undergoing CEA in Georgia | 60/943 (6.4%) stroke or death; 16/943 (1.7%) death | GOOD. Ascertainment of complications by abstractor validated by physician review. | Tabulated results exclude asymptomatic patients. Combined stroke/death rate may be an overestimate; if "all stroke" doesn't exclude fatal, then combined stroke/death = 48/943 (5.1%). Older age, female gender, low-volume hospital, higher baseline comorbidity associated.
Kirshner 1989 | US, multicenter Population-based, retrospective 1984-1985 | Surgery | All patients undergoing CEA in Rochester | 43/813 (5.3%) stroke or death; 12/813 (1.5%) death | GOOD. Ascertainment blinded to patient and surgeon. | Tabulated results exclude asymptomatic patients. Cardiac risk factors, contralateral carotid disease, female gender, crescendo TIA associated with increased complications.
Mayberg 1991 (VACSP) | US, multicenter RCT 1988-1991 | Multi-disciplinary | Symptomatic patients with >50% stenosis randomized to CEA | 6/90 (6.7%) stroke (2 minor, 1 major) or death; 3/90 (3.3%) death | GOOD. Ascertainment independent but not clear if blinded to treatment. | 30-day post-randomization event rates in medical subjects were 4/101 crescendo TIA, 2/101 minor stroke, 0/101 major stroke, 0/101 deaths; 2/101 stroke or death.
Muuronen 1984 | Finland, single center Prospective 1980-1982 | Neurology | Consecutive symptomatic patients undergoing CEA | 16/110 (14.5%) stroke (9 slight, 3 severe) or death; 4/110 (3.6%) death | GOOD. Complications not specified or defined. Inadequate analysis of confounders.
Richardson 1989 | US, multicenter Population-based, retrospective 1983-1984 | Surgery | All Medicare patients undergoing CEA in Kentucky | 39/630 (6.2%) stroke or death; death alone not reported | GOOD. Ascertainment blinded to surgeon. | Tabulated results exclude asymptomatic patients. Low-volume surgeons associated with increased complications.
Wilson 1993 | US, multicenter Post-hoc analysis of RCT 1988-1991 | Multi-disciplinary | Symptomatic patients assigned to medical rx who later developed crescendo TIAs and underwent CEA | 0/12 (0%) stroke or death; 0/12 (0%) death | GOOD. Ascertainment independent but not clear if blinded. | Small sample size. Post-hoc followup of VA Cooperative Study. Patients selected for CEA based on development of crescendo TIAs.
Wong 1997 | Canada, multicenter Population-based, retrospective 1994-1995 | Surgery and public health | All patients undergoing CEA in Edmonton | 9/174 (5.2%) stroke or death; death alone not reported | GOOD. Not clear if ascertainment independent. | Surgeon specialty not associated with increased complications; age, cardiac risk factors, renal insufficiency associated with increased complications.
Burns 1991 | Australia, multicenter Population-based (prospective) 20 months | Neurology | All patients undergoing CEA in South Australia | 10/130 (7.7%) stroke or death; 2/130 (1.5%) death | FAIR. Complications not specified or defined. Inadequate description of ascertainment technique. Inadequate statistical analysis of confounders. Unclear if duration of followup 30 days. | Tabulated results exclude asymptomatic patients. Prior stroke associated with greater risk of perioperative stroke/death compared to prior TIA (7/42 vs. 3/88).
Golledge 1996 | UK, single center Prospective 1980-1995 | Surgery | Consecutive symptomatic patients undergoing CEA | 19/460 (4.1%) stroke or death; 11/460 (2.4%) death | FAIR. Complications not specified or defined. Inadequate description of ascertainment technique. Ascertainment not independent. Inadequate statistical analysis of confounders. | Crescendo TIA/female gender assoc with increased perioperative complications. Amaurosis associated with fewest complications.
Hertzer 1997 | US, single center Prospective 1989-1995 | Surgery and epidemiology | Consecutive patients undergoing CEA | 25/750 (3.3%) combined stroke or death; 5/750 (0.7%) death | FAIR. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. Complication rates based on in-hospital (not 30-day) events. | Tabulated results exclude asymptomatic patients and patients undergoing concurrent CABG. Female gender, semi-elective CEA, and carotid reoperations assoc with increased complications. Patching associated with fewer complications.
Kadwa 1992 | South Africa, single center Prospective 1981-1991 | Surgery | Consecutive patients undergoing CEA | 31/427 (7.3%) stroke or death; 15/427 (3.5%) death | FAIR. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. Inadequate statistical analysis of confounders. | Tabulated results exclude asymptomatic pts, include pts with "global symptoms" (n=45). Stroke as indication associated with higher rate of complications compared with TIA, global symptoms, and asymptomatic.
Magee 1992 | UK, multicenter Prospective 1985-1989 | Surgery | Consecutive patients undergoing CEA | 21/203 (10.3%) stroke or death; 6/203 (3.0%) death | FAIR. Inadequate description of ascertainment technique. Not clear if ascertainment independent. No statistical analysis of confounders. Not clear if duration of followup 30 days. | Tabulated results include 8 asymptomatic patients; unable to calculate complication rates by indication. Rothwell used study by Earnshaw (1992) on same data but with less detailed info on complications/indications (n=235).
Shaw 1984 | UK, single center RCT 1965-1978 | Neurology | Symptomatic patients randomized to CEA versus no CEA | 7/20 (35%) stroke or death; 3/20 (15%) death | FAIR. Complications not specified or defined. No description of ascertainment technique. No statistical analysis of confounders. | All patients in series symptomatic. Study lasted 13 years with slow recruitment; no information on patients who did not participate. Trial terminated early because of unfavorable results in surgical group.
Troeng 1999 | Sweden, multicenter Population-based, retrospective 1994-1996 | Surgery | All patients undergoing CEA in Sweden | 62/1247 (5.0%) stroke or death; death alone not reported | FAIR. Complications not specified or defined. No statistical analysis of confounders. | Tabulated results exclude asymptomatic patients.
UK-TIA Study Group 1983 | UK, multi-center Post-hoc analysis of RCT 1979-1982 | Multi-disciplinary | All patients in RCT who underwent CEA following randomization | 10/41 (24.4%) stroke or death; 4/41 (9.8%) death | FAIR. Not clear how patients selected for CEA. No description of ascertainment technique. No statistical analysis of confounders. Not clear if duration of followup 30 days. | All patients in series had TIAs. Small proportion (7%) of subjects underwent CEA, selection for CEA unclear. Post-hoc analysis of RCT of aspirin versus placebo for patients with TIAs.
Whisnant 1983 | US, single center Prospective 1970-1974 | Neurology and surgery | Consecutive patients with TIA undergoing ipsilateral CEA | 6/151 (4.0%) stroke or death; 1/151 (0.6%) death | FAIR. Complications not specified or defined. Inadequate description of ascertainment techniques. Not clear if duration of followup 30 days. | All patients in series had TIAs. Study appears prospective, but not entirely clear. CEA technique changed over time of study to routine venous patch grafting.
Whitney 1980 | US, single group of surgeons in multiple community hospitals Retrospective 1965-1980 | Surgery | Consecutive patients undergoing CEA | 71/1638 (4.3%) stroke or death; 34/1638 (2.1%) death | FAIR. Complications not specified or defined. Not clear if ascertainment independent. No statistical analysis of confounders. | Tabulated results exclude asymptomatic patients; results do include 9 patients with "chronic ischemia." Shunting not performed for any procedure. Study appears retrospective, though classified as prospective by Rothwell.
Zbornikova 1998 | Sweden, single center Prospective 1982-1987 | Neurology | Symptomatic patients undergoing CEA who underwent followup duplex; not clear if consecutive | 10/64 (15.6%) stroke (1 major) or death; 0/64 (0%) death | FAIR. Not clear how patients selected for study. Complications not specified or defined. Inadequate description of ascertainment technique. Inadequate statistical analysis of confounders. | Study focuses on signficance of post-operative occlusion (measured by Doppler) as marker of risk. Earlier study from same institution (Erikson) showed 1.4% mortality rate.
Zeiger 1987 | US, single center Prospective 1979-1985 | Surgery (neurosurgery) | Consecutive symptomatic patients undergoing CEA | 5/142 (3.5%) stroke (1 major) or death; 2/142 (1.4%) death | FAIR. Inadequate description of population. Inadequate description of ascertainment technique. Ascertainment not independent. Inadequate statistical analysis of confounders. | Patients with worse pre-op neurologic status/risk factors had increased rate of complications.
Carmichael 1980 | US, single surgeon at multiple community hospitals Retrospective 1966-1978 | Single surgeon | Consecutive patients undergoing CEA | 11/411 (2.7%) stroke or death; 1/411 (0.2%) death | POOR. Inadequate description of population. No statistical analysis of confounders. No description of ascertainment technique. Complications not specified or defined. Ascertainment not independent. | Tabulated results exclude asymptomatic patients.
Enevoldsen 1999 | Denmark, single center Prospective 1992-1994 | Neurology and radiology | Consecutive symptomatic patients with carotid stenosis >69% who underwent post-op MRI and TCD | 3/33 9.1% stroke or death; 0/33 (0%) death | POOR. Selected patients for inclusion only if they had post-operative MRI/TCD. Complications not specified or defined. Inadequate statistical analysis of confounders. Unclear if duration of followup 30 days. | Study focuses on significance of post-operative trans-cranial Doppler and MRI findings.
Erikkson 1981 | Sweden, single center Retrospective Duration 4 years | Neurology, surgery and radiology | Consecutive symptomatic patients undergoing CEA | 8/87 (9.2%) stroke or death; 2/87 (2.3%) death | POOR. Complications not specified or defined. Not clear if ascertainment independent. No description of ascertainment technique. No statistical analysis of confounders. Duration of followup 2 weeks. | Tabulated results exclude 1 patient with asymptomatic bruit. Post-operative complications recorded for first 2 wks and then for 2 wks-48 months. Study appears retrospective.
Gumerlock 1988 | US, single center RCT 1982-1986 | Surgery | Symptomatic patients undergoing CEA, randomized to shunt vs. no shunt | 8/138 (5.8%) stroke or death; 1/138 (0.7%) death; 2/138 (1.4%) non-fatal MI | POOR. Inadequate description of study population. Ascertainment not independent. Complications not specified or defined. No description of ascertainment technique. Inadequate statistical analysis of confounders. | All patients in series symptomatic. Study compared shunt procedure (n=63) with non-shunt (n=75); shunt associated with fewer peri-operative strokes.
Hafner 1984 | US, group practice at single center Retrospective 1971-1983 | Single surgeon | Consecutive patients undergoing CEA | 8/496 (1.6%) stroke or death; 4/496 (0.8%) death | POOR. No description of ascertainment technique. Complications not specified or defined. No statistical analysis of confounders. Ascertainment not independent. Not clear if followup 30 days. | Tabulated results exclude asymptomatic patients.
Hertzer 1982 | US, single center Retrospective 1980-1981 | Neurology, surgery and radiology | Patients undergoing CEA; unclear if consecutive | 8/154 (5.2%) combined stroke or death; 3/154 (1.9%) death | POOR. Not clear if series consecutive. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. No statistical analysis of confounders. | Tabulated results exclude asymptomatic patients. Not clear if deaths occurred in symptomatic patients; tabulated results assume that deaths were in symptomatic patients and excluded deaths associated with CABG (2/154). Study appears retrospective.
Hoyne 1990 | US, single surgeon at 2 hospitals Retrospective 1984-1988 | Single surgeon | Consecutive patients undergoing CEA | 9/234 (3.8%) stroke or death; 1/234 (0.4%) death | POOR. No description of ascertainment technique. Complications not specified or defined. Inadequate statistical analysis of confounders. Ascertainment not independent. Not clear if followup 30 days. | Tabulated results do not include asymptomatic patients.
Nunn 1988 | US, single surgeon at single hospital Retrospective 1963-1986 | Single surgeon | Consecutive patients with TIAs undergoing CEA | 13/651 (2.0%) stroke or death; 5/651 (0.7%) death | POOR. Inadequate description of ascertainment technique. Ascertainment not independent. Complications not specified or defined. No statistical analysis of confounders. Not clear if followup 30 days. | All patients presented with TIAs.
Parkin 1981 | UK, single center Retrospective 1973-1980 | Neurology | Consecutive patients with amaurosis; 19/56 underwent CEA | 3/19 (1.6%) stroke or death; 0/19 (0%) death | POOR. Unclear how patients selected for CEA. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. No statistical analysis of confounders. Not clear if duration of followup 30 days. | All patients in series had amaurosis. Study clearly appears retrospective, though classified as prospective by Rothwell.
Rubin 1988 | US, multicenter Prospective 1973-1985 | Surgery | Patients undergoing CEA by 51 participating surgeons | 208/7480 (2.8%) stroke or death; 117/7480 (1.6%) death | POOR. Not clear if consecutive series from participating surgeons. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. Inadequate statistical analysis of confounders. Not clear if duration of followup 30 days | Tabulated results exclude asymptomatic patients. Increased surgical volume associated with fewer complications. 20-25% of surgeons in this community (Cleveland) did not participate in study; participating surgeons were members of Cleveland Vascular Society.
Sacquegna 1986 | Italy, single center Retrospective 1975-1981 | Neurology and surgery | Consecutive patients with TIAs undergoing CEA | 3/76 (3.9%) stroke or death; 1/76 (1.3%) death; 1/76 (1.3%) non-fatal MI | POOR. Inadequate description of population. Complications not specified or defined. No description of ascertainment technique. Ascertainment not independent. No statistical analysis of potential confounders/risk factors. Not clear if duration of followup 30 days. | All patients in series had TIAs. Not clear how pts selected to undergo CEA. Study appears retrospective, though classified as prospective by Rothwell.
Takolander 1983 | Sweden, single center Retrospective 1971-1979 | Surgery | Consecutive patients undergoing CEA | 7/60 (11.7%) stroke or death; 4/60 (6.7%) death | POOR. Inadequate description of population. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. No statistical analysis of confounders. Not clear if duration of followup 30 days. | Tabulated results exclude asymptomatic patients. Study appears retrospective, though classified as prospective by Rothwell.
Thompson 1983 | US, surgical group at single center Retrospective 24 years | Single surgeon | Consecutive patients undergoing CEA | Combined stroke or death not reported; 33/1420 (2.3%) death | POOR. Inadequate description of population. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. No statistical analysis of confounders. Not clear if duration of followup 30 days | Tabulated results exclude asymptomatic patients; results do include 22 patients with "chronic ischemia." Study appears retrospective, though classified as prospective by Rothwell. Single surgeon author, though classified as multiple surgeon authors
Whittemore 1980 | US, single surgeon with senior residents at single center Retrospective 1977-1979 | Single surgeon | Consecutive patients undergoing CEA | 2/57 (3.5%) stroke or death; 1/57 (1.8%) death | POOR. Inadequate description of population. Complications not specified or defined. No description of ascertainment technique. Ascertainment not independent. No statistical analysis of confounders. Not clear if duration of followup 30 days. | Tabulated results exclude asymptomatic patients. CEA performed with routine shunting. Study appears retrospective though classified as prospective by Rothwell.

RCT: randomized controlled trial; CEA: carotid endarterectomy; TIA: transient ischemic attack; MRI: magnetic resonance imaging; TCD: transctranial doppler; VA: Veterans Affairs

Evidence Table 13. Effect of timing on safety of carotid endarterectomy

Study Year | Setting Study Type Duration | Author Affiliation | Sample Size and Selection | Peri-operative (30-day) Complications | Quality | Comments
Gasecki 1994 | US and Canada, multicenter Post-hoc subgroup analysis of RCT 1988-1991 | Neurology | Of 328 CEA in patients with 70-99% stenosis, 100 performed in patients with hemispheric stroke Group A: 42/100 had CEA prior to 30 days Group B: 58/100 had CEA after 30 days (grp B) | Group A : 2/42 (4.8%) stroke or death; 0/42 (0%) death Group B: 3/58 (5.2%) stroke or death; 0/58 (0%) death | FAIR. More patients with normal CT in grp A, grp A had overall greater degree of angiographically seen diagnosis. Other clinical/demographic features similar. No statistical analysis of confounders. | Post-hoc analysis of NASCET. Did not find evidence that in patients with abnormal CT, delaying surgery results in less morbidity.
Hoffmann 1999 | S Africa, single center Retrospective 1981-1988 | Neurology and surgery | 207/1005 CEA had stroke as indication Group A: 86/207 had CEA within 6 weeks Group B: 121/207 had CEA after 6 weeks study analyzed 86 early (<6 wks, grp A) vs 121 late (>6 wks, grp B) CEA. | Group A: 3/86 (3.5%) stroke or death; 1/86 (1.2%) death Group B: 7/121 (5.8%) stroke or death; 3/121 (2.5%) death | FAIR. Unclear how patients selected for early surgery. Groups relatively comparable by most demographic/clinical factors. No description of ascertainment technique. No statistical analysis of confounders. Not clear if ascertainment independent. | RR 1.90 (NS) for morbidity/mortality in later surgery group. Rankin score 1.5 across groups.
Plotrowski 1990 | US, single center Retrospective 1978-1988 | Surgery | 129/140 CEA had stroke as indication Group A: 82/129 had CEA within 6 weeks Group B: 47/129 had CEA after 6 weeks | Group A: 1/82 (1.2%) stroke or death; 1/82 (1.2%) death Group B: 2/47 (4.3%) stroke or death; 1/47 (2.1%) death | FAIR. Later surgery group evaluated for CEA after recovery from stroke established. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. Groups appear comparable clinically and demographically. No statistical analysis of confounders. | patients had CEA according to protocol, after neurologic stability and soon (generally 24-48 hrs) after angiography.
Dosick 1985 | US, 2 centers Retrospective 1980-1983 | Surgery | Group A: Of 171 patients with mild-moderate neurologic deficits > 24 hours, 110 had negative CT scans and positive angiography and had CEA within 14 days Group B: Of 74 patients with mild-moderate neurologic deficits > 24 hours and positive CT scan, 51 had positive angiography and had CEA at 4-6 weeks | Group A: 1/110 (0.9%) stroke or death; 0/110 (0%) death Group B: 1/51 (2.0%) stroke or death; 0/51 (0%) death | POOR. No true comparator group. Inadequate data to compare clinical and demographic features between early and late groups. Complications not specified or defined. No description of ascertainment technique. Ascertainment not independent. No statistical analysis of confounders. | RIND defined as symptoms lasting >24 hours, thought ischemic, with normal CT scan. Other comparison groups reported were patients with old stroke (n=56), TIA (n=113; timing of CEA not clear), and asymptomatic (n=41).
Eckstein 1998 | US, single center Retrospective 1980-1995 | Surgery, neurology, radiology, anesthesiology | Group A: 56/2013 patients with TIA/minor stroke had CEA within 4 weeks Group B: No comparison group | Group A: 2/56 (3.6%) stroke or death; 0/56 (0%) death Group B: No comparison group | POOR. No comparator group. Unclear how patients selected for early CEA. No data to compare clinical and demographic features between early and late groups. No statistical analysis of confounders. Ascertainment not independent. Inadequate description of ascertainment technique. | Outcomes in patients with later (after 4 weeks) CEA not reported.
Giordano 1985 | US, single center Retrospective 1973-1983 | Surgery | 49/352 consecutive CEA had stroke as indication Group A: 31/49 had CEA within 6 weeks Group B: 18/49 had CEA after 6 weeks | Group A: 5/31 (16.1%) stroke or death; 1/31 (3.2%) death Group B: 0/18 (0%) stroke or death; 0/18 (0%) death | POOR. Unclear how patients selected for early surgery. Inadequate description of population. No description of ascertainment technique. No statistical analysis of confounders. Not clear if ascertainment independent. Not clear if followup was 30 days. | For patients with indication other than stroke, 2.3% stroke rate and 0.7% mortality rate. Significant difference in rates of post-op complications when comparing <5 wks with >5 wks CEA.
Paty 1997 | US, single center Retrospective 1987-1997 | Surgery | 215/1922 CEA were in patients with stroke <6 months prior Group A: 149/215 had CEA within 1 month Group B: 66/215 had CEA between 1 and 6 months | Group A: 3/149 (2.0%) stroke or death; deaths not reported according to timing of CEA Group B: 0/66 (0%) stroke or death; deaths not reported according to timing of CEA | POOR. Unclear how patients selected for early surgery. Unable to compare demographic/clinical factors with group with later surgery. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. Unclear duration of followup. No statistical analysis of confounders. | No characterization of stroke severity.
Ricotta 1985 | US, single center Retrospective 1978-1984 | Surgery | 181 CEA in patients who had preoperative CT Group A: 27/181 symptomatic patients had CEA within 2 wks Group B: 71/181had positive CT and CEA after 2 weeks | Group A: 5/27 (18.5%) stroke or death; 1/27 (3.7%) death Group B: 2/71 (2.8%) stroke or death; 0/71 (0%) death | POOR. No true comparator group. Not clear how patients selected for pre-op CT or for early CEA. Inadequate description of pt population. Complications not specified or defined. No description of ascertainment technique. Ascertainment not independent. No statistical analysis of confounders. Unclear duration of followup. | Tabulated results exclude 83 patients with later CEA and negative CT scans because complications for symptomatic patients not reported separately. 4/5 strokes in early CEA occurred in patients with positive CT scans.
Rosenthal 1988 | US, single center Retrospective 1977-1987 | Surgery, neurology, radiology | 151/253 CEA in patient with RIND or stroke Group A: 60/151 had CEA within 3 weeks Group B: 91/151 had CEA after 3 weeks | Group A: 2/60 (3.3%) stroke; deaths not clear Group B: 4/91 (4.4%) stroke; deaths not clear | POOR. Not clear how patients selected for surgery or early surgery. Not clear if ascertainment independent. Unable to compare major clinical and demographic factors in early and later CEA groups. Complications not specified or defined. No description of ascertainment technique. No statistical analysis of confounders. | 2 peri-operative deaths; not clear how many in early CEA or later CEA.
Whittemore 1987 | US, single center Retrospective 1979-1986 | Surgery | 651 CEA performed Group A: 44/651 had CEA within 30 days of small, stable stroke with >75% ipsilateral stenosis Group B: 607/651 had CEA after 30 days (severity of symptoms unclear) | Group A: 1/44 (2.3%) stroke or death; 1/44 (2.3%) death Group B: 12/607 (2.0%) stroke or death; 7/607 (1.2%) death | POOR. Unable to compare major clinical and demographic factors in early CEA and later CEA groups. Complications not specified or defined. No description of ascertainment technique. Not clear if ascertainment independent. No statistical analysis of confounders. | Includes data from Whittemore 1984.

RCT: randomized controlled trial; CEA: carotid endarterectomy; TIA: transient ischemic attack; MRI: magnetic resonance imaging; TCD: transcranial Doppler; VA: Veterans Affairs