# Bibliography

Aaron JO, Hesselink JR, Oot R, et al Complications of intravenous DSA performed for carotid artery disease: a prospective study Radiology 1984 153(3):675 8 6387790
AbuRahma AF, Khan JH, Robinson PA, et al Prospective randomized trial of carotid endarterectomy with primary closure and patch angioplasty with saphenous vein, jugular vein, and polytetrafluoroethylene: perioperative (30-day) results J Vasc Surg 1996 24(6):998 1006 discussion 1006 7 8976353
AbuRahma AF, Lim RY Management of vagus nerve injury after carotid endarterectomy Surgery 1996 119(3):245 7 8619177
AbuRahma AF, Pollack JA, Robinson PA, et al The reliability of color duplex ultrasound in diagnosing total carotid artery occlusion Am J Surg 1997 174(2):185 7 9293841
AbuRahma AF, Richmond BK, Robinson PA, et al Effect of contralateral severe stenosis or carotid occlusion on duplex criteria of ipsilateral stenoses: comparative study of various duplex parameters J Vasc Surg 1995 22(6):751 61 discussion 761 2 8523610
AbuRahma AF, Robinson P, Holt SM, et al Perioperative and late stroke rates of carotid endarterectomy contralateral to carotid artery occlusion : results from a randomized trial Stroke 2000 31(7):1566 71 10884455
AbuRahma AF, Robinson PA, Killmer SM, et al A critical analysis of cerebral computed tomography scanning before elective carotid endarterectomy and its correlation to carotid stenosis Surgery 1996 119(3):248 51 8619178
Aburahma AF, Robinson PA, Short YS Management options for post carotid endarterectomy stroke J Cardiovasc Surg 1996 37(4):331 6 8698774
AbuRahma AF, Robinson PA, Strickler DL, et al Proposed new duplex classification for threshold stenoses used in various symptomatic and asymptomatic carotid endarterectomy trials Ann Vasc Surg 1998 12(4):349 58 9676932
Acar J, Cormier B, Grimberg D, et al Diagnosis of left atrial thrombi in mitral stenosis--usefulness of ultrasound techniques compared with other methods Eur Heart J 1991 12(Suppl B):70 6
Acarturk E, Ozeren A, Sarica Y Detection of aortic plaques by transesophageal echocardiography in patients with ischemic stroke Acta Neurol Scand 1995 92(2):170 2 7484068
Acarturk E, Usal A, Demir M, et al Thromboembolism risk in patients with mitral stenosis Jpn Heart J 1997 38(5):669 75 9462416
Ackroyd N, Lane R, Dart L, et al. Colour-coded carotid Doppler imaging: an angio-graphic comparison of 324 bifurcations. Aust N Z J Surg. 1984;54:509-17. [pmid: 6393935].
Adams GF, Merrett JD, Hutchinson WM, et al Cerebral embolism and mitral stenosis: survival with and without anticoagulants J Neurol Neurosurg Psychiatry 1974 37(4):378 83 4838909
Adams HP, Jr. Use of anticoagulants or antiplatelet aggregating drugs in the prevention of ischemic stroke. Adv Intern Med. 1995;40:503-31. [pmid: 7747656].
Adams HP, Jr., Bendixen BH, Kappelle LJ, et al Classification of subtype of acute ischemic stroke. Definitions for use in a multicenter clinical trial. TOAST. Trial of Org 10172 in Acute Stroke Treatment Stroke 1993 24(1):35 41 7678184
Adler Y, Koren A, Fink N, et al Association between mitral annulus calcification and carotid atherosclerotic disease Stroke 1998 29(9):1833 7 9731604
Agmon Y, Khandheria BK, Meissner I, et al Frequency of atrial septal aneurysms in patients with cerebral ischemic events Circulation 1999 99(15):1942 4 10208995
Ahari A, Bergqvist D, Troeng T, et al Diabetes mellitus as a risk factor for early outcome after carotid endarterectomy--a population-based study Eur J Vasc Endovasc Surg 1999 18(2):122 6 10428751
Aita JA Cerebrovascular disease and cardiac lesions Nebr Med J 1971 56(12):470 2
Akbari CM, Pomposelli FB, Jr., Gibbons GW, et al Diabetes mellitus: a risk factor for carotid endarterectomy? J Vasc Surg 1997 25(6):1070 5 discussion 1075 6 9201168
Alam M, Rosman HS, Grullon C Transesophageal echocardiography in evaluation of atrial masses Angiology 1995 46(2):123 8 7702196
Albers GW Antithrombotic agents in cerebral ischemia Am J Cardiol 1995 75(6):34B 38B 7801861
Albers GW, Comess KA, DeRook FA, et al Transesophageal echocardiographic findings in stroke subtypes Stroke 1994 25(1):23 8 8266377
Aldoori MI, Baird RN Local neurological complication during carotid endarterectomy J Cardiovasc Surg 1988 29(4):432 6 3417743
Alexandrov AV, Black SE, Ehrlich LE, et al Predictors of hemorrhagic transformation occurring spontaneously and on anticoagulants in patients with acute ischemic stroke Stroke 1997 28(6):1198 202 9183351
Alexandrov AV, Vital D, Brodie DS, et al Grading carotid stenosis with ultrasound. An interlaboratory comparison Stroke 1997 28(6):1208 10 9183353
Alexandrova NA, Gibson WC, Norris JW, et al Carotid artery stenosis in peripheral vascular disease J Vasc Surg 1996 23(4):645 9 8627901
Allcutt DA, Chakraborty M, Sengupta RP Neurosurgical experience with carotid endarterectomy: a 12-year study Br J Neurosurg 1991 5(3):257 64 1892568
Alter M, Friday G, Lai SM, et al Hypertension and risk of stroke recurrence Stroke 1994 25(8):1605 10 8042211
Alter M, Lai SM, Friday G, et al Stroke recurrence in diabetics. Does control of blood glucose reduce risk? Stroke 1997 28(6):1153 7 9183342
Alter M, Lai SM, Friday GH, et al Aspirin, warfarin, and recurrent stroke [letter] Lancet 1991 337(8753):
Alter M, Sobel E, McCoy RL, et al Stroke in the Lehigh Valley: risk factors for recurrent stroke Neurology 1987 37(3):503 7 3822148
Amarenco P, Cohen A, Tzourio C, et al Atherosclerotic disease of the aortic arch and the risk of ischemic stroke N Engl J Med 1994 331(22):1474 9 7969297
Amarenco P, Duyckaerts C, Tzourio C, et al The prevalence of ulcerated plaques in the aortic arch in patients with stroke N Engl J Med 1992 326(4):221 5 1727976
2001 Heart and Stroke Statistical Update. 2001. http://www.americanheart.org/statistics/stroke.html. [pmcid: 369639].
Economic cost of cardiovascular diseases. 2001 Heart and Stroke Statistical Update. 2001. http://www.americanheart.org/statistics/economic.html. [pmcid: 369639].
Risk factors. 2001 Heart and Stroke Statistical Update 2001; http://www.americanheart.org/statistics/riskfactors.html.
Amy JR Carotid endarterectomies at Walter Reed Army Medical Center: morbidity and mortality, 1982-1983 Mil Med 1986 151(11):609 11 3097583
Anand SS, Yusuf S Oral anticoagulant therapy in patients with coronary artery disease: a meta-analysis [published erratum appears in JAMA 2000 Jul 5;284(1):45] JAMA 1999 282(21):2058 67 10591389
Anderson C, Saloner D, Lee R, et al. Assessment of carotid stenosis by MR angiography: comparison with x-ray angiography and color-coded Doppler ultrasound. AJNR Am J Neuroradiol. 1992;13:989-1003. [pmid: 1590203].
Anderson CM, Lee RE, Levin DL, et al Measurement of internal carotid artery stenosis from source MR angiograms Radiology 1994 193(1):219 26 8090894
Anderson DC Brain cardioembolism. Issues in diagnosis and management Postgrad Med 1987 82(3):48 50, 52-4, 56-7 3628126
Anderson DC Cardioembolic stroke. Primary and secondary prevention Postgrad Med 1991 90(8):67 72, 77 1749740
Anderson NE, Bonita R, Broad JB Early management and outcome of acute stroke in Auckland Aust N Z J Med 1997 27(5):561 7 9404588
Anonymous Anticoagulants and cerebral infarction Lancet 1966 1(7431):
Anonymous Anticoagulants in mitral valve disease BMJ 1972 1(801):
Anonymous Drug therapy review--coumarin and indandione derivatives Am J Hosp Pharm 1973 30(8):705 13 4579074
Anonymous Cerebral vascular disease, venous and arterial thrombosis Am J Cardiol 1975 36(5):611 3 1190084
Anonymous Cerebral embolism and anticoagulation [letter] Neurology 1983 33(8):1103 6 6683817
Anonymous Immediate anticoagulation of embolic stroke: a randomized trialCerebral Embolism Study Group.Stroke 1983 14(5):668 76 6362091
Anonymous. Variation in the use of angiography and carotid endarterectomy by neurologists in the UK-TIA Aspirin Trial. BMJ. 1983;286:514-517. [pmid: 6402129]. [pmcid: 1546595].
Anonymous Controversies in the medical management of stroke West J Med 1985 142(1):74 8 3976222 1305930
Anonymous Cardiogenic brain embolism. Cerebral Embolism Task Force Arch Neurol 1986 43(1):71 84 3510609
Anonymous Cardiogenic brain embolism. The second report of the Cerebral Embolism Task Force [published erratum appears in Arch Neurol 1989 Oct;46(10):1079] Arch Neurol 1989 46(7):727 43 2662950
AnonymousEuropean Stroke Prevention Study. ESPS Group.Stroke 1990 21(8):1122 30 2202093
Anonymous Left ventricular thrombosis and stroke following myocardial infarction Lancet 1990 335(8692):759 60 1969513
Anonymous Beneficial effect of carotid endarterectomy in symptomatic patients with high-grade carotid stenosis. North American Symptomatic Carotid Endarterectomy Trial Collaborators N Engl J Med 1991 325(7):445 53 1852179
Anonymous MRC European Carotid Surgery Trial: interim results for symptomatic patients with severe (70-99%) or with mild (0-29%) carotid stenosisEuropean Carotid Surgery Trialists' Collaborative Group.Lancet 1991 337(8752):1235 43 1674060
Anonymous North American Symptomatic Carotid Endarterectomy Trial. Methods, patient characteristics, and progress Stroke 1991 22(6):711 20 2057968
Anonymous Ancrod for the treatment of acute ischemic brain infarction Stroke 1994 25(9):1755 59 8073455
Anonymous Collaborative overview of randomised trials of antiplatelet therapy--I: Prevention of death, myocardial infarction, and stroke by prolonged antiplatelet therapy in various categories of patients. Antiplatelet Trialists' Collaboration [published erratum appears in BMJ 1994 Jun 11;308(6943):1540] BMJ 1994 308(6921):81 106 8298418
Anonymous How should clinicians choose treatment for preventing stroke when therapeutic trials are not available to guide the situation? Eur Neurol 1995 35(5):293 305 discussion 305 8 8542919
Anonymous Recurrent cerebrovascular events in patients with patent foramen ovale, atrial septal aneurysm, or both and cryptogenic stroke or transient ischemic attack. French Study Group on Patent Foramen Ovale and Atrial Septal Aneurysm Am Heart J 1995 130(5):1083 8 7484740
Anonymous Atherosclerotic disease of the aortic arch as a risk factor for recurrent ischemic strokeThe French Study of Aortic Plaques in Stroke Group.N Engl J Med 1996 334(19):1216 21 8606716
Anonymous Endarterectomy for moderate symptomatic carotid stenosis: interim results from the MRC European Carotid Surgery Trial Lancet 1996 347(9015):1591 3 8667868
Anonymous. Study design of the International Stroke Trial (IST), baseline data, and outcome in 984 randomised patients in the pilot study. J Neurol Neurosurg Psychiatry. 1996;60:371-376. [pmid: 8774398].
Anonymous The International Stroke Trial (IST): a randomised trial of aspirin, subcutaneous heparin, both, or neither among 19435 patients with acute ischaemic strokeInternational Stroke Trial Collaborative Group.Lancet 1997 349(9065):1569 81 9174558
Anonymous Consensus statement of the Royal College of Physicians of Edinburgh Consensus Conference on Medical Management of Stroke, 26-27 May 1998 [letter] Br J Haematol 1998 102(4):1107 8 9734665
Anonymous Low molecular weight heparinoid, ORG 10172 (danaparoid), and outcome after acute ischemic stroke: a randomized controlled trial. The Publications Committee for the Trial of ORG 10172 in Acute Stroke Treatment (TOAST) Investigators JAMA 1998 279(16):1265 72 9565006
Anonymous Randomised trial of endarterectomy for recently symptomatic carotid stenosis: final results of the MRC European Carotid Surgery Trial (ECST) Lancet 1998 351(9113):1379 87 9593407
Anonymous Royal College of Physicians of Edinburgh Consensus Conference on Medical Management of Stroke, 26-27 May 1998 Age Ageing 1998 27(6):665 6 10408657
Anonymous Transesophageal echocardiographic correlates of thromboembolism in high-risk patients with nonvalvular atrial fibrillation. The Stroke Prevention in Atrial Fibrillation Investigators Committee on Echocardiography Ann Intern Med 1998 128(8):639 47 9537937
Anonymous Effects of long-term, moderate-intensity oral anticoagulation in addition to aspirin in unstable angina. The Organization to Assess Strategies for Ischemic Syndromes (OASIS) Investigators J Am Coll Cardiol 2001 37(2):475 84 11216966
Anonymous. Warfarin-Aspirin Recurrent Stroke Study. Internet Stroke Center. 2001; http://www.strokecenter.org/trials/list/trialPage38.htm.
Ansari A, Maron BJ Possible sources of cryptogenic cerebral emboli as revealed by transesophageal echocardiography Tex Heart Inst J 1996 23(2):325379
Anthony T, Johansen K Optimal outcome for "high-risk" carotid endarterectomy Am J Surg 1994 167(5):469 71 8185028
Anzola GP, Magoni M, Ascari E, et al Early prognostic factors in ischemic stroke. The role of protein C and protein S Stroke 1993 24(10):1496 500 8378953
Arboix A, Vericat MC, Pujades R, et al Cardioembolic infarction in the Sagrat Cor-Alianza Hospital of Barcelona Stroke Registry Acta Neurol Scand 1997 96(6):407 12 9449481
Archer SL, James KE, Kvernen LR, et al Role of transesophageal echocardiography in the detection of left atrial thrombus in patients with chronic nonrheumatic atrial fibrillation Am Heart J 1995 130(2):287 95 7631609
Arko FR, Fritcher S, Mettauer M, et al Mobile atheroma of the aortic arch and the risk of carotid artery disease Am J Surg 1999 178(3):206 8 10527440
Aronow WS, Ahn C, Kronzon I, et al Association of plasma renin activity and echocardiographic left ventricular hypertrophy with frequency of new coronary events and new atherothrombotic brain infarction in older persons with systemic hypertension Am J Cardiol 1997 79(11):1543 5 9185653
Aronow WS, Ahn C, Kronzon I, et al Association of left ventricular hypertrophy and chronic atrial fibrillation with the incidence of new thromboembolic stroke in 2,384 older persons Am J Cardiol 1999 84(4):468 9, A9 10468090
Aronow WS, Koenigsberg M, Kronzon I, et al Association of mitral anular calcium with new thromboembolic stroke and cardiac events at 39-month follow-up in elderly patients Am J Cardiol 1990 65(22):1511 2 2353658
Aronow WS, Koenigsberg M, Schwartz KS Usefulness of echocardiographic left ventricular hypertrophy in predicting new coronary events and atherothrombotic brain infarction in patients over 62 years of age Am J Cardiol 1988 61(13):1130 2 2966554
Aschenberg W, Schluter M, Kremer P, et al Transesophageal two-dimensional echocardiography for the detection of left atrial appendage thrombus J Am Coll Cardiol 1986 7(1):163 6 3941205
Auer L, Gallhofer B, Ladurner G, et al Medical versus surgical treatment of patients with cerebrovascular insufficiency. A retrospective comparative study Eur Neurol 1980 19(3):152 162 7389760
Aungst M, Gahatan V, Berkowitz H, et al. Carotid endarterectomy outcome is not affected in patients with a contralateral carotid artery occlusion. Am J Surg. 1998;176:30-33. [pmid: 9683128].
Autore C, Cartoni D, Piccininno M Multiplane transesophageal echocardiography and stroke Am J Cardiol 1998 81(12A):79G 81G 9462611
Ay H, Oliveira-Filho J, Buonanno FS, et al Diffusion-weighted imaging identifies a subset of lacunar infarction associated with embolic source Stroke 1999 30(12):2644 50 10582991
Azar AJ, Koudstaal PJ, Wintzen AR, et al Risk of stroke during long-term anticoagulant therapy in patients after myocardial infarction Ann Neurol 1996 39(3):301 7 8602748
Bachmeyer C, Toulon P, Dhote R, et al Ischemic stroke and activated protein C resistance [letter] JAMA 1995 274(16):126 6
Back MR, Harward TR, Huber TS, et al Improving the cost-effectiveness of carotid endarterectomy J Vasc Surg 1997 26(3):456 62 discussion 463 4 9308591
Bahemuka M, al-Nozha M, Shamena AR, et al Cerebral infarction and left ventricular mass: a clinical and echocardiographic study Q J Med 1988 67(254):467 72 2977819
Baker DW, Wright RF Management of heart failure. IV. Anticoagulation for patients with heart failure due to left ventricular systolic dysfunction JAMA 1994 272(20):1614 8 7966873
Baker R. An evaluation of anticoagulant therapy in the treatment of cerebrovascular disease. Neurology. 1961;11:132-138.
Baker R, Broward J, Fang H, et al. Anticoagulant therapy in cerebral infarction. Report on a co-operative study. Neurology. 1962;12:823-829. [pmid: 13969171].
Baker R, Schwartz W, Rose M. Transient ischemic strokes. Neurology. 1964;16:841-847.
Baker RN, Broward JA, Fang HC, et al. Anticoagulant therapy of cerebral infarction: report of a national cooperative study. Res Publ Assoc Res Nerv Ment Dis. 1966;41:287-302. [pmid: 4163327].
Ball JB, Lukin RR, Tomsick TA, et al. Complications of intravenous digital subtraction angiography. Arch Neurol. 1985;42:969-972. [pmid: 3899062].
Ballard JL, Deiparine MK, Bergan JJ, et al Cost-effective evaluation and treatment for carotid disease Arch Surg 1997 132(3):268 71 9125026
Ballard JL, Fleig K, De Lange M, et al The diagnostic accuracy of duplex ultrasonography for evaluating carotid bifurcation Am J Surg 1994 168(2):123 6 discussion8053509
Ballotta E, Da Giau G, Abbruzzese E, et al Carotid endarterectomy without angiography: can clinical evaluation and duplex ultrasonographic scanning alone replace traditional arteriography for carotid surgery workup? A prospective study Surgery 1999 126(1):20 7 10418588
Ballotta E, Da Giau G, Renon L, et al Cranial and cervical nerve injuries after carotid endarterectomy: a prospective study Surgery 1999 125(1):85 91 9889802
Bamford J, Sandercock P, Dennis M, et al Classification and natural history of clinically identifiable subtypes of cerebral infarction Lancet 1991 337(8756):1521 6 1675378
Bamford J, Sandercock P, Jones L, et al The natural history of lacunar infarction: the Oxfordshire Community Stroke Project Stroke 1987 18(3):545 51 3590244
Bandyk D, Levine A, Pohl L, et al. Classification of carotid bifurcation disease using quantitative Doppler spectrum analysis. Arch Surg. 1985;120:306-14. [pmid: 3882079].
Bansal RC, Heywood JT, Applegate PM, et al Detection of left atrial thrombi by two-dimensional echocardiography and surgical correlation in 148 patients with mitral valve disease Am J Cardiol 1989 64(3):243 6 2741835
Barasch E, Kaushik V, Ahn C Aortic sinotubular atherosclerotic debris associated with cerebral embolic events can be identified by transthoracic echocardiography Cardiology 1998 90(4):253 7 10085485
Barinagarrementeria F, Cantu-Brito C, De La Pena A, et al Prothrombotic states in young people with idiopathic stroke. A prospective study Stroke 1994 25(2):287 90 8303733
Barker WF, Stern WE, Krayenbuhl H, et al Carotid endarterectomy complicated by carotid-cavernous sinus fistula Ann Surg 1968 167(4):568 72 5644730 1387248
Barletta GA, Gagliardi R, Benvenuti L, et al Cerebral ischemic attacks as a complication of aortic and mitral valve prolapse Stroke 1985 16(2):219 23 3975959
Barnes R, Garrett W, Laymaker E, et al. Doppler ultrasound and supraorbital photoplethysmography for noninvasive screening of carotid occlusive disease. Am J Surg. 1977;134:183-6. [pmid: 889026].
Barnes R, Rittgers S, Putney W. Real-time Doppler spectrum analysis: predictive value in defining operable carotid artery disease. Arch Surg. 1982;117:52-7. [pmid: 7055425].
Barnett HJ Prevention of stroke Int Anesthesiol Clin 1984 22(3):11 29 6384054
Barnett HJ, Boughner DR, Taylor DW, et al Further evidence relating mitral-valve prolapse to cerebral ischemic events N Engl J Med 1980 302(3):139 44
Barnett HJ, Eliasziw M, Meldrum HE Drugs and surgery in the prevention of ischemic stroke N Engl J Med 1995 332(4):238 48 7808491
Barnett HJ, Eliasziw M, Meldrum HE Evidence based cardiology: Prevention of ischaemic stroke BMJ 1999 318(7197):1539 43 10356014 1115906
Barnett HJ, Gunton RW, Eliasziw M, et al Causes and severity of ischemic stroke in patients with internal carotid artery stenosis JAMA 2000 283(11):1429 36 10732932
Barnett HJ, Taylor DW, Eliasziw M, et al Benefit of carotid endarterectomy in patients with symptomatic moderate or severe stenosis. North American Symptomatic Carotid Endarterectomy Trial Collaborators N Engl J Med 1998 339(20):1415 25 9811916
Barnett HJ The contribution of multicenter trials to stroke prevention and treatment Arch Neurol 1990 47(4):441 4 2181977
Barry R, Ne C. Comparison of duplex Doppler scanning with contrast angiography in carotid artery disease. S Afr Med J. 1987;72:851-2. [pmid: 3424031].
Bassand JP, Bihr E, Becque O, et al Cerebral emboli of cardiac origin. A report of 71 cases J Neuroradiol 1979 6(2):117 26 547045
Baum S, Stein G, Kuroda K. Complications of 'no arteriography'. Radiology. 1966;86:83-5.
Beal MF, Williams RS, Richardson EP, Jr., et al Cholesterol embolism as a cause of transient ischemic attacks and cerebral infarction Neurology 1981 31(7):860 5 7195508
Beattie JR, Cohen DJ, Manning WJ, et al Role of routine transthoracic echocardiography in evaluation and management of stroke J Intern Med 1998 243(4):281 91 9627142
Beebe HG, Clagett GP, DeWeese JA, et al Assessing risk associated with carotid endarterectomy. A statement for health professionals by an Ad Hoc Committee on Carotid Surgery Standards of the Stroke Council, American Heart Association Circulation 1989 79(2):472 3 2914359
Belkin RN, Hurwitz BJ, Kisslo J Atrial septal aneurysm: association with cerebrovascular and peripheral embolic events Stroke 1987 18(5):856 62 3629643
Belkin RN, Kisslo J Atrial septal aneurysm: recognition and clinical relevance Am Heart J 1990 120(4):948 57 2220548
Bendick P, Jackson V, Becker G. Comparison of ultrasound scanning/Doppler with digital subtraction angiography in evaluating carotid artery disease. Med Instrum. 1983;17:220-2. [pmid: 6348498].
Bendixen BH, Adams HP, Leira EC, et al. Responses to treatment with a low molecular weight heparinoid or placebo among persons with acute ischemic stroke secondary to large artery artherosclerosis. Neurology. 1998;50:A34-5.
Benjamin EJ, D'Agostino RB, Belanger AJ, et al Left atrial size and the risk of stroke and death. The Framingham Heart Study Circulation 1995 92(4):835 41 7641364
Benjamin EJ, Plehn JF, D'Agostino RB, et al Mitral annular calcification and the risk of stroke in an elderly cohort N Engl J Med 1992 327(6):374 9 1625711
Berge E, Sandercock P Anticoagulants versus antiplatelet agents for acute ischemic stroke (Cochrane Review) In The Cochrane LibraryIssue 3,2001 Oxford, England: Update Software
Bergeron GA, Shah PM Echocardiography unwarranted in patients with cerebral ischemic events [letter] N Engl J Med 1981 304(8):48 9
Bernstein EF, Humber PB, Collins GM, et al Life expectancy and late stroke following carotid endarterectomy Ann Surg 1983 198(1):80 6 6602597 1352937
Berwaerts J, Dijkhuizen RS, Robb OJ, et al Prediction of functional outcome and in-hospital mortality after admission with oral anticoagulant-related intracerebral hemorrhage Stroke 2000 31(11):2558 62 11062275
Beton DC, Brear SG, Edwards JD, et al Mitral valve prolapse: an assessment of clinical features, associated conditions and prognosis Q J Med 1983 52(206):150 64 6611838
Bevan H, Sharma K, Bradley W Stroke in young adults Stroke 1990 21(3):382 6 2309261
Biller J, Bruno A, Adams HP, Jr., et al A randomized trial of aspirin or heparin in hospitalized patients with recent transient ischemic attacks. A pilot study Stroke 1989 20(4):441 7 2648650
Biller J, Feinberg WM, Castaldo JE, et al Guidelines for carotid endarterectomy: a statement for healthcare professionals from a special writing group of the Stroke Council, American Heart Association Stroke 1998 29(2):554 62 9480580
Biller J, Johnson MR, Adams HP, Jr., et al Echocardiographic evaluation of young adults with nonhemorrhagic cerebral infarction Stroke 1986 17(4):608 12 3738939
Biller J, Martin GJ Cardiogenic cerebral embolism Compr Ther 1984 10(9):25 31
Black IW Left atrial spontaneous echo contrast and embolism [letter; comment] Stroke 1994 25(6):1295 6 8202999
Black IW, Hopkins A, Lee CL, et al The clinical role of transoesophageal echocardiography Aust N Z J Med 1990 20(6):759 64 2291724
Black IW, Hopkins A, Lee L, et al. Left atrial spontaneous echo contrast: a clinical and echocardiographic analysis. J Am Coll Cardiol. 1991;18:398-404. [pmid: 1856407].
Blakeley DD, Oddone EZ, Hasselblad V, et al Noninvasive carotid artery testing. A meta-analytic review Ann Intern Med 1995 122(5):360 7 7847648
Bland JE, Chapman RD, Wylie EJ Neurological complications of carotid artery surgery Ann Surg 1970 171(4):459 64 5436116 1396720
Bloom JM. Low-molecular-weight heparin for the treatment of acute ischemic stroke. N Engl J Med. 1996;334.
Bluth EI Evaluation and characterization of carotid plaque Semin Ultrasound CT MR 1997 18(1):57 65 9143066
Bogousslavsky J, Garazi S, Jeanrenaud X, et al Stroke recurrence in patients with patent foramen ovale: the Lausanne StudyLausanne Stroke with Paradoxal Embolism Study Group.Neurology 1996 46(5):1301 5 8628471
Bogousslavsky J, Hachinski VC, Boughner DR, et al. Cardiac and arterial lesions in carotid transient ischemic attacks. Arch Neurol. 1986;43:223-228. [pmid: 3947270].
Bogousslavsky J, Regli F Anticoagulant-induced intracerebral bleeding in brain ischemia. Evaluation in 200 patients with TIAs, emboli from the heart, and progressing stroke Acta Neurol Scand 1985 71(6):464 71 4024857
Bogousslavsky J, Regli F Ischemic stroke in adults younger than 30 years of age. Cause and prognosis Arch Neurol 1987 44(5):479 82 3579657
Bogousslavsky J, Van Melle G, Regli F The Lausanne Stroke Registry: analysis of 1,000 consecutive patients with first stroke Stroke 1988 19(9):1083 92 3413804
Bogousslavsky J Anticoagulation and bleeding into embolic infarcts [letter] Arch Neurol 1985 42(11):1033 5 4051826
Bommer WJ, Shah PM, Allen H, et al The safety of contrast echocardiography: report of the Committee on Contrast Echocardiography for the American Society of Echocardiography J Am Coll Cardiol 1984 3(1):6 13 6690558
Bone G, Ladurner G, Karas I, et al. Evaluation of the carotid bifurcation by duplex ultrasound, intravenous and intra-arterial digital subtraction angiography. Eur Neurol. 1988;28:73-6. [pmid: 3286270].
Boon A, Lodder J, Cheriex E, et al Risk of stroke in a cohort of 815 patients with calcification of the aortic valve with or without stenosis Stroke 1996 27(5):847 51 8623104
Boon A, Lodder J, Cheriex E, et al Mitral annulus calcification is not an independent risk factor for stroke: a cohort study of 657 patients J Neurol 1997 244(9):535 41 9352449
Boon A, Lodder J, Cheriex E, et al Risk of stroke in a cohort of 815 patients with calcification of the aortic valve with or without stenosis Stroke 1996 27(5):847 51 8623104
Bornstein NM, Aronovich BD, Karepov VG, et al The Tel Aviv Stroke Registry. 3600 consecutive patients Stroke 1996 27(10):1770 3 8841327
Bouchard JP, Fabia J, Simard D, et al Carotid endarterectomy: survival rates of 227 patients Can Med Assoc J 1975 113(10):949 51 1192311
Boughner DR, Barnett HJ The enigma of the risk of stroke in mitral valve prolapse Stroke 1985 16(2):175 7 3883579
Bousser MG Aspirin or heparin immediately after a stroke? Lancet 1997 349(9065):1564 5 9174553
Bradshaw P, Brennan S Trial of long-term anticoagulant therapy in the treatment of small stroke associated with a normal carotid arteriogram J Neurol Neurosurg Psychiatry 1975 38(7):642 7 1159434
Bradshaw P, Casey E Outcome of medically treated stroke associated with stenosis or occlusion of the internal carotid artery BMJ 1967 1(534):201 5 6018335 1840507
Brant-Zawadzki M, Gould R, Norman D, et al. Digital subtraction cerebral angiography by intraarterial injection: Comparison with convetnional angiography. AJNR Am J Neuroradiol. 1982;3:592-599.
Brickner ME Cardioembolic stroke Am J Med 1996 100(4):465 74 8610736
Bridges ND, Hellenbrand W, Latson L, et al Transcatheter closure of patent foramen ovale after presumed paradoxical embolism Circulation 1992 86(6):1902 8 1451261
Brinker RA, Skucas J Routine cerebral angiography by the femoral catheter approach Am J Roentol Radium Ther Nucl Med 1972 115(1):27 34
Brinkman SD, Braun P, Ganji S, et al Neuropsychological performance one week after carotid endarterectomy reflects intra-operative ischemia Stroke 1984 15(3):497 503 6729879
Broderick JP, Phillips SJ, O'Fallon WM, et al Relationship of cardiac disease to stroke occurrence, recurrence, and mortality Stroke 1992 23(9):1250 6 1519279
Brook RH, Park RE, Chassin MR, et al Carotid endarterectomy for elderly patients: predicting complications Ann Intern Med 1990 113(10):747 53 2240877
Brott TG, Labutta RJ, Kempczinski RF Changing patterns in the practice of carotid endarterectomy in a large metropolitan area JAMA 1986 255(19):2609 12 3701975
Brown RD, Whisnant JP, Sicks JD, et al Stroke incidence, prevalence, and survival: secular trends in Rochester, Minnesota, through 1989 Stroke 1996 27(3):373 80 8610298
Browse NL, Ross-Russell R Carotid endarterectomy and the Javid shunt: the early results of 215 consecutive operations for transient ischaemic attacks Br J Surg 1984 71(1):53 7 6689972
Bruno A Clinical features of ischemic stroke in Hispanics and non-Hispanic whites in New Mexico: a study of 341 consecutive patients at two hospitals Ethn Dis 1994 4(1):77 81 7742736
Brust JC Transient ischemic attacks: natural history and anticoagulation Neurology 1977 27(8):701 7 329156
Buckler P, Douglas AS Antithrombotic treatment BMJ 1983 287(6386):196 8 6191822 1548618
Bulkley BH, Hutchins GM Atrial myxomas: a fifty year review Am Heart J 1979 97(5):639 43 433739
Buren A, Ygge J Treatment program and comparison between anticoagulants and platelet aggregation inhibitors after transient ischemic attack Stroke 1981 12(5):578 80 7303042
Burger AJ, Sherman HB, Charlamb MJ Low incidence of embolic strokes with atrial septal aneurysms: A prospective, long-term study Am Heart J 2000 139(1 Pt 1):149 52 10618576
Burn J, Dennis M, Bamford J, et al Long-term risk of recurrent stroke after a first-ever stroke. The Oxfordshire Community Stroke Project [published erratum appears in Stroke 1994 Sep;25(9):1887] Stroke 1994 25(2):333 7 8303740
Burns RJ, Willoughby JO South Australian carotid endarterectomy study Med J Aust 1991 154(10):650 3 2034143
Cabanes L, Mas JL, Cohen A, et al Atrial septal aneurysm and patent foramen ovale as risk factors for cryptogenic stroke in patients less than 55 years of age. A study using transesophageal echocardiography Stroke 1993 24(12):1865 73 8248969
Cabell CH, Pond KK, Peterson GE, et al The risk of stroke and death in patients with aortic and mitral valve endocarditis Am Heart J 2001 142(1):75 80 11431660
Cabin HS, Roberts WC Left ventricular aneurysm, intraaneurysmal thrombus and systemic embolus in coronary heart disease Chest 1980 77(5):586 90 7363674
Caes F, Vierendeels T, Janssens-Willem E, et al. Comparison of ausculation, continuous wave Doppler imaging, intravenous digital subtraction angiography and conventional angiography in diagnosis of carotid artery disease. Angiology. 1987;38:799-806. [pmid: 3318569].
Caes F, Vierendeels T, Janssens-Willem E, et al Comparison of auscultation, continuous wave Doppler imaging, intravenous digital subtraction angiography and conventional angiography in diagnosis of carotid artery disease Angiology 1987 38(11):799 806 3318569
Calandre L, Molina JA Short-term outcome of medically treated patients with transient ischemic attacks, reversible ischemic neurologic deficits and strokes with minimum residuum Eur Neurol 1985 24(4):281 5 2408892
Camerlingo M, Casto L, Censori B, et al Immediate anticoagulation with heparin for first-ever ischemic stroke in the carotid artery territories observed within 5 hours of onset Arch Neurol 1994 51(5):462 7 8179495
Camerlingo M, Finazzi G, Casto L, et al Inherited protein C deficiency and nonhemorrhagic arterial stroke in young adults Neurology 1991 41(9):1371 3 1891083
Cao P, Giordano G, De Rango P, et al A randomized study on eversion versus standard carotid endarterectomy: study design and preliminary results: the Everest Trial J Vasc Surg 1998 27(4):595 605 9576071
Caplan LR, Hier DB, D'Cruz I Cerebral embolism in the Michael Reese Stroke Registry Stroke 1983 14(4):530 6 6658927
Carmichael J. Carotid surgery in the community hospital. Arch Surg. 1980;115:937-939. [pmid: 7396701].
Carolei A, Marini C, Nencini P, et al Prevalence and outcome of symptomatic carotid lesions in young adultsNational Research Council Study Group.BMJ 1995 310(6991):1363 6 7787538
Carriero A, Ucchino S, Magarelli N, et al Carotid bifurcation stenosis: a comparative study between MR angiography and duplex scanning with respect to digital subtraction angiography J Neuroradiol 1995 22(2):103 11 7629567
Cartier R, Cartier P, Fontaine A Carotid endarterectomy without angiography. The reliability of Doppler ultrasonography and duplex scanning in preoperative assessment Can J Surg 1993 36(5):411 6 8106136
Castaldo J, Nicholas G, Gee W, et al. Duplex ultrasound and ocular pneumoplethysmography concordance in detecting severe carotid stenosis. Arch Neurol. 1989;46:518-22. [pmid: 2653291].
Cebul RD, Paulus RA The failure of intravenous digital subtraction angiography in replacing carotid arteriography Ann Intern Med 1986 104(4):572 4 3082270
Cebul RD, Snow RJ, Pine R, et al Indications, outcomes, and provider volumes for carotid endarterectomy JAMA 1998 279(16):1282 7 9565009
Cebul RD, Whisnant JP Carotid endarterectomy Ann Intern Med 1989 111(8):660 70 2679284
Censori B, Colombo F, Valsecchi MG, et al Early transoesophageal echocardiography in cryptogenic and lacunar stroke and transient ischaemic attack J Neurol Neurosurg Psychiatry 1998 64(5):624 7 9598678
The Dartmouth Atlas of Vascular Health. Chicago: AHA Press. 2000. [pmcid: 384376].
Chaikof EL, Campbell BE, Smith RB, 3rd Paradoxical embolism and acute arterial occlusion: rare or unsuspected? J Vasc Surg 1994 20(3):377 84 8084029
Chambers J, Whaley A, Campbell S. Doppler echocardiography in massive left atrial thrombus before and after successful thrombolysis. Int J Cardiol. 1988;18:427-32. [pmid: 3360526].
Chambers JB, de Belder MA, Moore D Echocardiography in stroke and transient ischaemic attack Heart 1997 78(Suppl 1):2 6
Chamorro A, Vila N, Saiz A, et al Early anticoagulation after large cerebral embolic infarction: a safety study Neurology 1995 45(5):861 5 7746397
Chang JB, Stein TA Late stroke in patients after carotid endarterectomy J Surg Res 1997 73(2):155 9 9441810
Chaturvedi S Outcomes after carotid endarterectomy [letter] JAMA 1998 280(14):1228 9 9786367
Chee T, Quek S, Ding Z, et al Clinical utility, safety, acceptability and complications of transesophageal echocardiography (TEE) in 901 patients Singapore Med J 1995 35(5):479 83
Chen QT, Ling R A 1-4 year follow-up study of 306 cases of stroke Stroke 1985 16(2):323 7 3975972
Cheng TO Echocardiography and paradoxical embolism [letter] Ann Intern Med 1981 95(4):
Cheng TO Atrial septal aneurysm is not benign [letter; comment] Int J Cardiol 1999 70(3):
Chesebro JH, Ezekowitz M, Badimon L, et al. Intracardiac thrombi and systemic thromboembolism: detection, incidence, and treatment. Annu Rev Med. 1985;36:579-605. [pmid: 3888065].
Chiang CW, Lo SK, Ko YS, et al Predictors of systemic embolism in patients with mitral stenosis. A prospective study Ann Intern Med 1998 128(11):885 9 9634425
Chiang CW, Lo SK, Kuo CT, et al Noninvasive predictors of systemic embolism in mitral stenosis. An echocardiographic and clinical study of 500 patients Chest 1994 106(2):396 9 7774309
Chiang CW, Pang SC, Lin FC, et al Diagnostic accuracy of two-dimensional echocardiography for detection of left atrial thrombus in patients with mitral stenosis J Ultrasound Med 1987 6(9):525 9 3669148
CAST: randomised placebo-controlled trial of early aspirin use in 20,000 patients with acute ischaemic strokeCAST (Chinese Acute Stroke Trial) Collaborative Group.Lancet 1997 349(9066):1641 9 9186381
Ciaccheri M, Castelli G, Cecchi F, et al Lack of correlation between intracavitary thrombosis detected by cross sectional echocardiography and systemic emboli in patients with dilated cardiomyopathy Br Heart J 1989 62(1):26 9 2757871 1216726
Cina C, Clase C, Haynes R Carotid endarterectomy for symptomatic carotid stenosis (Cochrane Review) In The Cochrane LibraryIssue 3,2000 Oxford, England: Update Software
Cinat M, Lane CT, Pham H, et al Helical CT angiography in the preoperative evaluation of carotid artery stenosis J Vasc Surg 1998 28(2):290 300 9719324
Cioffi G, Pozzoli M, Forni G, et al Systemic thromboembolism in chronic heart failure. A prospective study in 406 patients Eur Heart J 1996 17(9):1381 9 8880024
Clavier I, Hommel M, Besson G, et al Long-term prognosis of symptomatic lacunar infarcts. A hospital-based study Stroke 1994 25(10):2005 9 8091445
Cohen A Interpretation of IST and CAST stroke trials. International Stroke Trial. Chinese Acute Stroke Trial [letter; comment] Lancet 1997 350(9075):discussion 443 4
Collins GJ, Jr., Rich NM, Andersen CA, et al Stroke associated with carotid endarterectomy Am J Surg 1978 135(2):221 5 626297
Come P, Riley M, Bivas N. Roles of echocardiography and arrhythmia monitoring in the evaluation of patients with suspected systemic embolism. Ann Neurol. 1983;13:527-531. [pmid: 6870203].
Comess KA, DeRook FA, Beach KW, et al Transesophageal echocardiography and carotid ultrasound in patients with cerebral ischemia: prevalence of findings and recurrent stroke risk J Am Coll Cardiol 1994 23(7):1598 603 8195520
Connolly JE, Kwaan JH, Stemmer EA Improved results with carotid endarterectomy Ann Surg 1977 186(3):334 42 889376 1396339
Corson JD, Chang BB, Shah DM, et al The influence of anesthetic choice on carotid endarterectomy outcome Arch Surg 1987 122(7):807 12 3592971
Coulshed N, Epstein EJ, McKendrick CS, et al Systemic embolism in mitral valve disease Br Heart J 1970 32(1):26 34 5417843 487269
Counsell CE, Salinas R, Naylor R, et al Routine or selective carotid artery shunting for carotid endarterectomy (and different methods of monitoring in selective shunting) (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
Counsell CE, Salinas R, Naylor R, et al A systematic review of the randomised trials of carotid patch angioplasty in carotid endarterectomy Eur J Vasc Endovasc Surg 1997 13(4):345 54 9133984
Counsell CE, Salinas R, Warlow C, et al Patch angioplasty versus primary closure for carotid endarterectomy (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
Counsell CE, Warlow C, Naylor R Patches of different types for carotid patch angioplasty (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
Cucchiara RF, Sundt TM, Jr., Michenfelder JD Myocardial infarction in carotid endarterectomy patients anesthetized with halothane, enflurane, or isoflurane Anesthesiology 1988 69(5):783 4 3189929
Cujec B, Polasek P, Voll C, et al Transesophageal echocardiography in the detection of potential cardiac source of embolism in stroke patients Stroke 1991 22(6):727 33 2057970
Czlonkowska A Haemorrhagic Transformation (HT) of ischemic lesions in patients treated with heparin or aspirin J Neurol 1997 244(suppl 3):S6 9
Dahl T, Abildgaard U, Sandset PM Long-term anticoagulant therapy in cerebrovascular disease: does bleeding outweigh the benefit? J Intern Med 1995 237(3):323 9 7891054
Dahl T, Sandset PM, Toska K, et al Heparin treatment of acute stroke J Oslo City Hosp 1986 36(12):133 7 3819917
Dalal PM, Shah PM, Aiyar RR, et al Cerebrovascular diseases in west central India. A report on angiographic findings from a prospective study BMJ 1968 3(621):769 74 5676713
Dalen JE, Hirsh J Antithrombotic therapy. Introduction Chest 1992 102(4 Suppl):303S 304S 1395817
D'Alotto C, Pelz DM, Rankin RN A comparison of angiography, intravenous digital subtraction angiography and duplex ultrasound in the diagnosis of carotid artery atherosclerosis J Can Assoc Radiol 1985 36(3):200 8 3900078
D'Alton J, Norris J. Carotid Doppler evaluation in cerebrovascular disease. Can Med Assoc J. 1983;129:1184-9. [pmid: 6640454]. [pmcid: 1875533].
Daniel WG, Erbel R, Kasper W, et al Safety of transesophageal echocardiography. A multicenter survey of 10,419 examinations Circulation 1991 83(3):817 21 1999032
Daniel WG, Mugge A Transesophageal echocardiography N Engl J Med 1995 332(19):1268 79 7708072
Dardik H, Wolodiger F, Silvestri F, et al Clinical experience with everted cervical vein as patch material after carotid endarterectomy J Vasc Surg 1997 25(3):545 53 9081137
Das Gupta A Anticoagulant therapy in cerebrovascular disorders J Indian Med Assoc 1970 54(10):477 8 5503452
DaSilva A, McCollum P, Szymanska T, et al. Prospective study of carotid endarterectomy and contralateral occlusion. Br J Surg. 1996;83:1370-1372. [pmid: 8944454].
Davenport J Shunting during carotid endarterectomy [letter] Arch Neurol 1986 43(12):1222 3 3778255
David M, Stanescu B Occlusion of the central retinal artery as an arteriographic accident Confin Neurol 1969 31(5):327 9 5383226
Davies KN, Humphrey PR Complications of cerebral angiography in patients with symptomatic carotid territory ischaemia screened by carotid ultrasound J Neurol Neurosurg Psychiatry 1993 56(9):967 72 8410036
Dawson DL, Zierler RE, Strandness DE, Jr., et al The role of duplex scanning and arteriography before carotid endarterectomy: a prospective study J Vasc Surg 1993 18(4):673 80 discussion 680 3 8411475
de Belder M, Tourikis L, Leech G, et al. Risk of patent foramen ovale for thromboembolic events in all age groups. Am J Cardiol. 1992;69:1316-1320. [pmid: 1585866].
de Belder MA, Leech G, Camm AJ Transesophageal echocardiography in unsedated outpatients: technique and patient tolerance J Am Soc Echocardiogr 1989 2(6):375 9 2627439
de Belder MA, Lovat LB, Tourikis L, et al Limitations of transoesophageal echocardiography in patients with focal cerebral ischaemic events Br Heart J 1992 67(4):297 303 1389703 1024836
de Bono DP, Warlow CP Mitral-annulus calcification and cerebral or retinal ischaemia Lancet 1979 2(8139):383 5 89448
de Bono DP, Warlow CP Potential sources of emboli in patients with presumed transient cerebral or retinal ischaemia Lancet 1981 1(8216):343 6 6109988
De Castro S, Cartoni D, Fiorelli M, et al Patent foramen ovale and its embolic implications Am J Cardiol 2000 86(4A):51G 52G
De Castro S, Magni G, Beni S, et al Role of transthoracic and transesophageal echocardiography in predicting embolic events in patients with active infective endocarditis involving native cardiac valves Am J Cardiol 1997 80(8):1030 4 9352973
De Leo D, Serraiotto L, Pellegrini C, et al Outcome from carotid endarterectomy. Neuropsychological performances, depressive symptoms and quality of life: 8-month follow-up Int J Psychiatry Med 1987 17(4):317 25 3440706
De Letter JA, Moll FL, Welten RJ, et al Benefits of carotid patching: a prospective randomized study with long-term follow-up Ann Vasc Surg 1994 8(1):54 8 8193000
De Schryver EL Design of ESPRIT: an international randomized trial for secondary prevention after non-disabling cerebral ischaemia of arterial originEuropean/Australian Stroke Prevention in Reversible Ischaemia Trial (ESPRIT) group.Cerebrovasc Dis 2000 10(2):147 50 10686454
DeBono D, Warlow C. Potential source of emboli in patients with presumed transient cerebral or retinal ischemia. Lancet. 1981;1:343-346. [pmid: 6109988].
DeBord JR, Marshall WH, Wyffels PL, et al Carotid endarterectomy in a community hospital surgical practice Am Surg 1991 57(10):627 32 discussion 632 3 1928980
Dehn TC, Taylor GW Cranial and cervical nerve damage associated with carotid endarterectomy Br J Surg 1983 70(6):365 8 6860913
DeMarinis M Post-endarterectomy headache [letter; comment] Cephalalgia 1993 13(3):218 20 8358785
Demopoulos LA, Tunick PA, Bernstein NE, et al Protruding atheromas of the aortic arch in symptomatic patients with carotid artery disease Am Heart J 1995 129(1):40 4 7817922
Dennis MS, Burn JP, Sandercock PA, et al Long-term survival after first-ever stroke: the Oxfordshire Community Stroke Project Stroke 1993 24(6):796 800 8506550
Derdeyn CP, Powers WJ Cost-effectiveness of screening for asymptomatic carotid atherosclerotic disease Stroke 1996 27(11):1944 50 8898796
Derdeyn CP, Powers WJ, Moran CJ, et al Role of Doppler US in screening for carotid atherosclerotic disease Radiology 1995 197(3):635 43 7480731
DeRook FA, Comess KA, Albers GW, et al Transesophageal echocardiography in the evaluation of stroke Ann Intern Med 1992 117(11):922 32 1443955
Desbiens NA Should all patients with atrial fibrillation be screened with echocardiography? J Gen Intern Med 1992 7(2):131 9 1487759
Deverall PB, Olley PM, Smith DR, et al Incidence of systemic embolism before and after mitral valvotomy Thorax 1968 23(5):530 6 5680237
Devereux RB, Kramer-Fox R, Kligfield P Mitral valve prolapse: causes, clinical manifestations, and management Ann Intern Med 1989 111(4):305 17 2667419
Devuyst G, Despland PA, Bogousslavsky J, et al Complementarity of contrast transcranial Doppler and contrast transesophageal echocardiography for the detection of patent foramen ovale in stroke patients Eur Neurol 1997 38(1):21 5
Deykin D, Gurewich V, Harker L, et al Treating thromboembolic disease Geriatrics 1977 32(10):119 21, 125-8 302814
Di Pasquale G, Andreoli A, Grazi P, et al Cardioembolic stroke from atrial septal aneurysm Stroke 1988 19(5):640 3 3363600
Di Salvo G, Habib G, Pergola V, et al Echocardiography predicts embolic events in infective endocarditis J Am Coll Cardiol 2001 37(4):1069 76 11263610
Di Tullio M, Sacco RL, Gopal A, et al Patent foramen ovale as a risk factor for cryptogenic stroke Ann Intern Med 1992 117(6):461 5 1503349
Di Tullio M, Sacco RL, Venketasubramanian N, et al Comparison of diagnostic techniques for the detection of a patent foramen ovale in stroke patients Stroke 1993 24(7):1020 4 8322376
Di Tullio MR, Sacco RL, Gersony D, et al Aortic atheromas and acute ischemic stroke: a transesophageal echocardiographic study in an ethnically mixed population Neurology 1996 46(6):1560 6 8649549
Di Tullio MR, Sacco RL, Savoia MT, et al Aortic atheroma morphology and the risk of ischemic stroke in a multiethnic population Am Heart J 2000 139(2 Pt 1):329 36 10650307
Di Tullio MR, Sacco RL, Sciacca RR, et al Left atrial size and the risk of ischemic stroke in an ethnically mixed population Stroke 1999 30(10):2019 24 10512901
Dick MT, Cape CA Complications of duplex carotid imaging. A case report Angiology 1994 45(3):235 8 8129206
Diener HCl Stroke prevention: anti-platelet and anti-thrombolytic therapy Neurol Clin 2000 18(2):343 55 10757830
Dion J, Gates P, Fox AJ, et al. Clinical events following neuroangiography. A prospective study. Acta Radiol Suppl. 1986;369:29-33. [pmid: 2980476].
Dion JE, Gates PC, Fox AJ, et al Clinical events following neuroangiography: a prospective study Stroke 1987 18(6):997 1004 3686597
Dippel DW, de Kinkelder A, Bakker SL, et al The diagnostic value of colour duplex ultrasound for symptomatic carotid stenosis in clinical practice Neuroradiology 1999 41(1):1 8 9987759
Dippel DW, Koudstaal PJ We need stronger predictors of major vascular events in patients with a recent transient ischemic attack or nondisabling strokeDutch TIA Trial Study Group.Stroke 1997 28(4):774 6 9099195
Dittrich HC Transient ischemic attack after air-contrast echocardiography Ann Intern Med 1995 123(9):731 2 7574235
Donnan GA Therapy in cerebrovascular disease: current status and future directions Med J Aust 1991 155(8):563 71 1943940
Donnan GA Investigation of patients with stroke and transient ischaemic attacks Lancet 1992 339(8791):473 7 1346828
Donnan GA Angiography, air embolism, and ultrasound [comment] Lancet 1993 341(8848):
Donnan GA, Davis SM, Chambers BR, et al Surgery for Preventive Care of Stroke Lancet 1998 351(9113):1372 1373 9593402
Dosick SM, Whalen RC, Gale SS, et al Carotid endarterectomy in the stroke patient: computerized axial tomography to determine timing J Vasc Surg 1985 2(1):214 9 3965754
Douglas AS Management of thrombotic diseases Semin Hematol 1971 8(2):95 139 4396057
Downs AR, Jessen M, Lye CR Peripheral nerve injuries during carotid endarterectomy Can J Surg 1987 30(1):22 4 3815175
Dressler FA, Craig WR, Castello R, et al Mobile aortic atheroma and systemic emboli: efficacy of anticoagulation and influence of plaque morphology on recurrent stroke J Am Coll Cardiol 1998 31(1):134 8 9426031
Droste DW, Reisener M, Kemeny V, et al Contrast transcranial Doppler ultrasound in the detection of right-to-left shunts. Reproducibility, comparison of 2 agents, and distribution of microemboli Stroke 1999 30(5):1014 8 10229737
Duke RJ, Bloch RF, Turpie AG, et al Intravenous heparin for the prevention of stroke progression in acute partial stable stroke Ann Intern Med 1986 105(6):825 8 3535601
Dunbabin DW, Sandercock PA Investigation of acute stroke: what is the most effective strategy? Postgrad Med J 1991 67(785):259 70 2062773
Dunkman WB, Johnson GR, Carson PE, et al Incidence of thromboembolic events in congestive heart failureThe V-HeFT VA Cooperative Studies Group.Circulation 1993 87(6 Suppl):VI94 101 8419029
Dyken ML, Conneally M, Haerer AF, et al Cooperative study of hospital frequency and character of transient ischemic attacks. I. Background, organization, and clinical survey JAMA 1977 237(9):882 6 576327
Earnest Ft, Forbes G, Sandok BA, et al Complications of cerebral angiography: prospective assessment of risk AJR Am J Roentgenol 1984 142(2):247 53 6198889
Earnshaw J, Hayward J, Horrocks M, et al. The importance of vascular surgical audit to surgeons, patients and purchasers. Eur J Vasc Surg. 1992;6:540-544. [pmid: 1397350].
Easton JD, Sherman DG Management of cerebral embolism of cardiac origin Stroke 1980 11(5):433 42 6999670
Eckstein HH, Schumacher H, Laubach H, et al Early carotid endarterectomy after non-disabling ischaemic stroke: adequate therapeutical option in selected patients Eur J Vasc Endovasc Surg 1998 15(5):423 8 9633498
Eddy DM, Hasselblad V. FAST*PRO: Software for Meta-analysis by the Confidence Profile Method. Boston, MA: Academic Press. 1992. [pmcid: 402151].
Edoute Y, Haim N, Rinkevich D, et al Cardiac valvular vegetations in cancer patients: a prospective echocardiographic study of 200 patients Am J Med 1997 102(3):252 8 9217593
Edwards EA, Tilney N, Lindquist RR Causes of peripheral embolism and their significance JAMA 1966 196(2):133 8 5952109
Egeblad H, Soelberg Sorensen P Prevalence of mitral valve prolapse in younger patients with cerebral ischaemic attacks. A blinded controlled study Acta Med Scand 1984 216(4):385 91 6516907
Eggers F, Price A, Allen J, et al. Neuroradiologic applications of interarterial digital subtraction angiography. AJNR Am J Neuroradiol. 1983;4:854-856. [pmid: 6410872].
Eikelboom B, Ackerstaff R, Ludwig J, et al. Digital video subtraction angiography and duplex scanning in assessment of carotid artery disease: comparison with conventional angiography. Surgery. 1983;94:821-5. [pmid: 6356431].
Eisenberg RL, Bank WO, Hedgcock MW Neurologic complications of angiography for cerebrovascular disease Neurology 1980 30(8):895 7 7191076
Eisenberg RL, Bank WO, Hedgcock MW Neurologic complications of angiography in patients with critical stenosis of the carotid artery Neurology 1980 30(8):892 5 7191075
Elgersma OE, van Leersum M, Buijs PC, et al Changes over time in optimal duplex threshold for the identification of patients eligible for carotid endarterectomy Stroke 1998 29(11):2352 6 9804647
Eliasziw M, Rankin RN, Fox AJ, et al Accuracy and prognostic consequences of ultrasonography in identifying severe carotid artery stenosisNorth American Symptomatic Carotid Endarterectomy Trial (NASCET) Group.Stroke 1995 26(10):1747 52 7570719
Eliasziw M, Smith RF, Singh N, et al Further comments on the measurement of carotid stenosis from angiogramsNorth American Symptomatic Carotid Endarterectomy Trial (NASCET) Group.Stroke 1994 25(12):2445 9 7974588
Eliasziw M, Streifler JY, Fox AJ, et al Significance of plaque ulceration in symptomatic patients with high-grade carotid stenosis. North American Symptomatic Carotid Endarterectomy Trial Stroke 1994 25(2):304 8 8303736
Eljamel MS, Humphrey PR, Shaw MD Dissection of the cervical internal carotid artery. The role of Doppler/Duplex studies and conservative management J Neurol Neurosurg Psychiatry 1990 53(5):379 83 2351965
Ellekjaer H, Holmen J, Indredavik B, et al Epidemiology of stroke in Innherred, Norway, 1994 to 1996. Incidence and 30-day case-fatality rate Stroke 1997 28(11):2180 4 9368561
Ellis SJ, Hans R Using anticoagulation or aspirin to prevent stroke. Research was methodologically flawed [letter; comment] BMJ 2000 320(7240):1008 9 discussion 1010 1 10753166 1117881
Elneihoum AM, Goransson M, Falke P, et al Three-year survival and recurrence after stroke in Malmo, Sweden: an analysis of stroke registry data Stroke 1998 29(10):2114 7 9756591
Enevoldsen EM, Torfing T, Kjeldsen MJ, et al Cerebral infarct following carotid endarterectomy. Frequency, clinical and hemodynamic significance evaluated by MRI and TCD Acta Neurol Scand 1999 100(2):106 10 10442452
Enger E, Boyesen Sl. Long-term anticoagulant therapy in patients with cerebral infarction. A controlled clinical study. Acta Med Scand Suppl. 1965;438:1-61. [pmid: 5323519].
Erdoes LS, Marek JM, Mills JL, et al The relative contributions of carotid duplex scanning, magnetic resonance angiography, and cerebral arteriography to clinical decisionmaking: a prospective study in patients with carotid occlusive disease J Vasc Surg 1996 23(5):950 6 8667521
Eriksson S, Backman C, Osterman G Pulmonary-artery cineangiocardiography and echocardiography for detection of cardiac sources of cerebral embolism Acta Med Scand 1988 223(1):27 33 3348101
Eriksson SE, Link H Evaluation of anticoagulants in patients with cerebral infarction with slight to moderate neurological deficit Acta Neurol Scand 1983 68(2):96 106 6356767
Eriksson SE, Link H, Alm A, et al. Results from 88 consecutive prophylactic carotid endarterectomies in cerebral infarction and transient ischaemic attacks. Acta Neurol Scand. 1981;63:209-219. [pmid: 7211186].
Eriksson SE Enteric-coated acetylsalicylic acid plus dipyridamole compared with anticoagulants in the prevention of ischemic events in patients with transient ischemic attacks Acta Neurol Scand 1985 71(6):485 93 4024860
Erly WK, Zaetta J, Borders GT, et al Gadopentetate dimeglumine as a contrast agent in common carotid arteriography AJNR Am J Neuroradiol 2000 21(5):964 7 10815678
Espinoza FI, MacGregor FB, Doughty JC, et al Vocal fold paralysis following carotid endarterectomy J Laryngol Otol 1999 113(5):439 41 10505157
Estes JM, Guadagnoli E, Wolf R, et al The impact of cardiac comorbidity after carotid endarterectomy J Vasc Surg 1998 28(4):577 84 9786249
Estol CJ Intravenous heparin for acute stroke: what can we learn from the megatrials? [letter; comment] Neurology 2000 54(7):1542 3 10751280
Estol CJ, Pessin MS Anticoagulation: is there still a role in atherothrombotic stroke? Stroke 1990 21(5):820 4 2187290
Evans A, Perez I, Kalra L Using anticoagulation or aspirin to prevent stroke. Anticoagulation has a major role in primary prevention of stroke in general practice [letter; comment] BMJ 2000 320(7240):27404
Evans DB Principles involved in costing Med J Aust 1990 153(Suppl):S10 2 2116580
Evans WE, Mendelowitz DS, Liapis C, et al Motor speech deficit following carotid endarterectomy Ann Surg 1982 196(4):461 4 7125731 1352709
Ezekowitz MD, Wilson DA, Smith EO, et al Comparison of Indium-111 platelet scintigraphy and two-dimensional echocardiography in the diagnosis of left ventricular thrombi N Engl J Med 1982 306(25):1509 13 7078607
Falk RH A plea for a clinical trial of anticoagulation in dilated cardiomyopathy Am J Cardiol 1990 65(13):914 5 2181847
Falk RH, Foster E, Coats MH Ventricular thrombi and thromboembolism in dilated cardiomyopathy: a prospective follow-up study Am Heart J 1992 123(1):136 42 1729816
Falke P, Stavenow L, Young M, et al Differences in mortality and cardiovascular morbidity during a 3-year follow-up of transient ischemic attacks and minor strokes Stroke 1989 20(3):340 4 2922772
Fatkin D, Kelly RP, Feneley MP Relations between left atrial appendage blood flow velocity, spontaneous echocardiographic contrast and thromboembolic risk in vivo J Am Coll Cardiol 1994 23(4):961 9 8106703
Fatkin D, Scalia G, Jacobs N, et al Accuracy of biplane transesophageal echocardiography in detecting left atrial thrombus Am J Cardiol 1996 77(4):321 3 8607421
Faught E, Trader SD, Hanna GR Cerebral complications of angiography for transient ischemia and stroke: prediction of risk Neurology 1979 29(1):4 15 570676
Faught WE, Mattos MA, van Bemmelen PS, et al Color-flow duplex scanning of carotid arteries: new velocity criteria based on receiver operator characteristic analysis for threshold stenoses used in the symptomatic and asymptomatic carotid trials J Vasc Surg 1994 19(5):818 27 discussion 827 8 8170035
Faught WE, van Bemmelen PS, Mattos MA, et al Presentation and natural history of internal carotid artery occlusion J Vasc Surg 1993 18(3):512 23 discussion8377246
Feinberg WM Guidelines for the management of transient ischemic attacks. Ad Hoc Committee on Guidelines for the Management of Transient Ischemic Attacks of the Stroke Council, American Heart Association Stroke 1994 3(5):275 83
Feinberg WM, RuDusky BM Anticoagulation for prevention of stroke Spontaneous carotid artery dissection and stroke [letter; comment] Neurology 1998 51(3 Suppl 3):S20 2 9744827
Fell G, Breslau P, Knox R, et al. Importance of noninvasive ultrasonic-Doppler testing in the evaluation of patients with symptomatic carotid bruits. Am Heart J. 1981;102:221-6. [pmid: 7258096].
Fellner C, Strotzer M, Fraunhofer S, et al MR angiography of the supra-aortic arteries using a dedicated head and neck coil: image quality and assessment of stenoses Neuroradiology 1997 39(11):763 71 9406200
Feussner JR, Matchar DB When and how to study the carotid arteries Ann Intern Med 1988 109(10):805 18 3056158
Fields WS Heparins and stroke. Is there a place for low molecular weight heparins? Semin Thromb Hemost 1991 17(4):371 4 1666458
Fieschi C, Francia A, Allori L, et al Mitral valve prolapse as a risk factor for TIA. A study with echocardiography and dynamic ECG Eur Neurol 1983 22(4):233 9 6884393
Fillinger MF, Baker RJ, Jr., Zwolak RM, et al Carotid duplex criteria for a 60% or greater angiographic stenosis: variation according to equipment J Vasc Surg 1996 24(5):856 64 8918334
Fisher C. Anticoagulant therapy in cerebral thrombosis and cerebral embolism. Neurology. 1961;11:119-131. [pmid: 13699939].
Fisher DC, Fisher EA, Budd JH, et al The incidence of patent foramen ovale in 1,000 consecutive patients. A contrast transesophageal echocardiography study Chest 1995 107(6):1504 9 7781337
Fisher EA, Goldman ME Transesophageal echocardiography: a new view of the heart Ann Intern Med 1990 113(2):91 3 2360758
Fisher ES, Malenka DJ, Solomon NA, et al Risk of carotid endarterectomy in the elderly Am J Public Health 1989 79(12):1617 20 2817189 1349764
Fisher M, Sandler R, Weiner J. Delayed cerebral ischemia following arteriography. Stroke. 1985;16.
Fogelholm R, Melin J Echocardiography in ischaemic cerebrovascular disease BMJ 1987 295(6593):305 6 3115420 1247143
Fontenelle LJ, Simper SC, Hanson TL Carotid duplex scan versus angiography in evaluation of carotid artery disease Am Surg 1994 60(11):864 8 7978683
Foster E, Kusumoto FM, Sobol SM, et al Streptococcal endocarditis temporally related to transesophageal echocardiography J Am Soc Echocardiogr 1990 3(5):424 7 2245038
Frawley JE, Hicks RG, Beaudoin M, et al Hemodynamic ischemic stroke during carotid endarterectomy: an appraisal of risk and cerebral protection J Vasc Surg 1997 25(4):611 9 9129615
Frawley JE, Hicks RG, Woodforth IJ Risk factors for peri-operative stroke complicating carotid endarterectomy: selective analysis of a prospective audit of 1000 consecutive operations Aust N Z J Surg 2000 70(1):52 6 10696944
Freedberg RS, Goodkin GM, Perez JL, et al Valve strands are strongly associated with systemic embolization: a transesophageal echocardiographic study J Am Coll Cardiol 1995 26(7):1709 12 7594107
Frericks H, Kievit J, van Baalen JM, et al Carotid recurrent stenosis and risk of ipsilateral stroke: a systematic review of the literature Stroke 1998 29(1):244 50 9445358
Friedman SG Transient ischemic attacks resulting from carotid duplex imaging Surgery 1990 107(2):153 5 2405535
Fryback D, Dasbach E, Klein R, et al. The Beaver Dam Health Outcomes Study: initial catalog of health-state quality factors. Med Decis Making. 1993;13:89-102. [pmid: 8483408].
Frye RLB Does it really make a difference? J Am Coll Cardiol 1992 19(2):468 70 1732377
Fujitani R, Mills J, Wang L, et al. The effect of unilateral internal carotid artery occlusion upon contralateral duplex study: criteria for accurate interpretation. J Vasc Surg. 1992;16:459-67. [pmid: 1522650].
Furlan AJ, Cavalier SJ, Hobbs RE, et al Hemorrhage and anticoagulation after nonseptic embolic brain infarction Neurology 1982 32(3):280 2 7199638
Furlan AJ CVA: reducing the risk of a confused vascular analysis. The Feinberg lecture Stroke 2000 31(6):1451 6 10835471
Furuya Y, Isoda H, Hasegawa S, et al. Magnetic resonance angiography of extracranial carotid and vertebral arteries, including their origins: comparison with digital subtraction angiography. Neuroradiology. 1992;35:42-5. [pmid: 1289737].
Gage BF, Cardinalli AB, Owens DK The effect of stroke and stroke prophylaxis with aspirin or warfarin on quality of life Arch Intern Med 1996 156(16):1829 36 8790077
Gagliardi R, Benvenuti L, Frosini F, et al Frequency of echocardiographic abnormalities in patients with ischemia of the carotid territory--a preliminary report Stroke 1985 16(1):118 20 3966255
Gaines KJ, Chesney C, Vander Zwaag R, et al Racial differences in coagulation studies in stroke Neurol Res 1992 14(2 Suppl):103 8 1355861
Gallet B, Malergue MC, Adams C, et al Atrial septal aneurysm--a potential cause of systemic embolism. An echocardiographic study Br Heart J 1985 53(3):292 7 3970786 481758
Gallhofer B, Ladurner G, Lechner H Prognosis of prophylactic anticoagulant treatment in ischaemic stroke Eur Neurol 1979 18(3):145 8 477686
Gandolfo C, Moretti C, Dall'Agata D, et al Long-term prognosis of patients with lacunar syndromes Acta Neurol Scand 1986 74(3):224 9 3788486
Gao MY, Sillesen HH, Lorentzen JE, et al Eversion carotid endarterectomy generates fewer microemboli than standard carotid endarterectomy Eur J Vasc Endovasc Surg 2000 20(2):153 7 10942686
Garde A, Samuelsson K, Fahlgren H, et al Treatment after transient ischemic attacks: a comparison between anticoagulant drug and inhibition of platelet aggregation Stroke 1983 14(5):677 81 6658949
Gardner TJ, Horneffer PJ, Manolio TA, et al Stroke following coronary artery bypass grafting: a ten-year study Ann Thorac Surg 1985 40(6):574 81 3878134
Garrard CL, Manord JD, Ballinger BA, et al Cost savings associated with the nonroutine use of carotid angiography Am J Surg 1997 174(6):650 3 discussion 653 4 9409591
Garth K, Carroll B, Sommer F, et al. Duplex ultrasound scanning of carotid arteries with velocity spectrum analysis. Radiology. 1983;147:823-7. [pmid: 6844621].
Gasecki A, Ferguson G, Eliasziw M, et al. Early endarterectomy for severe carotid artery stenosis after a nondisabling stroke: results from the North American Symptomatic Carotid Endarterectomy Trial. J Vasc Surg. 1994;20:288-95. [pmid: 8040954].
Gasparini M, Arosio M, Galbiati N, et al Neurological complications of cerebral angiography Ital J Neurol Sci 1986 7(3):353 7 3733415
Gawel M, Burkett M, Rose FC Platelet activation following cerebral angiography Acta Neurol Scand 1980 61(4):240 3 6155043
Geibel A, Kasper W, Behroz A, et al Risk of transesophageal echocardiography in awake patients with cardiac diseases Am J Cardiol 1988 62(4):337 9 3400617
Geltner D, Cernik-Harush H, Ayzenberg O Mitral valve prolapse in young Israelis with thromboembolic brain disease Isr J Med Sci 1991 27(1):5 7 1995502
Gendreau MA, Triner WR, Bartfield J Complications of transesophageal echocardiography in the ED Am J Emerg Med 1999 17(3):248 51 10337882
Gent M, Blakely JA, Easton JD, et al The Canadian American Ticlopidine Study (CATS) in thromboembolic stroke Lancet 1989 1(8649):1215 20 2566778
Genton E, Barnett HJ, Fields WS, et al XIV. Cerebral ischemia: the role of thrombosis and of antithrombotic therapy. Study group on antithrombotic therapy Stroke 1977 8(1):150 75 835152
Gianotta S, Dicks R, Kindt G. Cranial nerve injury during carotid endarterectomy. Neurosurgery. 1981;8.
Gibaldi M Prevention and treatment of stroke: where do we stand? J Clin Pharmacol 1997 37(9):784 90 9549631
Gilon D, Buonanno FS, Joffe MM, et al Lack of evidence of an association between mitral-valve prolapse and stroke in young patients N Engl J Med 1999 341(1):8 13 10387936
Giordano J. The timing of carotid endarterectomy after acute stroke. Semin Vasc Surg. 1998;11:19-23. [pmid: 9535282].
Giordano J, Trout H, Kozloff L, et al. Timing of carotid endarterectomy after stroke. J Vasc Surg. 1985;2:250-254. [pmid: 3974010].
Glen S, Grosset D, Lees K Anticoagulant monitoring with transcranial Doppler [letter; comment] Lancet 1995 345(8941):57 8
Glen SK, Grosset DG Duplex versus angiography [letter; comment] J R Soc Med 1995 88(7):423 4
Glover J, Bendick P, Jackson V, et al. Duplex ultrasonography, digital subtraction angiography, and conventional angiography in assessing carotid atherosclerosis. Arch Surg. 1984;119:664-9. [pmid: 6375629].
Goldstein LB Carotid endarterectomy [letter; comment] N Engl J Med 1999 340(15):discussion 1210 1 10206847
Goldstein LB, Bonito AJ, Matchar DB, et al US national survey of physician practices for the secondary and tertiary prevention of ischemic stroke. Design, service availability, and common practices Stroke 1995 26(9):1607 15 7660407
Goldstein LB, Hasselblad V, Matchar DB, et al Comparison and meta-analysis of randomized trials of endarterectomy for symptomatic carotid artery stenosis Neurology 1995 45(11):1965 70 7501142
Goldstein LB, Perry A Early recurrent ischemic stroke. A case-control study Stroke 1992 23(7):1010 3 1615533
Golledge J, Cuming R, Beattie DK, et al Influence of patient-related variables on the outcome of carotid endarterectomy J Vasc Surg 1996 24(1):120 6 8691514
Golledge J, Ellis M, Sabharwal T, et al Selection of patients for carotid endarterectomy J Vasc Surg 1999 30(1):122 30 10394162
Good DC, Frank S, Verhulst S, et al Cardiac abnormalities in stroke patients with negative arteriograms Stroke 1986 17(1):6 11 3945985
Gorge G, Erbel R, Henrichs KJ, et al Positive blood cultures during transesophageal echocardiography Am J Cardiol 1990 65(20):1404 5 2343830
Gorter JW Major bleeding during anticoagulation after cerebral ischemia: patterns and risk factors. Stroke Prevention In Reversible Ischemia Trial (SPIRIT). European Atrial Fibrillation Trial (EAFT) study groups Neurology 1999 53(6):1319 27 10522891
Gotshall RA, Harker LA Using antithrombotic therapy in ischemic cerebrovascular disease Geriatrics 1977 32(11):101 4
Grant EG, Duerinckx AJ, El Saden S, et al Doppler sonographic parameters for detection of carotid stenosis: is there an optimum method for their selection? AJR Am J Roentgenol 1999 172(4):1123 9 10587159
Grant EG, Duerinckx AJ, El Saden SM, et al Ability to use duplex US to quantify internal carotid arterial stenoses: fact or fiction? Radiology 2000 214(1):247 52 10644132
Grau AJ, Hacke W Is there still a role for intravenous heparin in acute stroke? Yes Arch Neurol 1999 56(9):1159 60 10488819
Gray W, Kitchin A, Logan A, et al Systemic embolism in rheumatic heart disease Br Heart J 1969 31(3):39 6
Green RM, McNamara J Optimal resources for carotid endarterectomy Surgery 1987 102(4):743 8 3660246
Greenland P, Knopman DS, Mikell FL, et al Echocardiography in diagnostic assessment of stroke Ann Intern Med 1981 95(1):51 3 7247127
Griewing B, Morgenstern C, Driesner F, et al Cerebrovascular disease assessed by color-flow and power Doppler ultrasonography. Comparison with digital subtraction angiography in internal carotid artery stenosis Stroke 1996 27(1):95 100 8553412
Groch S, McDevitt E, Wright I. A long-term study of cerebral vascular disease. Ann Intern Med. 1961;55:358-367. [pmid: 13708826].
Grzyska U, Freitag J, Zeumer H Selective cerebral intraarterial DSA. Complication rate and control of risk factors Neuroradiology 1990 32(4):296 9 2234388
Gubitz G, Counsell C, Sandercock P, et al Anticoagulants for acute ischemic stroke (Cochrane Review) In The Cochrane LibaryIssue 3,2001 Oxford, England: Update Software
Gubitz G, Sandercock P, Counsell C Antiplatetelet therapy for acute ischemic stroke (Cochrane Review) In The Cochrane LibraryIssue 3,2001 Oxford, England: Update Software
Gueyffier F, Boissel JP, Boutitie F, et al Effect of antihypertensive treatment in patients having already suffered from stroke. Gathering the evidence. The INDANA (INdividual Data ANalysis of Antihypertensive intervention trials) Project Collaborators Stroke 1997 28(12):2557 62 9412649
Gumerlock M, Neuwelt E. Carotid endarterectomy: to shunt or not to shunt?. Stroke. 1988;19:1485-1490. [pmid: 3201506].
Gurdijan ES, Darmody WR, Thomas LM Recurrent strokes due to occlusive disease of extracranial vessels Arch Neurol 1969 21(5):447 54 5344353
Ha JW, Kang WC, Chung N, et al Echocardiographic and morphologic characteristics of left atrial myxoma and their relation to systemic embolism Am J Cardiol 1999 83(11):1579 82, A8 10363879
Haapaniemi E, Tatlisumak T, Hamel K, et al Plasma endothelin-1 levels neither increase nor correlate with neurological scores, stroke risk factors, or outcome in patients with ischemic stroke Stroke 2000 31(3):720 5 10700510
Haerer AF, Gotshall RA, Conneally PM, et al Cooperative study of hospital frequency and character of transient ischemic attacks. III. Variations in treatment JAMA 1977 238(2):142 6 577284
Hafner CD Minimizing the risks of carotid endarterectomy J Vasc Surg 1984 1(3):392 7 6481888
Hallam M, Reid J, Cooperberg P Color-flow Doppler and conventional duplex scanning of the carotid bifurcation: a prospective, double-blind, correlative study AJR Am J Roentgenol 1989 152(5):1101 1105 2650482
Hallam M, Reid J, Cooperberg P Color-flow Doppler and conventional duplex scanning of the carotid bifurcation: a prospective, double-blind, correlative study AJR Am J Roentgenol 1989 152(5):1101 1105 2650482
Hallan S, Asberg A, Indredavik B, et al Quality of life after cerebrovascular stroke: a systematic study of patients' preferences for different functional outcomes J Intern Med 1999 246(3):309 16 10475999
Hallett JW, Jr., Pietropaoli JA, Jr., Ilstrup DM, et al Comparison of North American Symptomatic Carotid Endarterectomy Trial and population-based outcomes for carotid endarterectomy J Vasc Surg 1998 27(5):845 50 discussion9620136
Hames T, Humphries K, Gazzard V, et al. The role of continuous wave Doppler imaging in a vascular unit. Cardiovasc Res. 1985;19:631-5. [pmid: 3902235].
Hankey GJ Asymptomatic carotid stenosis: how should it be managed? Med J Aust 1995 163(4):197 200 7651254
Hankey GJ Heparin in acute ischaemic stroke. The T wave is negative and it's time to stop Med J Aust 1998 169(10):534 6 9861911
Hankey GJ, Jamrozik K, Broadhurst RJ, et al Long-term risk of first recurrent stroke in the Perth Community Stroke Study Stroke 1998 29(12):2491 500 9836757
Hankey GJ, Jamrozik K, Broadhurst RJ, et al Five-year survival after first-ever stroke and related prognostic factors in the Perth Community Stroke Study Stroke 2000 31(9):2080 6 10978033
Hankey GJ, Warlow CP Symptomatic carotid ischaemic events: safest and most cost effective way of selecting patients for angiography, before carotid endarterectomy BMJ 1990 300(6738):1485 91 2115384 1663209
Hankey GJ, Warlow CP, Molyneux AJ Complications of cerebral angiography for patients with mild carotid territory ischaemia being considered for carotid endarterectomy J Neurol Neurosurg Psychiatry 1990 53(7):542 8 2118171
Hankey GJ, Warlow CP, Sellar RJ Cerebral angiographic risk in mild cerebrovascular disease Stroke 1990 21(2):209 22 2406993
Hanley PC, Tajik AJ, Hynes JK, et al Diagnosis and classification of atrial septal aneurysm by two-dimensional echocardiography: report of 80 consecutive cases J Am Coll Cardiol 1985 6(6):1370 82 4067118
Hanna JP, Sun JP, Furlan AJ, et al Patent foramen ovale and brain infarct. Echocardiographic predictors, recurrence, and prevention Stroke 1994 25(4):782 6 8160221
Harbison JW Ticlopidine versus aspirin for the prevention of recurrent stroke. Analysis of patients with minor stroke from the Ticlopidine Aspirin Stroke Study Stroke 1992 23(12):1723 7 1448821
Harris RP, Helfand M, Woolf SH, et al Curent methods of the U.S. Preventive Services Task Force; a review of the process Am J Prev Med 2001 20(3S):21 35
Hart RG Cardiogenic stroke Am Fam Physician 1989 40(5 Suppl):35S 38S 2683693
Hart RG Cardiogenic embolism to the brain Lancet 1992 339(8793):589 94 1347101
Hart RG, Benavente O, McBride R, et al Antithrombotic therapy to prevent stroke in patients with atrial fibrillation: a meta-analysis Ann Intern Med 1999 131(7):492 501 10507957
Hart RG, Boop BS, Anderson DC Oral anticoagulants and intracranial hemorrhage. Facts and hypotheses Stroke 1995 26(8):1471 7 7631356
Hart RG, Coull BM, Hart D Early recurrent embolism associated with nonvalvular atrial fibrillation: a retrospective study Stroke 1983 14(5):688 93 6658950
Hart RG, Foster JW, Luther MF, et al Stroke in infective endocarditis Stroke 1990 21(5):695 700 2187287
Hart RG, Sherman DG, Easton JD, et al Prevention of stroke in patients with nonvalvular atrial fibrillation Neurology 1998 51(3):674 81 9748009
Hartmann A, Mohr JP, Thompson JL, et al Interrater reliability of plaque morphology classification in patients with severe carotid artery stenosis Acta Neurol Scand 1999 99(1):61 4 9925240
Harvey JR, Teague SM, Anderson JL, et al Clinically silent atrial septal defects with evidence for cerebral embolization Ann Intern Med 1986 105(5):695 7 3767150
Harward TR, Bernstein EF, Fronek A Continuous-wave versus range-gated pulsed Doppler power frequency spectrum analysis in the detection of carotid arterial occlusive disease Ann Surg 1986 204(1):32 7 3524481 1251219
Hass W, Fields W, North R, et al. Joint study of extracarnial arterial occlusion:II. Ateriography, techniques, sites, and complications. JAMA. 1968;203:961-968. [pmid: 5694318].
Hass WK Occlusive cerebrovascular disease Med Clin North Am 1972 56(6):1281 97 5085859
Hass WK, Clauss RH, Goldberg AF, et al Special problems associated with surgical and thrombolytic treatment of strokes Arch Surg 1966 92(1):27 31 5901258
Hass WK, Kamm B. The North American ticlopidine aspirin stroke study: structure, stratification variables, and patient characteristics. Agents Actions Suppl. 1984;15:273-8. [pmid: 6385651].
Hata JS, Ayres RW, Biller J, et al Impact of transesophageal echocardiography on the anticoagulation management of patients admitted with focal cerebral ischemia Am J Cardiol 1993 72(9):707 10 8249849
Haugland JM, Asinger RW, Mikell FL, et al Embolic potential of left ventricular thrombi detected by two-dimensional echocardiography Circulation 1984 70(4):588 98 6478564
Hausmann D, Mugge A, Becht I, et al Diagnosis of patent foramen ovale by transesophageal echocardiography and association with cerebral and peripheral embolic events Am J Cardiol 1992 70(6):668 72 1510018
Hausmann D, Mugge A, Daniel WG Identification of patent foramen ovale permitting paradoxic embolism J Am Coll Cardiol 1995 26(4):1030 8 7560596
Hayes PD, Lloyd AJ, Lennard N, et al Transcranial Doppler-directed Dextran-40 therapy is a cost-effective method of preventing carotid thrombosis after carotid endarterectomy Eur J Vasc Endovasc Surg 2000 19(1):56 61 10706836
Haynes C, Gideon D, King G. The improvement of cognition and personality after carotid endarterectomy. Surgery. 1976;80:699-704. [pmid: 1006516].
Haynes RB, Sandler RS, Larson EB, et al A critical appraisal of ticlopidine, a new antiplatelet agent. Effectiveness and clinical indications for prophylaxis of atherosclerotic events Arch Intern Med 1992 152(7):1376 80 1627017
Haynes RB, Taylor DW, Sackett D, et al. Prevention of functional impairment by endarterectomy for symptomatic high-grade carotid stenosis. JAMA. 1994;271:1256-1259. [pmid: 8151900].
Healy B From the National Institutes of Health JAMA 1991 266(21):
Heidenreich PA, Masoudi FA, Maini B, et al Echocardiography in patients with suspected endocarditis: a cost-effectiveness analysis Am J Med 1999 107(3):198 208 10492311
Heinle S, Wilderman N, Harrison JK, et al Value of transthoracic echocardiography in predicting embolic events in active infective endocarditis. Duke Endocarditis Service Am J Cardiol 1994 74(8):799 801 7942553
Heiro M, Nikoskelainen J, Engblom E, et al Neurologic manifestations of infective endocarditis: a 17-year experience in a teaching hospital in Finland Arch Intern Med 2000 160(18):2781 7 11025788
Heiserman J, Drayer B, Fram E, et al. Carotid artery stenosis: clinical efficacy of two-dimensional time-of-flight MR angiography. Radiology. 1992;182:761-8. [pmid: 1535891].
Heiserman JE, Dean BL, Hodak JA, et al Neurologic complications of cerebral angiography AJNR Am J Neuroradiol 1994 15(8):1401 7 discussion 1408 11 7985557
Helgason CM, Chomka E, Louie E, et al The potential role for ultrafast cardiac computed tomography in patients with stroke Stroke 1989 20(4):465 72 2929025
Heller R, O'Connell R, Lim L, et al Variation in in-patient stroke management in ten centres in different countries: the INCLEN multicentre stroke collaboration J Neurol Sci 1999 167(1):11 5 10500255
Hennekens CH, Buring JE. Epidemiology in Medicine. 1st ed. Boston: Little, Brown, and Co. 1987. [pmcid: 373129].
Hennerici M, Freund H. Efficacy of CW-Doppler and duplex system examinations for the evaluation of extracranial carotid disease. J Clin Ultrasound. 1984;12:155-61. [pmid: 6423689].
Hertzer NR, Beven EG, Modic M, et al. Early patency of the carotid artery after endarterectomy: digital subtraction angiography after two hundred sixty-two operations. Surgery. 1982;92:1049-1056. [pmid: 6755788].
Hertzer NR, O'Hara PJ, Mascha EJ, et al Early outcome assessment for 2228 consecutive carotid endarterectomy procedures: the Cleveland Clinic experience from 1989 to 1995 J Vasc Surg 1997 26(1):1 10 9240314
Hier DB, Foulkes MA, Swiontoniowski M, et al Stroke recurrence within 2 years after ischemic infarction Stroke 1991 22(2):155 61 2003278
Hill A, Marshall J, Shaw D. A controlled clinical trial of long-term anticoagulant therapy in cerebrovascular diease. Q J Med. 1960;29:597-609. [pmid: 13714253].
Hill AB Should patients be screened for asymptomatic carotid artery stenosis? Can J Surg 1998 41(3):208 13 9627545
Hill MD, Hachinski V Stroke treatment: time is brain Lancet 1998 352(Suppl 3):10 4
Hill SL, Donato AT Ability of the carotid duplex scan to predict stenosis, symptoms, and plaque structure Surgery 1994 116(5):914 20 7940197
Hillblom M, Erila T, Flosbach C, et al. Enoxaparin, a low molecular weight heaparin, is superior to heparin in the prevention of deep-vein thrombosis in stroke patients. Stroke. 1998;29.
Hindfelt B, Nilsson O The prognosis of ischemic stroke in young adults Acta Neurol Scand 1977 55(2):123 30 842283
Hindfelt B, Nilsson O Long-term prognosis of ischemic stroke in young adults Acta Neurol Scand 1992 86(5):440 5 1481624
Hinton RCl Treatment of cerebral ischemia Compr Ther 1981 7(4):24 31
Hirko MK, Morasch MD, Burke K, et al The changing face of carotid endarterectomy J Vasc Surg 1996 23(4):622 7 8627898
Hirsh J, Fuster V Guide to anticoagulant therapy. Part 2: Oral anticoagulants. American Heart Association [published erratum appears in Circulation 1995 Jan 15;91(2):A55-A56] Circulation 1994 89(3):1469 80 8124830
Hoffmann M, Robbs J Carotid endarterectomy after recent cerebral infarction Eur J Vasc Endovasc Surg 1999 18(1):6 10 10388632
Hofmann T, Kasper W, Meinertz T, et al Echocardiographic evaluation of patients with clinically suspected arterial emboli Lancet 1990 336(8728):1421 4 1978881
Holloway RG, Benesch CG, Rahilly CR, et al A systematic review of cost-effectiveness research of stroke evaluation and treatment Stroke 1999 30(7):1340 9 10390305
Holroyd-Leduc JM, Kapral MK, Austin PC, et al Sex differences and similarities in the management and outcome of stroke patients Stroke 2000 31(8):1833 7 10926943
Homma S, Di Tullio MR, Sacco RL, et al Characteristics of patent foramen ovale associated with cryptogenic stroke. A biplane transesophageal echocardiographic study Stroke 1994 25(3):582 6 8128511
Homma S, Di Tullio MR, Sacco RL, et al Surgical closure of patent foramen ovale in cryptogenic stroke patients Stroke 1997 28(12):2376 81 9412617
Hood DB, Mattos MA, Mansour A, et al Prospective evaluation of new duplex criteria to identify 70% internal carotid artery stenosis J Vasc Surg 1996 23(2):254 61 discussion 261 2 8637102
Horn M, Michelini M, Greisler HP, et al Carotid endarterectomy without arteriography: the preeminent role of the vascular laboratory Ann Vasc Surg 1994 8(3):221 4 8043354
Horner RD, Oddone EZ, Matchar DB Theories explaining racial differences in the utilization of diagnostic and therapeutic procedures for cerebrovascular disease Milbank Q 1995 73(3):443 62 7659047
Horner S, Ni XS, Weihs W, et al Simultaneous bilateral contrast transcranial doppler monitoring in patients with intracardiac and intrapulmonary shunts J Neurol Sci 1997 150(1):49 57 9260857
Hornig CR, Haberbosch W, Lammers C, et al Specific cardiological evaluation after focal cerebral ischemia Acta Neurol Scand 1996 93(4):297 302 8739442
Horowitz DR, Tuhrim S, Budd J, et al Aortic plaque in patients with brain ischemia: diagnosis by transesophageal echocardiography Neurology 1992 42(8):1602 4 1641158
Horwitz NH, Wener L Temporary cortical blindness following angiography J Neurosurg 1974 40(5):583 6 4817802
Howard G, Baker WH, Chambless LE, et al An approach for the use of Doppler ultrasound as a screening tool for hemodynamically significant stenosis (despite heterogeneity of Doppler performance). A multicenter experience. Asymptomatic Carotid Atherosclerosis Study Investigators Stroke 1996 27(11):1951 7 8898797
Hoyne RF Review of 272 consecutive carotid endarterectomies in a smaller community Surg Gynecol Obstet 1990 170(6):522 6 2343367
Huang Y, Gao S, Li S, et al Vascular lesions in Chinese patients with transient ischemic attacks Neurology 1997 48(2):524 5 9040750
Huckman MS, Shenk GI, Neems RL, et al Transfemoral cerebral arteriography versus direct precutaneous carotid and brachial arteriography: a comparison of complication rates Radiology 1979 132(1):93 7 451227
Hung J, Landzberg MJ, Jenkins KJ, et al Closure of patent foramen ovale for paradoxical emboli: intermediate-term risk of recurrent neurological events following transcatheter device placement J Am Coll Cardiol 2000 35(5):1311 6 10758974
Hunink MG, Polak JF, Barlan MM, et al Detection and quantification of carotid artery stenosis: efficacy of various Doppler velocity parameters AJR Am J Roentgenol 1993 160(3):619 25 8430567
Hurlbert SN, Krupski WC Carotid artery disease in women Semin Vasc Surg 1995 8(4):268 76 8775880
Huston J, Nichols DA, Luetmer PH, et al MR angiographic and sonographic indications for endarterectomy AJNR Am J Neuroradiol 1998 19(2):309 15 9504484
Huston Jr, Lewis B, Wiebers D, et al. Carotid artery: prospective blinded comparison of two-dimensional time-of-flight MR angiography with conventional angiography and duplex US. Radiology. 1993;186:339-44. [pmid: 8421731].
Hwang JJ, Chen JJ, Lin SC, et al Diagnostic accuracy of transesophageal echocardiography for detecting left atrial thrombi in patients with rheumatic heart disease having undergone mitral valve operations Am J Cardiol 1993 72(9):677 81 8249844
Iafrati MD, Salamipour H, Young C, et al Who needs surveillance of the contralateral carotid artery? Am J Surg 1996 172(2):136 9 8795515
Ibrahim SA, Kwoh CK Underutilization of oral anticoagulant therapy for stroke prevention in elderly patients with heart failure Am Heart J 2000 140(2):219 20 10925333
Ilercil A, Meisner JS, Vijayaraman P, et al Clinical significance of fossa ovalis membrane aneurysm in adults with cardioembolic cerebral ischemia Am J Cardiol 1997 80(1):96 8 9205032
International Stroke Trial Collaborative Group The International Stroke Trial (IST): a randomised trial of aspirin, subcutaneous heparin, both, or neither among 19435 patients with acute ischaemic strokeInternational Stroke Trial Collaborative Group.Lancet 1997 349(9065):1569 81 9174558
Inzitari D, Eliasziw M, Sharpe BL, et al Risk factors and outcome of patients with carotid artery stenosis presenting with lacunar strokeNorth American Symptomatic Carotid Endarterectomy Trial Group.Neurology 2000 54(3):660 6 10680800
Irie K, Yamaguchi T, Minematsu K, et al The J-curve phenomenon in stroke recurrence Stroke 1993 24(12):1844 9 8248966
Irwig L, Macaskill P, Glasziou P, et al Meta-analytic methods for diagnostic test accuracy J Clin Epidemiol 1995 48(1):119 30 discussion 131 2 7853038
Jackson MR, Chang AS, Robles HA, et al Determination of 60% or greater carotid stenosis: a prospective comparison of magnetic resonance angiography and duplex ultrasound with conventional angiography Ann Vasc Surg 1998 12(3):236 43 9588509
Jacobs LA, Ganji S, Shirley J, et al. Cognitive improvement after extracranial reconstruction for the low flow-endangered brain. Surgery. 1983;93:683-687. [pmid: 6845174].
Jacobs NM, Grant EG, Schellinger D, et al The role of duplex carotid sonography, digital subtraction angiography, and arteriography in the evaluation of transient ischemic attack and the asymptomatic carotid bruit Med Clin North Am 1984 68(6):1423 50 6392771
Jeans WD, Mackenzie S, Baird RN Angiography in transient cerebral ischaemia using three views of the carotid bifurcation Br J Radiol 1986 59(698):135 42 3947821
Jernigan WR, Hamman JL The causes and prevention of stroke associated with carotid artery surgery Am Surg 1982 48(2):79 84 7073127
Jerntorp P, Berglund G Stroke registry in Malmo, Sweden Stroke 1992 23(3):357 61 1542896
Jespersen CM, Egeblad H Mitral annulus calcification and embolism Acta Med Scand 1987 222(1):37 41 3630777
Jestico J, Harrison MJ, Marshall J Trial of aspirin during weaning patients with transient ischaemic attacks from anticoagulants BMJ 1978 1(6121):
Job FP, Ringelstein EB, Grafen Y, et al Comparison of transcranial contrast Doppler sonography and transesophageal contrast echocardiography for the detection of patent foramen ovale in young stroke patients Am J Cardiol 1994 74(4):381 4 7914717
Johnston DC, Goldstein LB Clinical carotid endarterectomy decision making: noninvasive vascular imaging versus angiography Neurology 2001 56(8):1009 15 11320170
Johnston K, deMorais D, Kassam M, et al. Cerebrovascular assessment using a Doppler carotid scanner and real-time frequency analysis. J Clin Ultrasound. 1981;9:443-9. [pmid: 6795239].
Jolobe OM Transient ischaemic attacks [letter] Q J Med 1998 91(9):
Jonas S, Sugimori M, Llinas R. Is low molecular weight heparin a neuroprotectant?. Ann N Y Acad Sci. 1997;825:389-93. [pmid: 9370003].
Jonas S Anticoagulant therapy in cerebrovascular disease: review and meta-analysis [published erratum appears in Stroke 1989 Apr;20(4):562] Stroke 1988 19(8):1043 8 3041650
Jones EF, Calafiore P, Donnan GA, et al. Evidence that patent foramen ovale is not a risk factor for cerebral ischemia in the elderly. Am J Cardiol. 1994;74:596-599. [pmid: 8074044].
Jones EF, Donnan GA, Calafiore P, et al Transoesophageal echocardiography in the investigation of stroke: experience in 135 patients with cerebral ischaemic events Aust N Z J Med 1993 23(5):477 83 8297277
Jones EF, Kalman JM, Calafiore P, et al Proximal aortic atheroma. An independent risk factor for cerebral ischemia Stroke 1995 26(2):218 24 7831691
Jones MR, Horner RD, Edwards LJ, et al Racial variation in initial stroke severity Stroke 2000 31(3):563 7 10700486
Jorgensen HS, Nakayama H, Reith J, et al Stroke recurrence: predictors, severity, and prognosis. The Copenhagen Stroke Study Neurology 1997 48(4):891 5 9109873
Joubert J, van Gelder AL, Darazs B, et al The cardiovascular status of the black stroke patient S Afr Med J 1989 76(12):657 64 2688143
Kaarisalo MM, Immonen-Raiha P, Marttila RJ, et al Atrial fibrillation in older stroke patients: association with recurrence and mortality after first ischemic stroke J Am Geriatr Soc 1997 45(11):1297 301 9361653
Kadwa AM, Robbs JV Carotid endarterectomy in Durban--the first 10 years S Afr Med J 1993 83(4):248 52 8316920
Kallmes DF, Omary RA, Dix JE, et al Specificity of MR angiography as a confirmatory test of carotid artery stenosis AJNR Am J Neuroradiol 1996 17(8):1501 6 8883649
Kamensky G, Drahos P, Plevova N Left atrial spontaneous echo contrast: its prevalence and importance in patients undergoing transesophageal echocardiography and particularly those with a cerebrovascular embolic event J Am Soc Echocardiogr 1996 9(1):62 70 8679238
Kappelle LJ, Adams HP, Jr., Heffner ML, et al Prognosis of young adults with ischemic stroke. A long-term follow-up study assessing recurrent vascular events and functional outcome in the Iowa Registry of Stroke in Young Adults Stroke 1994 25(7):1360 5 8023350
Kappelle LJ, Eliasziw M, Fox AJ, et al Importance of intracranial atherosclerotic disease in patients with symptomatic stenosis of the internal carotid artery. The North American Symptomatic Carotid Endarterectomy Trail Stroke 1999 30(2):282 6 9933260
Kappelle LJ, Eliasziw M, Fox AJ, et al Importance of intracranial atherosclerotic disease in patients with symptomatic stenosis of the internal carotid artery. The North American Symptomatic Carotid Endarterectomy Trail Stroke 1999 30(2):282 6 9933260
Kappelle LJ, van Latum JC, van Swieten JC, et al Recurrent stroke after transient ischaemic attack or minor ischaemic stroke: does the distinction between small and large vessel disease remain true to type?Dutch TIA Trial Study Group.J Neurol Neurosurg Psychiatry 1995 59(2):127 31 7629525
Kapral MK, Silver FL Preventive health care, 1999 update: 2. Echocardiography for the detection of a cardiac source of embolus in patients with stroke. Canadian Task Force on Preventive Health Care Can Med Assoc J 1999 161(8):989 96 10551199 1230713
Karalis DG, Chandrasekaran K, Victor MF, et al Recognition and embolic potential of intraaortic atherosclerotic debris J Am Coll Cardiol 1991 17(1):73 8 1987243
Karp HR, Flanders WD, Shipp CC, et al Carotid endarterectomy among Medicare beneficiaries: a statewide evaluation of appropriateness and outcome Stroke 1998 29(1):46 52 9445327
Karttunen V, Ventila M, Hillbom M, et al Dye dilution and oximetry for detection of patent foramen ovale Acta Neurol Scand 1998 97(4):231 6 9576637
Katz SD, Marantz PR, Biasucci L, et al Low incidence of stroke in ambulatory patients with heart failure: a prospective study Am Heart J 1993 126(1):141 6 8322656
Kaul S, Wozniak MA, Sloan MA, et al Influence of transesophageal echocardiography on therapy in stroke [letter; comment] Stroke 1996 27(10):1910 1
Kawaguchi S, Sakaki T, Tsunoda S, et al Strategies to improve the outcome of carotid endarterectomy Neurol Med Chir 1994 34(2):86 90
Kay R, Wong KS, Yu YL, et al Low-molecular-weight heparin for the treatment of acute ischemic stroke N Engl J Med 1995 333(24):1588 93 7477193
Kazui S, Levi CR, Jones EF, et al Risk factors for lacunar stroke: a case-control transesophageal echocardiographic study Neurology 2000 54(6):1385 7 10746618
Keith DS, Phillips SJ, Whisnant JP, et al Heparin therapy for recent transient focal cerebral ischemia [published erratum appears in Mayo Clin Proc 1988 Jan;63(1):92] Mayo Clin Proc 1987 62(12):1101 6 3682955
Kempczinski RF, Brott TG, Labutta RJ The influence of surgical specialty and caseload on the results of carotid endarterectomy J Vasc Surg 1986 3(6):911 6 3712637
Kent DL, Haynor DR, Longstreth WT, Jr., et al The clinical efficacy of magnetic resonance imaging in neuroimaging Ann Intern Med 1994 120(10):856 71 7818632
Kent KC, Kuntz KM, Patel MR, et al Perioperative imaging strategies for carotid endarterectomy. An analysis of morbidity and cost-effectiveness in symptomatic patients JAMA 1995 274(11):888 93 7674503
Kent S Can aspirin prevent recurrence of heart attacks and strokes? Geriatrics 1982 37(1):169 72 7033047
Kerber CW, Cromwell LD, Drayer BP, et al Cerebral ischemia. I. Current angiographic techniques, complications, and safety AJR Am J Roentgenol 1978 130(6):1097 103 418647
Kernan WN, Horwitz RI, Brass LM, et al A prognostic system for transient ischemia or minor stroke Ann Intern Med 1991 114(7):552 7 2001088
Kessler C, Mitusch R, Guo Y, et al Embolism from the aortic arch in patients with cerebral ischemia Thromb Res 1996 84(3):145 55 8914214
Khandheria BK Prophylaxis or no prophylaxis before transesophageal echocardiography? J Am Soc Echocardiogr 1992 5(3):285 7 1622622
Khandheria BK, Seward JB, Tajik AJ Transesophageal echocardiography Mayo Clin Proc 1994 69(9):856 63 8065188
Khandheria BK, Steckelberg JM, Anhalt JP, et al Transesophageal echocardiography and bacterial endocarditis [letter; comment] Circulation 1993 87(4):1426 7
Khoury AF, Afridi I, Quinones MA, et al Transesophageal echocardiography in critically ill patients: feasibility, safety, and impact on management Am Heart J 1994 127(5):1363 71 8172066
Kichura G, Camp A, Ofili EO, et al High incidence of cardiogenic embolic events during follow-up in patients with patent foramen ovale identified by transesophageal echocardiography Circulation 1991 84(Suppl II):
Kido D, Panzer R, Szumowski J, et al. Clinical evaluation of stenosis of the carotid bifurcation with magnetic resonance angiographic techniques. Arch Neurol. 1991;48:484-9. [pmid: 2021361].
Kido DK, Moran CJ When should third-party payers provide reimbursement for MR angiography of the carotid arteries? [comment] AJR Am J Roentgenol 1994 162(1):19 20 8273664
Kieny R, Hirsch D, Seiller C, et al Does carotid eversion endarterectomy and reimplantation reduce the risk of restenosis? Ann Vasc Surg 1993 7(5):407 13 8268085
Kiers L, Davis S, Ebeling P Cardiogenic brain embolism: role of anticoagulants Aust N Z J Med 1989 19(5):500 5 2686613
Kirsch JD, Wagner LR, James EM, et al Carotid artery occlusion: positive predictive value of duplex sonography compared with arteriography J Vasc Surg 1994 19(4):642 9 8164279
Kirshner DL, O'Brien MS, Ricotta JJ Risk factors in a community experience with carotid endarterectomy J Vasc Surg 1989 10(2):178 86 2760995
Kistler JP Cerebral embolism Compr Ther 1996 22(8):515 30 8879919
Kittner SJ, Stern BJ, Wozniak M, et al Cerebral infarction in young adults: the Baltimore-Washington Cooperative Young Stroke Study Neurology 1998 50(4):890 4 9566368
Klein GM, Seland TP Occlusive cerebrovascular disease in young adults Can J Neurol Sci 1984 11(2):302 4 6733611
Klotzsch C, Janssen G, Berlit P Transesophageal echocardiography and contrast-TCD in the detection of a patent foramen ovale: experiences with 111 patients Neurology 1994 44(9):1603 6 7936282
Knight F, Yaeger R, Morris D. Cranial nerve injuries during carotid endarterectomy. Am J Surg. 1987;154:529-32. [pmid: 3674303].
Knopman D, Anderson DC, Greenland P, et al Mitral-valve prolapse and cerebral ischemic events in the elderly [letter] N Engl J Med 1980 303(11):
Knopman DS, Anderson DC, Asinger RW, et al Indications for echocardiography in patients with ischemic stroke Neurology 1982 32(9):1005 11 7202147
Koca V, Bozat T, Akkaya V, et al Left atrial thrombus detection with multiplane transesophageal echocardiography: an echocardiographic study with surgical verification J Heart Valve Dis 1999 8(1):63 6 10096484
Koller RL Recurrent embolic cerebral infarction and anticoagulation Neurology 1982 32(3):283 5 7199639
Korb JR Cost-effectiveness of echocardiography after stroke [letter] Ann Intern Med 1998 128(10):872 3 9599206
Korczyn AD Heparin in the treatment of acute stroke Neurol Clin 1992 10(1):209 17 1557003
Korogi Y, Takahashi M, Mabuchi N, et al Intracranial vascular stenosis and occlusion: diagnostic accuracy of three-dimensional, Fourier transform, time-of-flight MR angiography Radiology 1994 193(1):187 93 8090890
Kotler MN, Mintz GS, Segal BL Two-dimensional echocardiography for stroke patients Geriatrics 1983 38(12):57 9, 63-4, 66
Koudstaal P Anticoagulants for preventing stroke in patients with nonrheumatic atrial fibrillation and a history of stroke or transient ischemic attacks (Cochrane Review) In The Cochrane LibraryIssue 3,2001 Oxford, England: Update Software
Kouvaras G, Bacoulas G Association of mitral valve leaflet prolapse with cerebral ischaemic events in the young and early middle-aged patient Q J Med 1985 56(219):387 92 4095250
Kuhl HP, Hoffmann R, Merx MW, et al Transthoracic echocardiography using second harmonic imaging: diagnostic alternative to transesophageal echocardiography for the detection of atrial right to left shunt in patients with cerebral embolic events J Am Coll Cardiol 1999 34(6):1823 30 10577576
Kuntz KM, Polak JF, Whittemore AD, et al Duplex ultrasound criteria for the identification of carotid stenosis should be laboratory specific Stroke 1997 28(3):597 602 9056618
Kuntz KM, Skillman JJ, Whittemore AD, et al Carotid endarterectomy in asymptomatic patients--is contrast angiography necessary? A morbidity analysis J Vasc Surg 1995 22(6):706 14 discussion 714 6 8523605
Kupper AJ, Verheugt FW, Peels CH, et al Left ventricular thrombus incidence and behavior studied by serial two-dimensional echocardiography in acute anterior myocardial infarction: left ventricular wall motion, systemic embolism and oral anticoagulation J Am Coll Cardiol 1989 13(7):1514 20 2723267
Kuramoto K, Matsushita S, Yamanouchi H Nonbacterial thrombotic endocarditis as a cause of cerebral and myocardial infarction Jpn Circ J 1984 48(9):1000 6 6481938
Labovitz AJ Transesophageal echocardiography and unexplained cerebral ischemia: a multicenter follow-up study. The STEPS Investigators. Significance of Transesophageal Echocardiography in the Prevention of Recurrent Stroke Am Heart J 1999 137(6):1082 7 10347335
Labovitz AJ, Camp A, Castello R, et al Usefulness of transesophageal echocardiography in unexplained cerebral ischemia Am J Cardiol 1993 72(18):1448 52 8256742
Lai SM, Alter M, Friday G, et al A multifactorial analysis of risk factors for recurrence of ischemic stroke Stroke 1994 25(5):958 62 8165690
Lamich R, Alonso C, Guma JR, et al Prospective study of bacteremia during transesophageal echocardiography Am Heart J 1993 125(5 Pt 1):1454 5 8480611
Lamy C, Hamon JB, Coste J, et al Ischemic stroke in young women: risk of recurrence during subsequent pregnancies. French Study Group on Stroke in Pregnancy Neurology 2000 55(2):269 74 10908903
Lancellotti P, Galiuto L, Albert A, et al Relative value of clinical and transesophageal echocardiographic variables for risk stratification in patients with infective endocarditis Clin Cardiol 1998 21(8):572 8 9702384
Landefeld CS, Goldman L Major bleeding in outpatients treated with warfarin: incidence and prediction by factors known at the start of outpatient therapy Am J Med 1989 87(2):144 52 2787958
Langhorne P, Stott DJ, Robertson L, et al Medical complications after stroke: a multicenter study Stroke 2000 31(6):1223 9 10835436
Langlois Y, Roederer G, Chan A, et al. Evaluating carotid artery disease. The concordance between pulsed Doppler/spectrum analysis and angiography. Ultrasound Med Biol. 1983;9:51-63. [pmid: 6879824].
Lapeyre AC, Steele PM, Kazmier FJ, et al Systemic embolism in chronic left ventricular aneurysm: incidence and the role of anticoagulation J Am Coll Cardiol 1985 6(3):534 8 4031266
Lauria G, Gentile M, Fassetta G, et al Incidence and prognosis of stroke in the Belluno province, Italy. First-year results of a community-based study Stroke 1995 26(10):1787 93 7570726
Layne RD Searching for patent foramen ovale in patients with stroke [letter; comment] Ann Intern Med 1993 118(8):
Lechat P, Mas JL, Lascault G, et al Prevalence of patent foramen ovale in patients with stroke N Engl J Med 1988 318(18):1148 52 3362165
Leclerc X, Godefroy O, Lucas C, et al Internal carotid arterial stenosis: CT angiography with volume rendering Radiology 1999 210(3):673 82 10207466
Lee DH, Gao FQ, Rankin RN, et al Duplex and color Doppler flow sonography of occlusion and near occlusion of the carotid artery AJNR Am J Neuroradiol 1996 17(7):1267 74 8871711
Lee RJ, Bartzokis T, Yeoh TK, et al Enhanced detection of intracardiac sources of cerebral emboli by transesophageal echocardiography Stroke 1991 22(6):734 9 2057971
Lee TT, Solomon NA, Heidenreich PA, et al Cost-effectiveness of screening for carotid stenosis in asymptomatic persons Ann Intern Med 1997 126(5):337 46 9054277
Lees KR, Bath PM, Naylor AR ABC of arterial and venous disease. Secondary prevention of transient ischaemic attack and stroke BMJ 2000 320(7240):991 4 10753157 1117915
Lehmann ED, Hopkins KD, Gosling RG Atherosclerosis in the ascending aorta and risk of ischaemic stroke Lancet 1995 346(8975):589 90 7651001
Lensing AW Anticoagulation in acute ischaemic stroke: deep vein thrombosis prevention and long-term stroke outcomes Blood Coagul Fibrinolysis 1999 10(Suppl 2):S123 7 10493241
Leon-Sotomayor L A new technique in the treatment of thromboembolic stroke Preliminary Report Angiology 1980 31(11):729 43 6161569
Leow K, Murie JA Cerebral angiography for cerebrovascular disease: the risks Br J Surg 1988 75(5):428 30 3292003
Lethen H, Flachskampf FA, Schneider R, et al Frequency of deep vein thrombosis in patients with patent foramen ovale and ischemic stroke or transient ischemic attack Am J Cardiol 1997 80(8):1066 9 9352979
Leung DY, Black IW, Cranney GB, et al Selection of patients for transesophageal echocardiography after stroke and systemic embolic events. Role of transthoracic echocardiography Stroke 1995 26(10):1820 4 7570732
Leung DY, Davidson PM, Cranney GB, et al Thromboembolic risks of left atrial thrombus detected by transesophageal echocardiogram Am J Cardiol 1997 79(5):626 9 9068521
Levine MN, Hirsh J Hemorrhagic complications of anticoagulant therapy Semin Thromb Hemost 1986 12(1):39 57 3515558
Levine MN, Raskob G, Hirsh J Hemorrhagic complications of long-term anticoagulant therapy Chest 1986 89(2 Suppl):16S 25S 3510826
Liapis C, Satiani B, Florance CL, et al. Motor speech malfunction following carotid endarterectomy. Surgery. 1981;89:56-9. [pmid: 7466612].
Liberopoulos K, Kaponis A, Kokkinis K, et al Comparative study of magnetic resonance angiography, digital subtraction angiography, duplex ultrasound examination with surgical and histological findings of atherosclerotic carotid bifurcation disease Int Angiol 1996 15(2):131 7 8803637
Lin JP Techniques of cerebral angiography Radiol Clin North Am 1974 12(2):223 40 4416054
Lindgren A, Roijer A, Norrving B, et al Carotid artery and heart disease in subtypes of cerebral infarction Stroke 1994 25(12):2356 62 7974573
Lindgren A, Roijer A, Norrving B, et al Carotid artery and heart disease in subtypes of cerebral infarction Stroke 1994 25(12):2356 62 7974573
Lindgren A, Roijer A, Rudling O, et al Cerebral lesions on magnetic resonance imaging, heart disease, and vascular risk factors in subjects without stroke. A population-based study Stroke 1994 25(5):929 34 8165686
Link H, Lebram G, Johansson I, et al Prognosis in patients with infarction and TIA in carotid territory during and after anticoagulant therapy Stroke 1979 10(5):529 32 505492
Link J, Brossmann J, Grabener M, et al Spiral CT angiography and selective digital subtraction angiography of internal carotid artery stenosis AJNR Am J Neuroradiol 1996 17(1):89 94 8770255
Link J, Brossmann J, Penselin V, et al Common carotid artery bifurcation: preliminary results of CT angiography and color-coded duplex sonography compared with digital subtraction angiography AJR Am J Roentgenol 1997 168(2):361 5 9016207
Lisovoski F, Rousseaux P Cerebral infarction in young people. A study of 148 patients with early cerebral angiography J Neurol Neurosurg Psychiatry 1991 54(7):576 9 1895119
Litt A, Eidelman E, Pinto R, et al. Diagnosis of carotid artery stenosis: comparison of 2DFT time-of-flight MR angiography with contrast angiography in 50 patients. AJNR Am J Neuroradiol. 1991;12:149-51. [pmid: 1903574].
Liu M, Counsell CE, Sandercock P Anticoagulants for preventing recurrence following ischaemic stroke or tranient ischaemic attack Cochrane Library Oxford, England: Update Software 2000(3).
Lloret RL, Cortada X, Bradford J, et al Classification of left ventricular thrombi by their history of systemic embolization using pattern recognition of two-dimensional echocardiograms Am Heart J 1985 110(4):761 5 4050647
Lloyd JV Uses of heparin and warfarin Med J Aust 1985 142(3):197 201 3969037
Lo L, Ford C, McKinney WM, et al. Asymptomatic bruit, carotid and vertbrobasilar transient ischemic attacks - a clinical and ultrasonic correlation. Stroke. 1986;17:65-8. [pmid: 3945986].
Lodder J, Krijne-Kubat B, van der Lugt PJ Timing of autopsy-confirmed hemorrhagic infarction with reference to cardioembolic stroke Stroke 1988 19(12):1482 4 3201505
Lodder J, van der Lugt PJ Evaluation of the risk of immediate anticoagulant treatment in patients with embolic stroke of cardiac origin Stroke 1983 14(1):42 6 6823685
Loeliger EA Cardiogenic embolism to the brain [letter] Lancet 1992 339(8797):
Loh E, Sutton MS, Wun CC, et al Ventricular dysfunction and the risk of stroke after myocardial infarction N Engl J Med 1997 336(4):251 7 8995087
Londrey G, Spadone D, Hogsdon K, et al. Does color-flow imaging improve the accuracy of duplex carotid evaluation?. J Vasc Surg. 1991;13:659-63. [pmid: 2027204].
Lopez JA, Ross RS, Fishbein MC, et al Nonbacterial thrombotic endocarditis: a review Am Heart J 1987 113(3):773 84 3548296
Louie EK, Konstadt SN, Rao TL, et al Transesophageal echocardiographic diagnosis of right to left shunting across the foramen ovale in adults without prior stroke J Am Coll Cardiol 1993 21(5):1231 7 8459082
Love BB, Struck LK, Stanford W, et al Comparison of two-dimensional echocardiography and ultrafast cardiac computed tomography for evaluating intracardiac thrombi in cerebral ischemia Stroke 1990 21(7):1033 8 2368104
Lovett JL, Sandok BA, Giuliani ER, et al Two-dimensional echocardiography in patients with focal cerebral ischemia Ann Intern Med 1981 95(1):1 4 7247111
Low RI, Takeda PA, Lee G, et al Potential efficacy of calcium antagonists and heparin in patients with embolic stroke Am Heart J 1986 112(6):1338 9 3788787
Lucas A, Rolland Y, Calon E, et al Quantification of carotid stenoses using 3D morphometer, CT angiography and conventional angiography J Cardiovasc Surg 2000 41(1):73 8 10836227
Lucas C, Goullard L, Marchau M, Jr., et al Higher prevalence of atrial septal aneurysms in patients with ischemic stroke of unknown cause Acta Neurol Scand 1994 89(3):210 3 8030403
Lucas F, Wennberg D, Malenka D. Variation in the use of echocardiography. Effect Clin Pract. 1999;2:71-75.
Luft H, Bunker J, Enthoven A. Should operations be regionalized? The empirical relation between surgical volume and mortality. N Engl J Med. 1979;301:1364-1369. [pmid: 503167].
Lutas EM, Roberts RB, Devereux RB, et al Relation between the presence of echocardiographic vegetations and the complication rate in infective endocarditis Am Heart J 1986 112(1):107 13 3728266
Madias JE Mitral annular calcification and the risk of stroke [letter; comment] N Engl J Med 1992 327(24):1761 2 1435928
Magarelli N, Scarabino T, Simeone AL, et al Carotid stenosis: a comparison between MR and spiral CT angiography Neuroradiology 1998 40(6):367 73 9689624
Magee TR, Earnshaw J, Cole S, et al. A 5-year review of carotid endarterectomy in a vascular unit using a computerised audit system. Ann R Coll Surg Engl. 1992;74:430-433. [pmid: 1471842].
Makhoul RG, Moore WS, Colburn MD, et al Benefit of carotid endarterectomy after prior stroke J Vasc Surg 1993 18(4):666 70 discussion 670 1 8411474
Mandel MM, Strimel WH Ventricular myxoma associated with cerebral embolism JAMA 1970 214(12):2154 6 5536579
Mani RL, Eisenberg RL Complications of catheter cerebral arteriography: analysis of 5,000 procedures. II. Relation of complication rates to clinical and arteriographic diagnoses AJR Am J Roentgenol 1978 131(5):867 9 101046
Mani RL, Eisenberg RL Complications of catheter cerebral arteriography: analysis of 5,000 procedures. III. Assessment of arteries injected, contrast medium used, duration of procedure, and age of patient AJR Am J Roentgenol 1978 131(5):871 4 101047
Mani RL, Eisenberg RL, McDonald EJ, Jr., et al Complications of catheter cerebral arteriography: analysis of 5,000 procedures. I. Criteria and incidence AJR Am J Roentgenol 1978 131(5):861 5 101045
Maniglia AJ, Han DP Cranial nerve injuries following carotid endarterectomy: an analysis of 336 procedures Head Neck 1991 13(2):121 4 2022476
Manning WJ Role of transesophageal echocardiography in the management of thromboembolic stroke Am J Cardiol 1997 80(4C):19D 28D discussion 35D 39D
Manning WJ, Weintraub RM, Waksmonski CA, et al Accuracy of transesophageal echocardiography for identifying left atrial thrombi. A prospective, intraoperative study Ann Intern Med 1995 123(11):817 22 7486462
Man-Son-Hing M Why aren't we falling for anticoagulant therapy? [letter; comment] Can Med Assoc J 2000 162(2):191 2 10674049
Mansour MA, Mattos MA, Hood DB, et al Detection of total occlusion, string sign, and preocclusive stenosis of the internal carotid artery by color-flow duplex scanning Am J Surg 1995 170(2):154 8 7631921
Mant J, Fitzmaurice D, Murray E, et al Using anticoagulation or aspirin to prevent stroke. Study does not have the power to show that aspirin is as good as anticoagulation [letter; comment] BMJ 2000 320(7240):27404
Marazanof M, Roudaut R, Cohen A, et al Atrial septal aneurysm. Morphological characteristics in a large population: pathological associations. A French multicenter study on 259 patients investigated by transoesophageal echocardiography Int J Cardiol 1995 52(1):59 65 8707438
Marcus CD, Ladam-Marcus VJ, Bigot JL, et al Carotid arterial stenosis: evaluation at CT angiography with the volume-rendering technique Radiology 1999 211(3):775 80 10352606
Marini C, Totaro R, Carolei A Long-term prognosis of cerebral ischemia in young adults. National Research Council Study Group on Stroke in the Young Stroke 1999 30(11):2320 5 10548665
Marks AR, Choong CY, Sanfilippo AJ, et al Identification of high-risk and low-risk subgroups of patients with mitral-valve prolapse N Engl J Med 1989 320(16):1031 6 2927482
Marshall J, Reynolds E. Withdrawal of anticoagulants from patients with transient ischaemic cerebrovascular attacks. Lancet. 1965;1.
Marshall J, Shaw DA. Anticoagulant therapy in acute cerebrovascular accidents: a controlled trial. Lancet. 1960;1:99-5. [pmid: 13857416].
Martin GJ, Biller J Nonseptic cerebral emboli of cardiac origin Arch Intern Med 1984 144(10):1997 9 6486983
Mas JL, Arquizan C, Lamy C, et al Recurrent cerebrovascular events associated with patent foramen ovale, atrial septal aneurysm, or both N Engl J Med 2001 345(24):1740 6 11742048
Mas JL, Zuber M Recurrent cerebrovascular events in patients with patent foramen ovale, atrial septal aneurysm, or both and cryptogenic stroke or transient ischemic attack. French Study Group on Patent Foramen Ovale and Atrial Septal Aneurysm Am Heart J 1995 130(5):1083 8 7484740
Masaryk A, Ross J, DiCello M, et al. 3DFT MR angiography of the carotid bifurcation: potential and limitations as a screening examination. Radiology. 1991;179:797-804. [pmid: 2027995].
Mason RA, Arbeit LA, Giron F Renal dysfunction after arteriography JAMA 1985 253(7):1001 4 3968822
Masuhr F, Busch M, Einhaupl KM Differences in medical and surgical therapy for stroke prevention between leading experts in North America and Western Europe Stroke 1998 29(2):339 45 9472871
Matchar DB, McCrory DC, Barnett HJ, et al Medical treatment for stroke prevention [published erratum appears in Ann Intern Med 1994 Sep 15;121(6):470 and 1995 Jun 1;122(11):885] Ann Intern Med 1994 121(1):41 53 7880225
Matchar DB, Samsa GP. Secondary and Tertiary Prevention of Stroke. Patient Outcomes Research Team (PORT) Final Report - Phase 1. Rockville, MD: Agency for Healthcare Research and Quality. 2000. [pmcid: 384376].
Matsumoto N, Whisnant JP, Kurland LT, et al Natural history of stroke in Rochester, Minnesota, 1955 through 1969: an extension of a previous study, 1945 through 1954 Stroke 1973 4(1):20 9 4685804
Matsuzaki M, Toma Y, Kusukawa R Clinical applications of transesophageal echocardiography Circulation 1990 82(3):709 22 2203552
Mattos MA, Hodgson KJ, Londrey GL, et al Carotid endarterectomy: operative risks, recurrent stenosis, and long-term stroke rates in a modern series J Cardiovasc Surg 1992 33(4):387 400 1527142
Mattos MA, Shamma AR, Rossi N, et al Is duplex follow-up cost-effective in the first year after carotid endarterectomy? Am J Surg 1988 156(2):91 5 3135761
Mattos MA, van Bemmelen PS, Barkmeier LD, et al Routine surveillance after carotid endarterectomy: does it affect clinical management? J Vasc Surg 1993 17(5):819 30 discussion 830 1 8487350
Mayberg MR, Wilson S, Yatsu F. Carotid endarterectomy and prevention of cerebral ischemia in symptomatic carotid stenosis. JAMA. 1991;266:3289-3294. [pmid: 1960828].
Mazoyer E, Drouet L, Soria C, et al Risk factors and outcomes for atherothrombotic disease in French patients: the RIVAGE study. RIsque VAsculaire Group d'Etude Thromb Res 1999 95(4):163 76 10498386
McCutchen JJ Bradycardia and hypotension producing transitory cerebral ischemia as a complication of cerebral angiography Dis Nerv Syst 1968 29(1):38 42 5635746
McDevitt E, Groch S, Wright I. A cooperative study of cerebrovascular disease. Circulation. 1959;20:215-223. [pmid: 13671708].
McDowell FH, McDevitt E, Wright IS. Anticoagulant therapy: Five years experience with an established cerebrovascular accident. Arch Neurol. 1963;8:209-214.
McGonigal G Aspirin for frail elderly stroke patients? [letter; comment] J R Coll Physicians Lond 1996 30(2):
McHenry MM Systemic arterial embolism in patients with mitral stenosis and minimal dyspnea Am J Cardiol 1966 18(2):169 74 5913010
McIvor J, Steiner TJ, Perkin GD, et al Neurological morbidity of arch and carotid arteriography in cerebrovascular disease. The influence of contrast medium and radiologist Br J Radiol 1987 60(710):117 22 3815006
McIvor J, Steiner TJ, Perkin GD, et al Neurological morbidity of cerebral arteriography in cerebrovascular disease; the effect of contrast medium and radiologist Ann Radiol 1987 30(2):125 7 3619331
McKittrick JE, Cisek PL, Pojunas KW, et al Are both color-flow duplex scanning and cerebral arteriography required prior to carotid endarterectomy? Ann Vasc Surg 1993 7(4):311 6 8268068
McLaren JT, Donaghue CC, Drezner AD Accuracy of carotid duplex examination to predict proximal and intrathoracic lesions Am J Surg 1996 172(2):149 50 8795518
McNamara RL, Lima JA, Whelton PK, et al Echocardiographic identification of cardiovascular sources of emboli to guide clinical management of stroke: a cost-effectiveness analysis Ann Intern Med 1997 127(9):775 87 9382398
Meissner I, Whisnant JP, Garraway WM Hypertension management and stroke recurrence in a community (Rochester, Minnesota, 1950-1979) Stroke 1988 19(4):459 63 3363575
Meissner I, Whisnant JP, Khandheria BK, et al Prevalence of potential risk factors for stroke assessed by transesophageal echocardiography and carotid ultrasonography: the SPARC study. Stroke Prevention: Assessment of Risk in a Community Mayo Clin Proc 1999 74(9):862 9 10488786
Melendez LJ, Chan KL, Cheung PK, et al Incidence of bacteremia in transesophageal echocardiography: a prospective study of 140 consecutive patients J Am Coll Cardiol 1991 18(7):1650 4 1960310
Meltzer RS, Guthaner D, Rakowski H, et al Diagnosis of left ventricular thrombi by two-dimensional echocardiography Br Heart J 1979 42(3):261 5 508446 482145
Meltzer RS, Visser CA, Fuster V Intracardiac thrombi and systemic embolization Ann Intern Med 1986 104(5):689 98 3516044
Meltzer RS, Visser CA, Kan G, et al Two-dimensional echocardiographic appearance of left ventricular thrombi with systemic emboli after myocardial infarction Am J Cardiol 1984 53(11):1511 3 6731294
Mendel H, Olbert F, Schlegl A, et al. Duplex ultrsonography, intravenous digital subtraction angiography, intraarterial digitan subtraction angiography and conventional angiography in assessing carotid atherosclerosis. Ann Radiol. 1987;30:115-20. [pmid: 3304102].
Mendel T, Pasierski T, Szwed H, et al Transesophageal echocardiographic findings in patients with anterior and posterior circulation infarcts Acta Neurol Scand 1998 97(1):63 7 9482680
Merino A, Hauptman P, Badimon L, et al Echocardiographic "smoke" is produced by an interaction of erythrocytes and plasma proteins modulated by shear forces J Am Coll Cardiol 1992 20(7):1661 8 1452941
Messina AG, Paranicas M, Fiamengo S, et al Risk of dysphagia after transesophageal echocardiography Am J Cardiol 1991 67(4):313 4 1990797
Millac P, Wood K Letter: Control of transient cerebral ischaemic attacks by heparin BMJ 1975 3(5983):
Miller CA Update on Warfarin: special considerations for the elderly Geriatr Nurs 1993 14(3):167 8 8508978
Miller JD, Grace MG, Russell DB, et al Complications of cerebral angiography and pneumography Radiology 1977 124(3):741 4 887769
Mitchell JB, Ballard DJ, Whisnant JP, et al Using physician claims to identify postoperative complications of carotid endarterectomy Health Serv Res 1996 31(2):141 52 8675436 1070110
Mittl RL, Broderick M, Carpenter JP, et al Blinded-reader comparison of magnetic resonance angiography and duplex ultrasonography for carotid artery bifurcation stenosis Stroke 1994 25(1):4 10 8266380
Mitusch R, Stierle U, Tepe C, et al Systemic embolism in aortic arch atheromatosis Eur Heart J 1994 15(10):1373 80 7821315
Mohr JP, Caplan LR, Melski J. The Harvard Cooperative Stroke registry: A prospective registry. Neurology. 1978;28:754-762. [pmid: 567291].
Mohr JP, Sacco RL, Hauser WA, et al Aspirin, warfarin, and stroke prevention [letter] Lancet 1988 1(8582):40 9
Mohr JP, Thompson JL, Lazar RM, et al A comparison of warfarin and aspirin for the prevention of recurrent ischemic stroke N Engl J Med 2001 345(20):1444 51 11794192
Moneta GL, Edwards JM, Chitwood RW, et al Correlation of North American Symptomatic Carotid Endarterectomy Trial (NASCET) angiographic definition of 70% to 99% internal carotid artery stenosis with duplex scanning J Vasc Surg 1993 17(1):152 7 discussion 157 9 8421332
Mononen H, Lepojarvi MV, Kallantranta T. Early neurophychological outcome after carotid endarterectomy. Eur Neurol. 1990;30:328-33. [pmid: 2289509].
Moran KT, Persson AV Adverse reactions to duplex scanning Lancet 1987 2(8571):134 1
Morgenstern LB, Fox AJ, Sharpe BL, et al The risks and benefits of carotid endarterectomy in patients with near occlusion of the carotid arteryNorth American Symptomatic Carotid Endarterectomy Trial (NASCET) Group.Neurology 1997 48(4):911 5 9109876
Moroney JT, Bagiella E, Paik MC, et al Risk factors for early recurrence after ischemic stroke: the role of stroke syndrome and subtype Stroke 1998 29(10):2118 24 9756592
Moroney JT, Bagiella E, Tatemichi TK, et al Dementia after stroke increases the risk of long-term stroke recurrence Neurology 1997 48(5):1317 25 9153465
Moroney JT, Tseng CL, Paik MC, et al Treatment for the secondary prevention of stroke in older patients: the influence of dementia status J Am Geriatr Soc 1999 47(7):824 9 10404926
Morrissey J Center is key to administering anticoagulent safely and easily Mod Healthc 1994 24(51):19 26 10131375
Mugge A, Daniel WG, Haverich A, et al Diagnosis of noninfective cardiac mass lesions by two-dimensional echocardiography. Comparison of the transthoracic and transesophageal approaches Circulation 1991 83(1):70 8 1984900
Mukherjee D Carotid endarterectomy: changing practice patterns [published erratum appears in J Cardiovasc Surg (Torino) 1999 Jun;40(3):465] J Cardiovasc Surg 1998 39(6):703 7 9972885
Musser DJ, Calligaro KD, Dougherty MJ, et al Safety and cost-efficiency of 24-hour hospitalization for carotid endarterectomy Ann Vasc Surg 1996 10(2):143 6 8733866
Muto PM, Welch HJ, Mackey WC, et al Evaluation of carotid artery stenosis: is duplex ultrasonography sufficient? J Vasc Surg 1996 24(1):17 22 discussion 22 4 8691519
Muuronen A Outcome of surgical treatment of 110 patients with transient ischemic attack Stroke 1984 15(6):959 964 6506124
Naggar CZ, Pearson WN, Seljan MP Frequency of complications of mitral valve prolapse in subjects aged 60 years and older Am J Cardiol 1986 58(13):1209 12 3788809
Nair CK, Thomson W, Ryschon K, et al Long-term follow-up of patients with echocardiographically detected mitral anular calcium and comparison with age- and sex-matched control subjects Am J Cardiol 1989 63(7):465 70 2916432
Naqvi N, Popp RL, Coltart DJ Diagnosis of left ventricular thrombus by two-dimensional echocardiography Eur J Cardiol 1980 11(3):235 9 7389805
Natterson PD, Stevenson WG, Saxon LA, et al Risk of arterial embolization in 224 patients awaiting cardiac transplantation Am Heart J 1995 129(3):564 70 7872188
Naylor AR, John T, Howlett J, et al Fate of the non-operated carotid artery after contralateral endarterectomy Br J Surg 1995 82(1):44 8 7881954
Naylor AR, John T, Howlett J, et al Surveillance imaging of the operated artery does not alter clinical outcome following carotid endarterectomy Br J Surg 1996 83(4):522 6 8665249
Neale ML, Chambers JL, Kelly AT, et al Reappraisal of duplex criteria to assess significant carotid stenosis with special reference to reports from the North American Symptomatic Carotid Endarterectomy Trial and the European Carotid Surgery Trial J Vasc Surg 1994 20(4):642 9 7933267
Nendaz M, Sarasin FP, Bogousslavsky J How to prevent stroke recurrence in patients with patent foramen ovale: anticoagulants, antiaggregants, foramen closure, or nothing? Eur Neurol 1997 37(4):199 204 9208257
Nendaz MR, Sarasin FP, Junod AF, et al Preventing stroke recurrence in patients with patent foramen ovale: antithrombotic therapy, foramen closure, or therapeutic abstention? A decision analytic perspective Am Heart J 1998 135(3):532 41 9506341
Nicholas GG, Osborne MA, Jaffe JW, et al Carotid artery stenosis: preoperative noninvasive evaluation in a community hospital J Vasc Surg 1995 22(1):9 16 7602719
Nicholls SC, Phillips DJ, Bergelin RO, et al Carotid endarterectomy. Relationship of outcome to early restenosis J Vasc Surg 1985 2(3):375 81 3889378
Nieto F, Castano L, Martin-Luengo C, et al Detection of spontaneous echo contrast in pulmonary artery and paradoxical cerebroembolism [letter] Eur Heart J 1995 16(12):2012 3 8682049
Nighoghossian N, Derex L, Perinetti M, et al Course of valvular strands in patients with stroke: cooperative study with transesophageal echocardiography Am Heart J 1998 136(6):1065 9 9842021
Nighoghossian N, Perinetti M, Barthelet M, et al Potential cardioembolic sources of stroke in patients less than 60 years of age Eur Heart J 1996 17(4):590 4 8733093
Nikutta P, Mantey-Stiers F, Becht I, et al Risk of bacteremia induced by transesophageal echocardiography: analysis of 100 consecutive procedures J Am Soc Echocardiogr 1992 5(2):168 72 1571172
Nishide M, Irino T, Gotoh M, et al Cardiac abnormalities in ischemic cerebrovascular disease studied by two-dimensional echocardiography Stroke 1983 14(4):541 5 6658929
Nishimura RA, McGoon MD, Shub C, et al Echocardiographically documented mitral-valve prolapse. Long-term follow-up of 237 patients N Engl J Med 1985 313(21):1305 9 4058522
Norris JW, Hachinski VC, Froggatt GM Diagnosis of cerebral embolism [letter] N Engl J Med 1976 295(18):
Norris JW, Zhu CZ, Bornstein NM, et al Vascular risks of asymptomatic carotid stenosis Stroke 1991 22(12):1485 90 1962321
Norrving B, Cronqvist S. Doppler examination of the carotid arteries A comparative study with angiography. Acta Neurol Scand. 1981;64:241-52. [pmid: 7315193].
Norrving B, Nilsson B Carotid artery occlusion: acute symptoms and long-term prognosis Neurol Res 1981 3(3):229 36 6122174
Nunn DB Carotid endarterectomy in patients with territorial transient ischemic attacks J Vasc Surg 1988 8(4):447 52 3172381
Nussbaum M, Moschos CB Anticoagulants and Anticoagulation Med Clin North Am 1976 60(5):855 69 781413
Nye DA Mitral valve prolapse and cerebral ischemia events [letter] N Engl J Med 1980 302(24):
O'Brien PJ, Thiemann DR, McNamara RL, et al Usefulness of transesophageal echocardiography in predicting mortality and morbidity in stroke patients without clinically known cardiac sources of embolus Am J Cardiol 1998 81(9):1144 51 9605057
Obuchowski NA, Modic MT, Magdinec M, et al Assessment of the efficacy of noninvasive screening for patients with asymptomatic neck bruits Stroke 1997 28(7):1330 9 9227679
O'Connor GT, Plume SK, Olmstead EM, et al A regional intervention to improve the hospital mortality associated with coronary artery bypass graft surgeryThe Northern New England Cardiovascular Disease Study Group.JAMA 1996 275(11):841 6 8596221
Oddone E, Brass LM, Booss J, et al Quality Enhancement Research Initiative in stroke: prevention, treatment, and rehabilitation Med Care 2000 38(6 Suppl 1):I92 104 10843274
Oddone E, Horner R, Diem S, et al Understanding racial variation in utilization of carotid endarterectomy: role of clinical factors J Natl Med Assoc 1998 90(1):25 33 9473926
Oddone EZ, Horner RD, Monger ME, et al Racial variations in the rates of carotid angiography and endarterectomy in patients with stroke and transient ischemic attack Arch Intern Med 1993 153(24):2781 6 8257254
Oddone EZ, Horner RD, Sloane R, et al Race, presenting signs and symptoms, use of carotid artery imaging, and appropriateness of carotid endarterectomy Stroke 1999 30(7):1350 6 10390306
O'Donnell TF, Jr., Callow AD, Willet C, et al The impact of coronary artery disease on carotid endarterectomy Ann Surg 1983 198(6):705 12 6605729 1353218
Ofili EO, Rich MW Safety and usefulness of transesophageal echocardiography in persons aged greater than or equal to 70 years Am J Cardiol 1990 66(17):1279 80 2239741
Oh JK, Seward JB, Khandheria BK, et al Transesophageal echocardiography in critically ill patients Am J Cardiol 1990 66(20):1492 5 2251998
Olinger CP, Brott TG, Barsan WG, et al Use of ancrod in acute or progressing ischemic cerebral infarction Ann Emerg Med 1988 17(11):1208 9 3056131
Olivecrona H Complications of cerebral angiography Neuroradiology 1977 14(4):175 81 600381
Olson JD, Goldenberg IF, Pedersen W, et al Exclusion of atrial thrombus by transesophageal echocardiography J Am Soc Echocardiogr 1992 5(1):52 6 1739471
Olsson JE, Brechter C, Backlund H, et al Anticoagulant vs anti-platelet therapy as prophylactic against cerebral infarction in transient ischemic attacks Stroke 1980 11(1):4 9 7355429
Olsson JE, Muller R, Berneli S Long-term anticoagulant therapy for TIAs and minor strokes with minimum residuum Stroke 1976 7(5):444 51 60808
Omran H, Rang B, Schmidt H, et al Incidence of left atrial thrombi in patients in sinus rhythm and with a recent neurologic deficit Am Heart J 2000 140(4):658 62 11011342
Orencia AJ, Petty GW, Khandheria BK, et al Risk of stroke with mitral valve prolapse in population-based cohort study Stroke 1995 26(1):7 13 7839400
Orencia AJ, Petty GW, Khandheria BK, et al Mitral valve prolapse and the risk of stroke after initial cerebral ischemia Neurology 1995 45(6):1083 6 7783867
Orgera M, O'Malley P, Taylor A. Secondary prevention of cerebral ischemia in patent foramen ovale: systematic review and meta-analysis. South Med J. 2001;94:699-703. [pmid: 11531177].
Ossemann M, Laloux P, Marchandise B, et al Association between stroke and atrial septal aneurysm assessed by transesophageal echocardiography in a cardiologic population Acta Neurol Belg 1995 95(3):170 7 7484054
Ott DA, Cooley DA, Chapa L, et al Carotid endarterectomy without temporary intraluminal shunt. Study of 309 consecutive operations Ann Surg 1980 191(6):708 14 7387232 1344778
Otto CM. Textbook of Clinical Echocardiography. 2nd ed. Philadelphia: W.B. Saunders. 2000. [pmcid: 384376].
Overell JR, Bone I, Lees KR Interatrial septal abnormalities and stroke: a meta-analysis of case-control studies Neurology 2000 55(8):1172 9 11071496
Ozaki CK, Irwin PB, Flynn TC, et al Surgical decision making for carotid endarterectomy and contemporary magnetic resonance angiography Am J Surg 1999 178(3):182 4 10527434
Ozer N, Tokgozoglu L, Ovunc K, et al Left atrial appendage function in patients with cardioembolic stroke in sinus rhythm and atrial fibrillation J Am Soc Echocardiogr 2000 13(7):661 5 10887350
Ozeren A, Acarturk E, Sarica Y, et al Transesophageal echocardiography in various ischemic stroke subtypes Jpn Heart J 1997 38(2):199 206 9201107
Paciaroni M, Eliasziw M, Sharpe BL, et al Long-term clinical and angiographic outcomes in symptomatic patients with 70% to 99% carotid artery stenosis Stroke 2000 31(9):2037 42 10978026
Pan XM, Saloner D, Reilly LM, et al Assessment of carotid artery stenosis by ultrasonography, conventional angiography, and magnetic resonance angiography: correlation with ex vivo measurement of plaque stenosis J Vasc Surg 1995 21(1):82 8 discussion 88 9 7823365
Panagiotopoulos K, Toumanidis S, Saridakis N, et al Left atrial and left atrial appendage functional abnormalities in patients with cardioembolic stroke in sinus rhythm and idiopathic atrial fibrillation J Am Soc Echocardiogr 1998 11(7):711 9 9692528
Papavasiliou AK, Magnadottir HB, Gonda T, et al Clinical outcomes after carotid endarterectomy: comparison of the use of regional and general anesthetics J Neurosurg 2000 92(2):291 6 10659017
Parkin P, Kendall B, Marshall J, et al. Amaurosis fugax: some aspects of management. J Neurol Neurosurg Psychiatry. 1982;45:1-6. [pmid: 7062065].
Parkin PJ Anticoagulants and stroke prevention: the current evidence N Z Med J 1990 103(895):368 9 2200988
Patel MR, Kuntz KM, Klufas RA, et al Preoperative assessment of the carotid bifurcation. Can magnetic resonance angiography and duplex ultrasonography replace contrast arteriography? Stroke 1995 26(10):1753 8 7570720
Patel ST, Haser PB, Korn P, et al Is carotid endarterectomy cost-effective in symptomatic patients with moderate (50% to 69%) stenosis? J Vasc Surg 1999 30(6):1024 33 10587386
Patel ST, Kuntz KM, Kent KC Is routine duplex ultrasound surveillance after carotid endarterectomy cost-effective? Surgery 1998 124(2):343 51 discussion 351 2 9706158
Paty PS, Darling RC, 3rd, Woratyla S, et al Timing of carotid endarterectomy in patients with recent stroke Surgery 1997 122(4):850 4 discussion 854 5 9347866
Pavone P, Marsili L, Catalano C, et al. Carotid arteries: evaluation with low-field strength MR angiography. Radiology. 1992;184:401-4. [pmid: 1620836].
Pearce J, Gubbay SS, Walton J. Long-term anticoagulant therapy in transient ischaemic attacks. Lancet. 1965;1:6-9. [pmid: 14246697].
Pearson AC, Castello R, Labovitz AJ Safety and utility of transesophageal echocardiography in the critically ill patient Am Heart J 1990 119(5):1083 9 2330866
Pearson AC, Labovitz AJ, Tatineni S, et al Superiority of transesophageal echocardiography in detecting cardiac source of embolism in patients with cerebral ischemia of uncertain etiology J Am Coll Cardiol 1991 17(1):66 72 1987242
Pearson AC, Nagelhout D, Castello R, et al Atrial septal aneurysm and stroke: a transesophageal echocardiographic study J Am Coll Cardiol 1991 18(5):1223 9 1918699
Peiper C, Nowack J, Ktendis K. Eversion endarterectomy versus open thromboendarterectomy and patch plasty for the treatment of internal carotid artery stenosis. Eur J Vasc Endovasc Surg. 1999;18:339-343. [pmid: 10550270].
Pelz DM Complication rates of DSA and conventional film cerebral angiography [letter; comment] Radiology 1992 185(3):
Pereira AC, Warburton E Heparin vs aspirin in acute ischaemic stroke [letter; comment] Lancet 2000 356(9223):
Perkins JM, Galland RB, Simmons MJ, et al Carotid duplex imaging: variation and validation Br J Surg 2000 87(3):320 2 10718801
Perler BA. The impact of advanced age on the results of carotid endarterectomy: an outcome analysis. J Am Coll Surg. 1996;183:559-564. [pmid: 8957457].
Petty GW, Brown RD, Jr., Whisnant JP, et al Ischemic stroke: outcomes, patient mix, and practice variation for neurologists and generalists in a community Neurology 1998 50(6):1669 78 9633709
Petty GW, Brown RD, Jr., Whisnant JP, et al Survival and recurrence after first cerebral infarction: a population-based study in Rochester, Minnesota, 1975 through 1989 Neurology 1998 50(1):208 16 9443482
Petty GW, Brown RD, Jr., Whisnant JP, et al Frequency of major complications of aspirin, warfarin, and intravenous heparin for secondary stroke prevention. A population-based study Ann Intern Med 1999 130(1):14 22 9890845
Petty GW, Brown RD, Jr., Whisnant JP, et al Ischemic stroke subtypes : a population-based study of functional outcome, survival, and recurrence Stroke 2000 31(5):1062 8 10797166
Petty GW, Khandheria BK, Chu CP, et al Patent foramen ovale in patients with cerebral infarction. A transesophageal echocardiographic study Arch Neurol 1997 54(7):819 22 9236569
Petty GW, Orencia AJ, Khandheria BK, et al A population-based study of stroke in the setting of mitral valve prolapse: risk factors and infarct subtype classification Mayo Clin Proc 1994 69(7):632 4 8015325
Petty GW, Tatemichi TK, Sacco RL, et al Fatal or severely disabling cerebral infarction during hospitalization for stroke or transient ischemic attack J Neurol 1990 237(5):306 9 2230846
Pexman JH, Coates RK Amnesia after femorocerebral angiography AJNR Am J Neuroradiol 1983 4(4):979 83 6410884
Phillips P New pharmaceutical approaches to stroke prevention, treatment [news] JAMA 1999 281(22):2075 6 10367806
Pinede L, Duhaut P, Loire R Clinical presentation of left atrial cardiac myxoma. A series of 112 consecutive cases Medicine 2001 80(3):159 72 11388092
Plotrowski J, Bernard V, Rubin JR. Timing of carotid endarterectomy after acute stroke. J Vasc Surg. 1990;11:45-52. [pmid: 2296104].
Poindexter JJ, Shah P, Clauss R, et al. The clinical study of carotid duplex scanning. J Cardiovasc Surg. 1991;32:64-8. [pmid: 2010456].
Polak J, Bajakian R, O'Leary D, et al. Detection of internal carotid stenosis: comparison of MR angiography, color Doppler sonography, and arteriography. Radiology. 1992;182:35-40. [pmid: 1727306].
Polak JF, O'Leary DH, Kronmal RA, et al Sonographic evaluation of carotid artery atherosclerosis in the elderly: relationship of disease severity to stroke and transient ischemic attack Radiology 1993 188(2):363 70 8327679
Pollick C, Wilansky S, Parker S Mitral valve prolapse: clinical and echocardiographic perspective Can Med Assoc J 1986 135(4):277 80 3730992 1491435
Pongratz G, Henneke KH, von der Grun M, et al Risk of endocarditis in transesophageal echocardiography Am Heart J 1993 125(1):190 3 8417517
Poole RM, Chimowitz MI Ischemic stroke and TIA: clinical clues to common causes Geriatrics 1994 49(6):37 42
Pop G, Sutherland GR, Koudstaal PJ, et al Transesophageal echocardiography in the detection of intracardiac embolic sources in patients with transient ischemic attacks Stroke 1990 21(4):560 5 2326837
Popp RL, Winters WL, Jr Clinical competence in adult echocardiography. A statement for physicians from the ACP/ACC/AHA Task Force on Clinical Privileges in Cardiology J Am Coll Cardiol 1990 15(7):1465 8 2345225
Portnoi VA Warfarin therapy in the nursing home [letter; comment] Arch Intern Med 1997 157(22):2664 5 9531239
Portnoi VA Warfarin treatment [letter; comment] J Am Geriatr Soc 1998 46(7):927 8 9670888
Prencipe M, Culasso F, Rasura M, et al Long-term prognosis after a minor stroke: 10-year mortality and major stroke recurrence rates in a hospital-based cohort Stroke 1998 29(1):126 32 9445340
Prestigiacomo CJ, Connolly ES, Quest DO Use of carotid ultrasound as a preoperative assessment of extracranial carotid artery blood flow and vascular anatomy Neurosurg Clin N Am 1996 7(4):577 87 8905773
Pritz M. Carotid endarterectomy after recent stroke: preliminary observations in patients undergoing early surgery. Neurosurgery. 1986;19:604-609. [pmid: 3785598].
Pullicino P Pathogenesis of stroke after nonanterior myocardial infarction [letter; comment] J Am Coll Cardiol 1995 25(6):1476 7 7722155
Putman SF, Adams HP, Jr Usefulness of heparin in initial management of patients with recent transient ischemic attacks Arch Neurol 1985 42(10):960 2 4038103
Ramadan NM Biologic responses to antithrombotic, anticoagulant, or fibrinolytic agents may differ in elderly patients [letter] Stroke 1993 24(1):
Ramirez G, O'Neill WM, Jr., Lambert R, et al Cholesterol embolization: a complication of angiography Arch Intern Med 1978 138(9):1430 2 686939
Ranger WR, Glover JL, Bendick PJ Carotid endarterectomy based on preoperative duplex ultrasound Am Surg 1995 61(7):548 54 discussion 554 5 7793732
Ranoux D, Cohen A, Cabanes L, et al. Patent foramen ovale: is stroke due to paradoxical embolism?. Stroke. 1993;24:31-34. [pmid: 8418547].
Rasanen HT, Manninen HI, Vanninen RL, et al Mild carotid artery atherosclerosis: assessment by 3-dimensional time-of-flight magnetic resonance angiography, with reference to intravascular ultrasound imaging and contrast angiography Stroke 1999 30(4):827 33 10187887
Raskind R, Weiss SR, Wermuth R, et al Complications of cerebral angiography: preliminary report of 432 examinations Angiology 1970 21(7):447 50 5430296
Ratliff D, Hames T, Humphries K, et al. The reliability of Doppler ultrasound techniques in the assessment of carotid disease. Angiology. 1985;36:333-40. [pmid: 3896047].
Rauh R, Fischereder M, Spengel FA Transesophageal echocardiography in patients with focal cerebral ischemia of unknown cause Stroke 1996 27(4):691 4 8614932
Read RC, Finch RG, Donald FE, et al Infective endocarditis after transesophageal echocardiography [letter; comment] Circulation 1993 87(4):142 6
Reeder GS, Lengyel M, Tajik AJ, et al Mural thrombus in left ventricular aneurysm: incidence, role of angiography, and relation between anticoagulation and embolization Mayo Clin Proc 1981 56(2):77 81 7464234
Reichel F Anticoagulants and cerebral embolism JAMA 1968 203(1):
Reilly L, Ehrenfeld W, Stoney R. Carotid digital subtraction angiography: The comparative roles of intra-arterial and intravenous imaging. Surgery. 1984;96:909-917. [pmid: 6387992].
Rem JA, Hachinski VC, Boughner DR, et al Value of cardiac monitoring and echocardiography in TIA and stroke patients Stroke 1985 16(6):950 6 4089926
Remonda L, Heid O, Schroth G Carotid artery stenosis, occlusion, and pseudo-occlusion: first-pass, gadolinium-enhanced, three-dimensional MR angiography--preliminary study Radiology 1998 209(1):95 102 9769818
Reynen K Cardiac myxomas N Engl J Med 1995 333(24):1610 7 7477198
Ricci S, Celani MG, Guercini G, et al First-year results of a community-based study of stroke incidence in Umbria, Italy Stroke 1989 20(7):853 7 2749844
Ricco JB, Gauthier JB, Richer JP, et al The evolution of carotid and coronary artery disease after operation for carotid stenosis Ann Vasc Surg 1992 6(5):408 12 1467178
Richardson JD, Main KA Carotid endarterectomy in the elderly population: a statewide experience J Vasc Surg 1989 9(1):65 73 2911143
Ricotta JJ, Hargadon T, O'Brien-Irr M Cost management strategies for carotid endarterectomy Am J Surg 1998 176(2):188 92 9737630
Ricotta JJ, Nanni KM, Green RM, et al Use of oculopneumoplethysmography (OPG-Gee) following carotid endarterectomy J Vasc Surg 1985 2(3):415 8 3999231
Rihal CS, Gersh BJ, Whisnant JP, et al Influence of coronary heart disease on morbidity and mortality after carotid endarterectomy: a population-based study in Olmsted County, Minnesota (1970-1988) [published erratum appears in J Am Coll Cardiol 1992 Nov 1;20(5):1304] J Am Coll Cardiol 1992 19(6):1254 60 1564225
Riles TS, Eidelman EM, Litt AW, et al Comparison of magnetic resonance angiography, conventional angiography, and duplex scanning Stroke 1992 23(3):341 6 1542893
Ringelstein EB Skepticism toward carotid ultrasonography. A virtue, an attitude, or fanaticism? [letter; comment] Stroke 1995 26(10):1743 6 7570718
Robbins J, Sagar K, French M, et al Influence of echocardiography on management of patients with systemic emboli Stroke 1983 14(4):546 9 6419417
Roberts JK, Omarali I, Di Tullio MR, et al Valvular strands and cerebral ischemia. Effect of demographics and strand characteristics Stroke 1997 28(11):2185 8 9368562
Robertson WD, Nugent RA, Russell DB, et al Clinical experience with Hexabrix in cerebral angiography Invest Radiol 1984 19(6 Suppl):S308 11 6511275
Roden-Jullig A The clinical course and outcome in patients with acute ischaemic stroke and transient ischaemic attack in relation to severe carotid disease J Intern Med 1997 242(5):355 60 9408062
Rodgers A, MacMahon S, Gamble G, et al Blood pressure and risk of stroke in patients with cerebrovascular diseaseThe United Kingdom Transient Ischaemic Attack Collaborative Group.BMJ 1996 313(7050):
Rodgers W, Root HD. Cranial nerve injuries after carotid artery endarterectomy. South Med J. 1988;81:1006-9. [pmid: 3406783].
Rogers PH, Sherry S Current status of antithrombotic therapy in cardiovascular disease Prog Cardiovasc Dis 1976 19(3):235 53 790462
Rogers PN, Goldberg JA, Reid E, et al Outcome of TIAs of unknown aetiology following non-invasive evaluation Eur J Vasc Surg 1989 3(2):107 11 2653873
Roijer A, Lindgren A, Algotsson L, et al Cardiac changes in stroke patients and controls evaluated with transoesophageal echocardiography Scand Cardiovasc J 1997 31(6):329 37 9455781
Roijer A, Lindgren A, Rudling O, et al Potential cardioembolic sources in an elderly population without stroke. A transthoracic and transoesophageal echocardiographic study in randomly selected volunteers Eur Heart J 1996 17(7):1103 11 8809529
Roldan CA, Shively BK, Crawford MH Valve excrescences: prevalence, evolution and risk for cardioembolism J Am Coll Cardiol 1997 30(5):1308 14 9350932
Rosario JA, Hachinski VC, Lee DH, et al Adverse reactions to duplex scanning Lancet 1987 2(8566):102 3
Rosenbloom M, Friedman S, Lamparello P, et al. Glossopharyngeal nerve injury complicating carotid endarterectomy. J Vasc Surg. 1987;5:469-71. [pmid: 3509601].
Rosenthal D, Borrero E, Clark MD, et al Carotid endarterectomy after reversible ischemic neurologic deficit or stroke: is it of value? J Vasc Surg 1988 8(4):527 34 3172388
Rosenthal D, Zeichner WD, Lamis PA, et al Neurologic deficit after carotid endarterectomy: pathogenesis and management Surgery 1983 94(5):776 80 6635942
Rothrock JF, Dittrich HC, McAllen S, et al Acute anticoagulation following cardioembolic stroke Stroke 1989 20(6):730 4 2728037
Rothwell P. Can overall results of clinical trials be applied to all patients?. Lancet. 1995;345:1616-1619. [pmid: 7783541].
Rothwell PM, Gibson RJ, Slattery J, et al Equivalence of measurements of carotid stenosis. A comparison of three methods on 1001 angiogramsEuropean Carotid Surgery Trialists' Collaborative Group.Stroke 1994 25(12):2435 9 7974586
Rothwell PM, Gibson RJ, Slattery J, et al Prognostic value and reproducibility of measurements of carotid stenosis. A comparison of three methods on 1001 angiogramsEuropean Carotid Surgery Trialists' Collaborative Group.Stroke 1994 25(12):2440 4 7974587
Rothwell PM, Slattery J, Warlow CP A systematic comparison of the risks of stroke and death due to carotid endarterectomy for symptomatic and asymptomatic stenosis Stroke 1996 27(2):266 9 8571421
Rothwell PM, Slattery J, Warlow CP A systematic review of the risks of stroke and death due to endarterectomy for symptomatic carotid stenosis Stroke 1996 27(2):260 5 8571420
Rothwell PM, Slattery J, Warlow CP Clinical and angiographic predictors of stroke and death from carotid endarterectomy: systematic review BMJ 1997 315(7122):1571 7 9437274
Rothwell PM, Warlow CP Prediction of benefit from carotid endarterectomy in individual patients: a risk-modelling studyEuropean Carotid Surgery Trialists' Collaborative Group.Lancet 1999 353(9170):2105 10 10382694
Roudaut R, Lartigue MC, Texier-Maugein J, et al Incidence of bacteraemia or fever during transoesophageal echocardiography: a prospective study of 82 patients Eur Heart J 1993 14(7):936 40 8375419
Rubin JR, Pitluk HC, King TA. Carotid endarterectomy in a metropolitan community: the early results after 8535 operations. J Vasc Surg. 1988;7:256-260. [pmid: 3339771].
Ruby S, Robinson D, Lynch J, et al. Outcome analysis of carotid endarterectomy in Connecticut: the impact of volume and specialty. Ann Vasc Surg. 1996;10:22-26. [pmid: 8688292].
Ruff RL, Dougherty JH, Jr Evaluation of acute cerebral ischemia for anticoagulant therapy: computed tomography or lumbar puncture Neurology 1981 31(6):736 40 7195488
Rush M, Thomas M, Zyroff J, et al. Duplex scanning with continuous wave Doppler for carotid disease. J Clin Ultrasound. 1985;13:325-8. [pmid: 3924962].
Russell D, Bakke SJ, Nakstad P, et al A comparison of pulsed Doppler spectral analysis and intravenous digital subtraction angiography in the detection of carotid occlusive disease Acta Neurol Scand 1985 72(6):571 6 3913272
Russell JW, Biller J, Hajduczok ZD, et al Ischemic cerebrovascular complications and risk factors in idiopathic hypertrophic subaortic stenosis Stroke 1991 22(9):1143 7 1822968
Ryglewicz D, Baranska-Gieruszczak M, Czlonkowska A, et al Stroke recurrence among 30 days survivors of ischemic stroke in a prospective community-based study Neurol Res 1997 19(4):377 9 9263216
Sacco RL, Foulkes MA, Mohr JP, et al Determinants of early recurrence of cerebral infarction. The Stroke Data Bank Stroke 1989 20(8):983 9 2756550
Sacco RL, Hauser WA, Mohr JP, et al One-year outcome after cerebral infarction in whites, blacks, and Hispanics Stroke 1991 22(3):305 11 2003300
Sacco RL, Shi T, Zamanillo MC, et al Predictors of mortality and recurrence after hospitalized cerebral infarction in an urban community: the Northern Manhattan Stroke Study Neurology 1994 44(4):626 34 8164815
Sacco RL, Wolf PA, Kannel WB, et al Survival and recurrence following stroke. The Framingham study Stroke 1982 13(3):290 5 7080120
Sacquegena T, D'Addato M, Baldrati A, et al. Long-term prognosis after carotid endarterectomy. Eur Neurol. 1986;25:36-39.
Sadanandan S, Sherrid MV Clinical and echocardiographic characteristics of left atrial spontaneous echo contrast in sinus rhythm J Am Coll Cardiol 2000 35(7):1932 8 10841246
Salgado AV, Ferro JM, Gouveia-Oliveira A Long-term prognosis of first-ever lacunar strokes. A hospital-based study Stroke 1996 27(4):661 6 8614926
Samama MM, Desnoyers PC, Conard J, et al Acute ischemic stroke and heparin treatments Thromb Haemost 1997 78(1):173 9 9198148
Sameshima T, Futami S, Morita Y, et al Clinical usefulness of and problems with three-dimensional CT angiography for the evaluation of arteriosclerotic stenosis of the carotid artery: comparison with conventional angiography, MRA, and ultrasound sonography Surg Neurol 1999 51(3):301 8 discussion 308 9 10086495
Samsa GP, Bian J, Lipscomb J, et al Epidemiology of recurrent cerebral infarction: a medicare claims-based comparison of first and recurrent strokes on 2-year survival and cost Stroke 1999 30(2):338 49 9933269
Samsa GP, Reutter RA, Parmigiani G, et al Performing cost-effectiveness analysis by integrating randomized trial data with a comprehensive decision model: application to treatment of acute ischemic stroke J Clin Epidemiol 1999 52(3):259 71 10210244
Sandercock P, Dunbabin D Aspirin, warfarin, and recurrent stroke [letter; comment] Lancet 1991 338(8759):
Sandercock PA, van den Belt AG, Lindley RI, et al Antithrombotic therapy in acute ischaemic stroke: an overview of the completed randomised trials J Neurol Neurosurg Psychiatry 1993 56(1):17 25 8429318
Sandok BA, von Estorff I, Giuliani ER CNS embolism due to atrial myxoma: clinical features and diagnosis Arch Neurol 1980 37(8):485 8 7417040
Sanfilippo AJ, Picard MH, Newell JB, et al Echocardiographic assessment of patients with infectious endocarditis: prediction of risk for complications J Am Coll Cardiol 1991 18(5):1191 9 1918695
Sansoy V, Abbott RD, Jayaweera AR, et al Low yield of transthoracic echocardiography for cardiac source of embolism Am J Cardiol 1995 75(2):166 9 7810494
Sarasin FP, Gaspoz JM, Bounameaux H Cost-effectiveness of new antiplatelet regimens used as secondary prevention of stroke or transient ischemic attack Arch Intern Med 2000 160(18):2773 8 11025787
Sardanelli F, Zandrino F, Parodi RC, et al MR angiography of internal carotid arteries: breath-hold Gd-enhanced 3D fast imaging with steady-state precession versus unenhanced 2D and 3D time-of-flight techniques J Comput Assist Tomogr 1999 23(2):208 15 10096327
Sato Y, Mizoguchi K, Ohkita Y, et al Anticoagulant and thrombolytic therapy for cerebral embolism of cardiac origin Kurume Med J 1986 33(2):89 95 3821053
Sauve JS, Thorpe KE, Sackett DL, et al Can bruits distinguish high-grade from moderate symptomatic carotid stenosis? The North American Symptomatic Carotid Endarterectomy Trial Ann Intern Med 1994 120(8):633 7 8135446
Savino JS, Weiss S Safety of transesophageal echocardiography is still unclear [letter; comment] Anesthesiology 1990 73(2):366 7 2382869
Scharf RE, Hennerici M, Bluschke V, et al Cerebral ischemia in young patients: it is associated with mitral valve prolapse and abnormal platelet activity in vivo? Stroke 1982 13(4):454 8 6213070
Schluter M, Hinrichs A, Thier W, et al Transesophageal two-dimensional echocardiography: comparison of ultrasonic and anatomic sections Am J Cardiol 1984 53(8):1173 8 6702699
Schmidt P, Sliwka U, Simon SG, et al High-grade stenosis of the internal carotid artery assessed by color and power Doppler imaging J Clin Ultrasound 1998 26(2):85 9 9460636
Schneider B, Hanrath P, Vogel P, et al Improved morphologic characterization of atrial septal aneurysm by transesophageal echocardiography: relation to cerebrovascular events J Am Coll Cardiol 1990 16(4):1000 9 2212349
Schwarz GA, Schwartzman RJ, Joyner CR Atrial myxoma. Cause of embolic stroke Neurology 1972 22(11):1112 21 4673555
Schweizer P, Bardos P, Erbel R, et al. Detection of left atrial thrombi by echocardiography. Br Heart J. 1981;45:148-56. [pmid: 7459174]. [pmcid: 482503].
Scmidt EV, Smirnov VE, Ryabova VS Results of the seven-year prospective study of stroke patients Stroke 1988 19(8):942 9 3400105
Scott PJ Anticoagulant drugs in the elderly: the risks usually outweight the benefits BMJ 1988 297(6658):
Scriven AJ, Cobbe SM Hypoxaemia during transoesophageal echocardiography Br Heart J 1994 72(2):133 5 7917684 1025475
Sechtem U, Theissen P, Heindel W, et al Diagnosis of left ventricular thrombi by magnetic resonance imaging and comparison with angiocardiography, computed tomography and echocardiography Am J Cardiol 1989 64(18):1195 9 2683713
Seelig MH, Oldenburg WA, Chowla A, et al Use of intraoperative duplex ultrasonography and routine patch angioplasty in patients undergoing carotid endarterectomy [published erratum appears in Mayo Clin Proc 1999 Oct;74(10):1056] Mayo Clin Proc 1999 74(9):870 6 10488787
Serfaty JM, Chirossel P, Chevallier JM, et al Accuracy of three-dimensional gadolinium-enhanced MR angiography in the assessment of extracranial carotid artery disease AJR Am J Roentgenol 2000 175(2):455 63 10915694
Seto TB, Taira DA, Tsevat J, et al Cost-effectiveness of transesophageal echocardiographic-guided cardioversion: a decision analytic model for patients admitted to the hospital with atrial fibrillation J Am Coll Cardiol 1997 29(1):122 30 8996304
Seward JB, Khandheria BK, Oh JK, et al Transesophageal echocardiography: technique, anatomic correlations, implementation, and clinical applications Mayo Clin Proc 1988 63(7):649 80 3290590
Seward JB, Khandheria BK, Oh JK, et al Critical appraisal of transesophageal echocardiography: limitations, pitfalls, and complications J Am Soc Echocardiogr 1992 5(3):288 305 1622623
Shapiro L, Westgate C, Shine K, et al. Is cardiac ultrasound mandatory in patients with transient ischemic attacks?. BMJ. 1985;291:786-787. [pmid: 3929941]. [pmcid: 1417143].
Shaw DA, Venables GS, Cartlidge NE, et al Carotid endarterectomy in patients with transient cerebral ischaemia J Neurol Sci 1984 64(1):45 53 6376714
Shaw RB, Myers JK Carotid endarterectomy: a review of surgical practice in a community hospital Tex Med 1993 89(5):63 7 8342163
Sheiban I, Casarotto D, Trevi G, et al Two-dimensional echocardiography in the diagnosis of intracardiac masses: a prospective study with anatomic validation Cardiovasc Intervent Radiol 1987 10(3):157 61 3111698
Sheinart KF, Tuhrim S, Horowitz DR, et al Stroke recurrence is more frequent in Blacks and Hispanics Neuroepidemiology 1998 17(4):188 98 9701833
Shenoy MM, Dhala A, Khanna A Transesophageal echocardiography in emergency medicine and critical care Am J Emerg Med 1991 9(6):580 7 1930404
Shenoy MM, Vijaykumar PM, Friedman SA, et al Atrial septal aneurysm associated with systemic embolism and interatrial right-to-left shunt Arch Intern Med 1987 147(3):605 6 3827440
Sherman DG Cardiac embolism: the neurologist's perspective Am J Cardiol 1990 65(6):32C 37C
Sherman DG Heparin and heparinoids in stroke Neurology 1998 51(3 Suppl 3):S56 8 9744837
Sherman DG, Atkinson RP, Chippendale T, et al Intravenous ancrod for treatment of acute ischemic stroke: the STAT study: a randomized controlled trial. Stroke Treatment with Ancrod Trial JAMA 2000 283(18):2395 403 10815082
Sherman DG, Barbour P, Levy D, et al. Ancrod for the treatment of acute ischemic brain infarction. Stroke. 1994;25:1755-1759. [pmid: 8073455].
Sherman DG, Dyken ML, Fisher M, et al Cerebral embolism Chest 1986 89(2 Suppl):82S 98S 3510833
Shiran A, Goldstein SA, Zafar S, et al Determination of pretest probability for detection of a cardiovascular source of emboli by transesophageal echocardiography using clinical and transthoracic echocardiographic data Am J Cardiol 1998 81(12):1506 8 9645909
Shrestha NK, Moreno FL, Narciso FV, et al Two-dimensional echocardiographic diagnosis of left-atrial thrombus in rheumatic heart disease. A clinicopathologic study Circulation 1983 67(2):341 7 6848223
Shriver ME, Prockop LD The economic approach to the stroke work-up Curr Opin Neurol Neurosurg 1993 6(1):74 7 8428070
Shyu KG, Chen JJ, Huang ZS, et al Role of transesophageal echocardiography in the diagnostic assessment of cardiac sources of embolism in patients with acute ischemic stroke Cardiology 1994 85(1):53 60 7954558
Shyu KG, Hwang JJ, Lin SC, et al Prospective study of blood culture during transesophageal echocardiography Am Heart J 1992 124(6):1541 4 1462911
Siddiqui MA, Skolnick BE, Kochar GS Neurological deficits during duplex carotid imaging J Am Geriatr Soc 1996 44(3):338 9 8600216
Siegel R, Tresch DD, Keelan MH, et al Effects of anticoagulation on recurrent systemic emboli in mitral stenosis Am J Cardiol 1987 60(14):1191 2 3687755
Sillesen H, Bitsch K, Schroeder T, et al. Pulse multigated Doopler ultrasonography in the diagnosis of carotid artery disease. Stroke. 1988;19:846-51. [pmid: 2968688].
Silverstein A Arteriography of stroke. 3. Complications Arch Neurol 1966 15(2):206 10 5945975
Simons PC, Algra A, Eikelboom BC, et al Carotid artery stenosis in patients with peripheral arterial disease: the SMART studySMART Study Group.J Vasc Surg 1999 30(3):519 25 10477645
Sitzer M, Furst G, Fischer H, et al. Between-method correlation in quantifying internal carotid stenosis. Stroke. 1993;24:1513-8. [pmid: 8378955].
Sitzer M, Siebler M, Steinmetz H Non-invasive evaluation of internal carotid stenosis with colour doppler-assisted duplex imaging Clin Radiol 1996 51(Suppl 1):24 7 8605767
Sivenius J, Riekkinen PJ, Laakso M, et al European Stroke Prevention Study (ESPS): antithrombotic therapy is also effective in the elderly Acta Neurol Scand 1993 87(2):111 4 8442393
Skalpe IO Complications in cerebral angiography with iohexol (Omnipaque) and meglumine metrizoate (Isopaque cerebral) Neuradiology 1988 30(1):69 72
Skalpe IO, Anke IM Complications in cerebral angiography. A comparison between the non-ionic contrast medium iohexol and meglumine metrizoate (Isopaque Cerebral) Neuroradiology 1983 25(3):157 60 6350922
Skalpe IO, Lundervold A, Tjorstad K Cerebral angiography with non-ionic (metrizamide) and ionic (meglumine metrizoate) watersoluble contrast media. A comparative study with double blind technic Neuroradiology 1977 14(1):15 9 331137
Skalpe IO, Lundervold A, Tjorstad K Complications of cerebral angiography. Comparing metrizamide (Amipaque) and meglumine metrizoate (Isopaque Cerebral) Neuroradiology 1980 19(2):67 71 7366836
Slavin RE Best evidence synthesis: an intelligent alternative to meta-analysis J Clin Epidemiol 1995 48(1):9 18 7853053
Slosman F, Stolpen AH, Lexa FJ, et al Extracranial atherosclerotic carotid artery disease: evaluation of non-breath-hold three-dimensional gadolinium-enhanced MR angiography AJR Am J Roentgenol 1998 170(2):489 95 9456971
Sobel E, Alter M, Davanipour Z, et al Stroke in the Lehigh Valley: combined risk factors for recurrent ischemic stroke Neurology 1989 39(5):669 72 2710358
Soulez G, Therasse E, Robillard P, et al The value of internal carotid systolic velocity ratio for assessing carotid artery stenosis with Doppler sonography AJR Am J Roentgenol 1999 172(1):207 12 9888769
Spartera C, Morettini G, Marino G, et al Detection of internal carotid artery stenosis. Comparison of 2D-MR angiography, duplex scanning, and arteriography J Cardiovasc Surg 1993 34(3):209 13 8344970
Sporton SC, Holdright DR Echocardiography J R Coll Physicians Lond 1999 33(1):18 24 10192064
Sreerama V, Ivan LP, Dennery JM, et al Neurosurgical complications of anticoagulant therapy Can Med Assoc J 1973 108(3):305 7 4120581
Srinivasan J, Mayberg MR, Weiss DG, et al Duplex accuracy compared with angiography in the Veterans Affairs Cooperative Studies Trial for Symptomatic Carotid Stenosis Neurosurgery 1995 36(4):648 53 discussion 653 5 7596492
Srivastava TN, Undesser EK Transient ischemic attack after air contrast echocardiography in patients with septal aneurysm Ann Intern Med 1995 122(5):39 6
Staaf G, Samuelsson M, Lindgren A, et al Sensorimotor stroke; clinical features, MRI findings, and cardiac and vascular concomitants in 32 patients Acta Neurol Scand 1998 97(2):93 8 9517858
Stafford WJ, Petch J, Radford DJ Vegetations in infective endocarditis. Clinical relevance and diagnosis by cross sectional echocardiography Br Heart J 1985 53(3):310 3 3970787 481760
Starling MR, Crawford MH, Sorensen SG, et al Comparative value of invasive and noninvasive techniques for identifying left ventricular mural thrombi Am Heart J 1983 106(5 Pt 1):1143 9 6637770
Steckelberg JM, Khandheria BK, Anhalt JP, et al Prospective evaluation of the risk of bacteremia associated with transesophageal echocardiography Circulation 1991 84(1):177 80 2060093
Steckelberg JM, Murphy JG, Ballard D, et al Emboli in infective endocarditis: the prognostic value of echocardiography Ann Intern Med 1991 114(8):635 40 2003709
Steffens JC, Link J, Heller M Contrast-enhanced magnetic resonance angiography of the cervical arteries. A review Invest Radiol 1998 33(9):573 7 9766042
Stein JH, Marcus RH Utility of TEE for the evaluation of cerebral ischemia of uncertain origin [letter; comment] Arch Intern Med 1997 157(4):460 2
Steiner MM, Di Tullio MR, Rundek T, et al Patent foramen ovale size and embolic brain imaging findings among patients with ischemic stroke Stroke 1998 29(5):944 8 9596240
Steinke W, Kloetzsch C, Hennerici M. Carotid artery disease assessed by color Doppler flow imaging: correlation with standard Doppler sonography and angiography. AJNR Am J Neuroradiol. 1990;11:259-266. [pmid: 2107709].
Steinke W, Mangold J, Schwartz A, et al Mechanisms of infarction in the superficial posterior cerebral artery territory J Neurol 1997 244(9):571 8 9352455
Stephens N, Parsons A, Schofield P, et al. Randomised controlled trial of vitamin E in patients with coronary disease: Cambridge Heart Antioxidant Study (CHAOS). Lancet. 1996;347:781-86. [pmid: 8622332].
Sterpetti AV, Schultz RD, Feldhaus RJ, et al Natural history of recurrent carotid artery disease Surg Gynecol Obstet 1989 168(3):217 23 2645666
Stewart JA, Silimperi D, Harris P, et al Echocardiographic documentation of vegetative lesions in infective endocarditis: clinical implications Circulation 1980 61(2):374 80 7351063
Stoddard MF, Longaker RA The safety of transesophageal echocardiography in the elderly Am Heart J 1993 125(5 Pt 1):1358 62 8480589
Stollberger C Transesophageal echocardiography to assess embolic risk in patients with atrial fibrillation Ann Intern Med 1998 128(8):630 8 9537936
Stollberger C, Chnupa P, Kronik G, et al Transesophageal echocardiography to assess embolic risk in patients with atrial fibrillation. ELAT Study Group. Embolism in Left Atrial Thrombi Ann Intern Med 1998 128(8):630 8 9537936
Stone DA, Godard J, Corretti MC, et al Patent foramen ovale: association between the degree of shunt by contrast transesophageal echocardiography and the risk of future ischemic neurologic events Am Heart J 1996 131(1):158 61 8554004
Stone DA, Hawke MW, LaMonte M, et al Ulcerated atherosclerotic plaques in the thoracic aorta are associated with cryptogenic stroke: a multiplane transesophageal echocardiographic study Am Heart J 1995 130(1):105 8 7611098
Stone JA, Mukherji SK, Semelka R, et al Contrast-enhanced 3D FISP MR angiography of the aortic arch ostia: preliminary results J Comput Assist Tomogr 2000 24(3):369 74 10864070
Stordahl N, Linden C, Johnson BL, et al Magnetic resonance angiography is an accurate imaging adjunct to duplex ultrasound scan in patient selection for carotid endarterectomy J Vasc Surg 2000 32(3):429 38 discussion 439 40 10957649
Stratton JR, Lighty GW, Jr., Pearlman AS, et al Detection of left ventricular thrombus by two-dimensional echocardiography: sensitivity, specificity, and causes of uncertainty Circulation 1982 66(1):156 66 7083502
Stratton JR, Resnick AD Increased embolic risk in patients with left ventricular thrombi Circulation 1987 75(5):1004 11 3568301
Streifler JY, Eliasziw M, Fox AJ, et al Angiographic detection of carotid plaque ulceration. Comparison with surgical observations in a multicenter study. North American Symptomatic Carotid Endarterectomy Trial Stroke 1994 25(6):1130 2 8202969
Strik F. The complementary value of Doppler-ultrasonography and ocular pneumoplethysmography according to Gee (OPG-Gee) in carotid obstructions. Clin Neurol Neurosurg. 1988;90:227-33. [pmid: 3058370].
A randomized trial of anticoagulants versus aspirin after cerebral ischemia of presumed arterial originThe Stroke Prevention in Reversible Ischemia Trial (SPIRIT) Study Group.Ann Neurol 1997 42(6):857 65 9403477
Sullivan E, Cranley J. Noninvasive diagnosis of internal carotid artery occlusion. Am J Surg. 1983;146:577-80. [pmid: 6638263].
Suwanwela N, Can U, Furie KL, et al Carotid Doppler ultrasound criteria for internal carotid artery stenosis based on residual lumen diameter calculated from en bloc carotid endarterectomy specimens Stroke 1996 27(11):1965 9 8898799
Swanson PD, Calanchini PR, Dyken ML, et al A cooperative study of hospital frequency and character of transient ischemic attacks. II. Performance of angiography among six centers JAMA 1977 237(20):2202 6 576905
Sweeney KG, Pereira Gray DJ, Steele RJ, et al Commentary: Caution needed in introducing warfarin treatment [comment] BMJ 1995 311(7004):560 1 7663217
Syrek JR, Calligaro KD, Dougherty MJ, et al Five-step protocol for carotid endarterectomy in the managed health care era Surgery 1999 125(1):96 101 9889804
Takamoto T, Kim D, Urie PM, et al Comparative recognition of left ventricular thrombi by echocardiography and cineangiography Br Heart J 1985 53(1):36 42 3966950 481718
Takolander RJ, Bergentz SE, Ericsson BF Carotid artery surgery in patients with minor stroke Br J Surg 1983 70(1):13 6 6824875
Tam JW, Burwash I, Ascah K, et al Feasibility and complications of single-plane and biplane versus multiplane transesophageal imaging: a review of 2947 consecutive studies Can J Cardiol 1997 13(1):81 4 9039070
Tam JW, Lazarow N, Wolfe K Cost-effectiveness of echocardiography after stroke [letter] Ann Intern Med 1998 128(10):discussion
Tangkanakul C, Counsell CE, Warlow C Local versus general anaesthesia for carotid endarterectomy Cochrane Library Oxford, England: Update Software 2000(4).
Tangkanakul C, Counsell CE, Warlow C Local versus general anaesthesia for carotid endarterectomy (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
Taylor TN, Davis PH, Torner JC, et al Lifetime cost of stroke in the United States Stroke 1996 27(9):1459 66 8784113
Teague SM, Sharma MK Detection of paradoxical cerebral echo contrast embolization by transcranial Doppler ultrasound Stroke 1991 22(6):740 5 2057972
Tegeler CH, Downes TR Cardiac imaging in stroke Stroke 1991 22(9):1206 11 1926266
Tenenbaum A, Garniek A, Shemesh J, et al Dual-helical CT for detecting aortic atheromas as a source of stroke: comparison with transesophageal echocardiography Radiology 1998 208(1):153 8 9646807
Terent A Survival after stroke and transient ischemic attacks during the 1970s and 1980s Stroke 1989 20(10):1320 6 2799864
Terent A, Andersson Bl The outcome of patients with transient ischemic attacks and stroke treated with anticoagulants Acta Med Scand 1980 208(5):359 65 7457205
Tharakan J, Ahuja GK, Manchanda SC, et al Mitral valve prolapse and cerebrovascular accidents in the young Acta Neurol Scand 1982 66(3):295 302 7136491
The WARSS Clinical Trial Group. The warfarin aspirin recurrent stroke study (WARSS): initial results. Stroke. 2001;12:32-9.
Theiss W Anticoagulants: when and how? Pacing Clin Electrophysiol 1994 17(5 Pt 2):1011 5 7518587
Theodotou BC, Whaley R, Mahaley MS Complications following transfemoral cerebral angiography for cerebral ischemia. Report of 159 angiograms and correlation with surgical risk Surg Neurol 1987 28(2):90 2 3603359
Thijs VN, Albers GW Symptomatic intracranial atherosclerosis: outcome of patients who fail antithrombotic therapy Neurology 2000 55(4):490 7 10953179
Thompson JE Carotid endarterectomy, 1982--the state of the art Br J Surg 1983 70(6):371 6 6344957
Thompson JR, Simmons CR Arterial embolus. Manifestation of unsuspected myxoma JAMA 1974 228(7):864 5 4406303
Thomson KR, Thomson SM Complications of cerebral angiography in a teaching hospital Australas Radiol 1986 30(3):206 8 3813993
Thorvaldsen P, Asplund K, Kuulasmaa K, et al Stroke incidence, case fatality, and mortality in the WHO MONICA project. World Health Organization Monitoring Trends and Determinants in Cardiovascular Disease [published errata appear in Stroke 1995 Aug;26(8):1504 and 1995 Dec;26(12):2376] Stroke 1995 26(3):361 7 7886707
Thorvaldsen P, Davidsen M, Bronnum-Hansen H, et al Stable stroke occurrence despite incidence reduction in an aging population: stroke trends in the Danish Monitoring Trends and Determinants in Cardiovascular Disease (MONICA) population Stroke 1999 30(12):2529 34 10582973
Thygesen P, Christensen E, Dyrbye M, et al. Cerebral apoplexy: A clinical, radiological, electroencephalographic and pathological study with special reference to the prognosis of cerebral infarction and the result of long-term anticoagulant therapy. Dan Med Bull. 1964;11:233-257. [pmid: 14250709].
Tice FD, Slivka AP, Walz ET, et al Mitral valve strands in patients with focal cerebral ischemia Stroke 1996 27(7):1183 6 8685925
Timsit SG, Sacco RL, Mohr JP, et al Brain infarction severity differs according to cardiac or arterial embolic source Neurology 1993 43(4):728 33 8469331
Tischler MD, Vaitkus PT The ability of vegetation size on echocardiography to predict clinical complications: a meta-analysis J Am Soc Echocardiogr 1997 10(5):562 8 9203497
Todnem K, Vik-Mo H Cerebral ischemic attacks as a complication of heart disease: the value of echocardiography Acta Neurol Scand 1986 74(4):323 7 3811838
Toni D, Argentino C, Fieschi C Heparin versus aspirin in ischaemic stroke [letter] Lancet 2000 356(9228):discussion
Toole JF. Diagnostic techniques in the medical evaluation and treatment of transient ischemic attacks. Clin Neurosurg. 1975;22:148-62. [pmid: 1183107].
Toole JF, Janeway R, Choi K, et al Transient ischemic attacks due to atherosclerosis. A prospective study of 160 patients Arch Neurol 1975 32(1):5 12 1115659
Torvaldsen S, McCauley J, Patel A, et al. Assessment of cervical carotid artery disease. A comparison between the Doppler Echoflow and conventional angiography. Med J Aust. 1985;142:542-5. [pmid: 3887109].
Tos M, Rosenklint A Laryngeal complications of percutaneous cerebral angiography. Continued observations Acta Otolaryngol 1967 63(1):23 32 6030183
Toyoda K, Yasaka M, Nagata S, et al Aortogenic embolic stroke: a transesophageal echocardiographic approach Stroke 1992 23(8):1056 61 1636177
Toyoda K, Yasaka M, Nagata S, et al Transesophageal echocardiography for detecting intracardiac thrombi in embolic stroke Angiology 1993 44(5):376 83 8480915
Troeng T, Bergqvist D, Norrving B, et al Complications after carotid endarterectomy are related to surgical errors in less than one-fifth of cases. Swedvasc--The Swedish Vascular Registry and The Quality Committee for Carotid Artery Surgery Eur J Vasc Endovasc Surg 1999 18(1):59 64 10388641
Tsai LM, Chen JH, Fang CJ, et al Clinical implications of left atrial spontaneous echo contrast in nonrheumatic atrial fibrillation Am J Cardiol 1992 70(3):327 31 1632397
Tsuda Y, Kimura K, Yoneda S, et al Transient ischemic attacks: racial differences, treatment, and prognosis Neurol Res 1983 5(1):103 17 6140653
Tucker J, Gee W, Nicholas GG, et al. Accessory nerve injury during carotid endarterectomy. J Vasc Surg. 1987;5:440-4. [pmid: 3509598].
Tunick PA, Krinsky GA, Lee VS, et al Diagnostic imaging of thoracic aortic atherosclerosis AJR Am J Roentgenol 2000 174(4):1119 25 10749263
Tunick PA, Kronzon I Limitations of transoesophageal echocardiography in patients with focal cerebral ischaemic events [letter; comment] Br Heart J 1992 68(6):discussion 634 5
Tunick PA, Kronzon II The improved yield of transesophageal echocardiography over transthoracic echocardiography in patients with neurological events is largely due to the detection of aortic protruding atheromas Echocardiography 1992 9(5):491 5 10147790
Tunick PA, Perez JL, Kronzon I Protruding atheromas in the thoracic aorta and systemic embolization Ann Intern Med 1991 115(6):423 7 1872490
Tuomilehto J, Sarti C, Narva EV, et al The FINMONICA Stroke Register. Community-based stroke registration and analysis of stroke incidence in Finland, 1983-1985 Am J Epidemiol 1992 135(11):1259 70 1626542
Turnipseed WD, Kennell TW, Turski PA, et al Magnetic resonance angiography and duplex imaging: noninvasive tests for selecting symptomatic carotid endarterectomy candidates Surgery 1993 114(4):643 8 discussion 648 9 8211677
Turpie AG, Bloch R, Duke R. Heparin in the treatment of thromboembolic stroke. Ann N Y Acad Sci. 1989;556:406-15. [pmid: 2660688].
Ullal SR, Kluge TH, Hill JD, et al Left atrial thrombi in mitral valve disease J Thorac Cardiovasc Surg 1971 62(6):932 7 5129396
Vaitkus PT, Barnathan ES Embolic potential, prevention and management of mural thrombus complicating anterior myocardial infarction: a meta-analysis J Am Coll Cardiol 1993 22(4):1004 9 8409034
Van Camp G, Schulze D, Cosyns B, et al Relation between patent foramen ovale and unexplained stroke Am J Cardiol 1993 71(7):596 8 8438748
van Everdingen KJ, van der Grond J, Kappelle LJ Overestimation of a stenosis in the internal carotid artery by duplex sonography caused by an increase in volume flow J Vasc Surg 1998 27(3):479 85 9546233
van Merode T, Lodder J, Smeets F, et al. Accurate noninvasive method to diagnose minor atherosclerotic lesions in carotid artery bulb. Stroke. 1989;20:1336-40. [pmid: 2678613].
Vandenbogaerde J, De Bleecker J, Decoo D, et al Transoesophageal echo-Doppler in patients suspected of a cardiac source of peripheral emboli Eur Heart J 1992 13(1):88 94 1577038
Vanninen R, Manninen H, Soimakallio S Imaging of carotid artery stenosis: clinical efficacy and cost-effectiveness AJNR Am J Neuroradiol 1995 16(9):1875 83 8693989
Vanninen RL, Manninen HI, Partanen PK, et al How should we estimate carotid stenosis using magnetic resonance angiography? Neuroradiology 1996 38(4):299 305 8738083
Venables G Anticoagulation and stroke [letter] BMJ 1988 296(6638):
Vigman MP, Byrne RJ Cerebral complications of angiography for transient ischemia and stroke [letter] Neurology 1980 30(9):1018 9 7191532
Vigo J, Brau RH Carotid endarterectomy in Puerto Rico Boletin - Asociacion Medica de Puerto Rico 1992 84(4-5):128 31 1295500
Viitanen M, Eriksson S, Asplund K Risk of recurrent stroke, myocardial infarction and epilepsy during long-term follow-up after stroke Eur Neurol 1988 28(4):227 31 3416892
Visser CA, Kan G, David GK, et al Two dimensional echocardiography in the diagnosis of left ventricular thrombus. A prospective study of 67 patients with anatomic validation Chest 1983 83(2):228 32 6822107
Visser CA, Kan G, Meltzer RS, et al Embolic potential of left ventricular thrombus after myocardial infarction: a two-dimensional echocardiographic study of 119 patients J Am Coll Cardiol 1985 5(6):1276 80 3998310
Visser CA, Kan G, Meltzer RS, et al Long-term follow-up of left ventricular thrombus after acute myocardial infarction. A two-dimensional echocardiographic study in 96 patients Chest 1984 86(4):532 6 6478891
Voller H, Spielberg C, Schroder K, et al Frequency of positive blood cultures during transesophageal echocardiography Am J Cardiol 1991 68(15):1538 40 1746442
Voyce SJ, Aurigemma GP, Dahlberg S, et al A comparison of two-dimensional echocardiography vs carotid duplex scanning in older patients with cerebral ischemia Arch Intern Med 1992 152(10):2089 93 1417383
Vrethem M, Johansson I Prognosis in patients with transient ischaemic attacks and minor stroke associated with a normal angiogram Eur Neurol 1990 30(4):203 6 2209673
Wackenheim A. Visualization of the choroid plexuses of the lateral ventricles in the frontal projection in vertebral angiography. Neuroradiology. 1973;6:231-232. [pmid: 4772448].
Wain RA, Lyon RT, Veith FJ, et al Accuracy of duplex ultrasound in evaluating carotid artery anatomy before endarterectomy J Vasc Surg 1998 27(2):235 42 discussion 242 4 9510278
Wallace DC. Cerebral vascular disease in relation to long-term anticoagulant therapy. J Chronic Dis. 1964;17:527-537. [pmid: 14168625].
Walsh AC Arterial insufficiency of the brain: progression prevented by long-term anticoagulant therapy in eleven patients J Am Geriatr Soc 1969 17(1):93 104 4177824
Warlow C Secondary prevention of stroke Lancet 1992 339(8795):724 7 1347592
Warlow C, Fish P. Pulsed Doppler imaging of the carotid artery. J Neurol Sci. 1980;45:135-41. [pmid: 7359163].
Warner MF, Momah KI Routine transesophageal echocardiography for cerebral ischemia. Is it really necessary? Arch Intern Med 1996 156(15):1719 23 8694671
Wasserman D, Hobson RN, Lynch T, et al. Ultrasonic imaging and oculoplethysmography in diagnosis of carotid occlusive disease. Arch Surg. 1983;118:1161-3. [pmid: 6615199].
Waugh JR, Sacharias N Arteriographic complications in the DSA era Radiology 1992 182(1):243 6 1727290
Webster MW, Chancellor AM, Smith HJ, et al Patent foramen ovale in young stroke patients Lancet 1988 2(8601):11 2 2898621
Weinberger J, Azhar S, Danisi F, et al A new noninvasive technique for imaging atherosclerotic plaque in the aortic arch of stroke patients by transcutaneous real-time B-mode ultrasonography: an initial report Stroke 1998 29(3):673 6 9506611
Weintraub WS, Ba'albaki HA Decision analysis concerning the application of echocardiography to the diagnosis and treatment of mural thrombi after anterior wall acute myocardial infarction Am J Cardiol 1989 64(12):708 16 2679023
Wesbey G, Bergan J, Moreland S, et al. Cerebrovascular magnetic resonance angiography: a critical verification. J Vasc Surg. 1992;16:619-28. [pmid: 1404682].
Wessler S Anticoagulant therapy--1974 JAMA 1974 228(6):757 61 4406270
Wessler S, Yin E. Theory and practice of mini-dose heaprin in surgical patients. Circulation. 1973;47:671-676. [pmid: 4572381].
Wessler Sl. Cardiac embolic stroke: anticoagulating the elderly. Adv Exp Med Biol. 1987;214:291-8. [pmid: 3310545].
Whisnant J, Sandok B, Sundt T. Carotid endarterectomy for unilateral carotid system transient cerebral ischaemia. Mayo Clin Proc. 1983;58:171-175. [pmid: 6827861].
Whisnant JP, Cartlidge NE, Elveback LRl. Carotid and vertebral basilar transient ischemic attacks: effect of anticoagulants, hypertension, and cardiac disorders on stroke occurrence in a community. Trans Am Neurol Assoc. 1977;102:22-4. [pmid: 616107].
Whisnant JP, Matsumoto N, Elveback LR The effect of anticoagulant therapy on the prognosis of patients with transient cerebral ischemic attacks in a community: Rochester, Minnesota, 1955 through 1969 Mayo Clin Proc 1973 48(12):844 8 passim 4760666
White JE, Russell WL, Greer MS, et al Efficacy of screening MR angiography and Doppler ultrasonography in the evaluation of carotid artery stenosis Am Surg 1994 60(5):340 8 8161084
Whitney DG, Kahn E, Estes J, et al. Carotid artery surgery without a temporary indwelling shunt: 1917 consecutive procedures. Arch Surg. 1980;115:1393-1398. [pmid: 7436734].
Whittemore A. Carotid endarterectomy: an alternative apporach. Arch Surg. 1980;115:940-942. [pmid: 7396702].
Whittemore A, Ruby S, Couch N, et al Early carotid endarterectomy in patients with small fixed neurological deficits J Vasc Surg 1984 1(6):795 799 6492307
Whittemore AD, Mannick J Surgical treatment of carotid disease in patients with neurologic deficits J Vasc Surg 1987 5(6).
Whittmore A. Carotid endarterectomy: an alternative apporach. Arch Surg. 1980;115:940-942. [pmid: 7396702].
Wildermuth S, Knauth M, Brandt T, et al Role of CT angiography in patient selection for thrombolytic therapy in acute hemispheric stroke Stroke 1998 29(5):935 8 9596238
Williams A Advances in secondary prevention of stroke Practitioner 1999 243(1596):222 5 10436580
Williams GR, Jiang JG, Matchar DB, et al Incidence and occurrence of total (first-ever and recurrent) stroke Stroke 1999 30(12):2523 8 10582972
Willig DS, Turski PA, Frayne R, et al Contrast-enhanced 3D MR DSA of the carotid artery bifurcation: preliminary study of comparison with unenhanced 2D and 3D time-of-flight MR angiography Radiology 1998 208(2):447 51 9680574
Willig V, Pawelec D, Mau J, et al Effects of heparin administration on outcome and bleeding complications after acute ischemic stroke in the European Cooperative Acute Stroke Study placebo cohort J Neurol 1997 244(Suppl 3):
Willig V, Pawelec D, Mau J, et al. Heparin effects in the European Cooperative Acute Stroke Study. Stroke. 1997;28.
Wilmshurst P Limitations of transoesophageal echocardiography in patients with focal cerebral ischaemic events [letter; comment] Br Heart J 1992 68(6):discussion 634 5
Wilson SE, Mayberg MR, Yatsu F, et al. Crescendo transient ischemic attacks: a surgical imperative. J Vasc Surg. 1993;17:249-256. [pmid: 8433420].
Wilterdink JL, Feldmann E, Easton JD, et al Performance of carotid ultrasound in evaluating candidates for carotid endarterectomy is optimized by an approach based on clinical outcome rather than accuracy Stroke 1996 27(6):1094 8 8650720
Winkelaar GB, Chen JC, Salvian AJ, et al New duplex ultrasound scan criteria for managing symptomatic 50% or greater carotid stenosis J Vasc Surg 1999 29(6):986 94 10359932
Wise G, Parker J, Burkholder J. Supraorbital Doppler studies, carotid bruits, and arteriography in unilateral ocular or cerebral ischemic disorders. Neurology. 1979;29:34-7. [pmid: 570674].
Wishart DL Complications in vertebral angiography as compared to non-vertebral cerebral angiography in 447 studies Am J Roentol Radium Ther Nucl Med 1971 113(3):527 37
Wolf PA, Lewis A Conner Lecture. Contributions of epidemiology to the prevention of stroke Circulation 1993 88(5 Pt 1):2471 8 8222142
Wolf PA Prevention of stroke Lancet 1998 352(Suppl 3):SIII15 8 9803957
Wolf PA, D'Agostino RB, O'Neal MA, et al Secular trends in stroke incidence and mortality. The Framingham Study Stroke 1992 23(11):1551 5 1440701
Wolverson M, Heiberg E, Sundaram M, et al. Carotid atherosclerosis: high-resolution real-time sonography correlated with angiography. AJR Am J Roentgenol. 1983;140:355-61. [pmid: 6600354].
Wong JH, Findlay JM, Suarez-Almazor ME Hemodynamic instability after carotid endarterectomy: risk factors and associations with operative complications Neurosurgery 1997 41(1):35 41 discussion 41 3 9218293
Wong JH, Findlay JM, Suarez-Almazor ME Regional performance of carotid endarterectomy. Appropriateness, outcomes, and risk factors for complications Stroke 1997 28(5):891 8 9158621
Wong JK, Gibson RN, Mitchell PJ Comparison of two Doppler ultrasound criteria for grading cervical internal carotid artery stenosis Australas Radiol 1999 43(2):153 5 10901893
Wong K, Huang Y, Gao S, et al Intracranial stenosis in Chinese patients with acute stroke Neurology 1998 50(3):812 813 9521286
Wong KS, Kay R Low-molecular-weight heparin and serum potassium [letter; comment] Lancet 1997 350(9078):
Woo D, Gebel J, Miller R, et al Incidence rates of first-ever ischemic stroke subtypes among blacks: a population-based study Stroke 1999 30(12):2517 22 10582971
Worthy SA, Henderson J, Griffiths PD, et al The role of duplex sonography and angiography in the investigation of carotid artery disease Neuroradiology 1997 39(2):122 6 9045973
Wright IS A critical evaluation of anticoagulant therapy Geriatrics 1969 24(3):96 100 4885555
Wu TH, Chen HH, Lee TK Factors affecting the first recurrence of noncardioembolic ischemic stroke Thromb Res 2000 97(3):95 103 10680640
Wylie EJ, Hein MF, Adams JE. Intracranial hemorrhage following revascularaization surgery for treatment of acute stroke. J Neurosurg. 1964;21:212-215. [pmid: 14127622].
Yarnell PR, Spann JF, Dougherty J, et al Episodic central nervous system ischemia of undetermined cause: relation to occult left atrial myxoma Stroke 1971 2(1):35 40 5112003
Yasaka M, Yamaguchi T Immediate anticoagulation for intracardiac thrombus in acute cardioembolic stroke Angiology 1992 43(11):886 92 1443761
Yasaka M, Yamaguchi T, Miyashita T, et al Regression of intracardiac thrombus after embolic stroke Stroke 1990 21(11):1540 4 2237946
Yasuno M, Onodera T, Kawata R, et al Pulmonary embolism as a complication of transfemoral arteriography--incidence, symptoms, and prevention Jpn Circ J 1984 48(5):439 44 6727025
Yates G, Bergamini TM, George SJ, et al. Carotid endarterectomy results from a state vascular society: Kentucky Vascular Surgery Study Group. Am J Surg. 1997;173:342-344. [pmid: 9136793].
Yatsu FM, Hart RG, Mohr JP, et al Anticoagulation of embolic strokes of cardiac origin: an update Neurology 1988 38(2):314 6 3340300
Yatsu FM, Mohr JPl Anticoagulation therapy for cardiogenic emboli to brain Neurology 1982 32(3):274 5 7199636
Yin D, Carpenter JP Cost-effectiveness of screening for asymptomatic carotid stenosis J Vasc Surg 1998 27(2):245 55 9510279
Young GR, Humphrey PR Skepticism and carotid ultrasonography [letter] Stroke 1996 27(4):768 70 8614949
Young GR, Humphrey PR, Shaw MD, et al Comparison of magnetic resonance angiography, duplex ultrasound, and digital subtraction angiography in assessment of extracranial internal carotid artery stenosis J Neurol Neurosurg Psychiatry 1994 57(12):1466 78 7798975
Zabalgoitia M, Gandhi DK, Evans J, et al Transesophageal echocardiography in the awake elderly patient: its role in the clinical decision-making process Am Heart J 1990 120(5):1147 53 2239667
Zabalgoitia-Reyes M, Herrera C, Gandhi DK, et al A possible mechanism for neurologic ischemic events in patients with atrial septal aneurysm Am J Cardiol 1990 66(7):761 4 2399898
Zbornikova V, Akesson J, Lassvik C. Diagnosis of carotid artery disease - comparison between Doppler, Duplex scanner and angiography. Acta Neurol Scand. 1982;65:335-46. [pmid: 7102260].
Zbornikova V, Lassvik C, Alm A. One year of prospective follow-up after carotid thromboendarterectomy - A clinical and duplex study. Acta Neurol Scand. 1998;98:248-253. [pmid: 9808274].
Zbornikova V, Lassvik C, Johansson I. Prospective evaluation of the accuracy of duplex scanning with spectral analysis in carotid artery disease. Clin Physiol. 1985;5:257-69. [pmid: 3891205].
Zeiger HE, Jr., Zampella EJ, Naftel DC, et al A prospective analysis of 142 carotid endarterectomies for occlusive vascular disease, 1979-1985 J Neurosurg 1987 67(4):540 4 3655892
Zeiler K, Siostrzonek P, Lang W, et al Different risk factor profiles in young and elderly stroke patients with special reference to cardiac disorders J Clin Epidemiol 1992 45(12):1383 9 1460476
Zenker G, Bone G, Ladurner G, et al The myxomatous mitral valve. A risk factor for ischemic stroke in young patients? Eur Neurol 1985 24(1):82 4 3967680
Zenker G, Erbel R, Kramer G, et al Transesophageal two-dimensional echocardiography in young patients with cerebral ischemic events Stroke 1988 19(3):345 8 3354020
Zhu CZ, Norris JW Complications of carotid angiography [letter; comment] J Neurol Neurosurg Psychiatry 1991 54(8):758 9 1940958
Zhu W, Khandheria BK, Click R, et al. Patent foramen ovale detected by contrast transesophageal echo: A lack of association with systemic events (abstract). Circulation. 1991;94:69-4.
Zuppiroli A, Rinaldi M, Kramer-Fox R, et al Natural history of mitral valve prolapse Am J Cardiol 1995 75(15):1028 32 7747683
Zwiebel WJ, Strother CM, Austin CW, et al Comparison of ultrasound and IV-DSA for carotid evaluation Stroke 1985 16(4):633 43 3895593