# References

1 Stroke. 2001 Heart and Stroke Statistical Update 2001; http://www.americanheart.org/statistics/stroke.html.
2 Economic cost of cardiovascular diseases. 2001 Heart and Stroke Statistical Update 2001; http://www.americanheart.org/statistics/economic.html.
3 Risk factors. 2001 Heart and Stroke Statistical Update 2001;http://www.americanheart.org/statistics/riskfactors.html.
4 McNamara RL, Lima JA, Whelton PK, et al Echocardiographic identification of cardiovascular sources of emboli to guide clinical management of stroke: a cost-effectiveness analysis Ann Intern Med 1997 127(9):775 87 9382398
5 Beattie JR, Cohen DJ, Manning WJ, et al Role of routine transthoracic echocardiography in evaluation and management of stroke J Intern Med 1998 243(4):281 91 9627142
6 Manning WJ Role of transesophageal echocardiography in the management of thromboembolic stroke Am J Cardiol 1997 80(4C):19D 28D discussion 35D-39D
7 Frye RLB Does it really make a difference? J Am Coll Cardiol 1992 19(2):468 70 1732377
8 Lucas F, Wennberg D, Malenka D. Variation in the use of echocardiography. Effect Clin Pract. 1999;2:71-75.
9 The Dartmouth Atlas of Vascular Health. Chicago: AHA Press. 2000. [pmcid: 384376].
10 Goldstein LB, Bonito AJ, Matchar DB, et al US national survey of physician practices for the secondary and tertiary prevention of ischemic stroke. Design, service availability, and common practices Stroke 1995 26(9):1607 15 7660407
11 Petty GW, Brown RD, Jr., Whisnant JP, et al Ischemic stroke: outcomes, patient mix, and practice variation for neurologists and generalists in a community Neurology 1998 50(6):1669 78 9633709
12 Oddone EZ, Horner RD, Monger ME, et al Racial variations in the rates of carotid angiography and endarterectomy in patients with stroke and transient ischemic attack Arch Intern Med 1993 153(24):2781 6 8257254
13 Horner RD, Oddone EZ, Matchar DB Theories explaining racial differences in the utilization of diagnostic and therapeutic procedures for cerebrovascular disease Milbank Q 1995 73(3):443 62 7659047
14 Oddone E, Horner R, Diem S, et al Understanding racial variation in utilization of carotid endarterectomy: role of clinical factors J Natl Med Assoc 1998 90(1):25 33 9473926
15 Otto CM. Textbook of Clinical Echocardiography. 2nd ed. Philadelphia: W.B. Saunders. 2000. [pmcid: 384376].
16 Popp RL, Winters WL, Jr Clinical competence in adult echocardiography. A statement for physicians from the ACP/ACC/AHA Task Force on Clinical Privileges in Cardiology J Am Coll Cardiol 1990 15(7):1465 8 2345225
17 Bommer WJ, Shah PM, Allen H, et al The safety of contrast echocardiography: report of the Committee on Contrast Echocardiography for the American Society of Echocardiography J Am Coll Cardiol 1984 3(1):6 13 6690558
18 Srivastava TN, Undesser EK Transient ischemic attack after air contrast echocardiography in patients with septal aneurysm Ann Intern Med 1995 122(5):
19 AbuRahma AF, Robinson PA, Strickler DL, et al Proposed new duplex classification for threshold stenoses used in various symptomatic and asymptomatic carotid endarterectomy trials Ann Vasc Surg 1998 12(4):349 58 9676932
20 Faught WE, Mattos MA, van Bemmelen PS, et al Color-flow duplex scanning of carotid arteries: new velocity criteria based on receiver operator characteristic analysis for threshold stenoses used in the symptomatic and asymptomatic carotid trials J Vasc Surg 1994 19(5):818 27 discussion 827-8 8170035
21 Golledge J, Ellis M, Sabharwal T, et al Selection of patients for carotid endarterectomy J Vasc Surg 1999 30(1):122 30 10394162
22 Grant EG, Duerinckx AJ, El Saden S, et al Doppler sonographic parameters for detection of carotid stenosis: is there an optimum method for their selection? AJR Am J Roentgenol 1999 172(4):1123 9 10587159
23 Moneta GL, Edwards JM, Chitwood RW, et al Correlation of North American Symptomatic Carotid Endarterectomy Trial (NASCET) angiographic definition of 70% to 99% internal carotid artery stenosis with duplex scanning J Vasc Surg 1993 17(1):152 7 discussion 157-9 8421332
24 Neale ML, Chambers JL, Kelly AT, et al Reappraisal of duplex criteria to assess significant carotid stenosis with special reference to reports from the North American Symptomatic Carotid Endarterectomy Trial and the European Carotid Surgery Trial J Vasc Surg 1994 20(4):642 9 7933267
25 Suwanwela N, Can U, Furie KL, et al Carotid Doppler ultrasound criteria for internal carotid artery stenosis based on residual lumen diameter calculated from en bloc carotid endarterectomy specimens Stroke 1996 27(11):1965 9 8898799
26 Winkelaar GB, Chen JC, Salvian AJ, et al New duplex ultrasound scan criteria for managing symptomatic 50% or greater carotid stenosis J Vasc Surg 1999 29(6):986 94 10359932
27 Kuntz KM, Polak JF, Whittemore AD, et al Duplex ultrasound criteria for the identification of carotid stenosis should be laboratory specific Stroke 1997 28(3):597 602 9056618
28 Alexandrov AV, Vital D, Brodie DS, et al Grading carotid stenosis with ultrasound. An interlaboratory comparison Stroke 1997 28(6):1208 10 9183353
29 Fillinger MF, Baker RJ, Jr., Zwolak RM, et al Carotid duplex criteria for a 60% or greater angiographic stenosis: variation according to equipment J Vasc Surg 1996 24(5):856 64 8918334
30 Elgersma OE, van Leersum M, Buijs PC, et al Changes over time in optimal duplex threshold for the identification of patients eligible for carotid endarterectomy Stroke 1998 29(11):2352 6 9804647
31 Howard G, Baker WH, Chambless LE, et al An approach for the use of Doppler ultrasound as a screening tool for hemodynamically significant stenosis (despite heterogeneity of Doppler performance). A multicenter experience. Asymptomatic Carotid Atherosclerosis Study Investigators Stroke 1996 27(11):1951 7 8898797
32 Ballotta E, Da Giau G, Abbruzzese E, et al Carotid endarterectomy without angiography: can clinical evaluation and duplex ultrasonographic scanning alone replace traditional arteriography for carotid surgery workup? A prospective study Surgery 1999 126(1):20 7 10418588
33 Cartier R, Cartier P, Fontaine A Carotid endarterectomy without angiography. The reliability of Doppler ultrasonography and duplex scanning in preoperative assessment Can J Surg 1993 36(5):411 6 8106136
34 Dawson DL, Zierler RE, Strandness DE, Jr., et al The role of duplex scanning and arteriography before carotid endarterectomy: a prospective study J Vasc Surg 1993 18(4):673 80 discussion 680-3 8411475
35 McKittrick JE, Cisek PL, Pojunas KW, et al Are both color-flow duplex scanning and cerebral arteriography required prior to carotid endarterectomy? Ann Vasc Surg 1993 7(4):311 6 8268068
36 Ranger WR, Glover JL, Bendick PJ Carotid endarterectomy based on preoperative duplex ultrasound Am Surg 1995 61(7):548 54 discussion 554-5 7793732
37 Kappelle LJ, Eliasziw M, Fox AJ, et al Importance of intracranial atherosclerotic disease in patients with symptomatic stenosis of the internal carotid artery. The North American Symptomatic Carotid Endarterectomy Trail Stroke 1999 30(2):282 6 9933260
38 Kent DL, Haynor DR, Longstreth WT, Jr., et al The clinical efficacy of magnetic resonance imaging in neuroimaging Ann Intern Med 1994 120(10):856 71 7818632
39 Eliasziw M, Streifler JY, Fox AJ, et al Significance of plaque ulceration in symptomatic patients with high-grade carotid stenosis. North American Symptomatic Carotid Endarterectomy Trial Stroke 1994 25(2):304 8 8303736
40 Caes F, Vierendeels T, Janssens-Willem E, et al Comparison of auscultation, continuous wave Doppler imaging, intravenous digital subtraction angiography and conventional angiography in diagnosis of carotid artery disease Angiology 1987 38(11):799 806 3318569
41 D'Alotto C, Pelz DM, Rankin RN A comparison of angiography, intravenous digital subtraction angiography and duplex ultrasound in the diagnosis of carotid artery atherosclerosis J Can Assoc Radiol 1985 36(3):200 8 3900078
42 Zwiebel WJ, Strother CM, Austin CW, et al Comparison of ultrasound and IV-DSA for carotid evaluation Stroke 1985 16(4):633 43 3895593
43 Eggers F, Price A, Allen J, et al. Neuroradiologic applications of intraarterial digital subtraction angiography. AJNR Am J Neuroradiol. 1983;4:854-856. [pmid: 6410872].
44 Rothwell PM, Gibson RJ, Slattery J, et al Equivalence of measurements of carotid stenosis. A comparison of three methods on 1001 angiogramsEuropean Carotid Surgery Trialists' Collaborative Group.Stroke 1994 25(12):2435 9 7974586
45 Eliasziw M, Smith RF, Singh N, et al Further comments on the measurement of carotid stenosis from angiogramsNorth American Symptomatic Carotid Endarterectomy Trial (NASCET) Group.Stroke 1994 25(12):2445 9 7974588
46 Harris RP, Helfand M, Woolf SH, et al Curent methods of the U.S. Preventive Services Task Force; a review of the process Am J Prev Med 2001 20(3S):21 35
47 Anonymous Cardiogenic brain embolism. Cerebral Embolism Task Force Arch Neurol 1986 43(1):71 84 3510609
48 Anonymous Cardiogenic brain embolism. The second report of the Cerebral Embolism Task Force [published erratum appears in Arch Neurol 1989 Oct;46(10):1079] Arch Neurol 1989 46(7):727 43 2662950
49 Hart RG, Foster JW, Luther MF, et al Stroke in infective endocarditis Stroke 1990 21(5):695 700 2187287
50 Coulshed N, Epstein EJ, McKendrick CS, et al Systemic embolism in mitral valve disease Br Heart J 1970 32(1):26 34 5417843 487269
51 Lopez JA, Ross RS, Fishbein MC, et al Nonbacterial thrombotic endocarditis: a review Am Heart J 1987 113(3):773 84 3548296
52 Koudstaal P Anticoagulants for preventing stroke in patients with nonrheumatic atrial fibrillation and a history of stroke or transient ischemic attacks (Cochrane Review) In The Cochrane LibraryIssue 3,2001 Oxford, England: Update Software
53 Slavin RE Best evidence synthesis: an intelligent alternative to meta-analysis J Clin Epidemiol 1995 48(1):9 18 7853053
54 Hennekens CH, Buring JE. Epidemiology in Medicine. 1st ed. Boston: Little, Brown, and Co. 1987. [pmcid: 373129].
55 Comess KA, DeRook FA, Beach KW, et al Transesophageal echocardiography and carotid ultrasound in patients with cerebral ischemia: prevalence of findings and recurrent stroke risk J Am Coll Cardiol 1994 23(7):1598 603 8195520
56 Anonymous Transesophageal echocardiographic correlates of thromboembolism in high-risk patients with nonvalvular atrial fibrillation. The Stroke Prevention in Atrial Fibrillation Investigators Committee on Echocardiography Ann Intern Med 1998 128(8):639 47 9537937
57 Stollberger C, Chnupa P, Kronik G, et al Transesophageal echocardiography to assess embolic risk in patients with atrial fibrillation. ELAT Study Group. Embolism in Left Atrial Thrombi Ann Intern Med 1998 128(8):630 8 9537936
58 Meltzer RS, Visser CA, Fuster V Intracardiac thrombi and systemic embolization Ann Intern Med 1986 104(5):689 98 3516044
59 Vaitkus PT, Barnathan ES Embolic potential, prevention and management of mural thrombus complicating anterior myocardial infarction: a meta-analysis J Am Coll Cardiol 1993 22(4):1004 9 8409034
60 Stratton JR, Resnick AD Increased embolic risk in patients with left ventricular thrombi Circulation 1987 75(5):1004 11 3568301
61 Hart RG, Coull BM, Hart D Early recurrent embolism associated with nonvalvular atrial fibrillation: a retrospective study Stroke 1983 14(5):688 93 6658950
62 Visser CA, Kan G, Meltzer RS, et al Embolic potential of left ventricular thrombus after myocardial infarction: a two-dimensional echocardiographic study of 119 patients J Am Coll Cardiol 1985 5(6):1276 80 3998310
63 Haugland JM, Asinger RW, Mikell FL, et al Embolic potential of left ventricular thrombi detected by two-dimensional echocardiography Circulation 1984 70(4):588 98 6478564
64 Meltzer RS, Visser CA, Kan G, et al Two-dimensional echocardiographic appearance of left ventricular thrombi with systemic emboli after myocardial infarction Am J Cardiol 1984 53(11):1511 3 6731294
65 Katz SD, Marantz PR, Biasucci L, et al Low incidence of stroke in ambulatory patients with heart failure: a prospective study Am Heart J 1993 126(1):141 6 8322656
66 Falk RH, Foster E, Coats MH Ventricular thrombi and thromboembolism in dilated cardiomyopathy: a prospective follow-up study Am Heart J 1992 123(1):136 42 1729816
67 Ciaccheri M, Castelli G, Cecchi F, et al Lack of correlation between intracavitary thrombosis detected by cross sectional echocardiography and systemic emboli in patients with dilated cardiomyopathy Br Heart J 1989 62(1):26 9 2757871 1216726
68 Cabin HS, Roberts WC Left ventricular aneurysm, intraaneurysmal thrombus and systemic embolus in coronary heart disease Chest 1980 77(5):586 90 7363674
69 Lapeyre AC, Steele PM, Kazmier FJ, et al Systemic embolism in chronic left ventricular aneurysm: incidence and the role of anticoagulation J Am Coll Cardiol 1985 6(3):534 8 4031266
70 Matsumoto N, Whisnant JP, Kurland LT, et al Natural history of stroke in Rochester, Minnesota, 1955 through 1969: an extension of a previous study, 1945 through 1954 Stroke 1973 4(1):20 9 4685804
71 Merino A, Hauptman P, Badimon L, et al Echocardiographic "smoke" is produced by an interaction of erythrocytes and plasma proteins modulated by shear forces J Am Coll Cardiol 1992 20(7):1661 8 1452941
72 Sadanandan S, Sherrid MV Clinical and echocardiographic characteristics of left atrial spontaneous echo contrast in sinus rhythm J Am Coll Cardiol 2000 35(7):1932 8 10841246
73 Meissner I, Whisnant JP, Khandheria BK, et al Prevalence of potential risk factors for stroke assessed by transesophageal echocardiography and carotid ultrasonography: the SPARC study. Stroke Prevention: Assessment of Risk in a Community Mayo Clin Proc 1999 74(9):862 9 10488786
74 Roijer A, Lindgren A, Rudling O, et al Potential cardioembolic sources in an elderly population without stroke. A transthoracic and transoesophageal echocardiographic study in randomly selected volunteers Eur Heart J 1996 17(7):1103 11 8809529
75 Mas JL, Arquizan C, Lamy C, et al Recurrent cerebrovascular events associated with patent foramen ovale, atrial septal aneurysm, or both N Engl J Med 2001 345(24):1740 6 11742048
76 Overell JR, Bone I, Lees KR Interatrial septal abnormalities and stroke: a meta-analysis of case-control studies Neurology 2000 55(8):1172 9 11071496
77 Agmon Y, Khandheria BK, Meissner I, et al Frequency of atrial septal aneurysms in patients with cerebral ischemic events Circulation 1999 99(15):1942 4 10208995
78 Ossemann M, Laloux P, Marchandise B, et al Association between stroke and atrial septal aneurysm assessed by transesophageal echocardiography in a cardiologic population Acta Neurol Belg 1995 95(3):170 7 7484054
79 Cabanes L, Mas JL, Cohen A, et al Atrial septal aneurysm and patent foramen ovale as risk factors for cryptogenic stroke in patients less than 55 years of age. A study using transesophageal echocardiography Stroke 1993 24(12):1865 73 8248969
80 Lindgren A, Roijer A, Norrving B, et al Carotid artery and heart disease in subtypes of cerebral infarction Stroke 1994 25(12):2356 62 7974573
81 Pearson AC, Nagelhout D, Castello R, et al Atrial septal aneurysm and stroke: a transesophageal echocardiographic study J Am Coll Cardiol 1991 18(5):1223 9 1918699
82 Mendel T, Pasierski T, Szwed H, et al Transesophageal echocardiographic findings in patients with anterior and posterior circulation infarcts Acta Neurol Scand 1998 97(1):63 7 9482680
83 Hausmann D, Mugge A, Becht I, et al Diagnosis of patent foramen ovale by transesophageal echocardiography and association with cerebral and peripheral embolic events Am J Cardiol 1992 70(6):668 72 1510018
84 Jones EF, Calafiore P, Donnan GA, et al. Evidence that patent foramen ovale is not a risk factor for cerebral ischemia in the elderly. Am J Cardiol. 1994;74:596-599. [pmid: 8074044].
85 de Belder M, Tourikis L, Leech G, et al. Risk of patent foramen ovale for thromboembolic events in all age groups. Am J Cardiol. 1992;69:1316-1320. [pmid: 1585866].
86 Lechat P, Mas JL, Lascault G, et al Prevalence of patent foramen ovale in patients with stroke N Engl J Med 1988 318(18):1148 52 3362165
87 Stone DA, Godard J, Corretti MC, et al Patent foramen ovale: association between the degree of shunt by contrast transesophageal echocardiography and the risk of future ischemic neurologic events Am Heart J 1996 131(1):158 61 8554004
88 Orgera M, O'Malley P, Taylor A. Secondary prevention of cerebral ischemia in patent foramen ovale: systematic review and meta-analysis. South Med J. 2001;94:699-703. [pmid: 11531177].
89 Barnett HJ, Boughner DR, Taylor DW, et al Further evidence relating mitral-valve prolapse to cerebral ischemic events N Engl J Med 1980 302(3):139 44
90 Scharf RE, Hennerici M, Bluschke V, et al Cerebral ischemia in young patients: it is associated with mitral valve prolapse and abnormal platelet activity in vivo? Stroke 1982 13(4):454 8 6213070
91 de Bono DP, Warlow CP Potential sources of emboli in patients with presumed transient cerebral or retinal ischaemia Lancet 1981 1(8216):343 6 6109988
92 Orencia AJ, Petty GW, Khandheria BK, et al Risk of stroke with mitral valve prolapse in population-based cohort study Stroke 1995 26(1):7 13 7839400
93 Orencia AJ, Petty GW, Khandheria BK, et al Mitral valve prolapse and the risk of stroke after initial cerebral ischemia Neurology 1995 45(6):1083 6 7783867
94 Gilon D, Buonanno FS, Joffe MM, et al Lack of evidence of an association between mitral-valve prolapse and stroke in young patients N Engl J Med 1999 341(1):8 13 10387936
95 Geltner D, Cernik-Harush H, Ayzenberg O Mitral valve prolapse in young Israelis with thromboembolic brain disease Isr J Med Sci 1991 27(1):5 7 1995502
96 Vandenbogaerde J, De Bleecker J, Decoo D, et al Transoesophageal echo-Doppler in patients suspected of a cardiac source of peripheral emboli Eur Heart J 1992 13(1):88 94 1577038
97 Egeblad H, Soelberg Sorensen P Prevalence of mitral valve prolapse in younger patients with cerebral ischaemic attacks. A blinded controlled study Acta Med Scand 1984 216(4):385 91 6516907
98 Zenker G, Erbel R, Kramer G, et al Transesophageal two-dimensional echocardiography in young patients with cerebral ischemic events Stroke 1988 19(3):345 8 3354020
99 Nair CK, Thomson W, Ryschon K, et al Long-term follow-up of patients with echocardiographically detected mitral anular calcium and comparison with age- and sex-matched control subjects Am J Cardiol 1989 63(7):465 70 2916432
100 Aronow WS, Koenigsberg M, Kronzon I, et al Association of mitral anular calcium with new thromboembolic stroke and cardiac events at 39-month follow-up in elderly patients Am J Cardiol 1990 65(22):1511 2 2353658
101 Benjamin EJ, Plehn JF, D'Agostino RB, et al Mitral annular calcification and the risk of stroke in an elderly cohort N Engl J Med 1992 327(6):374 9 1625711
102 de Bono DP, Warlow CP Mitral-annulus calcification and cerebral or retinal ischaemia Lancet 1979 2(8139):383 5 89448
103 Boon A, Lodder J, Cheriex E, et al Mitral annulus calcification is not an independent risk factor for stroke: a cohort study of 657 patients J Neurol 1997 244(9):535 41 9352449
104 Adler Y, Koren A, Fink N, et al Association between mitral annulus calcification and carotid atherosclerotic disease Stroke 1998 29(9):1833 7 9731604
105 Roldan CA, Shively BK, Crawford MH Valve excrescences: prevalence, evolution and risk for cardioembolism J Am Coll Cardiol 1997 30(5):1308 14 9350932
106 Nighoghossian N, Derex L, Perinetti M, et al Course of valvular strands in patients with stroke: cooperative study with transesophageal echocardiography Am Heart J 1998 136(6):1065 9 9842021
107 Roberts JK, Omarali I, Di Tullio MR, et al Valvular strands and cerebral ischemia. Effect of demographics and strand characteristics Stroke 1997 28(11):2185 8 9368562
108 Tice FD, Slivka AP, Walz ET, et al Mitral valve strands in patients with focal cerebral ischemia Stroke 1996 27(7):1183 6 8685925
109 Gardner TJ, Horneffer PJ, Manolio TA, et al Stroke following coronary artery bypass grafting: a ten-year study Ann Thorac Surg 1985 40(6):574 81 3878134
110 Beal MF, Williams RS, Richardson EP, Jr., et al Cholesterol embolism as a cause of transient ischemic attacks and cerebral infarction Neurology 1981 31(7):860 5 7195508
111 Ramirez G, O'Neill WM, Jr., Lambert R, et al Cholesterol embolization: a complication of angiography Arch Intern Med 1978 138(9):1430 2 686939
112 Tunick PA, Perez JL, Kronzon I Protruding atheromas in the thoracic aorta and systemic embolization Ann Intern Med 1991 115(6):423 7 1872490
113 Amarenco P, Duyckaerts C, Tzourio C, et al The prevalence of ulcerated plaques in the aortic arch in patients with stroke N Engl J Med 1992 326(4):221 5 1727976
114 Amarenco P, Cohen A, Tzourio C, et al Atherosclerotic disease of the aortic arch and the risk of ischemic stroke N Engl J Med 1994 331(22):1474 9 7969297
115 Anonymous Atherosclerotic disease of the aortic arch as a risk factor for recurrent ischemic strokeThe French Study of Aortic Plaques in Stroke Group.N Engl J Med 1996 334(19):1216 21 8606716
116 Jones EF, Kalman JM, Calafiore P, et al Proximal aortic atheroma. An independent risk factor for cerebral ischemia Stroke 1995 26(2):218 24 7831691
117 Di Tullio MR, Sacco RL, Gersony D, et al Aortic atheromas and acute ischemic stroke: a transesophageal echocardiographic study in an ethnically mixed population Neurology 1996 46(6):1560 6 8649549
118 Di Tullio MR, Sacco RL, Savoia MT, et al Aortic atheroma morphology and the risk of ischemic stroke in a multiethnic population Am Heart J 2000 139(2 Pt 1):329 36 10650307
119 Karalis DG, Chandrasekaran K, Victor MF, et al Recognition and embolic potential of intraaortic atherosclerotic debris J Am Coll Cardiol 1991 17(1):73 8 1987243
120 Stone DA, Hawke MW, LaMonte M, et al Ulcerated atherosclerotic plaques in the thoracic aorta are associated with cryptogenic stroke: a multiplane transesophageal echocardiographic study Am Heart J 1995 130(1):105 8 7611098
121 Ha JW, Kang WC, Chung N, et al Echocardiographic and morphologic characteristics of left atrial myxoma and their relation to systemic embolism Am J Cardiol 1999 83(11):1579 82, A8 10363879
122 Pinede L, Duhaut P, Loire R Clinical presentation of left atrial cardiac myxoma. A series of 112 consecutive cases Medicine 2001 80(3):159 72 11388092
123 Bulkley BH, Hutchins GM Atrial myxomas: a fifty year review Am Heart J 1979 97(5):639 43 433739
124 Sandok BA, von Estorff I, Giuliani ER CNS embolism due to atrial myxoma: clinical features and diagnosis Arch Neurol 1980 37(8):485 8 7417040
125 Schwarz GA, Schwartzman RJ, Joyner CR Atrial myxoma. Cause of embolic stroke Neurology 1972 22(11):1112 21 4673555
126 Yarnell PR, Spann JF, Dougherty J, et al Episodic central nervous system ischemia of undetermined cause: relation to occult left atrial myxoma Stroke 1971 2(1):35 40 5112003
127 Thompson JR, Simmons CR Arterial embolus. Manifestation of unsuspected myxoma JAMA 1974 228(7):864 5 4406303
128 2001 Heart and Stroke Statistical Update. 2001: http://www.americanheart.org/statistics/stroke.html.
129 Nishide M, Irino T, Gotoh M, et al Cardiac abnormalities in ischemic cerebrovascular disease studied by two-dimensional echocardiography Stroke 1983 14(4):541 5 6658929
130 Greenland P, Knopman DS, Mikell FL, et al Echocardiography in diagnostic assessment of stroke Ann Intern Med 1981 95(1):51 3 7247127
131 Shyu KG, Chen JJ, Huang ZS, et al Role of transesophageal echocardiography in the diagnostic assessment of cardiac sources of embolism in patients with acute ischemic stroke Cardiology 1994 85(1):53 60 7954558
132 Pop G, Sutherland GR, Koudstaal PJ, et al Transesophageal echocardiography in the detection of intracardiac embolic sources in patients with transient ischemic attacks Stroke 1990 21(4):560 5 2326837
133 Joubert J, van Gelder AL, Darazs B, et al The cardiovascular status of the black stroke patient S Afr Med J 1989 76(12):657 64 2688143
134 Bogousslavsky J, Hachinski VC, Boughner DR, et al. Cardiac and arterial lesions in carotid transient ischemic attacks. Arch Neurol. 1986;43:223-228. [pmid: 3947270].
135 Voyce SJ, Aurigemma GP, Dahlberg S, et al A comparison of two-dimensional echocardiography vs carotid duplex scanning in older patients with cerebral ischemia Arch Intern Med 1992 152(10):2089 93 1417383
136 Weinberger J, Azhar S, Danisi F, et al A new noninvasive technique for imaging atherosclerotic plaque in the aortic arch of stroke patients by transcutaneous real-time B-mode ultrasonography: an initial report Stroke 1998 29(3):673 6 9506611
137 Good DC, Frank S, Verhulst S, et al Cardiac abnormalities in stroke patients with negative arteriograms Stroke 1986 17(1):6 11 3945985
138 Toyoda K, Yasaka M, Nagata S, et al Transesophageal echocardiography for detecting intracardiac thrombi in embolic stroke Angiology 1993 44(5):376 83 8480915
139 Bevan H, Sharma K, Bradley W Stroke in young adults Stroke 1990 21(3):382 6 2309261
140 Biller J, Johnson MR, Adams HP, Jr., et al Echocardiographic evaluation of young adults with nonhemorrhagic cerebral infarction Stroke 1986 17(4):608 12 3738939
141 Albers GW, Comess KA, DeRook FA, et al Transesophageal echocardiographic findings in stroke subtypes Stroke 1994 25(1):23 8 8266377
142 Roijer A, Lindgren A, Algotsson L, et al Cardiac changes in stroke patients and controls evaluated with transoesophageal echocardiography Scand Cardiovasc J 1997 31(6):329 37 9455781
143 Jones EF, Donnan GA, Calafiore P, et al Transoesophageal echocardiography in the investigation of stroke: experience in 135 patients with cerebral ischaemic events Aust N Z J Med 1993 23(5):477 83 8297277
144 Omran H, Rang B, Schmidt H, et al Incidence of left atrial thrombi in patients in sinus rhythm and with a recent neurologic deficit Am Heart J 2000 140(4):658 62 11011342
145 Kessler C, Mitusch R, Guo Y, et al Embolism from the aortic arch in patients with cerebral ischemia Thromb Res 1996 84(3):145 55 8914214
146 Labovitz AJ, Camp A, Castello R, et al Usefulness of transesophageal echocardiography in unexplained cerebral ischemia Am J Cardiol 1993 72(18):1448 52 8256742
147 Censori B, Colombo F, Valsecchi MG, et al Early transoesophageal echocardiography in cryptogenic and lacunar stroke and transient ischaemic attack J Neurol Neurosurg Psychiatry 1998 64(5):624 7 9598678
148 Rauh R, Fischereder M, Spengel FA Transesophageal echocardiography in patients with focal cerebral ischemia of unknown cause Stroke 1996 27(4):691 4 8614932
149 Nighoghossian N, Perinetti M, Barthelet M, et al Potential cardioembolic sources of stroke in patients less than 60 years of age Eur Heart J 1996 17(4):590 4 8733093
150 DeRook FA, Comess KA, Albers GW, et al Transesophageal echocardiography in the evaluation of stroke Ann Intern Med 1992 117(11):922 32 1443955
151 Fatkin D, Scalia G, Jacobs N, et al Accuracy of biplane transesophageal echocardiography in detecting left atrial thrombus Am J Cardiol 1996 77(4):321 3 8607421
152 Manning WJ, Weintraub RM, Waksmonski CA, et al Accuracy of transesophageal echocardiography for identifying left atrial thrombi. A prospective, intraoperative study Ann Intern Med 1995 123(11):817 22 7486462
153 Aschenberg W, Schluter M, Kremer P, et al Transesophageal two-dimensional echocardiography for the detection of left atrial appendage thrombus J Am Coll Cardiol 1986 7(1):163 6 3941205
154 Hwang JJ, Chen JJ, Lin SC, et al Diagnostic accuracy of transesophageal echocardiography for detecting left atrial thrombi in patients with rheumatic heart disease having undergone mitral valve operations Am J Cardiol 1993 72(9):677 81 8249844
155 Acar J, Cormier B, Grimberg D, et al Diagnosis of left atrial thrombi in mitral stenosis--usefulness of ultrasound techniques compared with other methods Eur Heart J 1991 12(Suppl B):70 6
156 Koca V, Bozat T, Akkaya V, et al Left atrial thrombus detection with multiplane transesophageal echocardiography: an echocardiographic study with surgical verification J Heart Valve Dis 1999 8(1):63 6 10096484
157 Olson JD, Goldenberg IF, Pedersen W, et al Exclusion of atrial thrombus by transesophageal echocardiography J Am Soc Echocardiogr 1992 5(1):52 6 1739471
158 Bansal RC, Heywood JT, Applegate PM, et al Detection of left atrial thrombi by two-dimensional echocardiography and surgical correlation in 148 patients with mitral valve disease Am J Cardiol 1989 64(3):243 6 2741835
159 Shrestha NK, Moreno FL, Narciso FV, et al Two-dimensional echocardiographic diagnosis of left-atrial thrombus in rheumatic heart disease. A clinicopathologic study Circulation 1983 67(2):341 7 6848223
160 Schweizer P, Bardos P, Erbel R, et al. Detection of left atrial thrombi by echocardiography. Br Heart J. 1981;45:148-56. [pmid: 7459174]. [pmcid: 482503].
161 Ezekowitz MD, Wilson DA, Smith EO, et al Comparison of Indium-111 platelet scintigraphy and two-dimensional echocardiography in the diagnosis of left ventricular thrombi N Engl J Med 1982 306(25):1509 13 7078607
162 Starling MR, Crawford MH, Sorensen SG, et al Comparative value of invasive and noninvasive techniques for identifying left ventricular mural thrombi Am Heart J 1983 106(5 Pt 1):1143 9 6637770
163 Sechtem U, Theissen P, Heindel W, et al Diagnosis of left ventricular thrombi by magnetic resonance imaging and comparison with angiocardiography, computed tomography and echocardiography Am J Cardiol 1989 64(18):1195 9 2683713
164 Stratton JR, Lighty GW, Jr., Pearlman AS, et al Detection of left ventricular thrombus by two-dimensional echocardiography: sensitivity, specificity, and causes of uncertainty Circulation 1982 66(1):156 66 7083502
165 Visser CA, Kan G, David GK, et al Two dimensional echocardiography in the diagnosis of left ventricular thrombus. A prospective study of 67 patients with anatomic validation Chest 1983 83(2):228 32 6822107
166 Takamoto T, Kim D, Urie PM, et al Comparative recognition of left ventricular thrombi by echocardiography and cineangiography Br Heart J 1985 53(1):36 42 3966950 481718
167 Mugge A, Daniel WG, Haverich A, et al Diagnosis of noninfective cardiac mass lesions by two-dimensional echocardiography. Comparison of the transthoracic and transesophageal approaches Circulation 1991 83(1):70 8 1984900
168 Sheiban I, Casarotto D, Trevi G, et al Two-dimensional echocardiography in the diagnosis of intracardiac masses: a prospective study with anatomic validation Cardiovasc Intervent Radiol 1987 10(3):157 61 3111698
169 Alam M, Rosman HS, Grullon C Transesophageal echocardiography in evaluation of atrial masses Angiology 1995 46(2):123 8 7702196
170 Irwig L, Macaskill P, Glasziou P, et al Meta-analytic methods for diagnostic test accuracy J Clin Epidemiol 1995 48(1):119 30 discussion 131 2 7853038
171 Gendreau MA, Triner WR, Bartfield J Complications of transesophageal echocardiography in the ED Am J Emerg Med 1999 17(3):248 51 10337882
172 Messina AG, Paranicas M, Fiamengo S, et al Risk of dysphagia after transesophageal echocardiography Am J Cardiol 1991 67(4):313 4 1990797
173 Oh JK, Seward JB, Khandheria BK, et al Transesophageal echocardiography in critically ill patients Am J Cardiol 1990 66(20):1492 5 2251998
174 Seward JB, Khandheria BK, Oh JK, et al Critical appraisal of transesophageal echocardiography: limitations, pitfalls, and complications J Am Soc Echocardiogr 1992 5(3):288 305 1622623
175 Tam JW, Burwash I, Ascah K, et al Feasibility and complications of single-plane and biplane versus multiplane transesophageal imaging: a review of 2947 consecutive studies Can J Cardiol 1997 13(1):81 4 9039070
176 Daniel WG, Erbel R, Kasper W, et al Safety of transesophageal echocardiography. A multicenter survey of 10,419 examinations Circulation 1991 83(3):817 21 1999032
177 Khandheria BK, Seward JB, Tajik AJ Transesophageal echocardiography Mayo Clin Proc 1994 69(9):856 63 8065188
178 Chee T, Quek S, Ding Z, et al Clinical utility, safety, acceptability and complications of transesophageal echocardiography (TEE) in 901 patients Singapore Med J 1995 35(5):479 83
179 Black IW, Hopkins A, Lee CL, et al The clinical role of transoesophageal echocardiography Aust N Z J Med 1990 20(6):759 64 2291724
180 de Belder MA, Leech G, Camm AJ Transesophageal echocardiography in unsedated outpatients: technique and patient tolerance J Am Soc Echocardiogr 1989 2(6):375 9 2627439
181 Geibel A, Kasper W, Behroz A, et al Risk of transesophageal echocardiography in awake patients with cardiac diseases Am J Cardiol 1988 62(4):337 9 3400617
182 Khoury AF, Afridi I, Quinones MA, et al Transesophageal echocardiography in critically ill patients: feasibility, safety, and impact on management Am Heart J 1994 127(5):1363 71 8172066
183 Ofili EO, Rich MW Safety and usefulness of transesophageal echocardiography in persons aged greater than or equal to 70 years Am J Cardiol 1990 66(17):1279 80 2239741
184 Pearson AC, Castello R, Labovitz AJ Safety and utility of transesophageal echocardiography in the critically ill patient Am Heart J 1990 119(5):1083 9 2330866
185 Scriven AJ, Cobbe SM Hypoxaemia during transoesophageal echocardiography Br Heart J 1994 72(2):133 5 7917684 1025475
186 Stoddard MF, Longaker RA The safety of transesophageal echocardiography in the elderly Am Heart J 1993 125(5 Pt 1):1358 62 8480589
187 Zabalgoitia M, Gandhi DK, Evans J, et al Transesophageal echocardiography in the awake elderly patient: its role in the clinical decision-making process Am Heart J 1990 120(5):1147 53 2239667
188 Pongratz G, Henneke KH, von der Grun M, et al Risk of endocarditis in transesophageal echocardiography Am Heart J 1993 125(1):190 3 8417517
189 Gorge G, Erbel R, Henrichs KJ, et al Positive blood cultures during transesophageal echocardiography Am J Cardiol 1990 65(20):1404 5 2343830
190 Foster E, Kusumoto FM, Sobol SM, et al Streptococcal endocarditis temporally related to transesophageal echocardiography J Am Soc Echocardiogr 1990 3(5):424 7 2245038
191 Read RC, Finch RG, Donald FE, et al Infective endocarditis after transesophageal echocardiography [letter; comment] Circulation 1993 87(4):
192 Melendez LJ, Chan KL, Cheung PK, et al Incidence of bacteremia in transesophageal echocardiography: a prospective study of 140 consecutive patients J Am Coll Cardiol 1991 18(7):1650 4 1960310
193 Nikutta P, Mantey-Stiers F, Becht I, et al Risk of bacteremia induced by transesophageal echocardiography: analysis of 100 consecutive procedures J Am Soc Echocardiogr 1992 5(2):168 72 1571172
194 Roudaut R, Lartigue MC, Texier-Maugein J, et al Incidence of bacteraemia or fever during transoesophageal echocardiography: a prospective study of 82 patients Eur Heart J 1993 14(7):936 40 8375419
195 Shyu KG, Hwang JJ, Lin SC, et al Prospective study of blood culture during transesophageal echocardiography Am Heart J 1992 124(6):1541 4 1462911
196 Steckelberg JM, Khandheria BK, Anhalt JP, et al Prospective evaluation of the risk of bacteremia associated with transesophageal echocardiography Circulation 1991 84(1):177 80 2060093
197 Voller H, Spielberg C, Schroder K, et al Frequency of positive blood cultures during transesophageal echocardiography Am J Cardiol 1991 68(15):1538 40 1746442
198 Liu M, Counsell CE, Sandercock P Anticoagulants for preventing recurrence following ischaemic stroke or tranient ischaemic attack (Cochrane Review) In The Cochrane LibraryIssue 3,2000 Oxford, England: Update Software
199 Jonas Sl Anticoagulant therapy in cerebrovascular disease: review and meta-analysis [published erratum appears in Stroke 1989 Apr;20(4):562] Stroke 1988 19(8):1043 8 3041650
200 Diener HCl Stroke prevention: anti-platelet and anti-thrombolytic therapy Neurol Clin 2000 18(2):343 55 10757830
201 Genton E, Barnett HJ, Fields WS, et al XIV. Cerebral ischemia: the role of thrombosis and of antithrombotic therapy. Study group on antithrombotic therapy Stroke 1977 8(1):150 75 835152
202 Turpie AG, Bloch R, Duke R. Heparin in the treatment of thromboembolic stroke. Ann N Y Acad Sci. 1989;556:406-15. [pmid: 2660688].
203 Gubitz G, Counsell C, Sandercock P, et al Anticoagulants for acute ischemic stroke (Cochrane Review) In The Cochrane LibaryIssue 3,2001 Oxford, England: Update Software
204 CAST: randomised placebo-controlled trial of early aspirin use in 20,000 patients with acute ischaemic strokeCAST (Chinese Acute Stroke Trial) Collaborative Group.Lancet 1997 349(9066):1641 9 9186381
205 The International Stroke Trial (IST): a randomised trial of aspirin, subcutaneous heparin, both, or neither among 19435 patients with acute ischaemic strokeInternational Stroke Trial Collaborative Group.Lancet 1997 349(9065):1569 81 9174558
206 Gubitz G, Sandercock P, Counsell C Antiplatetelet therapy for acute ischemic stroke (Cochrane Review) In The Cochrane LibraryIssue 3,2001 Oxford, England: Update Software
207 Berge E, Sandercock P Anticoagulants versus antiplatelet agents for acute ischemic stroke (Cochrane Review) In The Cochrane LibraryIssue 3,2001 Oxford, England: Update Software
208 A randomized trial of anticoagulants versus aspirin after cerebral ischemia of presumed arterial originThe Stroke Prevention in Reversible Ischemia Trial (SPIRIT) Study Group.Ann Neurol 1997 42(6):857 65 9403477
209 Buren A, Ygge Jl Treatment program and comparison between anticoagulants and platelet aggregation inhibitors after transient ischemic attack Stroke 1981 12(5):578 80 7303042
210 Olsson JE, Brechter C, Backlund H, et al Anticoagulant vs anti-platelet therapy as prophylactic against cerebral infarction in transient ischemic attacks Stroke 1980 11(1):4 9 7355429
211 Eriksson SEl Enteric-coated acetylsalicylic acid plus dipyridamole compared with anticoagulants in the prevention of ischemic events in patients with transient ischemic attacks Acta Neurol Scand 1985 71(6):485 93 4024860
212 Mohr JP, Thompson JL, Lazar RM, et al A comparison of warfarin and aspirin for the prevention of recurrent ischemic stroke N Engl J Med 2001 345(20):1444 51 11794192
213 Garde A, Samuelsson K, Fahlgren H, et al Treatment after transient ischemic attacks: a comparison between anticoagulant drug and inhibition of platelet aggregation Stroke 1983 14(5):677 81 6658949
214 Rothrock JF, Dittrich HC, McAllen S, et al Acute anticoagulation following cardioembolic stroke Stroke 1989 20(6):730 4 2728037
215 Anand SS, Yusuf S Oral anticoagulant therapy in patients with coronary artery disease: a meta-analysis [published erratum appears in JAMA 2000 Jul 5;284(1):45] JAMA 1999 282(21):2058 67 10591389
216 Wolf PA, D'Agostino RB, O'Neal MA, et al Secular trends in stroke incidence and mortality. The Framingham Study Stroke 1992 23(11):1551 5 1440701
217 Brown RD, Whisnant JP, Sicks JD, et al Stroke incidence, prevalence, and survival: secular trends in Rochester, Minnesota, through 1989 Stroke 1996 27(3):373 80 8610298
218 Burn J, Dennis M, Bamford J, et al Long-term risk of recurrent stroke after a first-ever stroke. The Oxfordshire Community Stroke Project [published erratum appears in Stroke 1994 Sep;25(9):1887] Stroke 1994 25(2):333 7 8303740
219 Hankey GJ, Jamrozik K, Broadhurst RJ, et al Long-term risk of first recurrent stroke in the Perth Community Stroke Study Stroke 1998 29(12):2491 500 9836757
220 Landefeld CS, Goldman L Major bleeding in outpatients treated with warfarin: incidence and prediction by factors known at the start of outpatient therapy Am J Med 1989 87(2):144 52 2787958
221 Anonymous Effects of long-term, moderate-intensity oral anticoagulation in addition to aspirin in unstable angina. The Organization to Assess Strategies for Ischemic Syndromes (OASIS) Investigators J Am Coll Cardiol 2001 37(2):475 84 11216966
222 Baker DW, Wright RF Management of heart failure. IV. Anticoagulation for patients with heart failure due to left ventricular systolic dysfunction JAMA 1994 272(20):1614 8 7966873
223 Dunkman WB, Johnson GR, Carson PE, et al Incidence of thromboembolic events in congestive heart failureThe V-HeFT VA Cooperative Studies Group.Circulation 1993 87(6 Suppl):VI94 101 8419029
224 Loh E, Sutton MS, Wun CC, et al Ventricular dysfunction and the risk of stroke after myocardial infarction N Engl J Med 1997 336(4):251 7 8995087
225 Dressler FA, Craig WR, Castello R, et al Mobile aortic atheroma and systemic emboli: efficacy of anticoagulation and influence of plaque morphology on recurrent stroke J Am Coll Cardiol 1998 31(1):134 8 9426031
226 Archer SL, James KE, Kvernen LR, et al Role of transesophageal echocardiography in the detection of left atrial thrombus in patients with chronic nonrheumatic atrial fibrillation Am Heart J 1995 130(2):287 95 7631609
227 Matchar DB, Samsa GP. Secondary and Tertiary Prevention of Stroke. Patient Outcomes Research Team (PORT) Final Report - Phase 1. Rockville, MD: Agency for Healthcare Research and Quality. 2000. [pmcid: 384376].
228 Bogousslavsky J, Van Melle G, Regli F The Lausanne Stroke Registry: analysis of 1,000 consecutive patients with first stroke Stroke 1988 19(9):1083 92 3413804
229 Barnett HJ, Taylor DW, Eliasziw M, et al Benefit of carotid endarterectomy in patients with symptomatic moderate or severe stenosis. North American Symptomatic Carotid Endarterectomy Trial Collaborators N Engl J Med 1998 339(20):1415 25 9811916
230 Anonymous Randomised trial of endarterectomy for recently symptomatic carotid stenosis: final results of the MRC European Carotid Surgery Trial (ECST) Lancet 1998 351(9113):1379 87 9593407
231 Blakeley DD, Oddone EZ, Hasselblad V, et al Noninvasive carotid artery testing. A meta-analytic review Ann Intern Med 1995 122(5):360 7 7847648
232 Eliasziw M, Rankin RN, Fox AJ, et al Accuracy and prognostic consequences of ultrasonography in identifying severe carotid artery stenosisNorth American Symptomatic Carotid Endarterectomy Trial (NASCET) Group.Stroke 1995 26(10):1747 52 7570719
233 Dippel DW, de Kinkelder A, Bakker SL, et al The diagnostic value of colour duplex ultrasound for symptomatic carotid stenosis in clinical practice Neuroradiology 1999 41(1):1 8 9987759
234 Hunink MG, Polak JF, Barlan MM, et al Detection and quantification of carotid artery stenosis: efficacy of various Doppler velocity parameters AJR Am J Roentgenol 1993 160(3):619 25 8430567
235 Vanninen R, Manninen H, Soimakallio S Imaging of carotid artery stenosis: clinical efficacy and cost-effectiveness AJNR Am J Neuroradiol 1995 16(9):1875 83 8693989
236 Worthy SA, Henderson J, Griffiths PD, et al The role of duplex sonography and angiography in the investigation of carotid artery disease Neuroradiology 1997 39(2):122 6 9045973
237 Young GR, Humphrey PR, Shaw MD, et al Comparison of magnetic resonance angiography, duplex ultrasound, and digital subtraction angiography in assessment of extracranial internal carotid artery stenosis J Neurol Neurosurg Psychiatry 1994 57(12):1466 78 7798975
238 Huston J, Nichols DA, Luetmer PH, et al MR angiographic and sonographic indications for endarterectomy AJNR Am J Neuroradiol 1998 19(2):309 15 9504484
239 Jackson MR, Chang AS, Robles HA, et al Determination of 60% or greater carotid stenosis: a prospective comparison of magnetic resonance angiography and duplex ultrasound with conventional angiography Ann Vasc Surg 1998 12(3):236 43 9588509
240 Sardanelli F, Zandrino F, Parodi RC, et al MR angiography of internal carotid arteries: breath-hold Gd-enhanced 3D fast imaging with steady-state precession versus unenhanced 2D and 3D time-of-flight techniques J Comput Assist Tomogr 1999 23(2):208 15 10096327
241 Sillesen H, Bitsch K, Schroeder T, et al. Pulse multigated Doopler ultrasonography in the diagnosis of carotid artery disease. Stroke. 1988;19:846-51. [pmid: 2968688].
242 Russell D, Bakke SJ, Nakstad P, et al A comparison of pulsed Doppler spectral analysis and intravenous digital subtraction angiography in the detection of carotid occlusive disease Acta Neurol Scand 1985 72(6):571 6 3913272
243 Torvaldsen S, McCauley J, Patel A, et al. Assessment of cervical carotid artery disease. A comparison between the Doppler Echoflow and conventional angiography. Med J Aust. 1985;142:542-5. [pmid: 3887109].
244 Riles TS, Eidelman EM, Litt AW, et al Comparison of magnetic resonance angiography, conventional angiography, and duplex scanning Stroke 1992 23(3):341 6 1542893
245 Londrey G, Spadone D, Hogsdon K, et al. Does color-flow imaging improve the accuracy of duplex carotid evaluation?. J Vasc Surg. 1991;13:659-63. [pmid: 2027204].
246 Hallam M, Reid J, Cooperberg P Color-flow Doppler and conventional duplex scanning of the carotid bifurcation: a prospective, double-blind, correlative study AJR Am J Roentgenol 1989 152(5):1101 1105 2650482
247 Dick MT, Cape CA Complications of duplex carotid imaging. A case report Angiology 1994 45(3):235 8 8129206
248 Hankey GJ, Warlow CP, Sellar RJ Cerebral angiographic risk in mild cerebrovascular disease Stroke 1990 21(2):209 22 2406993
249 Kerber CW, Cromwell LD, Drayer BP, et al Cerebral ischemia. I. Current angiographic techniques, complications, and safety AJR Am J Roentgenol 1978 130(6):1097 103 418647
250 Skalpe IO, Anke IM Complications in cerebral angiography. A comparison between the non-ionic contrast medium iohexol and meglumine metrizoate (Isopaque Cerebral) Neuroradiology 1983 25(3):157 60 6350922
251 Earnest Ft, Forbes G, Sandok BA, et al Complications of cerebral angiography: prospective assessment of risk AJR Am J Roentgenol 1984 142(2):247 53 6198889
252 Ball JB, Lukin RR, Tomsick TA, et al. Complications of intravenous digital subtraction angiography. Arch Neurol. 1985;42:969-972. [pmid: 3899062].
253 Gasparini M, Arosio M, Galbiati N, et al Neurological complications of cerebral angiography Ital J Neurol Sci 1986 7(3):353 7 3733415
254 Jeans WD, Mackenzie S, Baird RN Angiography in transient cerebral ischaemia using three views of the carotid bifurcation Br J Radiol 1986 59(698):135 42 3947821
255 Dion JE, Gates PC, Fox AJ, et al Clinical events following neuroangiography: a prospective study Stroke 1987 18(6):997 1004 3686597
256 McIvor J, Steiner TJ, Perkin GD, et al Neurological morbidity of arch and carotid arteriography in cerebrovascular disease. The influence of contrast medium and radiologist Br J Radiol 1987 60(710):117 22 3815006
257 Skalpe IO, Lundervold A, Tjorstad K Complications of cerebral angiography. Comparing metrizamide (Amipaque) and meglumine metrizoate (Isopaque Cerebral) Neuroradiology 1980 19(2):67 71 7366836
258 Davies KN, Humphrey PR Complications of cerebral angiography in patients with symptomatic carotid territory ischaemia screened by carotid ultrasound J Neurol Neurosurg Psychiatry 1993 56(9):967 72 8410036
259 Hankey GJ, Warlow CP, Molyneux AJ Complications of cerebral angiography for patients with mild carotid territory ischaemia being considered for carotid endarterectomy J Neurol Neurosurg Psychiatry 1990 53(7):542 8 2118171
260 Heiserman JE, Dean BL, Hodak JA, et al Neurologic complications of cerebral angiography AJNR Am J Neuroradiol 1994 15(8):1401 7 discussion 1408 11 7985557
261 Skalpe IO Complications in cerebral angiography with iohexol (Omnipaque) and meglumine metrizoate (Isopaque cerebral) Neuradiology 1988 30(1):69 72
262 Aaron JO, Hesselink JR, Oot R, et al Complications of intravenous DSA performed for carotid artery disease: a prospective study Radiology 1984 153(3):675 8 6387790
263 Miller JD, Grace MG, Russell DB, et al Complications of cerebral angiography and pneumography Radiology 1977 124(3):741 4 887769
264 Dalal PM, Shah PM, Aiyar RR, et al Cerebrovascular diseases in west central India. A report on angiographic findings from a prospective study BMJ 1968 3(621):769 74 5676713
265 Dion J, Gates P, Fox AJ, et al. Clinical events following neuroangiography. A prospective study. Acta Radiol Suppl. 1986;369:29-33. [pmid: 2980476].
266 Skalpe IO, Lundervold A, Tjorstad K Cerebral angiography with non-ionic (metrizamide) and ionic (meglumine metrizoate) watersoluble contrast media. A comparative study with double blind technic Neuroradiology 1977 14(1):15 9 331137
267 Mason RA, Arbeit LA, Giron F Renal dysfunction after arteriography JAMA 1985 253(7):1001 4 3968822
268 Yasuno M, Onodera T, Kawata R, et al Pulmonary embolism as a complication of transfemoral arteriography--incidence, symptoms, and prevention Jpn Circ J 1984 48(5):439 44 6727025
269 Olivecrona H Complications of cerebral angiography Neuroradiology 1977 14(4):175 81 600381
270 Grzyska U, Freitag J, Zeumer H Selective cerebral intraarterial DSA. Complication rate and control of risk factors Neuroradiology 1990 32(4):296 9 2234388
271 Waugh JR, Sacharias N Arteriographic complications in the DSA era Radiology 1992 182(1):243 6 1727290
272 Baum S, Stein G, Kuroda K Complications of 'no arteriography' Radiology 1966 86(5):835 8 5936091
273 Shaw RB, Myers JK Carotid endarterectomy: a review of surgical practice in a community hospital Tex Med 1993 89(5):63 7 8342163
274 Mayberg MR, Wilson S, Yatsu F. Carotid endarterectomy and prevention of cerebral ischemia in symptomatic carotid stenosis. JAMA. 1991;266:3289-3294. [pmid: 1960828].
275 Anonymous Beneficial effect of carotid endarterectomy in symptomatic patients with high-grade carotid stenosis. North American Symptomatic Carotid Endarterectomy Trial Collaborators N Engl J Med 1991 325(7):445 53 1852179
276 Anonymous MRC European Carotid Surgery Trial: interim results for symptomatic patients with severe (70-99%) or with mild (0-29%) carotid stenosisEuropean Carotid Surgery Trialists' Collaborative Group.Lancet 1991 337(8752):1235 43 1674060
277 Barnett HJ, Eliasziw M, Meldrum HEl Evidence based cardiology: Prevention of ischaemic stroke BMJ 1999 318(7197):1539 43 10356014 1115906
278 Cina C, Clase C, Haynes R Carotid endarterectomy for symptomatic carotid stenosis (Cochrane Review) In The Cochrane LibraryIssue 3,2000 Oxford, England: Update Software
279 Anonymous North American Symptomatic Carotid Endarterectomy Trial. Methods, patient characteristics, and progress Stroke 1991 22(6):711 20 2057968
280 Rothwell PM, Slattery J, Warlow CP A systematic review of the risks of stroke and death due to endarterectomy for symptomatic carotid stenosis Stroke 1996 27(2):260 5 8571420
281 Rothwell PM, Slattery J, Warlow CP A systematic comparison of the risks of stroke and death due to carotid endarterectomy for symptomatic and asymptomatic stenosis Stroke 1996 27(2):266 9 8571421
282 Magee TR, Earnshaw J, Cole S, et al. A 5-year review of carotid endarterectomy in a vascular unit using a computerised audit system. Ann R Coll Surg Engl. 1992;74:430-433. [pmid: 1471842].
283 Earnshaw J, Hayward J, Horrocks M, et al. The importance of vascular surgical audit to surgeons, patients and purchasers. Eur J Vasc Surg. 1992;6:540-544. [pmid: 1397350].
284 Whittemore A. Carotid endarterectomy: an alternative apporach. Arch Surg. 1980;115:940-942. [pmid: 7396702].
285 Whitney DG, Kahn E, Estes J, et al. Carotid artery surgery without a temporary indwelling shunt: 1917 consecutive procedures. Arch Surg. 1980;115:1393-1398. [pmid: 7436734].
286 Eriksson SE, Link H, Alm A, et al. Results from 88 consecutive prophylactic carotid endarterectomies in cerebral infarction and transient ischaemic attacks. Acta Neurol Scand. 1981;63:209-219. [pmid: 7211186].
287 Parkin P, Kendall B, Marshall J, et al. Amaurosis fugax: some aspects of management. J Neurol Neurosurg Psychiatry. 1982;45:1-6. [pmid: 7062065].
288 Hertzer NR, Beven EG, Modic M, et al. Early patency of the carotid artery after endarterectomy: digital subtraction angiography after two hundred sixty-two operations. Surgery. 1982;92:1049-1056. [pmid: 6755788].
289 Thompson JE Carotid endarterectomy, 1982--the state of the art Br J Surg 1983 70(6):371 6 6344957
290 Takolander RJ, Bergentz SE, Ericsson BF Carotid artery surgery in patients with minor stroke Br J Surg 1983 70(1):13 6 6824875
291 Sacquegena T, D'Addato M, Baldrati A, et al. Long-term prognosis after carotid endarterectomy. Eur Neurol. 1986;25:36-39.
292 Burns RJ, Willoughby JO South Australian carotid endarterectomy study Med J Aust 1991 154(10):650 3 2034143
293 Golledge J, Cuming R, Beattie DK, et al Influence of patient-related variables on the outcome of carotid endarterectomy J Vasc Surg 1996 24(1):120 6 8691514
294 Hertzer NR, O'Hara PJ, Mascha EJ, et al Early outcome assessment for 2228 consecutive carotid endarterectomy procedures: the Cleveland Clinic experience from 1989 to 1995 J Vasc Surg 1997 26(1):1 10 9240314
295 Enevoldsen EM, Torfing T, Kjeldsen MJ, et al Cerebral infarct following carotid endarterectomy. Frequency, clinical and hemodynamic significance evaluated by MRI and TCD Acta Neurol Scand 1999 100(2):106 10 10442452
296 Zeiger HE, Jr., Zampella EJ, Naftel DC, et al A prospective analysis of 142 carotid endarterectomies for occlusive vascular disease, 1979-1985 J Neurosurg 1987 67(4):540 4 3655892
297 Zbornikova V, Lassvik C, Alm A. One year of prospective follow-up after carotid thromboendarterectomy - A clinical and duplex study. Acta Neurol Scand. 1998;98:248-253. [pmid: 9808274].
298 Rubin JR, Pitluk HC, King TA. Carotid endarterectomy in a metropolitan community: the early results after 8535 operations. J Vasc Surg. 1988;7:256-260. [pmid: 3339771].
299 Wilson SE, Mayberg MR, Yatsu F, et al. Crescendo transient ischemic attacks: a surgical imperative. J Vasc Surg. 1993;17:249-256. [pmid: 8433420].
300 Carmichael J. Carotid surgery in the community hospital. Arch Surg. 1980;115:937-939. [pmid: 7396701].
301 Hafner CD Minimizing the risks of carotid endarterectomy J Vasc Surg 1984 1(3):392 7 6481888
302 Nunn DB Carotid endarterectomy in patients with territorial transient ischemic attacks J Vasc Surg 1988 8(4):447 52 3172381
303 Hoyne RF Review of 272 consecutive carotid endarterectomies in a smaller community Surg Gynecol Obstet 1990 170(6):522 6 2343367
304 Kempczinski RF, Brott TG, Labutta RJ The influence of surgical specialty and caseload on the results of carotid endarterectomy J Vasc Surg 1986 3(6):911 6 3712637
305 Brott TG, Labutta RJ, Kempczinski RF Changing patterns in the practice of carotid endarterectomy in a large metropolitan area JAMA 1986 255(19):2609 12 3701975
306 Cebul RD, Snow RJ, Pine R, et al Indications, outcomes, and provider volumes for carotid endarterectomy JAMA 1998 279(16):1282 7 9565009
307 Karp HR, Flanders WD, Shipp CC, et al Carotid endarterectomy among Medicare beneficiaries: a statewide evaluation of appropriateness and outcome Stroke 1998 29(1):46 52 9445327
308 Troeng T, Bergqvist D, Norrving B, et al Complications after carotid endarterectomy are related to surgical errors in less than one-fifth of cases. Swedvasc--The Swedish Vascular Registry and The Quality Committee for Carotid Artery Surgery Eur J Vasc Endovasc Surg 1999 18(1):59 64 10388641
309 Wong JH, Findlay JM, Suarez-Almazor ME Regional performance of carotid endarterectomy. Appropriateness, outcomes, and risk factors for complications Stroke 1997 28(5):891 8 9158621
310 Kirshner DL, O'Brien MS, Ricotta JJ Risk factors in a community experience with carotid endarterectomy J Vasc Surg 1989 10(2):178 86 2760995
311 Richardson JD, Main KA Carotid endarterectomy in the elderly population: a statewide experience J Vasc Surg 1989 9(1):65 73 2911143
312 Dosick SM, Whalen RC, Gale SS, et al Carotid endarterectomy in the stroke patient: computerized axial tomography to determine timing J Vasc Surg 1985 2(1):214 9 3965754
313 Eckstein HH, Schumacher H, Laubach H, et al Early carotid endarterectomy after non-disabling ischaemic stroke: adequate therapeutical option in selected patients Eur J Vasc Endovasc Surg 1998 15(5):423 8 9633498
314 Giordano J, Trout H, Kozloff L, et al. Timing of carotid endarterectomy after stroke. J Vasc Surg. 1985;2:250-254. [pmid: 3974010].
315 Hoffmann M, Robbs J Carotid endarterectomy after recent cerebral infarction Eur J Vasc Endovasc Surg 1999 18(1):6 10 10388632
316 Paty PS, Darling RC, 3rd, Woratyla S, et al Timing of carotid endarterectomy in patients with recent stroke Surgery 1997 122(4):850 4 discussion 854 5 9347866
317 Plotrowski J, Bernard V, Rubin JR. Timing of carotid endarterectomy after acute stroke. J Vasc Surg. 1990;11:45-52. [pmid: 2296104].
318 Ricotta JJ, Nanni KM, Green RM, et al Use of oculopneumoplethysmography (OPG-Gee) following carotid endarterectomy J Vasc Surg 1985 2(3):415 8 3999231
319 Rosenthal D, Borrero E, Clark MD, et al Carotid endarterectomy after reversible ischemic neurologic deficit or stroke: is it of value? J Vasc Surg 1988 8(4):527 34 3172388
320 Whittemore AD, Mannick J Surgical treatment of carotid disease in patients with neurologic deficits J Vasc Surg 1987 5(6).
321 Gasecki A, Ferguson G, Eliasziw M, et al. Early endarterectomy for severe carotid artery stenosis after a nondisabling stroke: results from the North American Symptomatic Carotid Endarterectomy Trial. J Vasc Surg. 1994;20:288-95. [pmid: 8040954].
322 Counsell CE, Warlow C, Naylor R Patches of different types for carotid patch angioplasty (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
323 Counsell CE, Salinas R, Naylor R, et al Routine or selective carotid artery shunting for carotid endarterectomy (and different methods of monitoring in selective shunting) (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
324 Counsell CE, Salinas R, Warlow C, et al Patch angioplasty versus primary cosure for carotid endarterectomy (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
325 Tangkanakul C, Counsell CE, Warlow C Local versus general anaesthesia for carotid endarterectomy (Cochrane Review) In The Cochrane LibraryIssue 4,2000 Oxford, England: Update Software
326 AbuRahma AF, Khan JH, Robinson PA, et al Prospective randomized trial of carotid endarterectomy with primary closure and patch angioplasty with saphenous vein, jugular vein, and polytetrafluoroethylene: perioperative (30-day) results J Vasc Surg 1996 24(6):998 1006 discussion 1006 7 8976353
327 Cao P, Giordano G, De Rango P, et al A randomized study on eversion versus standard carotid endarterectomy: study design and preliminary results: the Everest Trial J Vasc Surg 1998 27(4):595 605 9576071
328 Dardik H, Wolodiger F, Silvestri F, et al Clinical experience with everted cervical vein as patch material after carotid endarterectomy J Vasc Surg 1997 25(3):545 53 9081137
329 Muuronen A Outcome of surgical treatment of 110 patients with transient ischemic attack Stroke 1984 15(6):959 964 6506124
330 Gumerlock M, Neuwelt E. Carotid endarterectomy: to shunt or not to shunt?. Stroke. 1988;19:1485-1490. [pmid: 3201506].
331 Kadwa AM, Robbs JV Carotid endarterectomy in Durban--the first 10 years S Afr Med J 1993 83(4):248 52 8316920
332 Shaw DA, Venables GS, Cartlidge NE, et al Carotid endarterectomy in patients with transient cerebral ischaemia J Neurol Sci 1984 64(1):45 53 6376714
333 Anonymous. Variation in the use of angiography and carotid endarterectomy by neurologists in the UK-TIA Aspirin Trial. BMJ. 1983;286:514-517. [pmid: 6402129]. [pmcid: 1546595].
334 Whisnant J, Sandok B, Sundt T. Carotid endarterectomy for unilateral carotid system transient cerebral ischaemia. Mayo Clin Proc. 1983;58:171-175. [pmid: 6827861].
335 Rothwell PM, Slattery J, Warlow CP Clinical and angiographic predictors of stroke and death from carotid endarterectomy: systematic review BMJ 1997 315(7122):1571 7 9437274
336 Feinberg WM Guidelines for the management of transient ischemic attacks. Ad Hoc Committee on Guidelines for the Management of Transient Ischemic Attacks of the Stroke Council, American Heart Association Stroke 1994 3(5):275 83
337 Wylie EJ, Hein MF, Adams JE. Intracranial hemorrhage following revascularaization surgery for treatment of acute stroke. J Neurosurg. 1964;21:212-215. [pmid: 14127622].
338 Giordano J. The timing of carotid endarterectomy after acute stroke. Semin Vasc Surg. 1998;11:19-23. [pmid: 9535282].
339 Pritz M. Carotid endarterectomy after recent stroke: preliminary observations in patients undergoing early surgery. Neurosurgery. 1986;19:604-609. [pmid: 3785598].
340 Whittemore A, Ruby S, Couch N, et al Early carotid endarterectomy in patients with small fixed neurological deficits J Vasc Surg 1984 1(6)795 799 6492307
341 Fryback D, Dasbach E, Klein R, et al. The Beaver Dam Health Outcomes Study: initial catalog of health-state quality factors. Med Decis Making. 1993;13:89-102. [pmid: 8483408].
342 Kent KC, Kuntz KM, Patel MR, et al Perioperative imaging strategies for carotid endarterectomy. An analysis of morbidity and cost-effectiveness in symptomatic patients JAMA 1995 274(11):888 93 7674503
343 Patel MR, Kuntz KM, Klufas RA, et al Preoperative assessment of the carotid bifurcation. Can magnetic resonance angiography and duplex ultrasonography replace contrast arteriography? Stroke 1995 26(10):1753 8 7570720