# Recommendations for Future Research

## Echocardiography

In the course of our review, we identified several information gaps related to the effectiveness of echocardiography in the management of patients with stroke. Most notable are the gaps in knowledge about the presence and degree of risk of stroke conveyed by echocardiographically identified lesions, and the efficacy of therapy in reducing that risk. Identifying the risk of recurrent stroke associated with echocardiographic lesions can be achieved through cohort studies of patients with and without these lesions, while the efficacy of treatment is best addressed through randomized controlled trials. Because randomized trials can address recurrent stroke risk and treatment efficacy simultaneously, this study design would provide the most valuable information needed to establish the usefulness of echocardiography in stroke. Trials of anticoagulation for complex aortic atheroma and ASA (with and without PFO) -- lesions for which available evidence suggests an association with stroke and which are observed relatively frequently -- may be the most appropriate for initial study. Some of these studies are already ongoing.

Additional studies that would help solidify the evidence related to echocardiography in stroke involve the accuracy and yield of echocardiography. Most studies of the accuracy of TTE in detecting LVT were conducted in the early 1980s, when echocardiography was still a relatively new technology. Newer studies assessing the accuracy of TTE in diagnosing LVT as verified surgically or pathologically would provide helpful data on which to base calculations of the effectiveness and cost-effectiveness of TTE in stroke patients. In addition, interobserver reliability should be assessed in these studies.

Further studies examining the yield of echocardiographic lesions on TTE and TEE would also add valuable information. Such studies would be most useful if consecutive stroke patients without AF were prospectively enrolled; if results were stratified by age, presence or absence of carotid artery stenosis, presence or absence of manifest cardiac disease, and stroke subtype and location; and if studies were conducted in community-based settings, preferably across multiple centers. This type of study would require collaboration across institutions, but data collection may be facilitated by the presence in some centers of stroke registries and registries of patients undergoing echocardiography.

Finally, studies establishing the complication rates of TEE in patients with stroke are needed. Because patients with stroke often have swallowing difficulties as well as coexisting heart disease, TEE-associated complications may occur more frequently in patients with stroke than in other patients. The harms associated with TEE must be accurately quantified in order to assess its overall utility.

Future economic evaluations would benefit from more accurate estimates of the cost of both TTE and TEE. While charges for these two tests, as assessed by Medicare, are similar, the actual cost of TEE may be substantially higher than that of TTE, due to the cost of additional time, equipment and personnel required for TEE. Microcosting studies may help clarify the cost of these additional expenditures.

## Carotid Imaging

While additional research on diagnostic accuracy, including studies that either eliminate or adjust for verification bias, may help to clarify the accuracy of CUS, the finding that accuracy may vary from center to center suggests that it may not be possible to establish a generalizable estimate of CUS sensitivity and specificity. It may be more fruitful to conduct studies examining the factors (e.g., technical experience, quality management programs) that allow some centers to achieve higher CUS accuracy than others.

High-quality studies of MRA accuracy and reliability, particularly for contrast-enhanced MRA, both alone and in combination with CUS, are needed. Such studies should prospectively image consecutive patients with stroke and angiographically verify the presence or absence of stenosis in all patients; if this is not possible, a random sample of patients with negative MRA should undergo angiography for the purpose of adjusting for verification bias. Multicenter studies would be helpful in limiting the potential influence of publication bias and in clarifying the variability of accuracy across centers.

Studies of CEA complications indicate that complication rates are highly variable. Collaborative studies assessing the sources of this variability and potential interventions to reduce it, as has been done for coronary artery bypass graft surgery, may improve the quality of operative care and thereby improve the effectiveness of all strategies for carotid imaging.

Trials assessing the efficacy and safety of early versus late CEA would help in determining the most appropriate timing of carotid imaging. If early CEA (e.g., within one week of initial symptoms) were found to be as safe as delayed CEA, early recurrent strokes (within 30 days of symptom onset) might be avoided, thereby increasing the efficacy of CEA. If this were the case, the effectiveness of carotid imaging might be maximized when done shortly after initial presentation.

In addition to these recommended clinical studies, future economic evaluations of carotid imaging strategies would benefit from comparisons of the outcomes of CEA with those of the latest non-surgical treatments for carotid stenosis. This would inform the issue of the appropriate comparator to CEA. Furthermore, economic evaluations would benefit from improved data on the epidemiology of recurrent stroke -- e.g., incidence of moderate and severe stenosis, relative benefits of CEA vs. non-surgical treatment -- and the utilization rates of various carotid imaging strategies among demographic subgroups. Finally, we recommend new studies of the costs and benefits of carotid imaging strategies beyond their use in decisionmaking about CEA -- e.g., the potential value of information from carotid imaging in the diagnosis and treatment of cardiac disease.