# Results -- Echocardiography

The effectiveness of echocardiography as a tool in the evaluation of patients with cerebral ischemia or infarction has not been established directly. Specifically, there have been no clinical trials comparing outcomes among patients managed with and without echocardiography after stroke or TIA. Assessing the usefulness of echocardiography in such patients therefore involves examining the evidence for several assertions that serve as links in a causal pathway between echocardiography and clinical outcomes, particularly recurrent stroke. These assertions are as follows:

- Clinically inapparent abnormalities identified by echocardiography convey increased risk of recurrent stroke;
- The prevalence of these abnormalities is not inconsequential;
- Echocardiography is accurate in diagnosing these abnormalities;
- Adverse events associated with echocardiography are small or infrequent compared to its benefits;
- Efficacious treatments exist that reduce morbidity and mortality associated with potential sources of cardioembolic stroke identified by echocardiography;
- Adverse events associated with these treatments are small or infrequent compared to their benefits.

## 1. Which clinically inapparent abnormalities identified by echocardiography among patients presenting with new ischemic brain syndrome represent risk factors for recurrent stroke?

### Background

Among patients presenting with stroke, echocardiography is useful to the extent that it can identify abnormalities that may have been causally related to the stroke and that, if persistent and untreated, may increase the risk of recurrent stroke or otherwise affect morbidity or mortality. Several abnormalities identifiable by echocardiography are thought to represent potential sources of cardioembolic stroke (Table 2).

Table 2. Potential sources of cardioembolic stroke

Identified Primarily by Echocardiography | Usually Known or Apparent at Presentation
Intracardiac thrombus | Atrial fibrillation
Left ventricle | Recent myocardial infarction
Left atrium | Dilated cardiomyopathy
Left atrial appendage | Rheumatic heart disease (mitral stenosis)
Left ventricular aneurysm | Prosthetic heart valves
Spontaneous echocardiographic contrast | Infective endocarditis
Atrial septal aneurysm | Non-bacterial thrombotic endocarditis
Patent foramen ovale
Mitral valve prolapse
Mitral annular calcification
Valvular strands
Aortic atheroma
Intracardiac tumors (atrial myxoma)

The presence of some potential sources of cardioembolic stroke is usually known or clinically apparent at the time a patient presents with a cerebral ischemic event. Atrial fibrillation, which accounts for nearly half of strokes classified as cardioembolic,^47, 48^ is diagnosed by electrocardiography, which is routinely performed in patients presenting with stroke. Likewise, the presence of a prosthetic heart valve can usually be established through the history or physical exam. Other potential sources of stroke -- recent myocardial infarction (MI), dilated cardiomyopathy (DCM), infective endocarditis, and rheumatic heart disease -- may be diagnosed echocardiographically but usually first manifest through symptoms other than cerebral ischemia and are therefore typically known at the time a patient presents with stroke or TIA. For instance, in a series of 133 cases of native-valve infective endocarditis, 17 patients (13 percent) presented with cerebral ischemia, but 15 of them also presented with other manifestations indicating the diagnosis of endocarditis.^ 49 ^ Among 839 patients with rheumatic mitral valve disease in one study, none developed cerebral ischemia before valvular disease was diagnosed.^ 50 ^ Stroke may frequently be the first manifestation of non-bacterial thrombotic endocarditis,^ 51 ^ but this condition typically occurs in the setting of malignancy, disseminated intravascular coagulation, or other severe acute or chronic illness^ 51 ^ and is therefore not relevant to the majority of patients presenting with stroke.

Some potential sources of cardioembolic stroke, however, are usually clinically occult at the time of presentation. Echocardiography has become the primary mechanism for identifying these abnormalities (Table 2). Prior to the advent of echocardiography, many of these lesions were not commonly detected and therefore not thought to be important in the pathogenesis of stroke. Only after the use of echocardiography became common among patients with stroke did these lesions garner attention as potentially important causes of cerebral ischemia. Some of these lesions are commonly observed on echocardiographic examinations of patients with stroke but are also common among individuals without stroke. Some abnormalities are seen more commonly in patients with stroke than in patients without stroke (e.g., left ventricular hypertrophy) but may serve merely as markers of other risk factors (e.g., hypertension) rather than as part of the etiologic pathway.

Finally, there are some patients for whom echocardiography may identify treatable lesions, but for whom other indications for the same treatment are evident without echocardiography. This is the case for patients with AF, who may have left atrial or ventricular thrombi identifiable by echocardiography, but for whom anticoagulant therapy is indicated regardless of whether or not thrombus is found.^ 52 ^ In other words, echocardiography may in some instances identify a source of stroke but not alter therapeutic management. In such cases, echocardiography typically does not add value in terms of management to reduce stroke recurrence, though it may be warranted for other reasons, such as to examine for the presence of structural heart disease. Echocardiography may also be useful in such cases if the decision about whether or not to initiate therapy is difficult; e.g., if anticoagulant therapy is relatively contraindicated in a patient with AF, echocardiography may help to "tip the scale" in making the decision to initiate therapy.

In this section, we address clinically inapparent lesions that are identified primarily by echocardiography and that may represent important sources of cardioembolic stroke. We reviewed the literature with the aim of elucidating the quality and strength of evidence for an independent association linking each lesion to ischemic stroke. We employed a "best evidence" approach, examining the highest quality evidence available for each lesion.^ 53 ^ We generally limited our review to studies of at least fair quality that used designs capable of assessing potential causal associations, i.e., cohort studies (including clinical trials) and case-control studies, and excluded case series and case reports. Because of limitations in the methods for selecting controls in many of the case-control studies, we also reviewed studies that reported the prevalence of lesions among random samples from general populations.

In addition to rating the quality of each study, we assessed the evidence for each lesion for the following features:

- Consistency of association across studies;
- Strength of association;
- Persistence of the size of the association after accounting for potential confounders;
- Incremental association between the severity of the lesion, or characteristics hypothesized to increase stroke risk, and the risk of stroke;
- Appropriate temporal relationship between occurrence of the lesion and stroke.

These factors represent epidemiological criteria that can aid in the judgment of whether or not a statistical association between two variables represents a cause-effect relationship.^ 54 ^ Particularly important is the issue of confounding. Because studies of associations between echocardiographic lesions and stroke are necessarily observational rather than experimental, it is essential to consider the possibility that observed associations are explained not by the hypothesized risk factor but rather by confounding factors -- variables that are associated with both risk factor (i.e., the echocardiographic lesion) and outcome (i.e., stroke). We examined not only whether studies accounted for potential confounding factors but also the degree to which the size of an observed association changed with adjustment for confounding factors. Even when an association remains statistically significant after adjustment for potential confounders, a substantial reduction in the size of the association with adjustment suggests that the remaining association may be due to "residual" confounding by unmeasured or inadequately measured variables.

### Findings

#### Cohort Study of Echocardiographic Lesions and Recurrent Stroke

We identified one fair-quality prospective cohort study examining the risk of recurrent stroke associated with several different echocardiographic lesions in patients presenting with stroke or TIA. This study, by Comess et al.,^ 55 ^ conducted at a university and Veterans Affairs hospital in California, examined 145 consecutive patients with acute stroke or TIA with TEE and followed 139 of these patients for a mean duration of 18 months. Recurrent stroke was ascertained by chart review and was not blinded to echocardiographic findings. The degree of association with recurrent stroke was reported for left atrial thrombus (LAT), interatrial shunt, and atrial septal aneurysm (ASA). The presence of potential confounding factors, including age, sex, cardiovascular risk factors, history of MI, carotid stenosis, and treatment with anticoagulants or aspirin, did not significantly differ among patients with and without recurrent stroke. Statistical adjustment for these confounding factors was not performed. We refer to this study in the sections below, where relevant.

#### Left Atrial Thrombus

Thrombi of the left atrium, including both the left atrial cavity and appendage, are thought to be important causes of stroke. Patients with AF have a high risk of stroke that is substantially reduced with anticoagulant therapy, suggesting that the pathogenesis of stroke in AF involves embolization from LAT. However, many patients with AF have structural heart disease or hypertension, both of which may contribute to a higher risk of stroke independent of LAT. Moreover, it is not clear if LAT occurring in patients without AF increases the risk of stroke.

The cohort study by Comess et al. included only four patients with LAT, two of whom were in AF.^ 55 ^ We did not identify any other studies of fair or good quality examining the risk of primary or recurrent stroke among patients with LAT but without AF.

We identified two fair-quality prospective cohort studies assessing the risk of primary stroke associated with LAT in patients with AF.^56, 57^ The first of these involved a subset of patients enrolled in the Stroke Prevention in Atrial Fibrillation study (SPAF-III), a North American, multicenter, randomized controlled trial of high-dose warfarin vs. low-dose warfarin plus aspirin for patients with AF.^ 56 ^ Three hundred eighty-two patients voluntarily underwent TEE after randomization. Thirty-eight of these patients (10 percent) were found to have thrombus in the left atrial appendage, and 3 of these 38 also had thrombus in the atrial cavity. The presence of LAT was associated with a 2.7-fold increased risk (p =.04) of ischemic stroke and systemic embolism over a period of 2.5 years.^ 56 ^ Outcomes were ascertained by an event verification committee when either routine clinical examinations or patients' responses to an annual questionnaire suggested a stroke. Although patients and outcome evaluators were blinded to treatment allocation, it is not clear that either party was blinded to the presence or absence of thrombus. It is possible that patients and evaluators were more likely to recognize or diagnose stroke in patients with known thrombus. This potential bias is mitigated by the fact that all patients had AF and were participating in a study of therapy to reduce stroke risk, which likely heightened clinicians' and patients' awareness of the possibility of stroke, regardless of the presence or absence of thrombus. Adjustment for potential confounding factors, including age and cardiovascular risk factors, was not reported.

The Embolism in Left Atrial Thrombi (ELAT) study, conducted in Austria and Slovakia, compared the incidence of stroke in 10 patients with definite LAT diagnosed by TEE with the incidence in 376 patients without LAT over a mean followup period of nearly 5 years.^ 57 ^ Four patients (40 percent) with LAT suffered a stroke compared with 42 (11 percent) without LAT (relative risk 3.9; 95 percent confidence interval [CI] 1.4 to 10.1). After adjustment for hypertension, age, and previous stroke, the size of this association diminished and was no longer statistically significant, though a strong association could not be excluded (relative risk 2.4; 95 percent CI, 0.9 to 6.9).^ 57 ^ As with the previous study, outcome ascertainment was not blinded to the presence of LAT.

In summary, there is insufficient evidence regarding an association between LAT and stroke among patients without AF. Among patients with AF, evidence from two fair-quality cohort studies suggests a possible association, but whether this association is confounded by other factors is unclear.

#### Left Ventricular Thrombus

Left ventricular thrombus (LVT) typically occurs in the setting of a diseased left ventricle. Conditions predisposing to LVT include DCM; MI, particularly of the anterior myocardium; and left ventricular aneurysm.^ 58 ^ It is thought that "fresh" thrombus in the left ventricle, which classically develops within the first 4 weeks after an anterior MI, is a source of systemic embolism. In a systematic review of 11 cohort studies with a total of 856 patients, Vaitkus et al. found that patients with LVT detected by two-dimensional echocardiography after acute anterior Q-wave myocardial infarction had a significantly increased risk of systemic embolism when compared to patients without LVT after MI (pooled odds ratio 5.45; 95 percent CI, 3.02 to 9.83).^ 59 ^ The authors also observed that in seven cohort studies including 270 patients with LVT, anticoagulant therapy was associated with decreased risk of systemic embolism (pooled odds ratio 0.14; 95 percent CI, 0.04 to 0.52).^ 59 ^ In both of these analyses, statistical testing demonstrated heterogeneity across the included studies, suggesting uncertainty with regard to the validity of pooling data. The review was also limited by inadequate description of search strategies and of the criteria, if any, employed to rate the quality of included studies. Moreover, confounding factors were not assessed. Given the poor quality of this meta-analysis, firm conclusions regarding the association between LVT and stroke cannot be drawn. However, the size and consistency of the relationship between acute LVT and systemic embolism across studies suggest an independent association in patients with MI.

More controversial is whether chronic LVT in patients without recent MI carries a risk of embolization. Over time, LVT undergoes organization and becomes less friable. Moreover, the surface of a LVT may become smooth, particularly when it occurs within a left ventricular aneurysm, so that it becomes less prone to fragmentation from turbulent blood flow.

We identified a single fair-quality prospective cohort study that examined the relationship between chronic LVT and stroke.^ 60 ^ In this study, 85 consecutive patients with LVT detected by two-dimensional echocardiography were compared to 91 consecutive patients without thrombus, who were either referred for echocardiography to detect LVT or were at high risk for developing thrombus (had left ventricular (LV) aneurysm or anterior MI with reduced LV function). The two groups were similar in terms of age, history and recency of MI, left ventricular function, presence of atrial fibrillation, and treatment with warfarin or anti-platelet therapy. Patients were followed for an average of 22 months for surgically or autopsy-confirmed systemic embolism or embolic stroke defined by clinical criteria.^ 61 ^ Ascertainment of stroke was not blinded to echocardiographic findings. Rates of all systemic embolism were higher in the group with thrombus than in the control group (13 percent vs. 2 percent, relative risk 5.89, p<.01), as were rates of stroke (9 percent vs. 2 percent, relative risk 4.28, p=.04).^ 60 ^ All embolic events associated with LVT occurred more than one month after MI, and nine of them occurred more than 6 months after MI. The authors also found that thrombus protrusion and mobility, characteristics hypothesized to increase the risk of embolism,^62-64^ were strongly associated with the rate of embolism. Rates of embolism were similar for thrombi associated and not associated with LV aneurysms.

Although this prospective study found a strong association between chronic LVT and subsequent stroke, and an incremental risk associated with LVT characteristics hypothesized to increase stroke risk, it is the only study we identified that examined this association. Furthermore, patients with LVT in this study were more likely than those without LVT to have a history of prior embolism. While prior embolic events may have been due to LVT, they may also have been due to other factors that placed the patients with LVT at higher risk of recurrent embolism, independent of the LVT itself. Statistical adjustment for this and other risk factors for stroke was not performed.

We identified three other cohort studies that assessed the risk of systemic embolism associated with LVT in patients with DCM.^65-67^ In a prospective study of good quality, 54 of 109 ambulatory patients (50 percent) with DCM, and without recent MI, were found by TTE to have LVT.^ 65 ^ Those with and without thrombus were comparable in terms of baseline characteristics, including presence of atrial fibrillation (13 percent) and use of anticoagulants (13 percent). During a mean followup period of 2 years, cerebral embolization occurred in four patients with and no patients without LVT (5.3 vs. 0 events per 100 patient-years). Outcome assessment in this study was masked to echocardiographic findings. In another, fair-quality, prospective cohort study employing serial echocardiograms, 11 of 25 patients were found at enrollment to have LVT, and another three developed LVT during followup. Five of the 25 patients experienced systemic emboli (four with stroke or TIA) over a 21-month followup period.^ 66 ^ Four of these five patients had a thrombus on the echocardiogram most recently preceding their embolic event. Finally, in a third, poor-quality retrospective study, five of 112 patients without LVT and none of 14 patients with LVT had a systemic embolic event over a mean followup period of 41 months.^ 67 ^ However, all patients with LVT were receiving anticoagulant drugs; the proportion of those without LVT on anticoagulants was not mentioned.

In summary, there is fair overall evidence from three prospective cohort studies for an association between LVT and systemic embolism -- including stroke -- among patients without recent MI. Two of these studies involved only patients with DCM. The estimated absolute increase in risk of primary stroke associated with LVT in one study was 7 percent over a period of 22 months,^ 60 ^ and in another was 5.3 percent per year.^ 65 ^

#### Left Ventricular Aneurysm

Left ventricular aneurysms are thin-walled, dyskinetic areas of myocardium that typically develop in the aftermath of transmural MI.^ 68 ^ Surgery and autopsy studies have demonstrated that nearly half of LV aneurysms contain thrombi.^ 68 ^ However, because thrombi within LV aneurysms often do not protrude into the ventricular cavity, they are not exposed to the shearing forces of blood flowing through the ventricle and thus may not pose a significant risk of embolization. The benefit of treating or preventing thrombus in an identified LV aneurysm in patients without recent MI is therefore uncertain.

We did not identify any cohort studies of the incidence of stroke in patients with and without LV aneurysm, nor any case-control studies of LV aneurysm in patients with and without stroke. One uncontrolled, retrospective study of fair quality examined the incidence of stroke among all patients diagnosed with LV aneurysm by ventriculography at the Mayo Clinic during a 9-year period.^ 69 ^ No patient had experienced MI within the month prior to the identification of LV aneurysm. Over a median followup period of 5 years, one of 76 patients suffered an embolic event. The incidence of any embolism among patients not treated with anticoagulants was 0.35 per 100 patient-years. This is approximately three times higher than the rate of cerebral infarction in the general population of Rochester, Minnesota,^ 70 ^ where this study was conducted, but the comparability of patients in this cohort with those in the general population is unknown. Outcome assessment in this study was subjective and not blinded to the purpose of the study.

In summary, there is insufficient evidence to draw conclusions regarding an association between LV aneurysm and stroke.

#### Spontaneous Echocardiographic Contrast

Spontaneous echocardiographic contrast (SEC) refers to the observation of swirling, smoke-like echoes observed within the heart chambers during echocardiography. SEC is thought to represent aggregates of red blood cells and plasma proteins in the setting of low flow states^ 71 ^ and is typically observed in the left atrium. SEC is associated with LAT and is therefore felt to be a marker of high thromboembolic risk.^ 56 ^

SEC is most frequently observed in the setting of AF, occurring in more than half of such patients in some series.^ 56 ^ As with LAT, it is important to understand whether SEC is associated with a high risk of stroke in patients with a normal cardiac rhythm, because the treatment implications of SEC in patients with AF, for whom anticoagulant therapy is usually indicated regardless of echocardiographic findings, are less clear. We identified one poor-quality study of patients with left atrial SEC and sinus rhythm.^ 72 ^ In this cross-sectional study, a review of 1,288 consecutive reports from TEE examinations performed at a university hospital from 1993 to 1997 revealed 195 cases of left atrial SEC, 24 of which were in patients with sinus rhythm. The echocardiographic and clinical characteristics of these 24 patients were compared to 45 age-matched patients without SEC. Criteria for selection of controls included normal sinus rhythm, left atrial dilatation (> 4 cm), and absence of mitral regurgitation. These criteria were chosen to eliminate the potential effect of confounding from these variables. Clinical variables were abstracted from medical records. The authors found that patients with SEC had larger left atria than controls, more frequently had LAT (three cases vs. zero controls, p <.02), and were more likely to have experienced stroke (83 percent vs. 56 percent, p < 02).^ 72 ^ The association of SEC with stroke persisted after adjustment for left atrial size (p = .03). This study was limited in several ways. First, the temporal relationship between the finding of SEC and the occurrence of stroke was not clear; i.e., the authors did not indicate whether documented strokes occurred before or after determination of SEC nor the duration of time between the occurrence of stroke and the TEE demonstrating SEC. Second, ascertainment of stroke was not blinded to the presence or absence of SEC. Finally, TEE operators were not blinded to clinical information and may have been more apt to search for SEC in patients referred for TEE for the purpose of identifying a source of cardioembolic stroke.

Studies of SEC in patients with AF have provided conflicting information.^56, 57^ In the SPAF-III trial, 63 percent of 382 patients with AF undergoing TEE were found to have SEC. Over a 2.5-year followup period, SEC was not associated with stroke.^ 56 ^ However, when patients with "dense" SEC, defined as continuously visible SEC at standard sonographic gain settings, were compared to those with lesser or no SEC, there was a trend toward higher incidence of embolism among patients who were not receiving high-dose anticoagulant therapy (relative risk 2.7, p = .06). This association was unchanged after multivariate analysis adjusting for other echocardiographic findings, including LAT (p = .06). The association was not observed among patients receiving high-dose anticoagulation. The investigators also found a graded association between SEC and LAT: 24 percent of patients with dense SEC, 10 percent with faint SEC, and 3 percent with no SEC were found to have LAT. These data suggest that SEC may be a marker or precursor of LAT, that patients with AF and SEC may be at particularly high risk of embolism, and that the benefit of anticoagulation in reducing stroke risk among patients with AF may be more pronounced in the presence of SEC.

In contrast to these findings, the ELAT investigators found no significant association between the presence of SEC and subsequent stroke or embolism during a 5-year followup period.^ 57 ^ The prevalence of SEC in this study, in which all patients had AF, was only 11.5 percent. Moreover, the quantity, or density, of SEC was not determined in this study. The potential limitations of these two studies were discussed earlier in this report (see section on LAT).

In summary, there is insufficient evidence regarding an association between SEC and stroke in patients without AF. Evidence from two fair-quality cohort studies provides conflicting information about the risk of stroke among patients with SEC and AF.

#### Atrial Septal Aneurysm

Atrial septal aneurysms (ASAs) are typically defined as a bulging of a portion of the atrial septum into the right and/or left atrium. It is thought that ASA may give rise to stroke either through the formation of thrombi within the aneurysm itself or through paradoxical embolization of venous thrombi through fenestrations of the ASA or through an associated atrial septal defect or patent foramen ovale (PFO). The prevalence of ASA in the general population ranges from 2 to 13 percent.^73, 74^

The best evidence of an association between ASA and stroke comes from a good-quality, prospective cohort study conducted in 30 academic neurology departments throughout Europe that included 581 patients aged 18-55 with cryptogenic stroke (stroke of undetermined cause).^ 75 ^ All patients underwent TEE assessment for atrial septal abnormalities, including ASA and PFO, and were followed for four years. Echocardiograms underwent blinded review, outcome assessment was masked, and confounding factors were assessed and controlled in statistical analyses. Recurrent stroke was more common in the 61 patients with ASA than in the 520 patients without it (9.8 percent vs. 3.5 percent, p=0.03). All patients experiencing recurrent stroke in the ASA group, however, also had a PFO (see below).

In the cohort study by Comess et al. described earlier, the rate of recurrent stroke or TIA was significantly higher among 31 patients with ASA than the 108 patients without ASA (16.9 vs. 6.2 recurrent events per 100 patient-years, p = 0.046).^ 55 ^ It was not clear whether this apparent association was confounded by AF or other risk factors for stroke.

A recent systematic review of good quality, by Overell and colleagues, summarized the evidence from published case-control studies of the association between ASA and stroke.^ 76 ^ In nine studies, the prevalence of ASA as detected by TEE was more common in 364 patients with stroke than in 532 control subjects without stroke (odds ratio 2.35; 95 percent CI, 1.46 to 3.77). There was significant heterogeneity across the nine studies, which appeared to be attributable to differences in the mean age of the study populations. Studies of younger patients consistently demonstrated an association between ASA and stroke (odds ratio 6.14; 95 percent CI, 2.47 to 15.22), while studies of older patients were inconsistent in their results. Three studies of ASA in patients with cryptogenic stroke, as compared to non-stroke control subjects, also found a consistent association (odds ratio 4.12; 95 percent CI, 2.72 to 6.26).

Four of the studies reviewed by Overell compared the prevalence of ASA in patients with and without stroke and met our criteria for being original, good- or fair-quality studies.^77-80^ One of the studies, of good quality, found no association between the prevalence of ASA in patients with first-ever stroke and in age- and sex-matched population controls in Sweden.^ 80 ^ The mean age of subjects in this study was 73.

One good- and two fair-quality studies found an association between ASA and stroke (odds ratios 3.65 to 4.67).^77-79^ One of these studies included only patients under 55.^ 79 ^ Another included only patients 45 and older.^ 77 ^ In the third study, the mean age was 63, and the prevalence of ASA was not different among those older and younger than 55.^ 78 ^ The pooled odds ratio from these three studies was 4.30 (95 percent CI, 2.67 to 6.93).

All three studies addressed the possibility of confounding by other potential risk factors for stroke by reanalyzing their data after excluding patients with potential confounding factors, including intracardiac thrombus, aortic atheroma, AF, mitral stenosis, MI, carotid artery disease, and cardiac tumors.^77-79^ An important potential confounder of the association between ASA and stroke is the presence of coexisting PFO. The prevalence of concomitant PFO in patients with ASA ranges from 34 to 82 percent.^75, 77-79, 81, 82^ In the European cohort study discussed above, 51 of the 61 patients with ASA had a concomitant PFO.^ 75 ^ All recurrent strokes occurred in these 51 patients, and the adjusted hazard ratio for recurrent stroke or TIA among patients with combined ASA and PFO was 4.17 (95 percent CI, 1.47-11.84). Because there were so few patients with ASA alone in this study, the authors could not statistically exclude the possibility that the risk of stroke with ASA alone was similar to the risk with combined ASA and PFO. It was therefore not clear whether the increased risk of stroke associated with ASA and PFO was attributable to ASA or to the combination of the two lesions.

In a good-quality case-control study, the association between ASA and stroke was similar in patients with or without a PFO.^ 77 ^ However, Overell and colleagues found in their meta-analysis that the association of combined ASA and PFO with stroke was consistent and stronger than the association with stroke of ASA or PFO alone.^ 76 ^ In four studies of patients of all ages, the odds ratio for the association of stroke with combined ASA and PFO was 5.25 (95 percent CI, 2.91 to 9.45); in two studies of young patients, the combined odds ratio was 15.6 (2.83 to 85.9).

One study examined the association of stroke and ASA of varying severity.^ 79 ^ The investigators found an odds ratio of 1.2 (95 percent CI, 0.3 to 5.2) when aneurysmal excursion was 10 millimeters or less, and 8.5 (95 percent CI, 1.0 to 69) when it was greater than 10 millimeters.

In two of the case-control studies discussed above, echocardiographic interpretation was blinded to clinical status,^77, 79^ while in others, interpretation was not blinded and was therefore subject to bias. It must be noted, however, that even when interpretation of recorded echocardiograms is blinded, the possibility of ascertainment bias remains when the technician performing the echocardiogram is aware of the patient's clinical status. In that case, the technician may be more vigilant about searching for ASA and other lesions in patients referred for the purpose of diagnosing potential sources of cardioembolic stroke. None of the three studies reported blinding of echocardiogram performance. Two studies, however, included community-based controls who underwent TEE for the purpose of documenting the prevalence of ASA and other stroke risk factors in the general population.^77, 80^ The fact that identifying ASA was an explicit purpose of conducting echocardiography in these controls may have reduced the potential for bias. In the European cohort study, echocardiograms were obtained at the time of the initial stroke, and recurrent strokes were determined by evaluators masked to echocardiographic findings. Ascertainment bias therefore did not affect this study.

In summary, there is fair evidence from two cohort studies and numerous case-control studies for an association between ASA and stroke. In the cohort studies, the absolute increase in annual risk of recurrent stroke associated with ASA was 10.7 percent in one^ 55 ^ and approximately 3 percent in the other.^ 75 ^

The association between ASA and stroke appears consistent across most studies and in one study was incrementally related to increasing aneurysmal excursion. The association has been most consistently observed, however, in young patients (under 55), and whether or not there is an independent association between ASA and stroke in elderly patients in unclear. In younger patients, the association appears to be stronger with the combination of ASA and PFO as compared to ASA alone.

#### Patent Foramen Ovale

Patent foramen ovale, an interatrial opening that allows shunting of blood between the right and left heart, occurs relatively commonly in the general population. In two population-based samples of individuals volunteering to undergo TEE, the prevalences of PFO were 26 and 22 percent.^73, 74^ By allowing emboli to pass from the right into the left atrium, PFOs, and less commonly atrial septal defects (ASD), provide a conduit for emboli arising in the systemic venous system to enter the systemic arterial system, without being filtered in the pulmonary vascular bed. It is thought that PFO may be particularly important in the pathogenesis of stroke among patients with known venous thrombosis and in patients whose symptoms develop after cough or Valsalva, which increases right-to-left shunting in patients with interatrial communications. Whether PFO plays an important role in other patients with stroke has remained unclear.

In the European cohort study discussed above (see section on ASA), there was no difference in recurrent stroke rates between patients with PFO (4.5 percent) and those without it (3.8 percent).^ 75 ^ In fact, when patients with PFO alone (i.e., without concomitant ASA) were considered, the recurrent stroke rate was only 2.8 percent.

The cohort study by Comess et al. found a higher rate of recurrent stroke or TIA among patients with PFO or ASD than among those without interatrial shunts (14.4 versus 6.9 recurrent events per 100 patient-years), although this association was not statistically significant (p=0.127) and was not adjusted for potential confounders.^ 55 ^ We did not identify other cohort studies of fair or good quality comparing recurrent stroke rates among patients with and without PFO.

The systematic review by Overell et al. included 15 studies comparing the prevalence of PFO, as detected by TTE, TEE, or transcranial Doppler (TCD), in 4,034 patients with and without stroke.^ 76 ^ The pooled odds ratio for the association between PFO and stroke was 1.83 (95 percent CI, 1.25 to 2.66). As in the studies of ASA, there appeared to be heterogeneity across studies due to different mean age. In patients < 55, the PFO-stroke relationship was stronger (odds ratio 3.10; 95 percent CI, 2.29 to 4.21) than in older patients (odds ratio 1.60; 95 percent CI, 0.63 to 4.06). The association was also stronger when only patients with cryptogenic stroke were included (odds ratio 2.95; 95 percent CI, 2.01 to 4.33).

Most of the studies reviewed by Overell met our criteria for being of good or fair quality. Of the studies assessing PFO as detectable by echocardiography, however, the majority used as control subjects patients who underwent echocardiography for reasons other than stroke. Because the diagnosis of PFO is typically less relevant in patients without stroke than in patients with stroke, it is possible that the diagnosis in these studies was pursued less vigorously in controls than in cases. This is especially pertinent in light of the fact that in most studies, neither echocardiographic operation nor interpretation was blinded to clinical data. The criterion for diagnosis in most studies was visualization of > 2 to 5 microbubbles of contrast in the left atrium within three cardiac cycles of contrast appearance in the right atrium. Because diagnosing PFO requires proper timing and positioning of the echocardiographic transducer, and in many cases also requires patients' cooperation, effort, and timing in performing Valsalva, it is possible for bias to enter studies in which operators are aware of the relative importance of diagnosing PFO. One method of diminishing such bias in ascertainment is to examine the reliability of diagnosis by two independent observers. Four studies reported inter-observer disagreement, which varied from 0 to 3.3 percent.^79, 83-85^ Three studies also used appropriate control subjects. Two used population-based controls and found no association between PFO and stroke.^80, 84^ The other examined patients undergoing a special type of surgery, for whom the diagnosis or exclusion of PFO was necessary to determine proper patient positioning to avoid risk of air embolism.^ 86 ^ This study found a strong association between PFO and stroke in patients under 55.

Further evidence of possible ascertainment bias comes from the prevalence of PFO among control groups. In the studies summarized by Overell that demonstrated a significant association between echocardiographically diagnosed PFO and stroke,^ 76 ^ the prevalence of PFO among controls was approximately 8 percent. In those studies that demonstrated no association, the prevalence among controls was 14 percent. Population-based studies have demonstrated the prevalence of PFO in the general population to be over 20 percent.^73, 74^ This discrepancy suggests that the association between PFO and stroke may have resulted from less rigorous ascertainment of PFO in control subjects than in stroke patients, rather than from a true independent relationship. In the European cohort study, in which echocardiograms were performed prospectively, and outcome assessment was masked, no association between PFO and stroke recurrence was found.^ 75 ^

Another factor that may confound the association of PFO with stroke is the high prevalence of coexisting ASA.^77-79, 81^ In the European cohort study, those with combined PFO and ASA had a significantly increased risk of stroke, while those with PFO alone did not.^ 75 ^ As discussed above, in the meta-analysis by Overell, the pooled odds ratio for the association between combined PFO and ASA with stroke was stronger (odds ratio 5.25; 95 percent CI, 2.91 to 9.45) than the association between isolated PFO and stroke.^ 76 ^ One study excluded patients with ASA and found no association between PFO and stroke.^ 83 ^ Another study examined the independent effect of PFO and ASA among patients under 55. In bivariate analysis, the odds ratio for the association between PFO and stroke was 3.4 (p <.005). When PFOs not associated with ASA were considered separately, the odds ratio fell to 2.0 and was no longer statistically significant. The combination of PFO and ASA in this study had a strong association with stroke (odds ratio 16.4; 95 percent CI, 2.1 to 129).^ 79 ^

We evaluated a cohort study of fair quality in which 34 patients diagnosed with PFO by TEE were divided into groups with large (16 patients) and small (18 patients) right-to-left shunts, defined as the appearance of 20 or more vs. less than 20 microbubbles in the right atrium.^ 87 ^ The echocardiographer in this study was blinded to clinical data. These patients were then followed for clinical outcomes, which were assessed by an evaluator blinded to degree of shunt. Five patients in the large-shunt group and no patient in the small-shunt group suffered fatal or non-fatal stroke or TIA during a mean followup period of 21 months (p = .03). The mean age in the large-shunt group was 58, compared with 54 in the small-shunt patients. Although this study was small and did not include adjustment for potential confounders, its findings, if verified in future studies, suggest the potential for a causal relationship between PFO and stroke that may not be restricted to young patients.

Further evidence that PFO may be a risk factor for stroke comes from studies of treatment. A recent meta-analysis demonstrated that patients with stroke found to have PFO had a lower rate of recurrent stroke when treated with warfarin or surgical closure of the PFO than when treated with antiplatelet therapy alone.^ 88 ^ There were, however, no randomized trials among the five studies reviewed. All were retrospective cohort studies, leaving the possibility that differences in outcome were attributable to confounding factors, rather than treatment; for example, those selected for therapy may have been the healthiest patients and therefore the least likely to experience recurrent stroke.

In summary, good- and fair-quality studies provide conflicting information as to whether an independent association exists between PFO and stroke. Although there is suggestive evidence that PFO may be a risk factor for stroke among young patients, this evidence is hampered by potentially significant biases. The best available evidence, from a prospective, multicenter cohort study, determined that there was no association between PFO alone and stroke.^ 75 ^ If PFO does play a role in the pathogenesis of stroke, it is likely to be most important among patients with coexisting ASA.

#### Mitral Valve Prolapse

Several studies published in the early 1980s in which TTE findings among patients with stroke were compared to those in patients undergoing TTE for other reasons reported an association between mitral valve prolapse (MVP) and stroke, particularly among young patients.^89-91^ The pathogenesis of stroke related to MVP was unclear but thought to be due to thrombi developing on the surface of the prolapsing valve. The strongest and most convincing association between MVP and stroke was demonstrated in a study in which 60 patients of age 45 years or younger presenting with stroke were compared to age-matched controls.^ 89 ^ MVP occurred in 40 percent of cases and only 6.8 percent of controls (odds ratio 6.0, p <.001). Six of the 24 cases of stroke in patients with MVP had recognizable causes identified. Of the other 18, most had no atherosclerotic disease on angiography and no other traditional risk factors for stroke. The authors concluded that MVP was a significant risk factor for stroke.^ 89 ^

Since that time, several studies have cast doubt on the association between MVP and stroke.^92-97^ One fair-quality cohort study conducted in Olmsted County, Minnesota, revealed that although individuals with MVP had an increased risk of stroke compared with the general population (standardized morbidity ratio 2.1; 95 percent CI, 1.3 to 3.2), this risk was observable only in those with MVP and coexisting ischemic heart disease, congestive heart failure, or diabetes.^ 92 ^ Among patients with isolated MVP, there was no increased risk (standardized morbidity ratio 1.0; 95 percent CI, 0.2 to 2.9). The authors did not report whether comorbidities confounded the association between MVP and stroke or merely modified its effect. In a separate study, the same investigators found that among patients with initial stroke, MVP did not increase the risk of recurrent stroke over a 4-year followup period.^ 93 ^

A recent good-quality case-control study conducted at a teaching hospital in Massachusetts compared the prevalence of MVP among stroke patients < 45 years old to age-matched controls undergoing echocardiography prior to receiving anthracycline chemotherapy.^ 94 ^ The authors designed their study to be similar to the study by Barnett et al.,^ 89 ^ which demonstrated a six-fold increase in the prevalence of MVP in young stroke patients compared to controls using M-mode echocardiography. The motivation for replicating the earlier study was to determine whether the association between MVP and stroke was spuriously observed due to inaccurate diagnosis. Improved two-dimensional echocardiographic methods demonstrated that the diagnosis of MVP using M-mode echocardiography was highly dependent on the angle of insonation.^ 94 ^ The investigators found that when more reliable and specific criteria for diagnosis were used, the prevalence of MVP was much lower (2.3 percent) than previously observed and was similar among 213 young patients with stroke (1.9 percent) and 263 age-matched controls (2.7 percent). Patients with cryptogenic stroke also had the same prevalence of MVP (2.8 percent) as the control group. The apparent prevalence of MVP was higher when M-mode echocardiography alone was used to make the diagnosis (9.2 percent). Moreover, changing the angle of the ultrasound beam during M-mode exams varied the observed prevalence of MVP from 9.2 percent to 53 percent. The authors hypothesized that although the study by Barnett et al. included blinded interpretation of echocardiograms, recording of echocardiograms was not blinded and may have been biased, giving rise to a spuriously high prevalence of M-mode MVP patterns in stroke patients as compared to controls.^ 94 ^ One case-control study attempted to avoid the bias introduced by unblinded echocardiographers by including controls who had conditions that mimicked stroke (e.g., multiple sclerosis, intracranial tumor).^ 97 ^ The investigators found no association between MVP and stroke, although the study included only 30 patients with stroke and only one with MVP.

One fair-quality case-control study using two-dimensional TTE and TEE found MVP to be associated with stroke in young patients in Germany.^ 98 ^ In this study, 24 (60 percent) of 40 patients under 45 with stroke were found to have MVP by TEE, as compared to 5 (17 percent) of 29 age-matched control subjects (odds ratio 7.20; 95 percent CI, 2.27 to 22.7). Most of the patients with MVP had morphologic changes of the mitral valve as well. Echocardiographic performance and interpretation in this study were reported to be blinded to clinical data. Adjustment for confounders was not performed, but several risk factors for stroke (e.g., hypertension) were more frequent in patients without MVP. It is noteworthy that in this study, the prevalence of MVP in stroke patients was substantially higher than in other studies using two-dimensional echocardiography,^94-97^ suggesting that the investigators may have used diagnostic criteria that were highly sensitive but not specific.

In summary, previous studies linking MVP to stroke may have been biased due to inaccurate measurement. Evidence from most studies using two-dimensional rather than M-mode echocardiography, including one fair-quality cohort study and one good-quality case-control study, suggests that the prevalence of MVP is lower than previously documented and is not more prevalent among patients with stroke than among those without stroke.

#### Mitral Annular Calcification

Calcium deposits in the annulus of the mitral valve are thought to be potential sources of calcific emboli to the brain, particularly among elderly patients. Several early cohort studies^99-101^ and one case-control study^ 102 ^ examined the association between mitral annular calcification (MAC) and stroke. Three of these studies demonstrated a significant association between MAC and stroke (relative risk 1.7 to 4.6) but did not account for potential confounding factors.^99, 100, 102^ In a report from the Framingham cohort study, individuals with MAC compared to those without it had a 2.7-fold increased risk of having a first stroke, as determined by evaluators blinded to the presence or absence of MAC.^ 101 ^ The risk of stroke increased with increasing thickness of annular calcium deposits. After adjusting for age, sex, blood pressure, diabetes, smoking, AF, coronary heart disease, and congestive heart failure, the relative risk decreased to 2.1 but remained statistically significant (p = .006). Notably, however, the investigators did not adjust for the degree of carotid stenosis.

A subsequent prospective cohort study of fair quality followed 657 patients with MAC and 562 without MAC in the Netherlands over an average period of 2.4 years. Patients with MAC were slightly more likely to experience stroke than those without MAC (relative risk 1.62).^ 103 ^ After adjusting for multiple risk factors, including carotid artery stenosis, there was no apparent association of MAC with stroke (hazard ratio 0.76, 95 percent CI, 0.42 to 1.36). A good-quality cross-sectional study examined the prevalence and degree of carotid artery stenosis among patients with and without MAC in Israel and found that patients with MAC were more likely to have carotid stenosis and that the strength of this association increased with MAC thickness.^ 104 ^

In summary, there is fair evidence that the association between MAC and stroke is confounded by carotid stenosis. MAC may be a marker of increased stroke risk due to cerebrovascular disease but is not likely an independent predictor of stroke risk.

#### Valvular Strands

The discovery with TEE of thin, filamentous material attached to the mitral and aortic valves of patients with stroke has raised suspicion that valvular excrescences, or "strands," may play a role in the pathogenesis of stroke. One fair-quality cohort study from a Veterans Affairs hospital in New Mexico compared the incidence of cerebral ischemia among 74 subjects with and 99 subjects without valvular excrescences over a 53-month followup period.^ 105 ^ One percent of patients with strands compared to 2 percent of patients without strands experienced a cerebral ischemic event. In the same report, a case-control study found the prevalence of valvular strands to be similarly high in 49 patients with and 178 patients without stroke (41 vs. 42 percent).

Four studies, two of fair and two of poor quality, compared the prevalence of valvular strands among patients with and without stroke.^106-108^ Each study found a statistically significant association between valvular strands and cerebral ischemia, with odds ratios ranging from 4.4 to 21.7. None of these studies assessed the prevalence of potential confounders in their control groups. However, in one study, the authors noted that among stroke patients, risk factors such as hypertension and hyperlipidemia were evenly distributed across groups with and without strands.^ 106 ^ In another study, strands were just as common in strokes categorized as lacunar or atherothrombotic as they were in cryptogenic strokes.^ 107 ^ These results all suggest that strands may be incidental findings rather than causally related to stroke.

Two of the above studies reported blinded echocardiographic interpretation, but none reported blinded performance of the test.^106, 107^ In all of the studies, control subjects were patients undergoing TEE for reasons other than to identify potential sources of cardioembolic stroke. In the four studies combined, the overall prevalence of strands in the control groups was 2 percent, compared with 12.8 percent in patients with stroke. A population-based study demonstrated that strands may be seen in up to 46 percent of the general population without stroke.^ 73 ^ Thus, there is a possibility that observed differences were partially due to biased ascertainment in the diagnosis of valvular strands.

In summary, evidence regarding an association between valvular strands and stroke is conflicting, though in one fair-quality cohort study, no association was observed. The association demonstrated in case-control studies may have been confounded by risk factors for stroke and may have been biased by unequal diagnostic testing between cases and controls. Future studies with attention to potential confounding by known risk factors for stroke will be necessary before making conclusions about this association.

#### Aortic Atheroma

Atheromatous plaque or debris within the thoracic aorta, proximal to the takeoff points of the cerebral arteries, may cause stroke through embolization of cholesterol fragments within the plaque or through disruption or ulceration of the plaque, with attendant thrombus formation and subsequent thromboembolism. Aortic atheroma has long been recognized as a source of systemic embolism, including stroke, particularly in the setting of surgical or catheter instrumentation of the aortic arch.^109-111^ Whether or not embolism from aortic plaques is an important cause of spontaneous ischemic stroke, however, has been less clear. TEE technology allows visualization of plaques within the aorta and over the last decade has facilitated the demonstration of a high prevalence of aortic atheromas in patients with stroke.^ 112 ^ However, aortic atheromas frequently coexist with atherosclerotic lesions in the carotid and intracranial arteries, which are well-established risk factors for ischemic stroke. Whether or not aortic atheromas are independently associated with stroke has been the subject of substantial recent study. Because of the obvious potential for confounding, we limited our review to studies that assessed patients for the presence and degree of carotid stenosis.

Three studies of fair to good quality -- one cross-sectional, one case-control, and one cohort -- conducted by the same group of investigators in France have provided the most robust information about the risk of stroke associated with aortic atheroma.^113-115^ The first study, a fair-quality cross-sectional study, involved an autopsy comparison of 239 patients with pathologically confirmed stroke and 261 patients with other neurologic diseases.^ 113 ^ Within the former group, pathological examination was used to classify the probable cause of stroke as due to atherosclerotic cardiovascular disease, cardioembolism (source within the heart), both, or neither (i.e., undetermined cause). Aortic specimens were explicitly examined for ulcerated plaques. The investigators found an adjusted prevalence of ulcerated aortic plaque of 5 percent among patients without stroke, 20 percent among patients with ischemic stroke of determined cause, and 58 percent among patients with stroke of undetermined cause. By definition, no patients in the latter group had ulcerated plaque or stenosis of 40 percent or more within the cervical arteries, suggesting that aortic plaque ulceration may have played a role in the pathogenesis of stroke in this subgroup of patients. Nearly all aortic plaques were found in patients over 60. A significant limitation of this study was that the investigators examining aortic specimens did not appear to be blinded to stroke status or assigned cause of stroke, introducing potential ascertainment bias. It is notable, however, that there was excellent agreement between two investigators independently determining the presence of ulcerated aortic plaque (kappa 0.94).

In a good-quality case-control study, the same investigators examined the prevalence of aortic plaque in patients with and without stroke, this time using TEE.^ 114 ^ Two hundred fifty consecutive patients with stroke were compared to 250 consecutive patients undergoing TEE for assessment of cardiac conditions. Recorded TEE exams were reviewed by an observer blinded to case status. Patients with stroke were more likely than controls to have aortic atheroma. Moreover, the association between stroke and atheroma increased with atheroma thickness. Compared to patients without stroke, the adjusted odds of having atheroma among patients with stroke were four-fold greater for atheroma of 1 to 3.9 mm and nine-fold greater for atheroma of > 4 mm (p <.001 for both findings). The authors reported several other findings supporting an independent association between atheroma > 4 mm and stroke. First, aortic plaques in the ascending aorta and proximal aortic arch (proximal to the takeoff of the cerebral arteries) were strongly associated with stroke, while plaques within the descending aorta were not. Second, aortic atheromas of 1 to 3.9 mm increased in prevalence with the degree of carotid artery stenosis, while atheromas of > 4 mm did not. Finally, atheromas of > 4 mm were found substantially more often in patients with stroke of undetermined cause than in other stroke patients. In this study, assignment of stroke cause was conducted without knowledge of TEE findings, and TEE exams were reviewed without information about cause of stroke. Performance of TEE, however, was not blinded to stroke status or cause of stroke.

In their third study, a fair-quality prospective cohort study, the investigators followed a consecutive series of 331 patients over 60 years of age with stroke to determine the risk of recurrent stroke associated with aortic atheroma.^ 115 ^ Patients without atheroma had a recurrent stroke rate of 2.8 per 100 person-years, compared to 3.5 with atheroma of 1 to 3.9 mm and 11.9 with atheroma > 4 mm. After adjustment for age, carotid stenosis, AF, treatment, and other risk factors for stroke, atheroma of > 4 mm remained a significant predictor of recurrent stroke (relative risk 3.8, 95 percent CI, 1.8 to 7.8). Outcome assessment in this study was not blinded to atheroma status.

In a fair-quality retrospective study conducted by another group of investigators in Australia, aortic atheromas were found more frequently among 215 consecutive patients with stroke than in 202 community-based control subjects (55 percent vs. 26 percent).^ 116 ^ The association with stroke was stronger for "complex" atheromas, defined as having thickness > 5 mm, ulceration, or mobile elements, than for simple atheromas (adjusted odds ratio 7.1 vs. 2.3). Complex atheromas were correlated with carotid stenosis, but their association with stroke remained significant after adjusting for carotid stenosis and numerous other risk factors for stroke (adjusted odds ratio 7.1; 95 percent CI, 2.7 to 18.4). In contrast to the French studies, these authors did not find an association between aortic atheroma and stroke of undetermined cause, despite similar diagnostic criteria. Echocardiographic identification of atheroma in this study was not blinded to case status.

Several other case-control studies have examined the association between aortic atheroma and stroke, but none assessed for the presence of carotid stenosis in both case and control subjects.^112, 117-120^ These studies are notable for at least two significant findings. First, Karalis et al. found that embolic rates associated with aortic atheroma were higher when the atheroma was pedunculated or mobile, providing supportive evidence for a mechanism of stroke.^ 119 ^ Second, Di Tullio and colleagues studied a multiethnic population in New York City and found that although complex aortic atheroma was a risk factor for stroke in all ethnic groups studied, they occurred twice as frequently in white as compared to African American or Hispanic patients.^ 118 ^

In summary, there is overall fair evidence for an association between stroke and aortic atheroma with ulceration, mobile elements, or thickness > 4mm, independent of the presence and degree of carotid stenosis. Firmer conclusions are limited by lack of blinding of echocardiographic performance in case-control studies and unmasked outcome assessment in cohort studies. The absolute increase in annual risk of recurrent stroke associated with complex atheroma was 9.8 percent in one study.^ 115 ^

#### Intracardiac Tumors

Numerous case reports and case series have described the occurrence of cardioembolic stroke in patients with intracardiac tumors, particularly left atrial myxoma.^121-127^ Because myxoma is relatively rare, however, its association with stroke is difficult to establish using traditional epidemiological methods. We did not identify any cohort studies comparing the incidence of stroke in patients with and without myxoma, or any case-control studies comparing the prevalence of myxoma in patients with and without stroke. We therefore examined case series to determine whether the incidence of stroke in patients with myxoma is sufficiently high in comparison with the incidence in the general population to suggest an association.

We identified four retrospective series that reported the prevalence of stroke in patients with myxoma. In a series of 24 Korean patients with surgically proven left atrial myxoma, medical records reviewed for presenting symptoms revealed that six patients presented with cerebral embolism.^ 121 ^ Among 112 cases of left atrial myxoma at a single institution in France, 24 developed cerebral embolism, and in 18 embolism was the tumor's initial manifestation.^ 122 ^ In a review of 37 cases of left atrial myxoma at the Mayo Clinic, 10 had clinically documented cerebral embolism.^ 124 ^ Finally, among 22 patients with left atrial myxoma seen at the Johns Hopkins Hospital, stroke occurred in four.^ 123 ^ Across the four studies, the rate of stroke among patients with left atrial myxoma ranged from 18 to 27 percent, with a pooled rate of 22.7 percent (95 percent CI, 17.2 to 29.0).

Drawing conclusions from these studies is hampered not only by lack of comparison groups but also by limited reporting of other risk factors for stroke among study subjects. The mean age in the four series ranged from 47 to 55. One study reported the ages of patients presenting with cerebral embolism; the mean age among these 10 patients was 38.2 (S.D. +/- 13.0).^ 124 ^ The female:male ratio ranged from 2:1 to 3:1. AF occurred in 5 percent of patients in one study^ 124 ^ and 12 percent in another study,^ 123 ^ though whether it occurred in patients with cerebral embolism was unclear. In another study, 8 percent were reported to have a "rhythm disturbance."^ 122 ^ If these arrhythmias are assumed to have occurred in patients with cerebral embolism, the pooled rate of stroke in these three studies would decrease to 15.9 (95 percent CI, 10. to 22.3). While it is possible that this residual rate of stroke was explained by factors other than myxoma, the substantially higher prevalence of stroke in this population than in the general population between ages 45 and 54 (2.2 percent for men, 1.0 percent for women),^ 128 ^ and the lack of clear association between myxoma and other risk factors for stroke, suggest that myxoma is itself an independent risk factor for stroke.

### Summary

Several different cardiac and aortic abnormalities identifiable by echocardiography have been studied as potential sources of cardioembolic stroke (Table 3). There is fair evidence that LVT is associated with an increased risk of systemic embolization, including stroke. Evidence regarding the presence and degree of stroke risk associated with LAT in patients without AF is insufficient to make firm conclusions. There is fair evidence that complex aortic atheromas (ulcerated, mobile, or > 4 mm in thickness) represent risk factors for stroke, independent of coexisting carotid artery disease. There is also fair evidence for an association between ASA and stroke, particularly in the presence of coexisting PFO. PFO alone may be an important risk factor for stroke in young patients, but evidence for an association is conflicting. Epidemiological studies of left atrial myxoma and stroke are lacking, but several case series suggest a substantially higher prevalence of stroke in patients with myxoma than in the general population. Evidence for an independent association of LV aneurysm, SEC, and valvular strands with stroke is insufficient. Previously documented associations between MVP and stroke were likely due to inaccuracy in the determination of MVP with early echocardiographic techniques. Finally, mitral annular calcification appears to be an indicator of atherosclerotic vascular disease rather than an independent cause of stroke.

Table 3. Evidence for independent association between clinically inapparent echocardiographic lesions and stroke

Fair to good evidence of association | Insufficient evidence | Fair to good evidence of no association
Atrial septal aneurysm (particularly with coexisting patent foramen ovale) | Left atrial thrombus | Mitral annular calcification
Atrial septal aneurysm (particularly with coexisting patent foramen ovale) | Left ventricular aneurysm | Mitral valve prolapse
Complex aortic atheroma (> 4mm, mobile, or ulcerated) | Patent foramen ovale
Left atrial myxoma | Spontaneous echocardiographic contrast
Left ventricular thrombus | Valvular strands

It must be emphasized that the absence of sufficient evidence regarding an association between a cardiac abnormality and stroke does not necessarily indicate that an association does not exist. When biomedical knowledge and experience suggest a high likelihood that a particular lesion -- such as LAT -- is an independent risk factor for stroke, that likelihood will remain high in the face of inconclusive evidence. Stated from a Bayesian perspective, if the prior probability that a lesion is associated with stroke is high, and if studies provide insufficient evidence to change that probability in either direction, then the posterior probability of an association remains high. Likewise, if the prior probability of an association is low or moderate, studies providing evidence of an association will increase the posterior probability, but the degree to which that probability rises may not be enough in some cases to firmly establish the presence of a true association. Finally, the presence of an association does not always imply a causal relationship. Establishing causation in epidemiology depends not only on the presence of an association but on other factors, such as the biological plausibility of a cause-effect relationship between the risk factor and disease under study.

## 2. What is the yield of echocardiography in detecting potential sources of cardioembolism among patients with a new ischemic brain syndrome?

### Background

The importance of using echocardiography to identify a potential source of cardioembolism rests not only on the existence of an association between a specific lesion and the risk of recurrent stroke but also on the prevalence of that lesion. For instance, some lesions are likely to represent true sources of cardioembolic stroke but may be so uncommon that the number of patients who would need to undergo echocardiography to detect one lesion would be extremely high. It would be difficult to rationalize routine use of echocardiography to detect such lesions. Lesions that are more prevalent, and that therefore may account for a larger burden of illness, may represent an important rationale for the use of echocardiography, provided effective treatments exist to reduce morbidity or mortality associated with those lesions. Because determining actual prevalence would require direct inspection of the heart and aorta through surgical exploration or autopsy, which are not performed on the vast majority of patients presenting with stroke, we report prevalences from echocardiographic series. While such series may under- or overestimate the true prevalence of lesions, they provide important data on the expected yield of echocardiography.

We sought to examine the prevalence of potential sources of cardioembolic stroke in consecutive patients with stroke or TIA and in patient subgroups for whom the selective use of echocardiography has been proposed: patients without significant carotid stenosis, patients with heart disease, and young patients. Although studies generally reported the presence of several lesions representing potential source of cardioembolic stroke, we focus here on the yield of clinically inapparent lesions most likely to be amenable to treatment (LAT, LVT, and intracardiac tumors) and lesions for which we found fair or good evidence of an association with stroke (ASA and complex aortic atheroma).

We examined studies that reported findings from consecutive or random samples of patients with stroke or TIA, or that selectively examined patients based on objective, clearly defined criteria. We excluded studies that examined patients who were referred for echocardiography, unless objective criteria for referral were explicitly stated. The rationale for excluding these studies relates to variability in referral patterns across centers. At some centers, it is routine to refer all patients presenting with stroke for echocardiography, whereas at other centers, only patients for whom the index of suspicion for cardioembolism is high are referred. The implicit criteria that define this index of suspicion, or pre-test probability, vary from clinician to clinician and from center to center. Without knowing these criteria, it is difficult to know to which population the reported prevalence applies.

We sought to discover the yield of echocardiography in patients presenting with stroke or TIA who do not have AF. As discussed earlier, the echocardiographic identification of a potential source of cardioembolic stroke is less relevant in patients with AF than in those without AF, because treatment with anticoagulant therapy is indicated in patients with AF presenting with stroke, regardless of the findings of echocardiography.^ 52 ^ We therefore excluded studies that did not allow differentiation of echocardiographic findings between patients with and without AF.

### Findings

#### Transthoracic Echocardiography

##### Unselected patients

Five case series ranging from good to poor quality reported the yield of TTE in consecutive patients without AF presenting with stroke or TIA (Evidence Table 1).^129-133^ In these studies, the majority of ischemic events involved the carotid artery territory, or anterior cerebral circulation. Two additional studies examined exclusively patients with anterior circulation ischemia or infarct.^134, 135^ These seven studies were similar in terms of population age and gender mix. Criteria for defining heart disease varied from study to study but typically included history of MI, congestive heart failure, valvular heart disease, and arrhythmia. The prevalence of heart disease was approximately 30 to 40 percent in studies that reported it. The criteria for defining carotid artery disease also varied; most commonly it was defined as > 50 percent stenosis. In studies that reported the prevalence of carotid disease, it was approximately 30 percent. Most studies included patients with AF in their samples. As noted above, we analyzed results only for subsets of patients without AF.

We rated the quality of studies reporting the yield of echocardiography based on four criteria: patient spectrum, inclusion of definitions for echocardiographic diagnoses, description of echocardiographic methods, and sample size. Only one study met all four quality criteria.^ 129 ^ Most of the other studies included fewer than 100 patients, and none of them provided diagnostic criteria for echocardiographic lesions.

In the single study meeting all four quality criteria, the prevalence of any intracardiac thrombus among patients without AF was 2.1 percent (95 percent CI, 0.8 to 4.6 percent). Of the five patients with thrombus, two had evidence of MI, but the recentness of MI was not indicated. The location of thrombus (atrial or ventricular) was also not indicated. In four studies of fair quality, there were no cases of LVT.^130-132, 134^ Notably, however, none of these four studies reported results in a manner that would allow distinction of patients with AF from patients with other forms of pre-existing heart disease. Thus, in deriving estimates of the prevalence of LVT from these studies, we excluded patients with any heart disease.

One study of fair quality reported a prevalence of LVT of 13.2 percent. All cases of LVT occurred in patients with a history of MI indicated by Q-waves on electrocardiography.^ 135 ^ Patients with acute MI were excluded, but it is not clear how many, if any, of the patients had experienced recent MI, a situation in which the prevalence of LVT is known to be high.^ 59 ^

Only one poor-quality study explicitly reported finding LAT with TTE.^ 133 ^ The population for this study was black patients in South Africa, and the prevalence of rheumatic heart disease in this population was relatively high (15 percent), which may have increased the prevalence of LAT in this study. One study found a single case of atrial myxoma among 235 patients.^ 129 ^ Aortic atheroma was not explicitly sought in any of the studies of TTE. Although methods for detecting aortic atheroma using TTE have been reported,^ 136 ^ because of the difficulty in visualizing the aortic arch, the diagnosis of aortic atheroma is generally not part of TTE examinations. No cases of atrial septal aneurysm were identified with TTE.

##### Patients without carotid artery stenosis

Two case series of fair quality specifically examined patients who had no significant carotid artery disease.^137, 138^ In both studies, patients with lacunar stroke were also explicitly excluded.^137, 138^ By excluding patients without other obvious etiologies for stroke, the authors of these studies hypothesized that the yield of TTE might be higher than in unselected patients. No cases of LVT or LAT were found in patients without AF. The studies had a combined sample, however, of only 82 patients.^137, 138^

##### Patients with cardiac disease

Two studies stratified their results according to the presence or absence of pre-existing heart disease,^135, 137^ and one study included only patients with heart disease.^ 138 ^ One study, as discussed above, defined heart disease as history of MI, indicated by electrocardiographic Q-waves.^ 135 ^ In this study, 9 of 25 patients (36 percent) with evidence of prior MI had LVT. The recentness of MI in these patients was not reported. In the other studies, heart disease was defined broadly but included patients with history of prior MI, congestive heart failure, valvular disease, pacemaker, and cardiac murmur, or patients meeting a set of clinical definitions for being at high risk of cardioembolism.^137, 138^ Among the 43 patients who had one of these conditions but did not have AF, there were no cases of intracardiac thrombus identified by TTE.

The small numbers of patients in these three studies, as well as their conflicting results, makes it difficult to determine the impact of cardiac disease on the prevalence of intracardiac thrombus in patients with stroke. Indirect evidence, however, suggests that thrombus occurs more frequently in patients with cardiac disease than without it. First, it is known that MI and LV aneurysm increase the risk of developing LVT.^ 59 ^ Second, LAT is associated with increased left atrial size and valvular disease.^ 56 ^ Third, an examination of Evidence Table 1 reveals that the occurrence of intracardiac thrombus is higher in studies for which patients with cardiac disease were not excluded. This indirect evidence suggests that patients with cardiac disease are more likely than those without it to have intracardiac thrombus. The prevalence of thrombus in such patients, however, is unclear.

##### Young patients

We retrieved two retrospective studies of echocardiographic findings in young patients with stroke.^139, 140^ Neither study met all of our criteria for inclusion, but because they represent the best available evidence on the prevalence of echocardiographic lesions in young patients, we report their findings here. One study reviewed all cases of stroke in patients aged 15 to 45 at a university hospital in Vermont between 1982 and 1987.^ 139 ^ Of the 48 patients with non-hemorrhagic stroke, four (8.3 percent; 95 percent CI, 2.8 to 18.6 percent) had intracardiac thrombus on TTE. Two patients had rheumatic heart disease, and one had congenital heart disease, though it was unclear if these diagnoses were known at the time of presentation or established by echocardiography. In another two patients, the authors attributed stroke to MVP. No cases of myxoma were reported.

The second study of young patients reviewed 132 non-hemorrhagic strokes among patients aged 15 to 45 at a university hospital in Iowa from 1977 to 1985.^ 140 ^ Seventeen patients had echocardiographic findings, including five cases of rheumatic heart disease and two cases of infective endocarditis, which were suspected clinically; echocardiography was used to confirm the diagnosis in these cases. One clinically occult right atrial myxoma was detected by TTE. The authors attributed the stroke in this case to the myxoma, because a PFO was found at surgery, indicating the possibility of paradoxical embolization. One patient had an unsuspected mitral valve vegetation, and another had a myxomatous mitral valve (marantic endocarditis). Another patient had clinically occult left ventricular dysfunction, and five patients had PFO. The prevalence of PFO (3.8 percent) was substantially lower than has been reported in population-based studies.^73, 74^

When these two studies are combined, the prevalence of myxoma in patients under 45 with stroke is 0.6 percent (95 percent CI, 0.06 to 2.6). The prevalence of thrombus is 2.2 percent (similar to that in unselected patients), and the prevalence of any unsuspected thrombus, tumor, valvular vegetation, or cardiomyopathy is 4.4 percent (95 percent CI, 2.1 to 8.2).

Most of the included studies of the yield of TTE were conducted at university or tertiary care hospitals^131-135, 138-140^ and may not be applicable to community settings. Moreover, several of the studies, including the single good-quality study, took place outside of North America^129, 131-133, 138^ and may therefore not be generalizable to patient populations within the U.S. Because of these factors and the inconsistency of findings across studies, we conclude that published data are insufficient to make a reliable estimate of the probability of finding potential cardioembolic sources of stroke using TTE in community practice among patients presenting with stroke or TIA.

#### Transesophageal Echocardiography

##### Unselected patients

We retrieved six case series of fair to good quality examining the yield of TEE in consecutive patients with stroke or TIA (Evidence Table 2).^131, 132, 141-144^ These studies were conducted on four different continents but, where reported, were generally similar in age distribution, gender mix, and proportion of anterior vs. posterior circulation syndromes. The proportion of patients with heart disease, which was defined similarly across studies, ranged from 26 to 64 percent. Three of the five studies did not describe the criteria used to make echocardiographic diagnoses.^131, 132, 143^

The pooled prevalence of intracardiac thrombus among patients without AF in these five studies was 1.7 percent (95 percent CI, 0.5 to 5.3 percent), with approximately three of every four thrombi detected being left atrial. No cases of LVT were found in the two studies that reported a relatively low prevalence of pre-existing heart disease.^131, 132^ Myxoma was found in one patients among over 1,200 undergoing TEE.

In three fair- to good-quality series that reported the finding of ASA in unselected patients without AF, the prevalence on TEE ranged from 3.8 percent to 21.6 percent.^131, 141, 143^ The highest yield came from a study in which 64 percent of subjects had broadly defined heart disease.

The prevalence of aortic atheromas of the ascending aorta and proximal aortic arch detected by TEE in patients with stroke and TIA is generally very high, up to 70 percent in one series.^ 145 ^ However, most of these atheromas are of unclear significance. Studies have provided evidence that the subset of aortic atheromas that are "complex" (ulcerated, mobile, or > 4 mm in thickness) may have an independent association with stroke, while those that are "simple" likely serve as markers of atherosclerotic disease but are not in themselves associated with risk of stroke. We therefore report only the findings of studies that allowed determination of the yield of complex atheromas. Three fair- to good-quality studies in unselected patients specifically pursued the diagnosis of aortic atheromas.^114, 131, 143^ One study found "mobile or protruding" atheromas in 1.9 percent of patients.^ 143 ^ When the same group of investigators later expanded their criteria to include atheromas that were ulcerated or > 5 mm in thickness in an extension of their original study, the yield increased to 22 percent,^ 116 ^ although in this latter report the authors did not distinguish findings in patients with and without AF. The expressed purpose of this second report was to examine, using a case-control study design, the association between atheroma and stroke. Increased vigilance and time spent scanning the aorta may have accounted for the higher prevalence in this study. The mean age of patients with complex atheroma in this study was 74, compared with 61 in patients without atheroma.^ 116 ^ Another case-control study of the association between atheroma and stroke reported the prevalence of atheromas > 4 mm to be 17.2 percent in consecutive patients over the age of 60 without atrial fibrillation presenting with stroke.^ 114 ^

##### Patients without carotid artery stenosis

Four fair to good studies examined the prevalence of TEE findings in stroke and TIA patients without significant carotid artery stenosis.^82, 146-148^ Three of these studies defined significant stenosis as >50 percent,^146-148^ while the fourth did not report a definition.^ 82 ^ Two of the studies also excluded patients with potential sources of cardioembolism detected by TTE,^146, 148^ and another excluded patients who met clinical criteria defining them as being at high risk for cardioembolism (e.g., recent MI).^ 147 ^ In these studies, the authors sought to discover the yield of TEE in patients with cryptogenic stroke, or stroke of undetermined cause. The range of LAT prevalence in these studies was 1.5 to 18 percent. The highest prevalence of LAT was reported from a multicenter study in which no criteria for diagnosing LAT were given and in which little information was provided about the spectrum of illness and stroke subtypes in the included patients.^ 146 ^

Three of these four studies reported the yield of ASA in patients without AF.^146-148^ The prevalence of ASA varied from 3.1 to 15 percent. Another study reported a prevalence of ASA of 25.4 percent in patients without carotid disease or any "major" cardioembolic sources of stroke on TEE, including thrombus and myxoma, that may have rendered the presence of ASA less meaningful.

Three studies reported the prevalence of complex atheroma, defined as being > 4 mm in thickness.^142, 147, 148^ Four of 67 patients (6.0 percent) without carotid stenosis in one study,^ 142 ^ and three of 65 (4.6 percent) in another,^ 147 ^ had complex atheromas, while in the third study, all aortic atheromas were less than 4 mm.^ 148 ^ In two fair- to good-quality case-control studies, the prevalence of complex atheromas was 17.8 percent among patients with < 60 percent carotid stenosis in one study,^ 143 ^ and 14.3 percent among patients with < 70 percent carotid stenosis in the other.^ 114 ^ The proportion of patients with atrial fibrillation or other indications for anticoagulation in these two studies was not reported.

##### Patients with cardiac disease

Only one study reported the yield of intracardiac thrombus in patients with cardiac disease without AF. This study included 14 patients, none of whom was found to have thrombus on TEE. There was no clear association between cardiac disease prevalence, among studies that reported it, and echocardiographic findings.

##### Young patients

We identified one study of young patients admitted to a referral center in France for management of stroke.^ 149 ^ Subjects were all under age 60 and had a mean age of 47. Patients with AF were excluded, as were those with thrombus, LV aneurysm, or other potential sources of cardioembolic stroke found on TTE. Thirty-three (28 percent) of 118 patients had ASA; 18 (15 percent) had concomitant PFO. Four patients (3.4 percent) had aortic atheroma. No patients were reported to have LAT or myxoma.

As with studies of TTE, the yield of potential sources of cardioembolic stroke using TEE was derived from patient populations in primarily university or referral hospitals outside North America and may not represent the yield in community settings in the U.S. The prevalence of intracardiac thrombus (1.7 percent) was relatively consistent across studies and was similar to the prevalence found in the single good-quality study of TTE. Findings for other lesions, however, were highly variable.

### Summary

In one study of good quality from Japan, the prevalence of intracardiac thrombus in consecutive patients with stroke or TIA undergoing TTE was 2.1 percent (95 percent CI, 0.8 to 4.6 percent). In three fair-quality studies, no cases of thrombus were diagnosed in patients without heart disease. Among patients with heart disease, the prevalence of thrombus was highly variable, ranging from 0 to 36 percent. This variability, as well as small sample sizes, makes it difficult to derive a reliable estimate of the yield of TTE among patients with a history of cardiac disease or without significant carotid disease. One atrial myxoma was diagnosed among 721 patients in eight studies. In most studies, LAT, ASA, and aortic atheroma were not found using TTE in patients without AF.

In two studies of TTE among young patients (aged 15 to 45) with stroke, the pooled prevalence of intracardiac thrombus in 180 patients was 2.2 percent (similar to that in unselected patients). No left atrial myxomas were detected. The prevalence of any unsuspected thrombus, tumor, valvular vegetation, or cardiomyopathy was 4.4 percent (95 percent CI, 2.1 to 8.2).

The overall yield of intracardiac thrombus using TEE in consecutive stroke patients was 1.7 percent (95 percent CI, 0.5 to 5.3 percent). The prevalence of heart disease was not reported in most studies of TEE, making it difficult to determine the importance of this variable. In four studies of patients without significant carotid disease, the prevalence of intracardiac thrombus on TEE was highly variable, ranging from 1.5 to 18 percent. One myxoma was detected in over 1,200 patients undergoing TEE. The yield of ASA (3.8 to 21.6 percent) and complex aortic atheroma (1.9 to 17.2 percent) using TEE also varied widely across studies. One study of patients under 60 with negative TTE reported a prevalence of ASA of 28 percent, with 15 percent having both ASA and PFO. The prevalence of complex aortic atheroma in this study excluding elderly patients was 3.4 percent.

The prevalence of complex aortic atheroma was variable across studies, ranging from 2 to 22 percent. The highest rates were reported by studies in which patients underwent TEE for the expressed purpose of detecting aortic atheroma. In studies of patients undergoing TEE to search for any source of cardioembolic stroke, the prevalence of complex atheromas ranged from 2 to 6 percent, suggesting that when conducted routinely, TEE may not yield the majority of atheromas present.

The finding from previous reviews of a higher yield of intracardiac thrombus and other potential sources of stroke using TEE largely reflects the inclusion in those reviews of patients with AF.^4, 150^ Our findings suggest that in patients without AF, TEE may be less useful than previously described.^ 4 ^ TEE may have advantages in patients who are found to have insignificant or no carotid disease or who have a negative TTE. There is little information on the yield of TEE in patients with pre-existing heart disease other than AF.

## 3. What are the operating characteristics (sensitivities, specificities, and likelihood ratios) of transthoracic and transesophageal echocardiography in detecting potential sources of cardioembolic stroke?

### Background

It is often assumed in clinical practice that echocardiography, particularly TEE, is perfectly accurate in detecting potential cardioembolic sources of stroke. That is, if TEE demonstrates a lesion, it is assumed that the lesion is present, and if TEE does not demonstrate a lesion, it is assumed that the lesion is absent. This is largely due to the lack of a more accurate imaging modality for most intracardiac pathology. Echocardiography has limitations and is almost certainly not perfectly accurate in detecting most cardiac lesions. Studying the accuracy of echocardiography entails comparing it to a more accurate "reference standard" examination. Unfortunately, for the purposes of intracardiac pathology, the reference standard is often direct inspection of the heart through surgical or autopsy examination. Although other cardiac imaging modalities exist, such as contrast ventriculography, computed tomography, magnetic resonance imaging, and nuclear scintigraphy, for most lesions none of these modalities is clearly superior to echocardiography such that it can serve as an appropriate reference standard.

Several studies have compared echocardiography to direct intracardiac inspection. We reviewed these studies for the purpose of estimating the accuracy of TTE and TEE in detecting potential sources of cardioembolic stroke.

### Findings

#### Left Atrial Thrombus

In order to accrue adequate numbers of patients with intracardiac thrombus demonstrated by autopsy or surgery, investigators have necessarily conducted studies of echocardiographic accuracy for detecting thrombus in highly selected patient groups. For LAT, these studies have examined patients undergoing elective surgery for mitral valve disease, primarily rheumatic mitral stenosis. We identified ten such studies (Evidence Tables 3 and 4).^151-160^ Two assessed the accuracy of TEE alone,^152, 156^ three assessed TTE alone,^158-160^ and five studies assessed both TTE and TEE.^151, 153-155, 157^ The prevalence of LAT ranged from 5 to 29 percent. In each case, surgical inspection of the left atrium served as the reference standard.

In the seven studies assessing TEE (Evidence Table 3), which included 969 patients, sensitivity ranged from 83 to 100 percent, with a pooled sensitivity of 92.5 percent (95 percent CI, 83.4 to 98.2 percent). Specificity varied from 93 to 100 percent, with a pooled estimate of 97.2 percent (95 percent CI, 91.2 to 99.8 percent). Among the eight studies that examined TTE (Evidence Table 4), sensitivity was expectedly lower, with a pooled estimate of 42.3 percent (95 percent CI, 14.2 to 73.8). Most of the thrombi missed by TTE were in the left atrial appendage. The specificity of TTE was at least 99 percent in all eight studies (pooled specificity 99.0, 95 percent CI, 98.0 to 99.7 percent). None of these estimates of accuracy was substantively different when poor-quality studies were excluded from the pooled results.

Interobserver agreement on the presence or absence of LAT using TEE ranged from 98 to 100 percent in the three studies that reported it.^151, 152, 154^ Inter-rater reliability was not assessed in any of the studies of TTE.

All of these studies were limited by spectrum bias. This bias occurs when the spectrum of patients studied is not representative of the population of patients for whom the test is intended. In this case, all of the patients studied had severe mitral valve disease requiring surgery. In such patients, the nature, location, and size of atrial thrombi may be quite different from thrombi that are likely to be found in other patient populations. Caution is therefore warranted in generalizing these estimates of accuracy to patients with stroke.

#### Left Ventricular Thrombus

We did not identify any studies of the accuracy of TEE in detecting LVT. We retrieved six studies examining the accuracy of TTE (Evidence Table 5).^161-166^ In three of these studies, patients were selected to undergo the reference standard procedure (typically surgery) based on echocardiographic findings, creating verification bias.^163, 164, 166^ In the other three, TTE was performed on consecutive patients scheduled to undergo left ventricular aneurysmectomy.^161, 162, 165^ Additionally, the echocardiographic findings of patients who died shortly after undergoing echocardiography were compared to autopsy diagnosis of thrombus. In one study, two independent observers agreed in 93 percent of cases and for the purposes of determining accuracy, reached consensus in the case of disagreement. The pooled sensitivity of TTE for detecting LVT in the six studies was 78.3 percent (95 percent CI, 62.7 to 90.5), and specificity was 86.6 percent (95 percent CI, 72.7-96.1). These estimates were not substantively different when pooling was confined to the three fair-quality studies.

In five of the six studies, the authors reported excluding cases in which the echocardiogram was considered inadequate for interpretation.^161, 163-166^ Excluding indeterminate tests provides accuracy estimates that overstate the usefulness of a test for the clinician (or other decisionmaker) interested in using that test in the management of an individual patient or population of patients. We therefore report sensitivity and specificity for these five studies with and without indeterminate tests. Only one study reported the prevalence of LVT among patients with indeterminate results.^ 163 ^ For the other four studies, we report sensitivity and negative likelihood ratios with all indeterminate tests assumed to be positive for LVT, and specificity and positive likelihood ratios with all indeterminate tests assumed to be negative for LVT, in order to provide estimates of the lower bound of accuracy in these studies.

As with the studies of LAT, studies of LVT all included a narrow spectrum of patients who might undergo TTE. Thus, the estimates of TTE accuracy reported in these studies must be interpreted with caution. It is also noteworthy that all six studies were published before 1990; advances in echocardiographic technique over the last decade may limit the applicability of these estimates of accuracy.

#### Atrial Septal Aneurysm

We did not identify any studies correlating the echocardiographic diagnosis of ASA with surgical or pathological findings. However, because the association of ASA with stroke has been established for ASA as echocardiographically defined, it is arguable that for the purpose of detecting ASA that predisposes to future stroke, TEE is the "gold standard." Interobserver reliability for the diagnosis of ASA is not well established.^ 79 ^

#### Aortic Atheromas

We did not identify any studies correlating the echocardiographic diagnosis of aortic atheroma with surgical or pathological findings. Complex atheroma is defined by its echocardiographic -- as opposed to pathologic -- features. Because the association with stroke has been established only for atheromas so defined, it is arguable that for the purpose of detecting atheromas that predispose to future stroke, TEE is the "gold standard." Interobserver agreement for the diagnosis of complex atheroma was high in two separate studies (kappa = 0.95 and 0.96).^114, 116^ As discussed above, there is as yet no role for TTE in diagnosing aortic atheroma, though methods for using TTE for this purpose have been proposed.^ 136 ^

#### Left Atrial Myxoma

Few studies have examined the accuracy of echocardiography in diagnosing myxoma, largely because of the rarity of the condition. In one study from an academic center in Germany, both TTE and TEE were 100 percent sensitive in the diagnosis of 13 left atrial myxomas.^ 167 ^ This study did not include patients without atrial masses; specificity could therefore not be determined. In another study, from a university hospital in Italy, TTE was 100 percent sensitive and specific in diagnosing myxoma in two patients.^ 168 ^ However, in a third study, from a community hospital in Michigan, TTE diagnosed only 9 of the 11 left atrial myxomas detected by TEE.^ 169 ^ Both of the tumors missed by TTE were less than 3 cm in diameter. There was no comparison in this study to a non-echocardiographic reference standard, leaving room for the possibility that the discrepancy between TTE and TEE may have been due to a problem with specificity of TEE rather than sensitivity of TTE.

### Supplemental Analyses

#### Summary Receiver Operating Characteristic Curves

Variation in sensitivity and specificity of the same diagnostic test may result from the choice of different diagnostic thresholds. For instance, a group of investigators may be interested in examining varying thresholds for the diagnosis of LAT using TEE. In one analysis, the investigators may want to determine the accuracy of TEE if readings of "definite," "probable," and "possible" thrombus are considered to be positive for LAT; i.e., the investigators may set a low diagnostic threshold in order to assess diagnostic accuracy when the number of undetected thrombi is minimized. Using this low diagnostic threshold, the sensitivity of TEE is likely to be high, while the specificity may be low. In another analysis, the investigators may include only readings of "definite" thrombus as positive. Using this high diagnostic threshold, specificity will likely be high, while sensitivity may be low. If the sensitivity and specificity from these two analyses were averaged, the pooled results may indicate moderate sensitivity and specificity, when in fact the test is capable of both high sensitivity and high specificity, depending on the diagnostic threshold chosen.

Receiver operating characteristic (ROC) curves capture the tradeoff between sensitivity and specificity by plotting a test's true positive rate against its false positive rate at varying diagnostic thresholds. The two-dimensional nature of test accuracy is more appropriately summarized as a ROC curve than as an average of sensitivity and specificity across different thresholds. When a single summary statistic is desired, ROC curves allow determination of sensitivity and specificity at the diagnostic threshold where maximal accuracy is achieved, which reflects a test's diagnostic potential more accurately than average sensitivity and specificity.

Just as a single study may assess a test's accuracy across different diagnostic thresholds, different studies examining the same diagnostic test may also use different thresholds. Thus, when summarizing the results across studies, simple averaging of sensitivity and specificity may not accurately reflect the test's true operating characteristics. To deal with this problem, statistical methods for calculating summary ROC (SROC) curves have been developed (see Appendix F).^ 170 ^

SROC curves for the diagnosis of intracardiac thrombus using echocardiography, constructed from the results of studies tabulated in Evidence Tables 3, 4, and 5, are displayed in Figure 1 (differences between sensitivity and specificity in Evidence Tables 3, 4, and 5 and those plotted on the SROC curves result from adding 0.5 to each cell in the statistical construction of the SROC curves, to avoid empty cells). The curves for TTE (Figure 1 parts B and C) display the typical shape of a ROC curve. The atypical shape of the ROC curve for TEE in detecting LAT reflects the fact that several studies with the highest sensitivity^152, 153, 157^ also had equal or higher specificity than other studies.^154-156^ In Figure 1, parts A and B, it is apparent that across most of the studies, accuracy estimates are clustered around similar false positive rates (1-specificity), suggesting that the studies had similar diagnostic thresholds. In Figure 1, part B, the point of maximal accuracy on the ROC curve falls outside the range of data from individual studies. The calculated sensitivity of TTE for diagnosing LAT at the point of maximal accuracy on the ROC curve is 97 percent, while sensitivities in the individual studies range from 0 to 59 percent. In this situation, the average sensitivity and specificity across studies provides a less-biased estimate of test accuracy than sensitivity and specificity at the point of maximal accuracy on the ROC curve. Because the diagnostic threshold appeared similar across studies in the ROC curves for each test in the diagnosis of LAT, average sensitivity and specificity likely reflect the true diagnostic potential in these testing situations. For the diagnosis of LVT, the sensitivity and specificity of TTE at the point of maximal accuracy were 77 and 95 percent, respectively, which provide higher overall accuracy than the pooled average sensitivity and specificity of 79 and 87 percent. As noted above, however, the estimates of sensitivity and specificity in several studies of the accuracy of TTE in diagnosing LVT were derived after exclusion of indeterminate test results. These estimates, and therefore the SROC curve constructed from them, may overstate the accuracy of TTE.

Figure 1. Summary receiver operating characteristic (ROC) curves for the diagnosis of intracardiac thrombus with echocardiography

1. Summary ROC curves for the diagnosis of left atrial thrombus using TEE. Black circles represent good and fair quality studies. Gray triangle represents poor quality study. Dotted curve is for all studies. Black curve is for good and fair quality studies. [image]
2. Summary ROC curves for the diagnosis of left atrial thrombus using TTE. Black circles represent good and fair quality studies. Gray triangles represent poor quality studies. Dotted curve is for all studies. Black curve is for good and fair quality studies. [image]
3. Summary ROC curves for the diagnosis of left ventricular thrombus using TTE. Black circles represent good and fair quality studies. Gray triangles represent poor quality studies. Dotted curve is for all studies. Black curve is for good and fair quality studies.

#### Outcomes of Diagnostic Testing

Using estimates of accuracy from our literature review along with varying estimates of prevalence for LAT and LVT, we calculated the number of patients with true and false positive and true and false negative echocardiographic diagnoses of LAT and LVT in a hypothetical cohort of 1,000 patients with stroke undergoing TTE or TEE (Figure 2). For these calculations, we assumed that TEE is equivalent to TTE in diagnosing LVT.

Figure 2. Estimates of true and false positive test results for a hypothetical cohort of 1000 patients with stroke undergoing echocardiography for the detection of intracardiac thrombus: effect of varying prevalence estimates

1. True and false positive tests among a hypothetical cohort of 1000 patients undergoing TEE for detection of left atrial thrombus, according to thrombus prevalence. Black line indicates true positive tests; dotted line indicates false positive tests. Dashed line indicates estimated true prevalence of thrombus in unselected patients. [image]
2. True and false positive tests among a hypothetical cohort of 1000 patients undergoing TTE for detection of left atrial thrombus, according to thrombus prevalence. Black line indicates true positive tests; dotted line indicates false positive tests. Dashed line indicates estimated true prevalence of thrombus in unselected patients. [image]
3. True and false positive tests among a hypothetical cohort of 1000 patients undergoing TTE for detection of left ventricular thrombus, according to thrombus prevalence. Black line indicates true positive tests; dotted line indicates false positive tests. Dashed line indicates estimated true prevalence of thrombus in unselected patients.

Assuming a sensitivity and specificity of 93 and 98 percent, respectively, for the diagnosis of LAT using TEE, approximately equal numbers would receive a false as compared to a true diagnosis of LAT, assuming a prevalence of 2 percent, which is greater than the estimated prevalence of LAT from our literature review. In order for the positive predictive value of TTE or TEE to reach 90 percent, the prevalence of LAT would have to exceed 15 percent.

For the diagnosis of LVT, assuming a sensitivity and specificity of 77 and 95 percent, respectively (maximal accuracy from SROC curve), false positive tests outnumber true positives unless the prevalence of LVT is greater than 6 percent. To achieve a positive predictive value of 90 percent, the prevalence of LVT would have to exceed 37 percent. It is possible to use very strict criteria for diagnosing LVT with TTE, thereby increasing specificity. In order for true positives to outnumber false positives in the diagnosis of LVT at a prevalence of 2 percent, specificity would need to exceed 98 percent. To reach a positive predictive value of 90 percent, the specificity of TTE would need to be greater than 99.8 percent. To achieve this specificity, sensitivity would likely be sacrificed, increasing the number of false negative tests.

### Summary

Because of the relatively low prevalence of intracardiac thrombus in patients with stroke, it is difficult to assess the accuracy of TTE and TEE in this population. Studies attempting to determine the accuracy of these tests for LAT and LVT have necessarily examined populations in which the prevalence of thrombus is high. These populations, patients with severe mitral valve disease or left ventricular aneurysms, are not representative of the general population of patients with stroke, and thrombi occurring in these patients may differ substantially from those likely to affect patients with cardioembolic stroke. It is therefore possible that the reported accuracy estimates in these studies differ from the accuracy of TTE and TEE in patients with stroke.

The average sensitivity and specificity of TEE in detecting LAT in these studies were 93 and 97 percent, respectively. For TTE, sensitivity and specificity averaged 42 and 99 percent. The low sensitivity of TTE was largely due to missed left atrial appendage thrombi. For the diagnosis of LVT, TTE had an average sensitivity of 78 percent and specificity of 87 percent. When results from individual studies were plotted on a SROC curve, however, it appeared that varying accuracy across studies may have been partly due to differing diagnostic thresholds. Using the SROC curve to estimate the accuracy, the sensitivity and specificity of TTE for diagnosing LVT were 77 and 95 percent, respectively. It should be noted, however, that approximately 15 percent of TTE examinations in studies of LVT were deemed inadequate for interpretation, limiting the diagnostic utility of this test. We did not identify any studies of the accuracy of TEE in diagnosing LVT.

When the prevalence of intracardiac thrombi in patients with stroke is assumed to be 2 percent or less, as many as or more patients would receive unnecessary treatment due to false positive tests than would receive potentially beneficial treatment for a true positive test, if echocardiographic technology is used to select patients for treatment with anticoagulants. Under current estimates of test accuracy, the prevalence of LAT would have to exceed 15 percent and the prevalence of LVT 37 percent in order to achieve 90 percent predictive value.

Studies examining the accuracy of echocardiography in diagnosing ASA and aortic atheroma are lacking. However, given that the association with stroke has been established for the echocardiographic, rather than anatomic, definitions of these lesions, it may be argued that TEE represents the gold standard for the diagnosis of these lesions as they relate to cardioembolic stroke.

Few studies have assessed the accuracy of echocardiography in diagnosing left atrial myxoma. These studies suggest accuracy approaching 100 percent, though one study found disagreement between TTE and TEE in 2 of 11 cases.

## 4. What are the incidence and nature of complications associated with transesophageal echocardiography?

### Findings of Individual Studies

We identified 24 studies reporting rates of complications in patients undergoing TEE for a variety of indications, including for evaluation of cerebral ischemia or for source of embolus (Evidence Table 6). Sixteen studies evaluated the incidence of periprocedural complications, and eight evaluated the incidence of transient bacteremia and subsequent infective endocarditis or systemic infection following TEE. We did not identify any systematic reviews or trials addressing this question.

We excluded three studies reporting TEE complications that evaluated only patients following trauma or being evaluated for aortic dissection,^ 171 ^ only patients who underwent cardiac surgery,^ 172 ^ and only critically ill patients being evaluated for hemodynamic insufficiency, valvular disease, or abscess.^ 173 ^

Of the five largest studies (sample size range 901 to 10,419), two were fair-quality^174, 175^ and three were poor^176-178^ (Evidence Table 6). The largest (n=10,419) and only multicenter (15 European sites) study^ 176 ^ had numerous methodological flaws, including inadequate description of the study population, unspecified or undefined complications, no description of ascertainment technique, lack of clarity as to independence of ascertainment, and unclear duration of followup. The other four large studies had two or more similar methodological flaws. In these studies, "major complication" was typically poorly and inconsistently defined. We defined "major complication" as any complication requiring specific treatment other than simply discontinuing the procedure. Major complications that were reported include laryngospasm, angina, bleeding, hypoxia, hypotension, sustained arrhythmia, esophageal rupture, and congestive heart failure.

The largest study reported a death rate of 0.01 percent (1/10,218) and major complication rate (pulmonary, cardiac, or bleeding) of 0.2 percent (18/10,218).^ 176 ^ In the other large series,^174, 175, 177, 178^ the death rates ranged from 0 percent (0/901)^ 178 ^ to 0.03 percent (1/2,947),^ 175 ^ and major complication rates ranged from 0.2 percent^ 174 ^ to 0.9 percent.^ 175 ^ In the largest series, 1.9 percent (201/10,419) of TEE procedures were unsuccessfully attempted, and 0.9 percent (90/10,218) had to be interrupted for minor or major complications, most (65/90) because of patient intolerance.^ 176 ^ Similar findings were reported in other large studies.^175, 178^

In 11 smaller series (sample size range 35 to 566),^56, 154, 179-187^ no deaths were reported, and the rate of major complications ranged from 0 percent^154, 179-181, 183, 184^ to 2.6 percent (2/77).^ 182 ^ Like the larger studies, the quality of these reports was poor^154, 179, 180, 182, 184^ or fair.^56, 181, 183, 185-187^

None of the reviewed studies reported complication rates specifically in patients who had experienced recent cerebral ischemia. Three studies^183, 186, 187^ assessed the incidence of complications in elderly patients (defined as either older than 65 years or 70 years), and three assessed the incidence of complications in "critically ill" patients (managed in intensive care unit or emergency room).^154, 182, 184^ In elderly patients, no deaths were reported (n=406), and the rate of major complications ranged from 0 percent (0/35)^ 183 ^ to 1.1 percent (1/88).^ 187 ^ In one study, there appeared to be an association between advanced age and transient hypotension (5 percent vs. 1.4 percent).^ 186 ^ In critically ill patients, no deaths were reported (n=219), and the rate of major complications ranged from 0 percent^154, 184^ to 2.6 percent (2/77).^ 182 ^ The rates of complications for other specific populations (including women, non-white, and lower socioeconomic status) and for specific indications were not reported in the reviewed studies.

Transient, asymptomatic bacteremia has been reported to occur in 0 percent (0/101)^ 188 ^ to 17 percent (4/24)^ 189 ^ of patients after TEE. In two case reports,^190, 191^ patients with known valvular or congenital heart disease developed infective endocarditis following TEE. However, in eight prospective studies (sample size range 24 to 144, total n=775),^188, 189, 192-197^ no case of endocarditis or systemic infection following TEE was found. There were major methodological flaws in all of these studies with regard to assessment of endocarditis or other systemic infection, including unclear duration and completeness of followup, inadequately defined complications, and poorly described ascertainment techniques. All of these studies were rated as having either poor^188, 189, 193, 194, 196^ or fair^192, 195, 197^ methodological quality.

### Pooled Results

We did not find significant heterogeneity between rates of death reported from 15 series of patients (we did not include data from Seward,^ 174 ^ which overlapped with a later study^ 177 ^). The pooled periprocedural death rate was 0.014 percent (4/23,123; 95 percent CI, 0.00004 to 0.04 percent). No deaths were reported in the subgroup of studies reporting rates in elderly patients (n=406) and critically ill patients (n=219).

We found significant heterogeneity (chi-square=42.7, df 14, p<.0001) among rates of major periprocedural complications from all 15 series. The between-study variation was reduced by 52 percent (from 0.78 to 0.38) when quality was included as a dependent parameter in the model, and we did not find significant heterogeneity (chi-square=3.6, df 7, p=0.83) between the rates of major complications from the eight fair-quality studies.^56, 175, 178, 181, 183, 185-187^ Pooled findings from these studies demonstrated a major complication rate of 0.7 percent (36/4679, 95 percent CI, 0.3 to 1.0 percent). This rate is significantly higher (chi-square=26.8, df 1, p<0.00005) than the 0.2 percent major complication rate reported in the largest and only multicenter series.^ 176 ^

We pooled the results of three studies reporting rates of major periprocedural complications in elderly patients^183, 186, 187^ (test for heterogeneity: chi-square=0.15, df 2, p=0.93) and three studies of critically ill patients^154, 182, 184^ (chi-square=1.17, df 2, p=0.22). The rate of major complications in these studies was 0.4 percent (3/406; 95 percent CI, 0.1 to 1.4 percent) in elderly patients and 0.8 percent (2/219; 95 percent CI, 0.1 to 2.6 percent) in critically ill patients. The rates of major complications in elderly patients and critically ill patients were not significantly different than the overall rates (chi-square=0.30, df 1, p=0.58 for elderly versus overall; chi-square=.10, df 1, p=0.75 for critically ill versus overall).

In eight studies^188, 189, 192-197^ assessing rates of transient bacteremia and subsequent infections, no cases of infective endocarditis or systemic infection were found in 775 patients followed after TEE.

### Summary

In observational studies of poor and fair quality, the pooled risk of periprocedural death was 0.014 percent. The risk of death in patients specifically undergoing TEE for evaluation of possible cardiac embolus cannot be directly calculated. Data are insufficient to determine whether the risk of death is higher in elderly or critically ill patients.

From observational studies of fair quality, the average risk of major (requiring treatment) cardiovascular, pulmonary, and gastrointestinal complications from TEE was 0.7 percent. The rates of major complications in elderly and critically ill patients were 0.4 percent and 0.8 percent respectively. Neither of these rates was significantly different from the overall rates. No cases of infective endocarditis or systemic infection were found in 775 patients followed after TEE. Approximately 1.9 percent of TEE are unsuccessfully attempted, and an additional 0.9 percent are stopped for complications, most frequently patient intolerance. The rate of minor complications (most commonly patient intolerance) requiring discontinuation of the procedure was not consistently reported, but appears to be about three times the rate of major complications.

Although the estimates of risk come from studies of poor or fair methodological quality (no included study was assessed as having overall good quality), no other data are available to provide more reliable estimates. Data are insufficient to determine whether complication rates are different in patients presenting with particular indications such as cerebral ischemic syndromes.

## 5. Are there clinically identifiable groups of patients with new ischemic brain syndrome who benefit from anticoagulation?

### Background

The primary role of echocardiography in patients with stroke is to identify sources of cardioembolism for which interventions, particularly anticoagulant therapy, may reduce the risk of recurrent stroke or other morbidity or mortality. As discussed earlier, some sources of cardioembolism are usually apparent clinically -- through history, physical examination, or routine testing -- and therefore do not require echocardiography for identification (Table 2). If effective therapy exists to reduce morbidity and mortality associated with these clinically identifiable conditions, echocardiography will not affect therapeutic decisionmaking for patients with those conditions. This is the case for patients with AF. There is convincing evidence that patients with AF who have experienced a stroke or TIA benefit from anticoagulant therapy.^ 52 ^ Echocardiography to identify potentially treatable sources of cardioembolic stroke in these patients is therefore of little use, since treatment is already indicated. Whether or not there are clinically identifiable groups of patients other than those with AF who benefit from therapy is unclear. Determining whether such groups exist is important in order to define the scope of patients with stroke who may benefit from echocardiographic imaging.

Because most ischemic strokes are thought to involve thrombosis with or without embolism, it has long been postulated that anticoagulant therapy may confer benefit when applied to all (i.e., unselected) patients with stroke. Numerous studies have been conducted to test this hypothesis, and reviews of these studies have generally found that any benefit of anticoagulation in reducing recurrent ischemic stroke is offset by a higher risk of hemorrhagic complications.^198-203^ These findings, however, were derived largely from studies conducted prior to 1975, pre-dating the routine use of computed tomography (CT) to differentiate ischemic stroke from ICH and the use of the international normalized ratio (INR) to monitor anticoagulant effect. Anticoagulation in patients with unsuspected hemorrhagic stroke and excessive anticoagulation may have contributed to high rates of adverse effects in these studies. Moreover, most of these studies compared anticoagulants to placebo, rather than antiplatelet therapy (e.g., aspirin). Because antiplatelet therapy has become standard care for patients with ischemic stroke,^204-206^ placebo comparisons are no longer clinically relevant. The Cochrane Collaboration has planned a review of studies of anticoagulants versus antiplatelet therapy in unselected patients with stroke, but this review has not yet been conducted.^ 207 ^ We therefore conducted a systematic review to determine whether unselected patients with stroke benefit from anticoagulant therapy, as compared to antiplatelet therapy, with the view that if anticoagulation were beneficial for unselected patients, echocardiography would be of limited use in guiding therapeutic management.

We also reviewed the literature addressing the efficacy and harms of anticoagulation in patients with stroke and clinically apparent cardiac disease. Certain cardiac conditions, such as acute MI, prosthetic heart valves, rheumatic heart disease and dilated cardiomyopathy, are thought to place patients at high risk of developing cardioembolic stroke. Evidence of therapeutic benefit with anticoagulants in such patients would limit the usefulness of echocardiography in guiding therapeutic decisionmaking.

### Findings of Individual Studies

#### Unselected Patients with Stroke

One randomized controlled trial comparing acute anticoagulation to antiplatelet therapy in patients with stroke met our criteria for inclusion.^ 205 ^ This study, the International Stroke Trial (IST), was a multicenter international trial of subcutaneous heparin versus aspirin in 19,435 unselected patients with acute stroke, 16 percent of whom had AF (Evidence Table 7). The main limitation of the IST was that outcome assessment of recurrent stroke and ICH was not masked; otherwise the quality of this trial would have been rated as good. Nearly all patients were evaluated with CT imaging to allow accurate discrimination of ischemic strokes from ICH. Two doses of heparin were used, 10,000 IU daily and 25,000 IU daily. The higher dose was associated with higher rates of hemorrhagic complications and death than the lower dose, without a compensatory reduction in ischemic events. In the group receiving the lower dose of heparin, there were 12 fewer recurrent ischemic strokes per 1,000 patients than in the group not receiving heparin. However, when compared to aspirin, heparin was not associated with lower rates of recurrent stroke. Rates of hemorrhage were similar between the two treatments. When compared to either treatment alone, the combination of low-dose heparin and aspirin appeared to be associated with fewer ischemic strokes and deaths, a benefit that was partially but not completely offset by an increase in major hemorrhage. However, results for combination therapy were derived from subgroup analyses and did not achieve statistical significance.

We identified six clinical trials comparing chronic anticoagulation with antiplatelet therapy in preventing recurrent stroke in unselected patients (Evidence Table 7).^208-213^ The largest of these studies was the Warfarin-Aspirin Recurrent Stroke Study (WARSS).^ 212 ^ In this good-quality, multicenter trial conducted in academic medical centers within the U.S., 2206 patients with ischemic stroke who were deemed acceptable candidates for anticoagulation were randomized within one month of the index stroke to receive warfarin (target INR 1.4-2.8, mean INR 2.0-2.1) or aspirin (325 mg per day). Although neither randomization nor allocation concealment was described, baseline characteristics were comparable across the two treatment groups. This was the only double-blind trial of chronic anticoagulation that we identified. A central laboratory provided true INR values for patients on warfarin and false INR values for patients on aspirin to maintain blinding. Outcome assessment was also masked. After 2 years of treatment, there were no significant differences between the two groups in recurrent stroke, major hemorrhage, or death.^ 212 ^

Other studies of anticoagulation for preventing stroke recurrence either used higher target INR values than those used in WARSS or predated the routine use of the INR. The Stroke Prevention in Reversible Ischemia Trial (SPIRIT) was an open-label, randomized, multicenter randomized trial of good quality that compared warfarin (target INR 3.0 to 4.5) with aspirin (30 mg per day).^ 208 ^ The study was terminated early due to an increase in primary outcomes (death from all vascular causes) in the warfarin group, with a hazard ratio of 2.3 (95 percent CI, 1.6 to 3.5). There was no difference in rates of recurrent arterial ischemic events (warfarin: 27/651, 4 percent; aspirin: 27/665, 4 percent). However, the annual ICH rate was 3.6 percent with warfarin and 0.4 percent with aspirin, and annual mortality was 4.6 percent with warfarin and 1.9 percent with aspirin.

Four poor-quality trials were performed in the late 1970s and early 1980s.^209-211, 213^ None of these studies used CT imaging to distinguish ischemic stroke from ICH, and none masked outcome ascertainment. In two of the studies, treatment allocation was non-random, and in the other two, neither the randomization method nor concealment of treatment allocation were described. One of the four studies had results indicating a benefit from anticoagulation;^ 211 ^ however, in addition to other limitations, group assignment was non-random (alternating month schedule) and unconcealed, which may have introduced bias in treatment allocation.

#### Patients with Cardiac Disease

We did not identify any randomized trials evaluating the efficacy of anticoagulation in preventing recurrent stroke among patients with clinically identifiable heart conditions other than AF. One poor-quality retrospective cohort study evaluated outcomes in 90 consecutive patients with acute stroke and AF (58 percent), MI (24 percent), valvular heart disease without AF (14 percent), or DCM (2 percent).^ 214 ^ Fifty-four percent of patients received intravenous heparin, at their physicians' discretion, within the first 96 hours after stroke onset, followed by oral anticoagulation for at least 2 weeks. The other 46 percent did not receive anticoagulants within the first 2 weeks; most received aspirin or dipyridamole. After one month, the two groups had similar rates of recurrent stroke (2 percent in both groups) and ICH (6 percent with and 5 percent without anticoagulation). The authors, however, did not report baseline patient characteristics and did not adjust for potential confounding factors.

We identified one good-quality systematic review of studies evaluating the effectiveness of chronic anticoagulation (at least 3 months duration) in preventing stroke among patients with coronary artery disease (CAD).^ 215 ^ Patients enrolled in these studies had had MI, unstable angina, or coronary artery bypass graft surgery, but had not necessarily experienced stroke. While data from these studies of primary stroke prevention offer insight as to whether anticoagulation proffers net benefit for patients with CAD and prior stroke (secondary prevention), they must be interpreted with caution. Patients with prior stroke have a higher risk of stroke than those without prior stroke and may therefore derive greater absolute benefit from preventive therapies.^216-219^ Alternatively, since patients with prior stroke are more prone to develop ICH while on anticoagulants,^ 220 ^ they may experience greater harm and therefore less net benefit from anticoagulation than those without prior stroke.

In the systematic review,^ 215 ^ anticoagulation of high (INR 2.8 to 4.8) and moderate (INR 2.0 to 3.0) intensity was not superior to aspirin in preventing MI, stroke, or death and caused a 2.7 percent absolute increase in major bleeding (requiring transfusion, surgery, or hospitalization). In three studies including 480 patients with acute coronary syndromes, high- and moderate-intensity anticoagulation combined with aspirin was associated with a significant 5.4 percent absolute reduction in the combined outcome of MI, stroke, or death, when compared to aspirin alone and a non-significant 1.6 percent increase in major bleeding. However, a subsequent good-quality randomized trial involving 3,712 patients with acute coronary syndromes found that when the combination of warfarin (INR 2.0 to 3.0) and aspirin was compared to aspirin alone, an absolute reduction in ischemic stroke of 0.5 percent after 5 months was offset by an increase in major hemorrhage of 1.4 percent.^ 221 ^ There were no significant differences in the combined outcome of MI, stroke, or cardiovascular death in the intention-to-treat analyses from this study.

We did not identify any randomized trials of anticoagulation for primary or secondary stroke prevention in patients with DCM, prosthetic heart valves, or rheumatic heart disease. One good-quality systematic review revealed that in 385 patients with DCM across five cohort studies, anticoagulation for primary prevention was associated with a reduced risk of stroke.^ 222 ^ In contrast, observational analyses from the Veterans Affairs Cooperative Studies Vasodilator-Heart Failure Trials (V-HeFT I and II), which included 1,446 patients, found no association between anticoagulation and stroke risk.^ 223 ^ None of these studies included adjustment for potential confounding factors or directly compared anticoagulation to antiplatelet therapy.

A more recent observational analysis of data from 2,231 patients enrolled in the Survival and Ventricular Enlargement trial (SAVE) demonstrated that for every decrease of 5 percentage points in the cardiac ejection fraction among patients with myocardial infarction, there was an 18 percent increase in the risk of stroke. Anticoagulation was independently associated with a reduced risk of stroke, with relative risks of 0.17, 0.14, and 0.23 in patients with ejection fractions of <29, 29 to 35, and >35, respectively, after adjustment for age, ejection fraction, comorbidities, and other treatments.^ 224 ^ While no direct comparisons between anticoagulation and antiplatelet therapy were made, the relative risk for anticoagulation was 0.19 (95 percent CI, 0.13, 0.27) and the relative risk for antiplatelet therapy was 0.44 (95 percent CI, 0.29, 0.65).

### Summary

For any given patient with stroke, the potential usefulness of echocardiography in detecting a source of cardioembolism depends on the absence of clinically apparent indications for treatment (i.e., anticoagulation). There is substantial evidence, for instance, that for patients with stroke and AF, anticoagulant drugs confer net benefit, making echocardiographic identification of lesions warranting anticoagulation in these patients superfluous. Whether anticoagulation is beneficial in stroke patients without AF is less clear.

There is fair evidence that unselected patients with stroke do not benefit from anticoagulation as compared to antiplatelet therapy. Evidence from a large, fair-quality international trial suggests that subcutaneous heparin given acutely to patients with stroke is not associated with improved outcomes when compared to aspirin. The two therapies used in combination may confer net benefit, but further study is needed to confirm this finding. A good-quality multicenter trial comparing chronic anticoagulation (target INR 1.4-2.8) and aspirin (325 mg) found no differences in either benefits or harms between the two treatments. Another good-quality trial employing higher degrees of anticoagulation (target INR 3.0-4.5) was stopped early due to increased rates of ICH and death with anticoagulation as compared to aspirin.

We found no fair- or good-quality studies examining the effectiveness of anticoagulation in the prevention of recurrent stroke among patients with stroke and cardiac conditions other than AF. Studies of primary stroke prevention among patients with MI suggest that when compared to aspirin, anticoagulation either alone or in combination with aspirin does not confer net benefit. For patients with DCM, evidence regarding anticoagulation for primary stroke prevention comes from observational studies that provide conflicting results. The only good-quality study found that anticoagulation was more effective than aspirin in the primary prevention of stroke, particularly for patients with moderate and severe cardiomyopathy, after acute MI.

Overall, we found fair evidence that neither acute nor chronic anticoagulation confers net benefit, as compared to aspirin, for unselected patients with stroke. We found insufficient evidence to reach conclusions regarding the effectiveness of anticoagulation for secondary prevention of stroke among patients with stroke and clinically apparent cardiac conditions other than AF. Studies of primary prevention suggest that anticoagulation may be beneficial for patients with DCM but is probably not beneficial in patients with MI; however, results from studies of primary stroke prevention may not be generalizable to patients who have already experienced stroke and are candidates for secondary prevention. Given these findings, we conclude that the scope of patients for whom echocardiography may be useful, if it can effectively identify treatable sources of recurrent stroke, includes all stroke patients except those with AF.

## 6. Are there echocardiographically identifiable groups of patients with new ischemic brain syndrome who benefit from anticoagulation?

In addition to the approximately 7 percent of strokes that are attributable to AF, another 8 percent are also thought to be of cardioembolic origin.^ 47 ^ Among this latter group, nearly half may be due to clinically inapparent sources.^ 47 ^ The usefulness of echocardiography in patients with stroke depends on its ability to accurately identify such clinically inapparent sources, but also on the availability of efficacious treatments to reduce morbidity and mortality associated with those sources once identified. We therefore sought studies that evaluated the efficacy of anticoagulation in patients with clinically inapparent, echocardiographically identifiable lesions that represent potential sources of cardioembolism.

### Findings

We identified no randomized trials examining the efficacy of anticoagulation for secondary prevention among stroke patients with echocardiographic lesions representing potential sources of cardioembolism. We found one systematic review of studies of patients with stroke found to have PFO, comparing outcomes in patients treated with anticoagulants, surgical PFO closure, and antiplatelet therapy.^ 88 ^ Another cohort study examined the effectiveness of anticoagulation in patients with systemic emboli and mobile aortic atheromas.^ 225 ^

The systematic review of secondary stroke prevention among patients with PFO included five retrospective cohort studies and was of fair quality.^ 88 ^ The five studies included 378 patients, whose mean age ranged from 38 to 48 and who were treated with warfarin, antiplatelet agents, or surgical PFO closure. None of the individual studies found significant differences across treatment groups. The pooled annual rates of recurrent stroke or TIA over a mean followup period of three years were 1.0 percent with surgical closure, 2.5 percent with warfarin, and 5.1 percent with antiplatelet therapy. Using meta-analytic methods, the reviewers found the difference between warfarin and antiplatelet therapy to be statistically significant (odds ratio 0.37; 95 percent CI, 0.23 to 0.60). Because the number of patients undergoing surgical PFO closure was small, the differences between surgical closure and either warfarin (odds ratio 1.19; 95 percent CI, 0.62 to 2.27) or antiplatelet therapy (odds ratio 0.36, 95 percent CI; 0.04 to 3.09) were not significant. While these results suggest a protective effect with warfarin and possibly with surgical PFO closure, as compared to antiplatelet therapy, it must be noted that the five individual studies were generally of poor quality, treatment assignment in all studies was discretionary, and the effect of potential confounding by differences in patient characteristics across treatment groups was not assessed.

One poor-quality prospective cohort study evaluated the effect of anticoagulation in 31 patients with systemic embolization found to have mobile aortic atheroma on TEE.^ 225 ^ Twenty-five of these patients (81 percent) presented with stroke. Twenty patients (65 percent) received warfarin (target INR 2.0) at their physicians' discretion, seven (23 percent) received antiplatelet therapy, and four (13 percent) received neither. During a followup period of 10 months, none of the 20 patients receiving warfarin experienced a recurrent stroke, compared to three of the eleven patients (27 percent) not treated with warfarin (p = 0.07); all three patients with recurrent stroke were taking aspirin. However, three patients (15 percent) on warfarin died, one of them from gastrointestinal hemorrhage, compared to one patient (9 percent) not receiving warfarin (not statistically significant). Overall, there were no significant differences in the combined outcome of any vascular event or death. The authors did not report or adjust for baseline differences between those receiving and those not receiving warfarin.

Because there was limited evidence regarding the efficacy of anticoagulation in the secondary prevention of stroke, we evaluated the evidence for primary prevention of stroke in patients with specific echocardiographic lesions. We identified one systematic review of seven studies addressing whether anticoagulation in patients with mural thrombi after anterior MI reduced embolic complications.^ 59 ^ Three of these studies demonstrated a statistically significant reduction of embolic events with anticoagulation. In all of these studies, control subjects received placebo rather than antiplatelet therapy. The pooled odds ratio for the effect of anticoagulation on the incidence of embolic events was 0.14 (95 percent CI, 0.04 to 0.52). However, there was significant heterogeneity across the included studies, making pooling of results of questionable validity. None of the studies was a randomized trial.

A cohort study within the SPAF-III trial included 382 patients with non-valvular atrial fibrillation who underwent TEE.^ 56 ^ The primary ischemic event rate was 12.9 percent in patients with demonstrated LAT on a combination therapy of low-dose warfarin and aspirin. In patients on high-dose warfarin, the primary ischemic event rate was 17.9 percent. The odds ratio for this comparison was 2.7 (p <0.05). This unexpected finding of a higher stroke rate among patients receiving high-dose anticoagulation may have been attributable to the fact that TEE was conducted approximately 3 weeks after initiation of therapy. Some patients with LAT may therefore have been effectively treated, with resolution of thrombus by the time TEE was performed, leaving only patients with the most severe thrombi or at highest risk of embolism with evident LAT on TEE. One other study assessing embolization in patients with intracardiac thrombus included too few patients with thrombus (n=5) to allow firm conclusions.^ 226 ^

### Summary

Studies of the effectiveness of anticoagulation for echocardiographically identifiable lesions were all observational in design. Pooled data from five retrospective cohort studies suggest that warfarin, and possibly surgical PFO closure, may reduce the rate of recurrent stroke or TIA among patients with stroke and PFO. However, these studies were generally of poor quality and did not account for differences in baseline characteristics that may have given rise to differences in outcomes across treatment groups. A small, poor-quality cohort study of patients with stroke found to have mobile aortic atheromas revealed a trend towards lower recurrent stroke rates with warfarin as compared to aspirin, but no differences in the combined outcome of all vascular events plus death. A poor-quality systematic review of primary stroke prevention in patients with intraventricular thrombus after acute MI suggested a net benefit with anticoagulation, but the reviewed studies were observational, and no adjustment for potential confounding was conducted. Moreover, whether or not findings from studies of primary stroke prevention among patients with acute MI can be used to draw conclusions regarding secondary prevention among a general population of patients with stroke is not clear. Based on our review, we conclude that there is insufficient evidence to draw conclusions about the effectiveness of anticoagulation in reducing morbidity and mortality among stroke patients with echocardiographically identified lesions.

## Cost Effectiveness of Echocardiography

### Echocardiography Decision Model

The echocardiography model follows a hypothetical cohort of patients with newly diagnosed ischemic (non-hemorrhagic) stroke over the course of their remaining lifetimes. The base case represents 65-year-old men with newly diagnosed ischemic stroke who have survived acute stroke treatment, and are now at the point where a decision will be made about further diagnostic testing. Patients are assumed not to have a prior indication for anticoagulation therapy, such as atrial fibrillation. They are also assumed not to have contraindications to anticoagulant therapy. The cohort consists of stroke patients with and without a history of cardiac disease, which is defined variably across studies but generally includes history of myocardial infarction, congestive heart failure, valvular disease, and arrhythmia. Patients diagnosed with intracardiac thrombus, either left atrial or left ventricular, receive anticoagulant therapy. Other echocardiographically identifiable lesions, for which indications for treatment are less clear, are not included in the model. The model excludes the clinically unacceptable course of not treating stroke patients with at least standard medical treatment such as antiplatelet therapy. Its time horizon is 30 years, at which time virtually all patients will have died of stroke-related or other causes. Decisions to initiate or change therapy are based on clinical events alone.

### Echocardiographic Testing Strategies

We evaluate nine diagnostic testing strategies in the echocardiography model, which are listed in Table 4. The purpose of the diagnostic tests is to identify an intracardiac thrombus that would be potentially treatable with anticoagulant therapy, with the primary clinical objective of reducing the mortality and morbidity associated with recurrent stroke.

Table 4. Echocardiography model testing strategies

Number | Strategy
1 | Treat all with standard medical treatment
2 | Treat all with anticoagulation plus standard medical treatment
3 | All receive TTE
4 | All receive TEE
5 | All with cardiac history receive TTE -- others receive standard medical treatment (Selective 1)
6 | All with cardiac history receive TEE -- others receive standard medical treatment (Selective 2)
7 | All receive TTE -- negative TTE prompts TEE (Sequential 1)
8 | All with cardiac history receive TTE -- negative TTE prompts TEE (Sequential 2)
9 | All with cardiac history receive TTE, negative TTE receives TEE -- all with no history receive TEE (Selective-sequential)

Figure 3 is a decision tree that illustrates the relationship of the nine diagnostic strategies. The baseline comparisons are treating all patients with standard medical treatment without anticoagulant therapy (strategy 1), assumed to be the minimal standard of care, or treating all patients with anticoagulant therapy plus standard medical treatment (strategy 2). Diagnostic testing strategies are to use TTE alone on either all patients (strategy 3) or those with a cardiac history (strategy 6), to use TEE alone on either all patients (strategy 4) or those with a cardiac history (strategy 7), or to adopt a sequential strategy of TTE followed by TEE for negative TTE results. In the sequential strategies, the initial TTE is either performed on all patients (strategy 5), or limited to those with a cardiac history (strategy 8). In strategy 9, all stroke patients with no cardiac history receive TEE, while those with a cardiac history undergo TTE first, and only undergo TEE if TTE is negative. Under all strategies, final positive test results lead to anticoagulant therapy plus standard medical treatment without aspirin, and final negative test results lead to standard medical treatment alone, including aspirin.

Figure 3. Echocardiography decision tree

Numbers in parentheses refer to Table 4.*SMT -- standard medical treatment TEE -- transesophageal echocardiography TTE -- transthoracic echocardiography

Stroke risk for patients with intracardiac thrombus on TTE or TEE is assumed to depend on the thrombus rather than on other patient characteristics such as age or gender, i.e., the stroke risk for all patients with a left atrial thrombus is the same.

### Markov Modeling

We constructed a semi-Markov model of stroke to model the time sequence of disease states, survival, and associated costs among the cohort of stroke patients. Semi-Markov models are decision trees that include Markov nodes, branching points in the tree that lead to a Markov process. In a Markov process, both specific health states and the possible transitions between them are defined. The prognosis of the patient (or cohort) in the analysis is described by the health states, the permissible transitions between states, and the rates of transition. Markov models can illustrate the relationship between the risk reduction of an intervention and the cost of a diagnostic or treatment strategy over the appropriate time horizon. Our models use a generalization of Markov processes in which transition rates between states are not fixed, but rather, can change with time.

The Markov nodes in the echocardiography decision model include five stroke-related health states: TIA, minor ischemic stroke, moderate ischemic stroke, severe ischemic stroke -- which are all based on the Rankin disability scale as shown in Table 5 -- and death (Figure 4).

Table 5. Health state definitions with associated Rankin Disability Scale categories

Name | Rankin | Description
TIA* | 0-1 | No significant disability; able to carry out all usual activities of daily living
Minor | 2 | Slight disability; unable to carry out some previous activities, but able to look after own affairs without assistance
Moderate | 3 | Moderate disability, requiring some help but able to walk without assistance
Severe | 4-5 | Combination of "Moderately severe disability; unable to walk and attend to own bodily needs without assistance" and "Severe disability; bedridden, incontinent, and requiring constant nursing care and attention"

* TIA: transient ischemic attack; category includes completed stroke with full functional recovery.

Figure 4. Markov diagram--Post-treatment health states (echo model)

A transition (event) is the passage from one state to another. For example, a patient that enters the model at age 65 with a TIA, has a severe ischemic stroke at 75 that lowers him to the severe stroke state, and dies at 80 would spend 10 years in the TIA state, then 5 years in the severe stroke state. We assume that the hypothetical patient cohort initially entering a Markov node is distributed among the stroke-related health states (excluding death) according to the prevalence of stroke severity among new stroke patients. Once in a stroke state, a person can remain in the same state for a given annual cycle, experience a recurrent stroke, die from either stroke-related or non-stroke-related causes, or experience short- or long-term treatment complications. A person experiencing a recurrent stroke that is more severe than the most recent stroke transitions into the more severe health state; e.g., a person initially experiencing a minor stroke, who subsequently has a moderate stroke, transitions from the minor stroke health state to the moderate stroke state. When a recurrent stroke is less severe than the most recent stroke, the person accrues a transient (single-cycle) decrement in utility, but thereafter remains in the prior health state; e.g., a person initially experiencing a moderate stroke who subsequently has a recurrent minor stroke will have a single-cycle decrement in health state but will thereafter remain in the moderate stroke state. When a recurrent stroke is of the same severity as the most recent stroke, the person generally accrues a transient (single-cycle) decrement in utility, but thereafter remains in the prior health state. The exception is the case of a person in the severe stroke health state experiencing a recurrent severe stroke. Because of the high mortality associated with this situation, the person is assumed to transition to the death state. Transitions between health states occur at the end of each cycle.

The model simulates the natural history for a large number of hypothetical patients, each of which is followed for relevant health events until death. During this process, health state dependent flows of costs and utilities are recorded. Hence, each patient generates a survival time, a quality-adjusted survival time, and a cost. Although the time course of any one patient occurs randomly, the selection is guided by the parameters of the decision model. If a large enough group of patients is simulated, the overall outcome pattern should reflect well the simulated population's natural history.

Complications of the testing procedures are limited to a small mortality risk from TEE-related esophageal perforation; TTE is assumed to carry no complication risk. We do not assume a short-term loss of quality of life from esophageal perforation. Tests are administered only once. On the basis of a final positive or negative test result, persons are assigned to a specified treatment regimen -- anticoagulation plus standard medical treatment or standard medical treatment alone.

Treatment-related complications are either gastrointestinal bleeding or ICH. All bleeds are assumed to be short-term, i.e., one annual cycle. Any temporary and meaningful loss of quality of life from a bleed within the first 30 days of treatment is assumed to be minor when averaged over the first year. ICHs can be either short- or long-term; long-term ICHs are considered permanent and to be equivalent in severity to a severe ischemic stroke. Short-term complications can occur repeatedly, but in any case patients experiencing anticoagulant-related complications are assumed to immediately and permanently discontinue anticoagulant therapy. The death state is terminal; with enough time all cohort members would die.

The Markov nodes in the echocardiography model are run up to 360 monthly cycles. We use life tables to establish the age- and gender-specific baseline mortality rate for the cohort and adjust these rates to account for the increased risk of cardiac-related deaths among patients with stroke. The echocardiography model includes eight separate Markov nodes that reflect the various prognoses of patients with or without an intracardiac thrombus, on aspirin or anticoagulant therapy, and experiencing or not experiencing a complication of TEE.

### Costs

We take the perspective of direct medical costs related to stroke evaluation and management, and exclude indirect costs related to lost work productivity. Cost estimates were derived from best estimates from the literature or from Medicare fee schedules (Table 6). All financial outcomes are adjusted to year 2000 dollars using the medical component of the Consumer Price Index. For the purposes of calculation, the model assumes that events occur in the middle of each year.

Table 6. Parameter List -- Echocardiography

| Baseline | Low | High | Source
Clinical/epidemiologic
Prevalence
Health states after stroke/TIA
TIA/full recovery | 0.24 | 0 | 0.5 | Evidence Tables 1, 2; Matchar (2000)
Minor stroke | 0.18 | 0 | 0.5 | Matchar (2000)
Moderate stroke | 0.19 | 0 | 0.5 | Matchar (2000)
Severe stroke | 0.39 | 0 | 0.5 | Matchar (2000)
Cardiac disease | 0.36 | 0.2 | 0.6 | Evidence Tables 1, 2
Intracardiac thrombus
Unselected population | 0.02 | 0.001 | 0.2 | Evidence Tables 1, 2
Patients with cardiac disease | 0.05 | 0.01 | 0.36 | Evidence Tables 1, 2
Patients without cardiac disease | 0.007 | 0.003 | 0.033 | Evidence Tables 1, 2
Test Accuracy
Left Atrial Thrombus
Sensitivity of TEE | 0.93 | 0.80 | 1.0 | Evidence Table 3
Specificity of TEE | 0.97 | 0.90 | 1.0 | Evidence Table 3
Sensitivity of TTE | 0.42 | 0.15 | 0.75 | Evidence Table 4
Specificity of TTE | 0.99 | 0.95 | 1.0 | Evidence Table 4
Left Ventricular Thrombus
Sensitivity of TEE and TTE | 0.78 | 0.60 | 1.0 | Evidence Table 5
Specificity of TTE and TEE | 0.87 | 0.70 | 1.0 | Evidence Table 5
Recurrent Stroke
Patients with untreated intracardiac thrombus, year 1 | 0.22 | 0.04 | 0.60 | Comess (1994), SPAF (1998), Stratton (1987), McNamara (1997)
Relative risk (RR) with anticoagulation, year 1 | 0.67 | 0.14 | 1.0 | McNamara(1997), Vaitkus(1993)
Patients without intracardiac thrombus, year 1 | 0.12 | 0.08 | 0.15 | Petty (1998, issue 50;1), Hankey (1998, Stroke), Sacco (1994), Burn (1994), Chen (1985)
Annual rate for all patients, after year 1 | 0.03 | 0.01 | 0.10 | Petty (1998, issue 50;1), Hankey (1998, Stroke), Sacco (1994), Burn (1994), Chen (1985)
Case fatality of recurrent stroke | 0.26 | 0.22 | 0.30 | Tuomilehto (1992), Jorgensen (1997), Ellekjaer (1997)
Complication Rates
Esophageal perforation--TEE | 0.0032 | 0 | 0.0064 | Evidence Table 6
Case fatality of esophageal perforation | 0.04 | 0.03 | 0.10 | Evidence Table 6
Mortality--TEE | 0.0001 | 0 | 0.0003 | Evidence Table 6
ICH incidence--anticoagulation, year 1 | 0.014 | 0.001 | 0.059 | Petty (1999), Landefeld (1989)
ICH incidence--antiplatelet therapy, annual | 0.0025 | 0.0002 | 0.008 | Petty (1999), SPIRIT (1997)
Case fatality of ICH | 0.50 | 0.38 | 0.64 | Berwaerts (2000), SPIRIT (1997), Landefeld (1989)
Proportion of ICH with no recovery (severe) | 0.09 | 0.03 | 0.20 | Berwaerts (2000)
GI bleed incidence--anticoagulation, year 1 | 0.034 | 0.008 | 0.068 | Petty (1999), Landefeld (1989)
GI bleed incidence--antiplatetelet therapy, annual | 0.018 | 0.009 | 0.031 | Petty (1999), SPIRIT (1997)
Case fatality of GI bleed | 0.06 | 0.008 | 0.016 | Petty (1999), SPIRIT (1997), Landefeld (1989)
Non-stroke Mortality
Baseline | Actuarial data | | | U.S. Life tables
Annual excess cardiovascular mortality | 0.048 | 0.012 | 0.12 | Dennis (1993), Hankey (2000)
Relative risk of death by health state | | | | Samsa (1999, J Clin Epi)
TIA/full recovery | 1.0 | 1.0 | 1.0
Minor stroke | 1.11 | 1.0 | 1.3
Moderate stroke | 1.27 | 1.05 | 1.4
Severe stroke | 2.04 | 1.35 | 3.0
Economic
Cost
Diagnosis
TTE | 466 | 233 | 932 | 2001 Medicare fee schedule
TEE | 564 | 282 | 1,128 | 2001 Medicare fee schedule
Complications
Esophageal perforation | 2,198 | 1,100 | 4,400 | Seto (1997)
Treatment
Annual cost of anticoagulation therapy | 900 | 450 | 1,800 | Matchar (2000)
Annual cost of antiplatelet therapy (aspirin) | 60 | 30 | 90 | Matchar (2000)
Complications
GI Bleed | 5,128 | 2,564 | 10,256 | Matchar (2000)
ICH-acute | 17,840 | 8,920 | 35,680 | McNamara (1997)
Downstream (i.e., cost of stroke)
Acute recurrent stroke | First 30 days
Minor stroke | 2,801 | 1,400 | 4,200 | Samsa (1999, Stroke)
Moderate stroke | 5,077 | 2,538 | 10,154 | Samsa (1999, Stroke)
Severe stroke or severe ICH | 14,706 | 7,353 | 20,000 | Samsa (1999, Stroke)
Chronic stroke (annual) | Month 2-4 | Months 5-12 | Months 13+
TIA/full recovery | 811 | 364 | 339 | Samsa (1999, Stroke)
Minor stroke | 1298 | 583 | 543 | Samsa (1999, Stroke)
Moderate stroke | 2353 | 1056 | 984 | Samsa (1999, Stroke)
Severe stroke or severe ICH | 6816 | 3059 | 2850 | Samsa (1999, Stroke)
Terminal costs (i.e., life-saving) | 10,000 | 5,000 | 20,000 | Estimate
Utilities
TIA/full recovery | 0.9 | 0.85 | 1.0 | Matchar (2000)
Minor stroke | 0.65 | 0.6 | 0.7 | Matchar (2000)
Moderate stroke | 0.5 | 0.45 | 0.55 | Matchar (2000)
Severe stroke | 0.27 | 0.22 | 0.32 | Matchar (2000)
Death | 0 | 0 | 0 | Convention
ICH-minor | 0.65 | 0.5 | 0.9 | Assumed (utility for minor stroke)
ICH-severe | 0.27 | 0.22 | 0.32 | Assumed (utility for severe stroke)
GI bleed | 0.997 | 0.98 | 1.0 | Matchar (2000)
Discount rate | 3% | 0 | 5% | Gold (1996)

### Utilities

Both stroke disability and the side effects of treatment can lower quality of life; therefore, we assigned utility values to each health state, ranging from 0.9 for a TIA to 0 for death. In our model, a recurrent stroke is manifested in a transition to a lower health state, and requires a utility loss, which will be to zero if the new stroke results in death. The utility level assigned to a long-term treatment-related ICH is the same as that assigned to a severe stroke, and that of a short-term ICH the same as that assigned to a minor stroke. Our utility values were based on the final, and predominately time-tradeoff (TTO)-based, values reported by the Stroke Patient Outcomes Research Team (PORT) in its discussion of the Stroke Policy Model.^ 227 ^ We made two modifications, however. First, although the PORT set the utility for TIA equal to that for asymptomatic patients at 1, we chose to acknowledge a small quality of life decrement for TIA patients relative to persons in perfect health, and therefore, conservatively assigned a value of 0.9 to the utility for TIA. Second, the number of health states in our model was based on PORT prevalence data, which distinguished between TIA and minor, moderate, and severe stroke. To map this qualitative scale to the Rankin scale, we averaged data for Rankin levels 4 and 5 to severe stroke. For utility values, we averaged the PORT utilities for Rankin level 4 (.35) and Rankin level 5 (.20) to generate the 0.27 value we used for severe stroke. The PORT team reported that the mean TTO utility for major stroke from its patient survey was 0.30, and that accounting for the significant number of respondents reporting negative utility reduced the mean to 0.23, supporting our use of 0.27 as the utility for patients experiencing severe stroke.

As stated earlier, we assigned a single-cycle decrement in utility to persons experiencing a recurrent stroke of the same or lower severity than their most recent stroke (e.g., persons in the moderate stroke health state who experience a recurrent minor or moderate stroke). We calculated that decrement by multiplying the person's prior health state utility by the difference: one minus the utility associated with the recurrent stroke. For example, a person in the moderate stroke health state (utility 0.5), who experienced a minor stroke (utility 0.65), would be assigned a decrement in utility of (0.5 x (1-0.65)) = 0.175. The rationale for this calculation is that the person having a recurrent stroke is assumed to have a relative decrement in utility similar to that experienced by a healthy person (utility 1.0) having a first stroke.

### Discount Rate

We discounted both costs and utilities using a base rate of 3 percent to reflect the common convention that costs and health benefits incurred or realized in the future are assigned lower values than costs and benefits realized in the present.

### Major Assumptions and Estimates

Wherever possible, we used estimates in the cost-effectiveness model that were derived from our systematic review. For parameters not identified in our evidence review and for those for which our review revealed insufficient evidence, we either used the best available estimates from the literature or made informed assumptions, guided by our technical expert group, and tested the effects of those assumptions in sensitivity analyses. Importantly, we identified no evidence supporting the use of anticoagulation in the treatment of LAT, and one poor-quality meta-analysis supporting its use to treat LVT. In a previous cost-effectiveness analysis, McNamara et al. addressed this lack of evidence by assuming that the relative risk reduction from anticoagulation among patients with stroke and documented left atrial thrombus was similar to that among patients with atrial fibrillation (33 percent).^ 4 ^ They also assumed no treatment benefit for left ventricular thrombus. Given the results of our literature review, we chose to assume equal benefits of anticoagulation for both lesions. We also adopted the 33 percent relative risk reduction in our baseline results to facilitate comparisons between our results and those of McNamara et al. -- which represents the only published cost-effectiveness analysis on this topic that we were able to identify -- and varied this figure widely in sensitivity analyses. Thus, accurately stated, our analysis addresses the question: "If treatment of intracardiac thrombus were effective, what strategies for testing would be cost-effective?"

Most major assumptions in our base-case analysis are included in Table 6. Other assumptions included: the prevalence of LAT and LVT are equal; intracardiac thrombus conveys an increased stroke risk for one year, and after one year, the recurrent stroke rate in patients with thrombus reverts to the rate of those without thrombus; the severity distribution of non-fatal strokes is the same as that for initial strokes, i.e., 24 percent minor, 25 percent moderate, and 51 percent severe; the annual excess cardiovascular mortality among patients with stroke is 4.8 percent per year and does not vary with stroke severity; and persons with more severe strokes, and therefore worse health states, have a higher rate of death not attributable to cardiac causes or recurrent stroke.

## Results

Table 7 describes the base-case results of the echocardiography decision model, which is follows a cohort of 65-year-old white males. The eight testing strategies are compared with the strategy of treating all with standard medical therapy. Only one strategy, performing TEE in patients with a history of cardiac disease, is undominated. The incremental cost-effectiveness ratio of this strategy is approximately $300,000 per QALY. For the purposes of this model, the only factor differentiating those with a cardiac history from those without it is the prevalence of intracardiac thrombus (5.0 percent in those with a cardiac history, 0.7 percent in those without a cardiac history). Thus, these results are most accurately interpreted as indicating that the incremental cost-effectiveness of TEE is approximately $300,000 in patients with a prevalence (pre-test probability) of intracardiac thrombus of 5 percent.

Table 7. Baseline echocardiography results

Strategy | Cost ($000) | Incremental Cost ($000) | QALY | Incremental QALY | Cost-effectiveness ratio ($000)
TTE sequential | 139.4 | 0.3 | 3.4503 | -0.0009 | Dominated
Other sequential | 139.1 | 0.2 | 3.4512 | -0.0002 | Dominated
TEE | 138.9 | 0.1 | 3.4514 | -0.0002 | Dominated
TTE | 138.8 | 0.1 | 3.4516 | -0.0007 | Dominated
Anticoagulation | 138.7 | 0.1 | 3.4523 | 0.0211 | Dominated
History/sequential | 138.6 | 0.0 | 3.4312 | -0.0214 | Dominated
History/TEE | 138.6 | 0.1 | 3.4526 | 0.0003 | 184.0
History/TTE | 138.5 | 0.2 | 3.4523 | 0.0005 | 337.4
Aspirin | 138.3 | -- | 3.4518 | -- | --
After all weakly or strongly dominated alternatives are removed:
History/TEE | 138.6 | 0.3 | 3.4526 | 0.001 | 294.0
Aspirin | 138.3 | -- | 3.4518 | -- | --
History/TTE eliminated by extended dominance.

### Influence of Demographics

We did not have sufficient data on either the incidence of recurrent stroke or the effectiveness of treatment within demographic subgroups to comment meaningfully on the specific influence of demographics. As an alternative, we used data from the U.S. Life Tables produced by the National Center for Health Statistics to adjust the all-causes mortality rate in the model, the baseline of which is for 65-year-old white males. We used the Life Tables to adjust baseline mortality according to various combinations of gender, race (specifically, African American), and age (55, 65, 75, and 85 years old).

Figure 5 illustrates the effect of increasing life expectancy on the cost per QALY for the strategy of performing TEE in patients with cardiac disease. Readers can apply this information to the specific circumstances of their patients.

Figure 5. Effect of Baseline Life Expectancy on Cost-Effectiveness of TEE in Patients with a History of Cardiac Disease (Cardiac History/TEE)

### Sensitivity Analysis

We performed sensitivity analyses on the model parameters listed in Table 6. Table 8 presents selected results. The variables to which the cost-effectiveness results are most sensitive are the cost of TEE, the prevalence of thrombus and the level of relative benefit from anticoagulation. Changes in the assumed accuracies of TTE and TEE changed the ranking of cost-effectiveness between the two tests, but did not substantively change the magnitude of the cost-effectiveness ratios. A two-way sensitivity analysis of the relative risk reduction associated with anticoagulation and the prevalence of intracardiac thrombus shows that the incremental cost-effectiveness of TEE (or under separate assumptions, TTE) drops below $50,000 per QALY when the relative risk reduction (RRR) with anticoagulation is 33 percent and the prevalence of thrombus at least 20 percent; when the RRR is 50 percent and the prevalence of thrombus is at least 13 percent; or when the RRR is 86 percent (the highest estimate supported by the literature) and the prevalence of thrombus is at least 6 percent (Figure 6). Thrombus prevalence of 6 percent or more is likely to be found in patients with structural heart disease, most notably dilated cardiomyopathy or recent MI.

Table 8. Sensitivity analyses--Echocardiography

| Strategy | Cost ($000) | Incremental Cost ($000) | QALY | Incremental QALY | Cost-effectiveness ratio ($000)
TEE cost = $282 ($564 at baseline) | History/TEE | 138.5 | 0.2 | 3.4525 | 0.0007 | 165.6
TEE cost = $282 ($564 at baseline) | Aspirin | 138.3 | -- | 3.4518 | -- | --
TEE cost = $1,128 | History/TEE | 138.8 | 0.3 | 3.4525 | 0.0000 | 1,091.0
TEE cost = $1,128 | History/TTE | 138.5 | 0.2 | 3.4525 | 0.0007 | 337.4
TEE cost = $1,128 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TEE--LAT = .8 | History/TEE | 138.6 | 0.1 | 3.4525 | 0.0000 | 386.7
Sensitivity of TEE--LAT = .8 | History/TTE | 138.5 | 0.2 | 3.4525 | 0.0007 | 337.4
Sensitivity of TEE--LAT = .8 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TEE--LAT = 1 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 272.6
Sensitivity of TEE--LAT = 1 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TEE--LVT = .6 | History/TEE | 138.6 | 0.1 | 3.4525 | 0.0000 | 706.4
Sensitivity of TEE--LVT = .6 | History/TTE | 138.5 | 0.2 | 3.4525 | 0.0007 | 337.4
Sensitivity of TEE--LVT = .6 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TEE--LVT = 1 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 236.2
Sensitivity of TEE--LVT = 1 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TTE--LAT =. 15 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 294
Sensitivity of TTE--LAT =. 15 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TTE--LAT = .75 | History/TTE | 138.5 | 0.2 | 3.4525 | 0.0007 | 223.4
Sensitivity of TTE--LAT = .75 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TTE--LVT =.6 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 294
Sensitivity of TTE--LVT =.6 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Sensitivity of TTE--LVT =1 | History/TEE | 138.6 | 0.1 | 3.4525 | -- | 2,230.2
Sensitivity of TTE--LVT =1 | History/TTE | 138.5 | 0.2 | 3.4525 | 0.0007 | 251.3
Sensitivity of TTE--LVT =1 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TEE--LAT = .9 | History/TTE | 138.5 | 0.2 | 3.4525 | 0.0007 | 337.4
Specificity of TEE--LAT = .9 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TEE--LAT = 1 | History/TEE | 138.6 | 0.3 | 3.4525 | -- | 253.4
Specificity of TEE--LAT = 1 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TEE--LVT = .7 | History/TEE | 138.6 | 0.3 | 3.4525 | -- | 253.4
Specificity of TEE--LVT = .7 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TEE--LVT = 1 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 172.7
Specificity of TEE--LVT = 1 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TTE--LAT = .95 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 294
Specificity of TTE--LAT = .95 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TTE--LAT = 1 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 294
Specificity of TTE--LAT = 1 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TTE--LVT = .7 | History/TEE | 138.6 | 0.3 | 3.4525 | 0.0007 | 294
Specificity of TTE--LVT = .7 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Specificity of TTE--LVT = 1 | History/TTE | 138.5 | 0.2 | 3.4525 | 0.0007 | 170.4
Specificity of TTE--LVT = 1 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Relative risk with anticoagulation = .14 | History/sequential | 138.8 | 0.2 | 3.4559 | 0.0001 | 1,645.6
(Baseline = .67) | History/TEE | 138.6 | 0.3 | 3.4558 | 0.0040 | 65.0
(Baseline = .67) | Aspirin | 138.3 | -- | 3.4518 | -- | --
Relative risk with anticoagulation = .3 | History/TEE | 138.6 | 0.3 | 3.4548 | 0.0030 | 83.4
Relative risk with anticoagulation = .3 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Relative risk with anticoagulation = .5 | History/TEE | 138.6 | 0.3 | 3.4536 | 0.0018 | 133.4
Relative risk with anticoagulation = .5 | Aspirin | 138.3 | -- | 3.4518 | -- | --
TEE complication rate = 0 | History/TEE | 138.6 | 0.3 | 3.4528 | 0.0010 | 243.0
TEE complication rate = 0 | Aspirin | 138.3 | -- | 3.4518 | -- | --
Prevalence of thrombus with no cardiac | All TEE | 138.9 | 0.4 | 3.4502 | 0.0004 | 964.3
history = .033 (.007 at baseline) | History/TEE | 138.5 | 0.2 | 3.4498 | 0.0008 | 294.0
history = .033 (.007 at baseline) | Aspirin | 138.3 | -- | 3.4490 | -- | --
Prevalence of thrombus with cardiac history = .1 | History/TEE | 138.6 | 0.3 | 3.4512 | 0.0024 | 105.5
Prevalence of thrombus with cardiac history = .1 | Aspirin | 138.3 | -- | 3.4488 | -- | --
Prevalence of thrombus with cardiac history = .2 | History/sequential | 138.7 | 0.2 | 3.4488 | 0.0004 | 400.2
Prevalence of thrombus with cardiac history = .2 | History/TEE | 138.5 | 0.3 | 3.4484 | 0.0056 | 53.3
Prevalence of thrombus with cardiac history = .2 | Aspirin | 138.2 | -- | 3.4428 | -- | --
Prevalence of thrombus with cardiac history = .3 | History/sequential | 138.7 | 0.2 | 3.4465 | 0.0008 | 176.7
Prevalence of thrombus with cardiac history = .3 | History/TEE | 138.5 | 0.2 | 3.4457 | 0.0090 | 39.2
Prevalence of thrombus with cardiac history = .3 | Aspirin | 138.3 | -- | 3.4367 | -- | --
ICH incidence with anticoagulation = (.059 year 1) | Aspirin | 138.3 | -- | 3.4517 | 0.0734 | 12.6
ICH incidence with anticoagulation = (.059 year 1) | Anticoagulation | 137.4 | -- | 3.3783 | -- | --
ICH incidence with anticoagulation = (.001 year 1) | Other sequential | 139.1 | 0.4 | 3.4536 | -- | 40,009
ICH incidence with anticoagulation = (.001 year 1) | History/sequential | 138.7 | 0.1 | 3.4536 | 0.0002 | 940.3
ICH incidence with anticoagulation = (.001 year 1) | History/TEE | 138.6 | 0.3 | 3.4534 | 0.0016 | 152.5
ICH incidence with anticoagulation = (.001 year 1) | Aspirin | 138.3 | -- | 3.4518 | -- | --
Stroke recurrence rate with thrombus--low estimates | Aspirin | 138.3 | -- | 3.4518 | -- | --
Stroke recurrence rate with thrombus--high estimates | History/sequential | 139.1 | 0.6 | 3.4828 | 0.0437 | 1,643,234.0
Stroke recurrence rate with thrombus--high estimates | History/TEE | 138.5 | 0.2 | 3.4391 | 0.0024 | 95.2
Stroke recurrence rate with thrombus--high estimates | Aspirin | 138.3 | -- | 3.4367 | -- | --

Figure 6. Cost-effectiveness of TEE as a function of 1) intracardiac thrombus prevalence, and 2) the relative risk (RR) of recurrent stroke with anticoagulation compared to aspirin (for patients with thrombus)

We also examined the sensitivity of the results to other parameters such as cost of TTE, chronic cost of stroke, terminal cost, health state utilities, and the rate and cost of complications, but these had little effect on the results.