# Methods

## Development of Key Questions

The original questions that served as the impetus for this evidence review broadly addressed issues related to the effectiveness and cost-effectiveness of echocardiography and carotid imaging studies in patients with new stroke or TIA. Our initial task was to refine these broad questions and to frame them in a way that would allow us to conduct systematic reviews of the existing evidence for specific questions of clinical and/or policy relevance. We conducted a preliminary literature search and identified relevant review articles, professional consensus statements, and cost-effectiveness studies. Based on this preliminary review and discussions within our research team, we refined the initial key questions. We then discussed the questions with a group of technical experts, who assisted us in formulating the final key questions addressed in this report.

## Technical Expert Advisory Group

We assembled a technical expert advisory group to help us refine key questions as described above. The group included two neurologists, one of whom represented the American Academy of Neurology; a vascular surgeon; a cardiologist; a primary care clinician who is medical director of an HMO; and a woman who had recently had a stroke, to represent the patient perspective. The panel met with the research team for a half-day session to discuss the key questions, which were then reformulated. Appendix B lists the research team and the technical expert advisory group members along with those who reviewed the report.

## Literature Search

We searched MEDLINE, HealthSTAR, the Cochrane Controlled Trials Register, the Cochrane Database of Systematic Reviews, the Database of Abstracts of Reviews of Effectiveness, and Health Technology Assessment from 1996 or their inception. Searches were limited to human studies and English language and excluded editorials and case reports.

We conducted three searches related to echocardiography. A search linking echocardiography and stroke identified studies relevant to key questions 1, 2, and 3. For question 4, we conducted a search on complications of transesophageal echocardiography. For questions 5 and 6, we conducted a series of six small searches related to anticoagulation and stroke.

Three searches identified studies relevant to the carotid imaging key questions. A search on diagnostic accuracy of carotid imaging found studies for question 1. For question 2, we performed a search on cerebral angiography complications. For question 3 on efficacy of CEA in reducing recurrent stroke, we used existing systematic reviews to identify randomized trials. Finally, for questions 4 and 5, we conducted a search on complications of CEA.

In addition, the librarian conducted database searches that focused on the economic aspects of echocardiography and stroke, anticoagulation, carotid imaging, and CEA. She searched three databases -- MEDLINE, HealthSTAR, and the NHS Economic Evaluation Database -- to find papers related to costs and cost analysis, quality of life, and life expectancy and mortality. Relevant papers were used in conducting the cost analyses. All search strategies are listed in Appendix C.

As an adjunct to the database searches, investigators reviewed the reference lists of included studies and contacted content experts in the areas of stroke, echocardiography, and carotid imaging, to identify additional studies. Citations identified through database searches, reference lists, and content experts were imported into EndNote reference management software files.

The total number of citations identified through database searching was:

- For Echocardiography: Echocardiography and Stroke: 546 Transesophageal Echocardiography Complications: 119 Anticoagulant Drugs and Stroke: 1,618
- For Carotid Imaging: Diagnostic Testing for Carotid Disease: 306 Cerebral Angiography Complications: 301 Carotid Endarterectomy Complications: 1,269

Appendix D lists search results.

## Data Abstraction

For each key question, two reviewers out of a pool of four investigators independently reviewed the citations and abstracts retrieved by the database searches, using predetermined inclusion/exclusion criteria, and then compared results. Table 1 lists the specific inclusion and exclusion criteria by key question. The reviewers included two internists (SS, RC), a neurologist (KS), and a research associate with a PharmD and several years' experience conducting systematic reviews (MMcD). Differences were resolved by a discussion between the two reviewers for that question.

Table 1. Inclusion/exclusion criteria for studies

Question | Topic | Inclusion Criteria | | | Exclusion Criteria
Question | Topic | Population | Intervention | Outcome | Exclusion Criteria
Echo 1 (cohort studies) | Association of echocardiographic lesions with stroke | Patients with potential sources of cardioembolic stroke | TTE, TEE | Stroke | No original data; case series or case report (no comparison group)
Echo 1 (case-control studies) | Association of echocardiographic lesions with stroke | Patients with and without new ischemic brain syndrome | TTE, TEE | Echocardiographic lesions | No original data; case series or case report (no comparison group)
Echo 2 | Yield of echocardiography | Patients with new ischemic brain syndrome | TTE, TEE | Echocardiographic lesions | No original data; non-consecutive, non-random sample without description of selection criteria; case report; unable to distinguish results in patients with and without atrial fibrillaton
Echo 3 | Operating characteristics of echocardiography | Patients with potential sources of cardioembolic stroke | TTE, TEE | Diagnostic accuracy | No original data; inappropriate reference standard
Echo 4 | TEE complications | Patients undergoing TEE | TEE | Complications requiring intervention | No original data; case report; populations with specific clinical indications for TEE other than stroke (e.g., trauma)
Echo 5 | Efficacy of anticoagulation | Unselected patients with stroke or patients with clinically apparent heart disease | Anticoagulant therapy | Stroke recurrence, hemorrhage, death | No original data; case report
Echo 6 | Efficacy of anticoagulation | Patients with potential sources of cardioembolism on echocardiography | Anticoagulant therapy | Stroke recurrence, hemorrhage, death | No original data; case report
Carotid 1 | Operating characteristics of CUS, MRA | Patients undergoing CUS or MRA for diagnosis of carotid stenosis | CUS, MRA | Diagnostic accuracy | No original data; verification bias; reference standard other than conventional angiography; no distinction between carotid stenosis and occlusion; unable to calculate sensitivity and specificity by degree of stenosis
Carotid 2 | Cerebral angiography complications | Patients with symptomatic cerebrovascular disease | Cerebral angiography | Peri-procedural stroke or death | No original data; outdated technique; case report; retrospective
Carotid 3 | Carotid endarterectomy efficacy | Patients with carotid artery stenosis undergoing carotid endarterectomy | Carotid endarterectomy | Stroke recurrence | No original data; study designs other than randomized controlled trials
Carotid 4 | Carotid endarterectomy timing | Patients with carotid artery stenosis undergoing carotid endarterectomy | Carotid endarterectomy | Peri-operative stroke or death | No original data, case series or case report (no comparison group)
Carotid 5 | Carotid endarterectomy complications | Patients with carotid artery stenosis undergoing carotid endarterectomy | Carotid endarterectomy | Peri-operative stroke or death | No original data; outdated technique; case report; retrospective; unless population-based; unable to distinguish results of symptomatic and asymptomatic patients

Studies that met inclusion criteria were retrieved in full text and distributed to the investigator working on that key question. Investigators reapplied the inclusion/exclusion criteria to the full text of studies to create a final set of included studies.

Each investigator developed abstraction forms using Excel software and abstracted data from each included study into evidence tables. For all questions, the following data elements were abstracted: author, journal, year of publication, time period of the study, study design, information about subjects (e.g., age, gender, race, number), subject selection criteria, and study setting.

In addition, certain data elements were abstracted for specific questions.

For echocardiography question 2 on yield:

Percent with atrial fibrillation, definition of clinical cardiac disease, percent with clinical cardiac disease, carotid imaging method(s), percent with carotid stenosis, stroke subtypes, diagnostic test technology, equipment manufacturer, transducer frequency, echocardiographic views, technician/reader, description of preparation/technique, use of air contrast (yes/no), cardiac lesions sought, lesions defined (yes/no), blinding of echocardiogram reader to clinical data, and the number/percent with the following lesions: any lesion, left atrial thrombus, left ventricular thrombus, left ventricular aneurysm, spontaneous echocardiographic contrast, atrial septal aneurysm, patent foramen ovale, mitral valve prolapse, mitral annular calcification, valvular strands, aortic atheroma (plaque, debris), atrial myxoma, valvular vegetation, mitral stenosis/rheumatic heart disease.

For echocardiography question 3 on accuracy:

Diagnostic test technology used, equipment manufacturer, technician/reader, lesion sought, reference standard used, blinding of reference standard reader, presence of verification bias, inter-rater reliability measurement, and number of true positives, false positives, true negatives, and false negatives.

For echocardiography question 4 on TEE complications, carotid imaging question 2 on angiography complications, carotid imaging question 4 on CEA timing, and carotid imaging question 5 on CEA complications:

Author departmental affiliation, number of procedures, completeness of followup, ascertainment techniques, independence of ascertainment, confounders, duration of followup, definition of complications, number of strokes and deaths, denominator for strokes + deaths, number of deaths, denominator for deaths, number of other major complications, and denominator for other major complications,

For echocardiography questions 5 and 6 on anticoagulant therapy:

Stroke source, maintenance of comparable groups, length of followup, definition of intervention, definition of outcomes, outcomes, complications, and mortality.

For carotid ultrasound question 1 on operating characteristics:

Diagnostic test technology used, equipment manufacturer, technician/reader, reference standard used, method of measuring degree of stenosis, blinding of reference standard reader, presence of verification bias, inter-rater reliability measurement, prevalence of carotid stenosis (by degree), prevalence of carotid occlusion, and the number of true positives (by degree of stenosis), false positives, true negatives, and false negatives. For carotid ultrasound, we also abstracted ultrasound method (e.g., continuous wave Doppler, color flow duplex, etc.), transducer frequency, and criteria used to grade stenosis. For magnetic resonance angiography, we also abstracted imaging method (e.g., two-dimensional time-of-flight, gadolinium-enhanced, etc.) and categorization of flow voids.

## Assessment of Study Quality

For all key questions excluding those related to echocardiographic yield, complications, and cost analyses, we used the quality criteria developed by the third US Preventive Services Task Force (USPSTF).^ 46 ^ In this rating system, a study is first categorized by study design: randomized controlled trial, cohort study, case-control study, systematic review, or diagnostic accuracy study. The internal validity and applicability (external validity) of each study is rated as good, fair, or poor, based on specific criteria for that type of study design. After consideration of the quality of each individual study, the overall body of evidence related to each key question is then rated as good, fair, or poor. Appendix E lists the internal validity criteria developed by the USPSTF.

Data on the yield of various findings from echocardiography came from case series of patients with stroke and the case subjects in case-control studies. We developed quality rating criteria based on relevant items from the criteria developed for case-control and cohort studies by the third USPSTF.^ 46 ^ These included 1) appropriate spectrum of patients; 2) explicit diagnostic criteria for defining echocardiographic lesions; 3) adequate explanation of echocardiographic methods; and 4) sample size (large > 100, moderate 50 to 99, small < 50). Studies of 100 or more subjects meeting all other criteria were rated as good. Studies meeting two to three criteria were rated as fair. Studies meeting no or one criterion were rated as poor.

For papers reporting complication rates for CEA, cerebral angiography, and TEE, we modified the USPSTF criteria as follows:

1. Non-biased selection of patients for inclusion.
2. Clear description of population and procedure under investigation.
3. Completeness of followup.
4. Specification and definition of investigated events.
5. Clear description of techniques used to identify events.
6. Non-biased and accurate ascertainment of events (independent ascertainer; validation of ascertainment technique).
7. Identification and examination of potential confounding variables and risk factors using acceptable statistical techniques.
8. Duration of followup correlated to reasonable timing for known and plausible complications.

For each of these criteria, a score of 0 was assigned if the paper did not adequately meet the criterion or if there were inadequate data to make this determination, and 1 was assigned if the paper met the criterion. For criterion 7 (statistical analysis), if the paper assessed one or two important confounders with acceptable statistical techniques but did not assess other important confounders, an intermediate value of 0.5 was assigned. An overall quality score was calculated by adding up the assigned quality ratings for all eight criteria. An overall quality of poor, fair, or good was assigned based on the quality score: <4=poor, 4 to 6=fair, and >6=good.

Supplemental analyses were performed to determine the relative influence of each of the quality ratings criteria and the overall quality score on reported complication rates (see Results).

## Synthesis of Evidence

After reviewing studies and rating their quality, we sought to synthesize the body of evidence related to each key question. For all questions, we summarized major findings from included studies within the text of the report. For most key questions, we also presented the key elements and results from each included study in evidence tables. Where appropriate, we pooled results from different studies to provide summary estimates of incidence, prevalence, diagnostic accuracy, or effect size, using meta-analytic statistical methods. These methods are outlined in detail in Appendix F. We also conducted supplemental analyses to address the impact of varying estimates of prevalence and diagnostic accuracy on the outcomes of diagnostic testing, and to assess the influence of selected study characteristics on the efficacy and complications of treatment.

## Cost-Effectiveness Methods

We applied standard methods of cost-effectiveness analysis to an economic evaluation of imaging strategies in the evaluation and management of stroke. We constructed two separate decision models in DATA 3.5.7 software (TreeAge Software, Inc.). One model analyzed various echocardiographic strategies to evaluate patients with stroke or TIA to identify a potential cardioembolic source of stroke. The other analyzed various carotid imaging strategies to evaluate patients with stroke or TIA to identify a potential carotid source of stroke. The testing procedures of interest in the echocardiography model are transesophageal echocardiography and transthoracic echocardiography; in the carotid imaging model, they are CUS, MRA, and cerebral angiography.

Both models follow a hypothetical cohort of stroke patients over time and assess three summary outcomes -- expected survival, quality of life, and treatment costs incurred. Disease progression leads to symptoms that reduce quality of life and result in changes in the type and quantity of health services used. We use quality-adjusted life years (QALYs) to reflect both length of survival and the average quality of life during a patient's remaining lifetime. A parallel analysis estimates lifetime costs of care representing the changing pattern of health care utilization. This process is repeated for each study arm, so that for each arm we estimate life expectancy, quality-adjusted survival, and lifetime cost of care. In both models, study arms represent different diagnostic testing strategies, not different treatments.

The summary measure used to compare two or more strategies is the incremental cost-effectiveness (CE) ratio, which is generated by calculating both costs and outcomes for any pair of study arms. The incremental CE ratio for any two strategies is the difference in their costs divided by the difference in health outcomes. Alternatives that are both more expensive and less effective than others are eliminated from consideration by simple dominance. Alternatives with a higher incremental cost-effectiveness ratio than the next most expensive option are eliminated by weak -- i.e., extended -- dominance.

The overarching question for both decision models is: What is the cost-effectiveness of routine vs. selective imaging procedures in new stroke patients? Below is a list of subquestions:

- Of routine, selective, and no imaging, what is the most cost-effective strategy to reduce the risk of recurrent stroke associated with modifiable risk factors potentially identifiable by imaging?
- How do cost-effectiveness estimates change with differences in clinical and demographic factors indicated by the initial stroke workup?
- How do cost-effectiveness estimates change with differences in treatment effectiveness? (For echocardiography, the treatment options are aspirin [minimal standard of care] and anticoagulation. For carotid imaging, the treatment options are CEA with and without standard medical treatment.)
- How do cost-effectiveness estimates change with differences in other uncertain model parameters? (For echocardiography, such model parameters are represented by, for example, bleeding risk from anticoagulation, or test accuracy. For carotid imaging, they are represented by, for example, surgical risk from CEA, or test accuracy.)