# Introduction

Each year, 600,000 Americans suffer a stroke, 500,000 of which are first attacks. In 1997, stroke directly accounted for about 1 of every 14.5 deaths (160,000) in the United States. Stroke was the third leading cause of death behind non-stroke-related heart disease and cancer, and was an underlying or contributing cause of 280,000 deaths. There are currently 4.4 million stroke survivors in the U.S., many of whom experience serious, long-term disability; 15 to 30 percent of stroke survivors are permanently disabled.^ 1 ^

The economic costs of stroke are also substantial -- $51.3 billion in 1999, about 16 percent of the total economic burden of all cardiovascular diseases. This includes $30.6 billion in direct health expenditures and $20.7 billion in lost productivity from morbidity and mortality. This estimate excludes the losses of quality of life experienced by the stroke patient and his or her family.^ 2 ^

The burden of stroke is not evenly distributed across the population. Although the prevalence and incidence of stroke are approximately equal for men and women, more women die of stroke than men at all ages; long-term survival is worse for men, however. Stroke is also predominantly a disease of the elderly -- in any year, persons 65 and over suffer 72 percent of all incident strokes and a similar percentage of all stroke-related deaths. African American men and women are more likely to die of stroke than are whites. The 1997 age-adjusted stroke death rates per 100,000 for white men and women were 61.5 and 57.8, respectively, compared with 88.5 and 76.1 for African American men and women.^ 1 ^ Risk factors for stroke are also unevenly distributed across the population. Non-Hispanic white women over 20, American Indians, and Alaska Natives are more likely to smoke than other groups. High cholesterol levels (above 200 mg/dL) predominate among non-Hispanic whites, African Americans, and Mexican Americans, both men and women. Although overweight and obesity are problems for both genders in most racial groups, differences are most pronounced among women 20 to 74.^ 3 ^

Preventing stroke recurrence is critical to reduce the overall burden of disease, because recurrent strokes are normally more devastating than first strokes. Most strokes (including most recurrent strokes) are ischemic in nature. Identification of a particular stroke mechanism guides clinical decisionmaking about therapy. The purpose of imaging procedures such as transthoracic echocardiography (TTE), transesophageal echocardiography (TEE), and carotid ultrasound (CUS) is to detect cardiac and carotid sources of cerebral ischemia or infarction. (A list of abbreviations for terms used frequently in the report appears in Appendix A.) However, the most (cost-)effective policies for implementing these technologies and the patient subgroups for which they provide greatest benefit are unclear. Although a 1997 cost-effectiveness analysis^ 4 ^ concluded that TEE should be performed on all new-onset stroke patients, other studies have not supported this strategy.^5, 6^ Cardiogenic embolism accounts for 15 to 30 percent of ischemic strokes; yet, many patients with such emboli also have a history of cardiac problems, such as atrial fibrillation (AF). Such problems are normally a direct indication for anticoagulation, which largely obviates the need for echocardiography. In addition, for many cardiac lesions that are potentially identifiable by echocardiography, both the rate of recurrent stroke associated with these lesions and the effectiveness of therapy in lowering the recurrent stroke rate are largely unknown. Additional questions arise about the appropriate choice of echocardiographic procedure (TEE, TTE, or a combination), as well as the use of such procedures within particular demographic subgroups such as women, the elderly, minorities, and lower-income persons. These are critical issues, in part because of the cost of these procedures and their extensive use. The number of echocardiographic studies performed on Medicare beneficiaries grew 143 percent between 1986 and 1989.^ 7 ^ One study reported that 3 million Medicare beneficiaries (10.5 percent of all such beneficiaries) underwent echocardiography (presumably TTE) in 1995. Given an average allowable charge for TTE at that time of $197, Medicare spent over $500 million on that procedure alone in 1995.^ 8 ^

Similar questions arise regarding the use of carotid imaging procedures to determine patients most likely to benefit from carotid endarterectomy (CEA). Although cerebral angiography is considered the gold standard for determining the level of carotid stenosis, it is an expensive, invasive test that is not risk-free. Some physicians have advocated greater use of non-invasive procedures such as carotid (duplex) ultrasound and magnetic resonance angiography (MRA), especially among asymptomatic patients, in whom stenosis that requires surgery can be identified only through diagnostic testing. These procedures are much less expensive but also less accurate than cerebral angiography. This introduces the possibility of inappropriate use of CEA, which carries a relatively small risk of death, but a higher and more variable risk of perioperative stroke. In fact, 1996 to 1997 endarterectomy rates among Medicare patients varied seven-fold across regions of the U.S.^ 9 ^

The U.S. National Survey of Physician Practices for the Secondary and Tertiary Prevention of Ischemic Stroke highlighted the variation in availability and use of diagnostic tests in the management of stroke.^ 10 ^ Although over 90 percent of physicians reported that CUS, TTE, computed tomography, and magnetic resonance imaging were readily available, only 68 percent reported availability of MRA. Eighty-eight percent of physicians had access to cerebral angiography. TEE was reported as available by 74 percent. The reported availability of these services varied with physician specialty and practice setting, with specialists and those practicing in metropolitan areas more likely to report availability of services. The actual use of services also varies; in one study, neurologists used echocardiography and carotid imaging tests more frequently in evaluating stroke patients than generalists did.^ 11 ^ Variation in resource utilization for the management of stroke occurs across patient groups as well. For example, it has been well documented that, despite their higher stroke risk, African American patients are less likely than white patients to obtain carotid imaging studies and CEA.^12-14^

The controversy over the appropriate use of these imaging procedures led the Therapeutic and Technology Assessment Subcommittee of the American Academy of Neurology to nominate this topic to the Agency for Healthcare Research and Quality for a formal technology assessment. This evidence report analyzes the available data on the effectiveness and cost-effectiveness of imaging strategies in the evaluation and management of new stroke patients. It is the collaborative effort of investigators at the Oregon Health & Science University and the Kaiser Permanente Center for Health Research, both in Portland, Oregon.

## Diagnostic Test Technology

### Ultrasonography

The application of ultrasound technology to medical diagnostics has evolved rapidly over the last 4 decades. Early techniques included B-mode ("brightness") ultrasound, which distinguishes structures within the body by translating reflected ultrasound waves of differing intensity into differing levels of brightness, and M-mode ("motion") ultrasound, which allows tracking of object motion (e.g., cardiac valves) across a defined distance. The incorporation of Doppler technology added the ability to characterize the direction, velocity, and turbulence of blood flow. Computer advances now allow translation of ultrasound signals into two-dimensional images, with Doppler signals translated into color patterns that can be superimposed on the image. Three-dimensional ultrasonographic imaging techniques are not yet commonly used in clinical practice.^ 15 ^

Ultrasound as used in medical diagnostics involves the transmission and reflection of sound waves at frequencies typically ranging from 2 to 10 megahertz (MHz). There is no known risk to human tissues from the ultrasonic waves themselves.^ 16 ^ Higher ultrasound frequencies are associated with finer resolution. However, at higher frequencies, ultrasound waves are less able to penetrate tissues. Thus, lower frequencies must often be used, particularly for echocardiography in adults, whose skin and soft tissues are typically thicker than those of children. Although this compromises resolution to some degree, frequencies between 2 and 5 MHz provide adequate resolution in most circumstances.

### Echocardiography

Echocardiography utilizes ultrasound technology to provide dynamic visual imaging of the cardiac chambers, valves, walls, and septa; the pericardium and pericardial space; and the thoracic aorta. Doppler techniques are particularly useful for assessing valvular function. Echocardiography has become widely used as a diagnostic tool to evaluate patients with cerebral ischemia. Specifically, echocardiography has been advocated as a method of identifying potential sources of stroke, particularly among patients whose ischemic syndrome is unexplained by cerebrovascular disease or whose clinical presentations suggest an embolic source.

Transthoracic and transesophageal echocardiography are the two most commonly used approaches to ultrasonic imaging of the heart. In TTE, the ultrasound transducer is placed on the patient's chest wall. Because the procedure is non-invasive, it is rarely if ever associated with complications. TTE typically allows excellent imaging of the right and left ventricles and the interventricular septum, owing to the proximity of these structures to the anterior chest wall. Images of the atria, interatrial septum, left atrial appendage, and aortic arch are less clear on TTE. In addition, TTE images may be inadequate for interpretation when patients cannot cooperate with the examination or when thick adipose tissue, scar, or air within hyperinflated lungs impedes the transmission of ultrasound waves to the heart.

TEE involves passing a small ultrasound transducer into the esophagus. Because the esophageal wall is thinner than the chest wall, higher frequency transducers can be used in TEE than in TTE, allowing better resolution. Moreover, imaging of posterior structures, including the atria, interatrial septum, left atrial appendage, mitral valve, and aortic arch, is superior with TEE. However, TEE offers less advantage in imaging anterior structures, including the left ventricle. Moreover, because TEE requires intubation of the esophagus and often involves conscious sedation of patients, it is associated with rare but significant complications (reviewed later in this report). TEE probes can be single-plane, biplane, or multiplane. Multiplane probes allow for visualization of multiple cross sections of the heart without probe manipulation but are typically larger than single-plane and biplane probes, making them potentially more difficult to pass into the esophagus.

With both TTE and TEE, shunting of blood from the right to left side of the heart can be visualized with the use of air contrast. Typically, a small amount of saline or gelatin is mixed with air and agitated to create small air bubbles. The agitated solution is then injected intravenously. Because the air bubbles become trapped in the pulmonary capillaries, no bubbles are seen in the left heart unless there is a communication between the right- and left-sided circulation. Contrast is most frequently used to detect an atrial septal defect or patent foramen ovale. Valsalva or other maneuvers to increase intrathoracic pressure may be used to maximize the chance of observing a right-to-left shunt. Complications of contrast echocardiography, including cerebral ischemia from air embolism, have been reported.^17, 18^

As with nearly all diagnostic uses of ultrasound, the quality of echocardiographic studies depends heavily on the experience and skill of the operator. Most TTEs in the U.S. are performed by non-physician technicians, but physicians are typically responsible for interpretation.^ 16 ^ Because the quality of echocardiography is so highly dependent on operator and interpreter skill and experience, the American College of Physicians, American Heart Association, and American College of Cardiology commissioned a task force on clinical competence in adult echocardiography, which has issued a set of standard expectations for all echocardiographic practitioners.^ 16 ^

### Carotid Ultrasound

Ultrasound has become the most commonly used modality for imaging the carotid arteries. Doppler technology has been particularly useful in this regard, allowing measurement of the degree of carotid stenosis based on changes in the spectrum and velocity of flow. Many different criteria have been developed to gauge the degree of carotid stenosis. The most frequently used are criteria based on the peak systolic velocity (PSV), end-diastolic velocity (EDV), and the ratio of velocities at the internal carotid artery vs. the common carotid artery (ICA/CCA ratio). Less commonly used is the measurement of "spectral broadening," a measure based on the observation that in stenotic arteries, the distribution, or spectrum, of different flow velocities is greater than in an artery without narrowing. While many have attempted to determine which Doppler criteria are most accurate in diagnosing carotid stenosis,^19-26^ others have observed that criteria may need to be lab-specific and updated over time, due to differences in equipment and technique.^27-30^ Over the last decade, the combination of color Doppler and B-mode ultrasound, known as color flow duplex, has become the standard method for examining carotid arteries with ultrasound.

The accuracy of ultrasound is highly dependent on skill, experience, and quality assurance. The variation in accuracy across labs can be substantial.^ 31 ^ Some centers claiming excellent accuracy have proposed selecting patients for CEA based on ultrasound alone.^19, 32-36^ One limitation of this practice is that ultrasound does not allow for imaging of the intracranial vasculature, but the importance of imaging the intracranial arteries before CEA is questionable.^ 37 ^

### Magnetic Resonance Angiography

Magnetic resonance angiography employs magnetic resonance technology to visualize flow within blood vessels. Radiofrequency pulses are applied to "saturate" the tissues in a given region, such that blood flowing into that region represents the only unsaturated substance in the field and can therefore be distinguished from surrounding structures. The most well studied application of this method is known as time-of-flight (TOF) imaging. TOF can be two-dimensional, imaging thin "slices" within the region of interest, or three-dimensional, imaging thick "slabs." These two methods are complementary and often used in conjunction. In most settings, the slices and slabs of 2D and 3D-TOF undergo computer processing to create a two-dimensional, longitudinal image of the blood vessel being studied, through a process known as maximum intensity projection.

When there is a severe stenosis, there may be a disruption in the visualization of flow using TOF MRA. When such "flow voids" occur, they usually indicate arterial occlusion if distal flow is not visualized, or tight stenosis if flow resumes distal to the flow void. Flow voids seen on MRA are typically categorized as severe stenoses but are the source of error in some cases where flow appears disrupted for other reasons, e.g., a tortuous blood vessel. Additionally, flow voids limit the quantification of precise degrees of stenosis, and thus some prognostic information may be lost. Contrast MRA involves the intravenous injection of magnetic contrast material, typically containing gadolinium. Contrast MRA eliminates the problem of flow voids.

Although MRA allows noninvasive imaging of the carotid arteries in a fashion similar to conventional angiography, it has limitations. First, although MRA can be used to image the intracranial arteries, this requires more time and is not routinely done as part of carotid imaging in all centers. Second, MRA is limited in its ability to characterize carotid artery plaques. Third, many patients cannot undergo MRA due to claustrophobia, intraocular metallic objects, cerebral aneurysm clips, or pacemakers. Finally, up to 10 percent of magnetic resonance scans are incomplete or technically inadequate due to motion artifact or signal interference from surgical clips or other metallic objects.^ 38 ^

### Conventional Angiography

Conventional cerebral or carotid angiography is considered the "gold standard" for determining carotid artery stenosis. Angiography involves the intra-arterial injection of contrast medium, with X-ray imaging. Angiography can be selective, with only the vessel of interest injected with contrast, or non-selective, with the entire aortic arch injected to provide visualization of the entire cerebral vascular tree. Angiography also allows visualization of carotid plaque ulceration, which may affect prognosis and lower the threshold for surgery.^ 39 ^ The major disadvantage of angiography compared to non-invasive imaging is the potential for complications, most notably stroke and death.

Angiography is two-dimensional and therefore may not be perfectly accurate in measuring the actual degree of stenosis in a particular artery. However, the studies that have determined the association between carotid stenosis and outcomes, including those that have demonstrated the benefits of CEA, have used angiography as the criterion for grading carotid stenosis. Thus, while angiography may not perfectly reflect actual carotid stenosis, it is angiographic measurement of stenosis, not pathological measurement of stenosis, that has been validated as a predictor of outcomes.

Digital subtraction angiography (DSA) employs digital image processing to increase imaging sensitivity to contrast and thereby reduce the amount of contrast needed. Intravenous DSA is not routinely used for carotid imaging because it does not offer improved accuracy when compared to other methods that are less costly and less invasive.^40-42^ Intra-arterial DSA is commonly used in conjunction with or as a substitute for conventional film angiography. Although there are disadvantages to DSA that may compromise its accuracy,^ 43 ^ DSA was used to measure carotid stenosis in approximately 30 percent of patients in the European Carotid Surgery Trial (ECST),^ 44 ^ which demonstrated a benefit of CEA for patients with severe angiographic stenosis. Intra-arterial DSA has therefore been validated as a tool for selecting patients who will benefit from carotid surgery.

Different methods have been used to measure the severity of carotid stenosis on angiography. The two most commonly used methods are those that were used in the two large, international trials demonstrating a benefit of CEA for patients with carotid stenosis.^44, 45^ The North American Symptomatic Carotid Endarterectomy Trial (NASCET) measured the degree of stenosis by subtracting the diameter of the carotid artery lumen at its narrowest point from the diameter of the internal carotid artery lumen distal to the area of stenosis, and dividing by the latter diameter. The ECST measured stenosis by subtracting the diameter of the carotid artery lumen at its narrowest point from the estimated external diameter of the artery at the point of stenosis and dividing by the latter. A third method uses the diameter of the proximal common carotid (CC) artery as the denominator. Because the diameters of the common carotid artery and of the internal carotid artery at the site of stenosis are typically larger than the diameter of the distal internal carotid artery, the NASCET method tends to estimate a lower degree of stenosis than the ECST and CC methods. Both the NASCET method and the ECST method, however, have been validated as predictors of outcomes with and without surgical intervention. Studies attempting to develop a formula for converting stenosis measured by one method to the other have derived both linear (ECST or CC = 0.6 x NASCET + 40 percent)^ 44 ^ and non-linear (ECST = 55.16 + 0.29 x NASCET + 0.002 x NASCET^2^) equations.^ 45 ^

## Scope and Key Questions

Our primary aim was to review, synthesize, and present evidence related to the effectiveness and cost-effectiveness of echocardiography and carotid imaging strategies in reducing the risk of recurrent stroke and death among patients presenting with new ischemic brain syndromes (i.e., stroke or transient ischemic attack [TIA]). To address this aim, we focused our review in several ways. First, we restricted our evaluation to the following diagnostic technologies: TTE, TEE, CUS, MRA, and carotid angiography. We did not examine other ultrasonographic technologies used in the management of stroke, such as transcranial Doppler. Based on input from our technical expert advisory group, we also did not evaluate other non-invasive carotid imaging techniques, such as oculoplethysmography and computed tomographic angiography, that are used less commonly than CUS and MRA. Second, we considered the impact of echocardiography and carotid imaging on recurrent stroke and death and did not assess the potential impact of these technologies on other conditions, such as coronary artery disease. Third, we restricted our evaluation to patients presenting with ischemic brain syndromes and excluded those with subarachnoid or cerebral hemorrhage of non-ischemic, non-embolic origin. Fourth, we limited our review to the management of patients presenting with stroke or TIA and did not address the use of diagnostic technologies in the primary prevention of stroke among asymptomatic persons (e.g., patients with asymptomatic carotid artery stenosis). Fifth, we evaluated echocardiography based on its ability to identify patients who would benefit from anticoagulant therapy. As recommended by our technical expert advisory group, we did not consider other therapies, such as cardiac surgery or catheter-based interventions. Sixth, we evaluated carotid imaging strategies based on their ability to identify patients who would benefit from CEA. We did not consider other interventions such as carotid angioplasty or stenting. Finally, at the urging of our expert advisory group, we addressed the impact of timing on the safety of CEA, as a way of addressing the appropriate timing of carotid imaging.

To facilitate our review, we began with a set of overarching questions that applied to both sets of testing strategies.

Do patients with stroke or TIA benefit from undergoing echocardiography (or carotid imaging)?

If so, to what degree?

Do identifiable subgroups exist that benefit more or less than others?

From these overarching questions, we generated a set of key questions that serve as links in a chain of evidence related to the effectiveness of the technologies we address in this report. We have organized this report according to these key questions.

Key questions for echocardiography were:

1. Which clinically inapparent abnormalities identified by echocardiography among patients presenting with a new ischemic brain syndrome represent risk factors for recurrent stroke?
2. What is the yield of echocardiography in detecting potential sources of cardioembolism among patients with a new ischemic brain syndrome?
3. What are the operating characteristics (sensitivities, specificities, and likelihood ratios) of transthoracic and transesophageal echocardiography in detecting potential sources of cardioembolic stroke?
4. What are the incidence and nature of complications associated with transesophageal echocardiography?
5. What is the efficacy of anticoagulant therapy in reducing the rate of recurrent stroke among patients with potential sources of cardioembolism?
6. What is the incidence of complications associated with anticoagulant therapy in patients with stroke?

Key questions for carotid imaging were:

1. What are the operating characteristics (sensitivities, specificities, and likelihood ratios) of carotid ultrasound and magnetic resonance angiography, used separately or in combination, in measuring carotid artery stenosis?
2. What is the incidence of complications associated with cerebral angiography?
3. What is the efficacy of carotid endarterectomy in reducing the rate of recurrent stroke among symptomatic patients with carotid artery stenosis?
4. What is the incidence of complications associated with carotid endarterectomy?
5. Does timing affect the safety of carotid endarterectomy?

For each area, echocardiography and carotid imaging, we conducted an economic evaluation to answer the key question: What is the cost-effectiveness of routine vs. selective imaging procedures in patients with a new ischemic brain syndrome? The following is a list of subquestions:

- Of routine, selective, and no imaging, what is the most cost-effective strategy to reduce the risk of recurrent stroke associated with modifiable risk factors potentially identifiable by imaging?
- How do cost-effectiveness estimates change with differences in clinical and demographic factors?
- How do cost-effectiveness estimates change with differences in treatment effectiveness?
- How do cost-effectiveness estimates change with differences in other uncertain model parameters?