# Appendix F. Statistical analysis report for effectiveness and cost-effectiveness of echocardiography and carotid imaging in the management of stroke

Benjamin K. S. Chan, M.S. ^*^ January 29, 2002

* Evidence-based Practice Center, Division of Medical Informatics and Outcomes Research, Oregon Health and Science University, Mail Code: BICC, 3181 SW Sam Jackson Park Road, Portland, Oregon 97201-3098, tel: 503 494 1607, fax: 503 494 4551, e-mail: chanb@ohsu.edu

## 1 Statistical methods

### 1.1 Logistic regression model

When the data was in the form of number of events (y_i_) per number of study subjects (n_i_) a logistic regression model was fit on the data. The model allowed for the estimation of odds ratios. Rates were estimated if the included studies were designed to allow for estimation.

If the length of follow-up varied between study we estimated the number of expected events over one month. Equation 1 was used to do this. [image] (1) y_i_ was rounded to the nearest integer. The units for t_i_ was months.

The logistic regression model used to fit the data was [image] This model is a random effects model where σ ^2^ is the between-study variance.

Bayesian data analysis was used to fit the models. Posterior probabilities distributions were simulated using Gibbs sampling. Bayesian data analysis produces credible intervals as opposed to confidence intervals. In this report, credible intervals (in the Bayesian context) are termed confidence intervals. A credible interval for π is an interval where 95% of the posterior probability lies between. A p-value shown in the results is the probability the parameter is greater than 0, p=Prob(β_j_ > 0). This is different from the usual p-value reported from a test of a null hypothesis, where low values indicate the null hypothesis is unlikely. Values of p close to 1 indicate β_j_ > 0 with high probability. Values of p close to 0 indicate β_j_ < 0 with high probability. In either case, there is a high probability of a difference.

Noninformative, proper priors are used in the analysis.

### 1.2 Model for receiver operating characteristic (ROC) curves

Let the true positive rate of a test be denoted by TPR and the false positive rate be denoted by FPR. The equation that describes an ROC curve has the form D = α + βS where D = logit(TPR) - logit(FPR), and S = logit(TPR) - logit(FPR), and α is the main determinant of shape. β is the determinant for symmetry about the 1:1 line.

The summary ROC meta-analysis used the following model. [image] The model is a random effects model where σ ^2^ is the between-study variance. Explanatory covariates can be added to the linear predictor η_i_.

Noninformative, proper priors are used in the analysis.

Summary ROC curves were plotted using the estimates for α and β. The relation between sensitivity and specificity is given in Equation 2. [image] (2) To draw the curves, 100 equally spaced points along the x-axis of FPR were taken and Equation 2 was used to calculate sensitivity (TPR).

#### Maximal accuracy

Overall accuracy is defined as

A = Sensitivity + Specificity

The point along the summary ROC curve where A is maximized was crudely found from the 100 points used for plotting. Accuracy was also examined for fixed points of sensitivity and specificity. These points were at 90%, 95%, and 99%.

## 2 Yield of echocardiography

Pooled rates for TTE and TEE are shown on Table 1. Rates and odds ratios for TTE stratified by unselected and no carotid artery diseased populations are shown on Table 2. Rates and odds ratios for TEE stratified by unselected and no carotid artery diseased populations are shown on Table 3. The results are from models described in Section 1.1.

## 3 Accuracy of echocardiography

The results are from models described in Section 1.2.

Estimates for the summary ROC parameters α and β are shown on Table 4. Plotted curves are shown on Figures 1, 2, and 3.

Sensitivities and specificities corresponding to points of maximum accuracy are shown on Table 5. Accuracy data from fixed points are shown in Table 6.

Figure 1: Summary ROC curve (thick lines) for TTE for LVT and 95% confidence intervals (thin lines)

The triangles are poor quality studies. The circles are good and fair quality studies. The solid curve is for all studies including poor quality studies. The dotted curve is for only good and fair quality studies.

Figure 2: Summary ROC curve (thick lines) for TTE for LAT and 95% confidence intervals (think lines)

The triangles are poor quality studies. The circles are good and fair quality studies. The solid curve is for all studies including poor quality studies. The dotted curve is for only good and fair quality studies.

Figure 3: Summary ROC curve (thick lines) for TEE for LAT and 95% confidence intervals (thin lines)

The triangles are poor quality studies. The circles are good and fair quality studies. The solid curve is for all studies including poor quality studies. The dotted curve is for only good and fair quality studies.

Figure 4: Summary ROC curve (thick lines) for CUS and 95% confidence intervals (thin lines).

The triangle is Eliasziw (1995). The circles are all other studies. The solid curve is for all studies including Eliasziw (1995). The dotted curve is for studies excluding Eliasziw (1995).

Figure 5: Summary ROC curve (thick line) for CUS for 50% stenosis cutoff and 95% confidence intervals (thin lines).

Figure 6: Summary ROC curve (thick lines) for CUS for 70% stenosis cutoff and 95% confidence intervals (thin lines).

The triangle is Eliasziw (1995). The circles are all other studies. The solid curve is for all studies including Eliasziw (1995). The dotted curve is for studies excluding Eliasziw (1995).

Figure 7: Summary ROC curve (thick lines) for MRA and 95% confidence intervals (thin lines).

The triangles are poor quality studies. The circles are good and fair quality studies. The solid curve is for all studies including poor quality studies. The dotted curve is for only good and fair quality studies.

Figure 8: Summary ROC curve (thick line) for MRA for 50% stenosis cutoff and 95% confidence intervals (thin lines).

Figure 9: Summary ROC curve (thick line) for MRA for 70% stenosis cutoff and 95% confidence intervals (thin lines).

Figure 10: Summary ROC curve (thick lines) for CUS+MRA and 95% confidence intervals (thin lines).

The triangles are poor quality studies. The circles are good and fair quality studies. The solid curve is for all studies including poor quality studies. The dotted curve is for only good and fair quality studies.

Figure 11: Summary ROC curve (thick line) for CUS+MRA for 50% stenosis cutoff and 95% confidence intervals (thin lines).

Figure 12: Summary ROC curve (thick lines) for CUS+MRA for 70% stenosis cutoff and 95% confidence intervals (thin lines).

The triangles are poor quality studies. The circles are good and fair quality studies. The solid curve is for all studies including poor quality studies. The dotted curve is for only good and fair quality studies.

## 4 Complications of transesophageal echocardiography

Quality rating (good, fair, or poor) was examined as a potential dependent variable in the logistic regression model for transesophageal echocardiography complications. The results are from models described in Section 1.1.

Between-study variation (σ ^2^) from TEE studies is shown in Table 7. Including regression parameters for quality rating to the mortality model appeared to increase the between-study variance. But this was likely an artifact of overfitting the data. Including quality rating parameters in the complications model decreased the between-study variance by 52% (from 0.7849 to 0.3802).

Estimated event probabilities from TEE are shown in Table 8. The probability that complication rates are different between quality ratings of poor versus fair was 98.88%. However, mortality rates did not differ between quality ratings. The confidence intervals for the complication subsets (elderly and critically ill) are wide because the random effects model was estimated from only 3 studies.

## 5 Accuracy of carotid imaging

The results are from models described in Section 1.2.

Estimates for the summary ROC parameters α and β are shown on Table 9. Plotted curves are shown on Figures 1, 2, and 3.

Sensitivities and specificities corresponding to points of maximum accuracy are shown on Table 10. Accuracy data from fixed points are shown in Table 11.

## 6 Complications of cerebral angiography

Potential explanatory variables for the logistic regression model are shown on Table 13. The results are from models described in Section 1.1.

Between-study variation (σ ^2^) from cerebral angiography studies is shown in Table 14. This table shows large between-study variance for mortality and overfitting for CVA + mortality when dependent variables are included. Since only 2 of the 10 studies had deaths, no further stratification by dependent variables was done for mortality.

Estimated event probabilities from cerebral angiography are shown in Table 15. None of the dependent variables exhibited significant association with CVA + mortality.

## 7 Complications of carotid endarterectomy

Between-study variation (σ ^2^) from CEA complications is shown in Table 17. For mortality, none of the dependent variables decreases the between-subject variability. For mortality + CVA, authorship decreases between-subject variability by 20%, and quality rating decreases between-subject variability by 12%.

Estimated event probabilities from CEA complications are shown in Tables 18 and 19. For mortality, authorship showed significant differences between single surgeon studies versus multiple surgeon studies and single surgeon studies versus other studies even though the between-subject variance was not reduced. For mortality + CVA, prospective study, RCT, CEA timing, authorship, and quality rating showed high probabilities of differences. Prospective studies and RCTs had higher rates, studies of late CEAs had higher rates, single surgeon studies had low rates followed by multiple surgeon studies followed by other studies, and poor quality studies had low rates.

### 7.1 Carotid endarterectomy timing

Between-study variation (σ ^2^) from CEA timing is shown in Table 21. This table shows overfitting for mortality when dependent variables are included. Since only 2 of the 10 studies had deaths, no further stratification by dependent variables was done for mortality. The dependent variables are no effect in decreasing between-study variability for mortality + CVA in the early CEA studies. However, for the late CVA studies, authorship (surgeon vs other) and quality rating (fair vs poor) lowered between-study variability by 31% and 21%, respectively.

Estimated event probabilities from CEA timing are shown in Tables 22 and 23. Consistent with the statements in the preceding paragraph, authorship and quality rating were significantly associated with mortality + CVA events for late CEA; while none of the dependent variables examined were associated with any of the other outcomes.

One study (Whittemore, 1987) had an unusually large number of late CEAs (n = 607). With a relatively large denominator, this study may impose a significant influence on the meta-analysis results. Scaling down Whittemore's death + CVA data by a factor of 4, decreasing the number of events to y = 3 and the denominator to n = 152 did not significantly change the results. Stratifying by authorship σ ^2^ = 0.3746, p = 0.9708, π(Surgeon) = 0.01845, and π(Other) = 0.05269.

Table 1: Pooled yield rates of echocardiography using all studies, unstratified

Test | Event | π % | 95% CI
TTE | LVT LAT+LVT Myxoma | 0.19 0.2123 2.767 x 10^−7^ | 7.688 x 10^−4^, 6.209 2.532 x 10^−3^, 6.357 0.0, 0.1595
TEE | LAT LAT+LVT ASA AoAth Myxoma | 1.766 2.593 6.883 3.364 0.0 | 0.5288, 4.644 1.039, 5.406 2.405, 14.1 1.212, 6.845 --

Table 2: Pooled yield rates of TTE stratifying by studies of unselected patients and studies having patients without carotid artery disease

Event | Stratum | π % | 95% CI
LVT | Unselected Without carotid artery disease | 0.09264 0.00884 p(β > 0) = 0.734 OR: 7.903 (1.874 x 10^−4^, 81580.0) | 1.851 x 10^−4^, 57.02 1.347 x 10^−3^, 67.0
LAT+LVT | Unselected Without carotid artery disease | 0.06479 0.03386 p(β > 0) = 0.317 OR: 0.2868 (2.593 x 10^−4^, 4512.0) | 2.909 x 10^−5^, 4.993 3.092 x 10^−7^, 4.725
Myxoma | Unselected Without carotid artery disease | 6.836 x 10^−11^ 0.0 p(β > 0) = -- OR: -- | 0.0, 0.3539 --

Table 3: Pooled yield rates of TEE stratifying by studies of unselected patients and studies having patients without carotid artery disease

Event | Stratum | π % | 95% CI
LAT | Unselected Without carotid artery disease | 0.9752 4.12 | 0.1314, 3.498 0.7867, 12.38
LAT | p(β > 0) = 0.9102 OR: 4.322 (0.4805, 33.99) | | 0.1314, 3.498 0.7867, 12.38
LAT+LVT | Unselected Without carotid artery disease | 1.691 4.53 | 0.4835, 5.331 1.194, 11.3
LAT+LVT | p(β > 0) = 0.8926 OR: 2.729 (0.4021, 12.14) | | 0.4835, 5.331 1.194, 11.3
ASA | Unselected Without carotid artery disease | 9.774 4.943 | 2.488, 37.45 1.197, 14.41
ASA | p(β > 0) = 0.2044 OR: 0.5032 (0.04074, 2.625) | | 2.488, 37.45 1.197, 14.41
AoAth | Unselected Without carotid artery disease | 3.504 3.027 | 0.2584, 25.98 0.383, 10.69
AoAth | p(β > 0) = 0.4508 OR: 0.894 (0.03474, 14.15) | | 0.2584, 25.98 0.383, 10.69
Myxoma | Unselected Without carotid artery disease | 0.0 0.0 | -- --
Myxoma | p(β > 0) = -- OR: -- | | -- --

Table 4: Estimated summary ROC curve parameters for echocardiography

Test | α | 95% CI | β | 95% CI
TTE for LVT excluding poor quality studies | 2.843 3.729 | −0.3596, 6.646 −4.177, 10.52 | −0.5991 −0.08464 | −3.511, 2.881 −7.014, 5.083
TTE for LAT excluding poor quality studies | 5.909 4.983 | −1.478, 13.16 −1.157, 12.6 | 0.3641 0.1564 | −1.039, 1.794 −1.149, 1.638
TEE for LAT excluding poor quality studies | 4.525 4.007 | 1.126, 8.471 −2.559, 8.407 | −1.08 −1.284 | −2.791, 0.7045 −4.605, 1.03

Table 5: Sensitivity and specificity of echocardiography corresponding to the points of maximal accuracy on the summary ROC curves

Test | Sensitivity % | Specificity % | A _max_
TTE for LVT excluding poor quality studies | 76.5 85.3 | 95.0 88.0 | 171.5 173.3
TTE for LAT excluding poor quality studies | 97.2 93.7 | 93.6 91.2 | 190.8 184.9
TEE for LAT ^*^ excluding poor quality studies | 100.0 100.0 | 100.0 100.0 | 200.0 200.0

* Due to the shape of the summary ROC curve (specifically, because β < −1), maximal accuracy is achieved when both sensitivity and specificity are 100%.

Table 6: Sensitivity and specificity of echocardiography corresponding to fixed points of accuracy on the summary ROC curves

Test | Sensitivity % | Specificity % | A
TTE for LVT | 90 95 99 | 27.8 2.1 0.004 | 117.8 97.1 99.0
TTE for LVT | 79.8 76.5 68.0 | 90 95 99 | 169.8 171.5 167.0
TTE for LVT, excluding poor quality studies | 90 95 99 | 81.3 64.2 20.2 | 171.3 159.2 119.2
TTE for LVT, excluding poor quality studies | 83.0 72.2 39.2 | 90 95 99 | 173.0 167.2 138.2
TTE for LAT | 90 95 99 | 96.5 95.1 89.9 | 186.5 190.1 188.9
TTE for LAT | 99.0 95.1 36.2 | 90 95 99 | 189.0 190.1 135.2
TTE for LAT, excluding poor quality studies | 90 95 99 | 93.7 89.7 72.3 | 183.7 184.7 171.3
TTE for LAT, excluding poor quality studies | 94.8 86.7 40.3 | 90 95 99 | 184.8 181.7 139.3
TEE for LAT | 90 95 99 | 63.8 100.0 100.0 | 153.8 195.0 199.0
TEE for LAT | 90.6 90.8 91.3 | 90 95 99 | 180.6 185.8 190.3
TEE for LAT, excluding poor quality studies | 90 95 99 | 97.2 100.0 100.0 | 187.2 195.0 199.0
TEE for LAT, excluding poor quality studies | 88.4 89.3 91.1 | 90 95 99 | 178.4 184.3 190.1

Table 7: Between-study variation for TEE complications

Event | # studies | Dependent variables | σ ^2^
Mortality | 15 | None Quality rating | 0.7728 1.003
Complications | 15 | None Quality rating | 0.6907 0.303

Table 8: Estimated complication probabilities for TEE

Event | # studies | Dependent variable | Level | π % | 95% CI
Mortality | 15 | None | -- | 0.01355 | 3.629 x 10^−5^, 0.03901
Mortality | 15 | Quality rating | Poor Fair | 0.01126 0.006221 | 8.127 x 10^−6^, 0.07173 3.355 x 10^−8^, 0.06428
Mortality | 15 | Quality rating | Poor Fair | p(β > 0) = 0.3796
Complications | 15 | None | -- | 0.4039 | 0.1909, 0.6902
Complications | 15 | Quality rating | Poor Fair | 0.2354 0.6714 | 0.082, 0.4421 0.3045, 1.049
Complications | 15 | Quality rating | Poor Fair | p(β > 0) = 0.9774
Complications (elderly)
random fixed | 3 3 | None None | -- -- | 2.778 x 10^−4^ 0.4177 | 0, 100 0.06097, 1.375
Complications (critically ill)
random fixed | 3 3 | None None | -- -- | 7.603 x 10^−6^ 0.7789 | 0.0, 11.5 0.1168, 2.598

Table 9: Estimated summary ROC curve parameters for carotid imaging

Test | α | 95% CI | β | 95% CI
CUS excluding Eliasziw (1995) | 3.149 3.492 | 1.982, 4.481 2.408, 4.7 | −0.2539 −0.04735 | −1.251, 0.7198 −0.8304, 0.7223
MRA excluding poor quality studies | 4.744 5.144 | 3.105, 6.646 3.061, 7.676 | −0.1739 −0.3108 | −1.07, 0.6748 −2.446, 1.876
CUS+MRA excluding poor quality studies | 6.04 5.925 | 4.803, 7.37 3.782, 9.333 | −0.1974 −0.1469 | −0.8365, 0.411 −1.991, 1.466

Table 10: Sensitivity and specificity of carotid imaging corresponding to the points of maximal accuracy on the summary ROC curves

Test | Sensitivity % | Specificity % | A _max_
CUS excluding Eliasziw (1995) 50% stenosis cutoff 70% stenosis cutoff 70% stenosis cutoff excluding Eliasziw (1995) | 78.2 84.3 79.8 75.4 94.4 | 88.8 86.0 91.2 87.2 84.0 | 167.0 170.3 171.0 162.6 178.4
MRA excluding poor quality studies 50% stenosis cutoff 70% stenosis cutoff | 90.2 91.0 91.2 91.8 | 93.0 95.5 73.5 96.5 | 183.2 186.5 164.7 188.3
CUS+MRA excluding poor quality studies 50% stenosis cutoff 70% stenosis cutoff 70% stenosis cutoff excluding poor quality studies | 94.5 94.3 95.5 95.1 95.0 | 96.4 96.0 95.2 98.4 99.9 | 190.9 190.3 190.7 193.5 194.9

Table 11: Sensitivity and specificity of carotid imaging corresponding to fixed points of accuracy on the summary ROC curves

Test | Sensitivity % | Specificity % | A
CUS | 90 95 99 | 62.9 32.6 2.9 | 152.9 127.6 101.9
CUS | 76.9 68.1 44.5 | 90 95 99 | 166.9 163.1 143.5
CUS, excluding Eliasziw (1995) | 90 95 99 | 77.7 60.5 2.0 | 167.7 155.5 119.0
CUS, excluding Eliasziw (1995) | 79.2 65.8 30.0 | 90 95 99 | 169.2 160.8 129.0
MRA | 90 95 99 | 93.2 82.6 31.3 | 183.2 177.6 130.3
MRA | 92.4 87.8 69.2 | 90 95 99 | 182.4 182.8 168.2
MRA, excluding poor quality studies | 90 95 99 | 96.4 86.6 21.8 | 186.4 181.6 120.8
MRA, excluding poor quality studies | 94.1 91.5 81.9 | 90 95 99 | 184.1 186.5 180.9
CUS+MRA | 90 95 99 | 98.6 95.8 66.2 | 188.6 190.8 165.2
CUS+MRA | 97.3 95.6 87.7 | 90 95 99 | 187.3 190.6 186.7
CUS+MRA, excluding poor quality studies | 90 95 99 | 98.2 95.2 68.3 | 188.2 190.2 167.6
CUS+MRA, excluding poor quality studies | 97.2 95.1 85.2 | 90 95 99 | 187.2 190.1 184.2

Table 12: Sensitivity and specificity of carotid imaging corresponding to fixed points of accuracy on the summary ROC curves from cutoff subanalyses

Test | Sensitivity % | Specificity % | A
CUS 50% stenosis cutoff | 90 95 99 | 65.6 29.0 1.4 | 155.6 124.0 100.4
CUS 50% stenosis cutoff | 80.9 74.6 56.9 | 90 95 99 | 170.9 169.6 155.9
CUS 70% stenosis cutoff | 90 95 99 | 52.8 24.2 2.0 | 142.8 119.2 101.0
CUS 70% stenosis cutoff | 72.2 62.4 38.2 | 90 95 99 | 162.2 157.4 137.2
CUS 70% stenosis cutoff excluding Eliasziw, 1995 | 90 95 99 | 87.0 83.4 72.7 | 177.0 178.4 171.7
CUS 70% stenosis cutoff excluding Eliasziw, 1995 | 80.4 36.9 0.8 | 90 95 99 | 170.4 131.9 99.8
MRA 50% stenosis cutoff | 90 95 99 | 74.7 68.3 51.7 | 164.7 163.3 150.7
MRA 50% stenosis cutoff | 39.0 9.8 0.2 | 90 95 99 | 129.0 104.8 99.2
MRA 70% stenosis cutoff | 90 95 99 | 97.8 90.0 21.4 | 187.8 185.0 120.4
MRA 70% stenosis cutoff | 95.0 93.0 86.0 | 90 95 99 | 185.0 188.0 185.0
CUS+MRA 50% stenosis cutoff | 90 95 99 | 97.9 95.7 81.0 | 187.9 190.7 180.0
CUS+MRA 50% stenosis cutoff | 97.9 95.7 81.1 | 90 95 99 | 187.9 190.7 180.1
CUS+MRA 70% stenosis cutoff | 90 95 99 | 99.9 98.5 26.2 | 189.0 193.5 125.2
CUS+MRA 70% stenosis cutoff | 97.3 96.5 94.3 | 90 95 99 | 187.3 191.5 193.3
CUS+MRA 70% stenosis cutoff excluding poor quality studies | 90 95 99 | 100.0 99.8 0.0 | 190.0 194.8 99.0
CUS+MRA 70% stenosis cutoff excluding poor quality studies | 95.5 95.4 95.2 | 90 95 99 | 185.5 190.4 194.2

Table 13: Potential dependent variables for cerebral angiography complications

Factor | Levels
Publication year | Pre-1990 1990-present
Authorship | Radiology Surgeon Single surgeon Multiple surgeons Other
Quality rating | Good Fair Poor

Table 14: Between-study variation for cerebral angiography complications

Event | # studies | Dependent variables | σ ^2^
Mortality | 10 | None | 6.942
CVA + mortality | 10 | None Publication year Authorship Quality rating | 1.279 1.426 1.401 1.729

Table 15: Estimated complication probabilities for cerebral angiography models

Event | # studies | Dependent variable | Level | π % | 95% CI
Mortality | 10 | None | -- | 0.0194 | 4.785 x 10^−12^, 0.1183
CVA + mortality | 10 | None | -- | 1.24 | 0.4222, 2.607
CVA + mortality | 10 | Publication year | Pre-1990 1990-present | 1.121 1.787 | 0.1382, 3.608 0.2135, 5.114
CVA + mortality | 10 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.2674
CVA + mortality | 10 | Authorship | Radiology Other | 1.139 1.526 | 0.1389, 3.4 0.2994, 4.029
CVA + mortality | 10 | Authorship | Radiology Other | p(β > 0) = 0.3396
CVA + mortality | 10 | Quality rating | Good(ref) Fair Poor | 1.525 3.375 1.23 | 0.1733, 5.438 0.0884, 19.74 0.0310, 5.954
CVA + mortality | 10 | Quality rating | Good(ref) Fair Poor | p(β _Fair_ > 0) = 0.6346 p(β _Poor_ > 0) = 0.3270

Table 16: Potential dependent variables for carotid endarterectomy complications

Factor | Levels
Publication year | Pre-1990 1990-present
Authorship | Radiology Surgeon Single surgeon Multiple surgeons Other
Quality rating | Good Fair Poor
Prospective study design | Yes No
Population-based | Yes No
RCT | Yes No
CEA timing | Early Late

Table 17: Between-study variation for CEA complications

Event | # studies | Dependent variables | σ ^2^
Mortality | 42 | None Publication year Prospective study Population based RCT Early CEA Authorship Quality rating Quality rating (good/fair vs poor | 0.5295 0.5425 0.5543 0.5428 0.5667 0.5241 0.5424 0.5215 0.5046
Mortality + CVA | 46 | None Publication year Prospective study Population based RCT Early CEA Authorship Quality rating Quality rating (good/fair vs poor | 0.6536 0.6759 0.6087 0.6503 0.6154 0.6091 0.5228 0.5765 0.5613
Mortality + CVA (Rothwell studies included) | 69 | None Publication year Prospective study Authorship Independent ascentainment | 0.5474 0.5479 0.5178 0.4538 0.4644

Table 18: Estimated event probabilities for CEA complications - mortality

Event | # studies | Dependent variable | Level | π % | 95% CI
Mortality | 42 | None | -- | 1.525 | 1.178, 1.902
Mortality | 42 | Publication year | Pre-1990 1990-present | 1.553 1.495 | 1.545, 2.075 1.004, 2.16
Mortality | 42 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.5898
Mortality | 42 | Prospective study | Yes No | 1.738 1.379 | 1.194, 2.45 0.9305, 1.848
Mortality | 42 | Prospective study | Yes No | p(β > 0) = 0.8324
Mortality | 42 | Population based | Yes No | 1.892 1.482 | 0.8987, 3.428 1.109, 1.92
Mortality | 42 | Population based | Yes No | p(β > 0) = 0.7154
Mortality | 42 | RCT | Yes No | 1.835 1.463 | 0.9648, 3.181 1.076, 1.885
Mortality | 42 | RCT | Yes No | p(β > 0) = 0.7216
Mortality | 42 | CEA timing | Early Late | 1.108 1.588 | 0.5396, 1.961 1.214, 1.999
Mortality | 42 | CEA timing | Early Late | p(β > 0) = 0.1212
Mortality | 42 | Authorship | Single surgeon (ref) Multiple surgeons Other | 0.8963 1.75 1.616 | 0.3903, 1.614 1.167, 2.478 1.06, 2.291
Mortality | 42 | Authorship | Single surgeon (ref) Multiple surgeons Other | p(β _Multiple surgeons_ > 0) = 0.9636 p(β _Other_ > 0) = 0.9504
Mortality | 42 | Quality rating | Good (ref) Fair Poor | 1.632 2.13 1.124 | 0.9822, 2.505 1.366, 3.131 0.7336, 1.611
Mortality | 42 | Quality rating | Good (ref) Fair Poor | p(β _Fair_ > 0) = 0.8108 p(β _Poor_ > 0) = 0.1088
Mortality | 42 | Quality rating | Good/fair (ref) Poor | 1.857 1.147 | 1.385, 2.427 0.7809, 1.576
Mortality | 42 | Quality rating | Good/fair (ref) Poor | p(β > 0) = 0.0116

Table 19: Estimated event probabilities for CEA complications -- mortality + CVA

Event | # studies | Dependent variable | Level | π % | 95% CI
Mortality + CVA | 46 | None | -- | 5.328 | 4.248, 6.461
Mortality + CVA | 46 | Publication year | Pre-1990 1990-present | 5.479 5.044 | 4.114, 7.209 3.482, 6.928
Mortality + CVA | 46 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.6536
Mortality + CVA | 46 | Prospective study | Yes No | 7.159 4.385 | 5.347, 9.365 3.373, 5.496
Mortality + CVA | 46 | Prospective study | Yes No | p(β > 0) = 0.9958
Mortality + CVA | 46 | Population based | Yes No | 6.376 5.17 | 3.953, 9.499 4.046, 6.545
Mortality + CVA | 46 | Population based | Yes No | p(β > 0) = 0.7782
Mortality + CVA | 46 | RCT | Yes No | 9.047 4.802 | 5.629, 13.75 3.87, 5.962
Mortality + CVA | 46 | RCT | Yes No | p(β > 0) = 0.9936
Mortality + CVA | 46 | CEA timing | Early Late | 3.21 5.938 | 1.914, 5.026 4.786, 7.248
Mortality + CVA | 46 | CEA timing | Early Late | p(β > 0) = 0.0082
Mortality + CVA | 46 | Authorship | Single surgeon (ref) Multiple surgeons Other | 2.298 4.482 7.235 | 1.305, 3.932 3.325, 5.898 5.665, 9.227
Mortality + CVA | 46 | Authorship | Single surgeon (ref) Multiple surgeons Other | p(β _Multiple surgeons_ > 0) = 0.9788 p(β _Other_ > 0) = 1.0
Mortality + CVA | 46 | Quality rating | Good (ref) Fair Poor | 6.833 6.4 3.806 | 4.55, 9.522 4.485, 8.652 2.714, 5.156
Mortality + CVA | 46 | Quality rating | Good (ref) Fair Poor | p(β _Fair_ > 0) = 0.3994 p(β _Poor_ > 0) = 0.0216
Mortality + CVA | 46 | Quality rating | Good/fair (ref) Poor | 6.626 3.773 | 5.193, 8.484 2.706, 5.1
Mortality + CVA | 46 | Quality rating | Good/fair (ref) Poor | p(β > 0) = 0.0

Table 20: Estimated event probabilities for CEA complications -- mortality + CVA. Includes studies used by Rothwell

Event | # studies | Dependent variable | Level | π % | 95% CI
Mortality + CVA | 69 | None | -- | 5.024 | 4.297, 5.831
Mortality + CVA | 69 | Publication year | Pre-1990 1990-present | 4.784 5.482 | 3.884, 5.807 4.225, 6.934
Mortality + CVA | 69 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.2082
Mortality + CVA | 69 | Prospective study | Yes No | 6.969 4.482 | 5.254, 8.971 3.795, 5.325
Mortality + CVA | 69 | Prospective study | Yes No | p(β > 0) = 0.9984
Mortality + CVA | 69 | Population based | Yes No | 6.376 5.17 | 3.953, 9.499 4.046, 6.545
Mortality + CVA | 69 | Population based | Yes No | p(β > 0) = 0.7782
Mortality + CVA | 69 | Authorship | Single surgeon (ref) Multiple surgeons Other | 2.304 4.544 6.581 | 1.381, 3.405 3.76, 5.421 5.446, 7.846
Mortality + CVA | 69 | Authorship | Single surgeon (ref) Multiple surgeons Other | p(β _Multiple surgeons_ > 0) = 1.0 p(β _Other_ > 0) = 1.0
Mortality + CVA | 69 | Independent ascertainment | Yes No | 7.596 4.289 | 5.873, 9.646 3.581, 5.025
Mortality + CVA | 69 | Independent ascertainment | Yes No | p(β > 0) = 0.9994

Table 21: Between-study variation for CEA timing

Event | # studies | Dependent variables | σ ^2^
Mortality, early CEA | 8 | None Publication year Authorship Quality rating | 1.057 1.468 1.529 1.698
Mortality, late CEA | 7 | None Publication year Authorship Quality rating | 1.596 8.313 6.413 4.023
Mortality | 15* | CEA timing | 0.6545
Mortality + CVA, early CEA | 10 | None Publication year Authorship Quality rating | 1.141 1.151 1.172 1.225
Mortality + CVA, late CEA | 9 | None Publication year Authorship Quality rating Authorship, Quality rating | 0.4993 0.5184 0.3427 0.3944 0.4576
Mortality + CVA | 19* | CEA timing | 0.6545

* Number of data points; some studies contributed more than 1 data point.

Table 22: Estimated event probabilities for CEA timing -- mortality

Event | # studies | Dependent variable | Level | π % | 95% CI
Mortality, early CEA | 8 | None | -- | 0.9912 | 0.1095, 2.538
Mortality, early CEA | 8 | Publication year | Pre-1990 1990-present | 1.991 0.6812 | 0.06401, 8.866 8.472 x 10^−3^, 2.572
Mortality, early CEA | 8 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.7756
Mortality, early CEA | 8 | Authorship | Surgeon Other | 1.076 1.996 | 0.05087, 3.297 1.534 x 10^−3^, 10.76
Mortality, early CEA | 8 | Authorship | Surgeon Other | p(β > 0) = 0.3138
Mortality, early CEA | 8 | Quality rating | Fair Poor | 1.526 1.433 | 7.912 x 10^−3^, 5.951 7.858 x 10^−3^, 5.783
Mortality, early CEA | 8 | Quality rating | Fair Poor | p(β > 0) = 0.4232
Mortality, late CEA | 7 | None | -- | 0.994 | 0.05687, 2.644
Mortality, late CEA | 7 | Publication year | Pre-1990 1990-present | 0.6429 3.993 | 5.985 x 10^−15^, 2.366 7.94 x 10^−5^, 48.26
Mortality, late CEA | 7 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.1552
Mortality, late CEA | 7 | Authorship | Surgeon Other | 0.9001 5.042 | 2.384 x 10^−5^, 6.119 8.557 x 10^−14^, 68.7
Mortality, late CEA | 7 | Authorship | Surgeon Other | p(β > 0) = 0.5478
Mortality, late CEA | 7 | Quality rating | Fair Poor | 4.796 0.4281 | 1.2 x 10^−4^, 58.47 6.175 x 10^−5^, 1.981
Mortality, late CEA | 7 | Quality rating | Fair Poor | p(β > 0) = 0.7744
Mortality | 15* | CEA timing | Early Late | 0.9665 0.981 | 0.196, 2.25 0.1653, 2.094
Mortality | 15* | CEA timing | Early Late | p(β > 0) = 0.5344 OR: 1.058 (0.2393, 5.717)

* Number of data points; some studies contributed more than 1 data point.

Table 23: Estimated event probabilities for CEA timing -- mortality + CVA

Event | # studies | Dependent variable | Level | π % | 95% CI
Mortality + CVA, early CEA | 10 | None | -- | 3.754 | 1.289, 7.57
Mortality + CVA, early CEA | 10 | Publication year | Pre-1990 1990-present | 5.837 2.74 | 1.324, 14.81 0.5226, 7.263
Mortality + CVA, early CEA | 10 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.8364
Mortality + CVA, early CEA | 10 | Authorship | Surgeon Other | 3.996 4.204 | 1.188, 8.858 0.4798, 14.33
Mortality + CVA, early CEA | 10 | Authorship | Surgeon Other | p(β > 0) = 0.4376
Mortality + CVA, early CEA | 10 | Quality rating | Fair Poor | 3.303 4.684 | 0.3441, 12.01 1.383, 11.15
Mortality + CVA, early CEA | 10 | Quality rating | Fair Poor | p(β > 0) = 0.2656
Mortality + CVA, late CEA | 9 | None | -- | 2.818 | 1.45, 4.563
Mortality + CVA, late CEA | 9 | Publication year | Pre-1990 1990-present | 2.361 3.796 | 0.929, 4.647 1.325, 7.363
Mortality + CVA, late CEA | 9 | Publication year | Pre-1990 1990-present | p(β > 0) = 0.1834
Mortality + CVA, late CEA | 9 | Authorship | Surgeon Other | 1.929 5.185 | 0.7756, 3.317 2.314, 9.769
Mortality + CVA, late CEA | 9 | Authorship | Surgeon Other | p(β > 0) = 0.9788
Mortality + CVA, late CEA | 9 | Quality rating | Fair Poor | 5.297 2.028 | 1.979, 10.18 0.85, 3.633
Mortality + CVA, late CEA | 9 | Quality rating | Fair Poor | p(β > 0) = 0.9574
Mortality + CVA | 19* | CEA timing | Early Late | 3.863 2.706 | 1.785, 6.661 1.227, 4.826
Mortality + CVA | 19* | CEA timing | Early Late | p(β > 0) = 0.2076 OR: 0.702 (0.2541, 1.883)

* Number of data points; some studies contributed more than 1 data point.