# Appendix E. Criteria for Grading Individual Studies Developed by the Third US Preventive Services Task Force, 1999

## Design-Specific Criteria and Quality Category Definitions

Presented below are categories of criteria by which to judge the internal validity of systematic reviews, case-control studies, randomized trials, and cohort studies. With these are general definitions of three ratings -- "good," "fair," and "poor" -- relating to those criteria. These specifications are not meant to be rigid rules. Rather, they are intended to be general guidelines, and topic teams can make individual exceptions when those are explicitly explained and justified.

In general, a "good" study is one that meets all criteria well. A "fair" study is one that meets all but one criterion but has no known "fatal flaw." "Poor" studies have at least one fatal flaw.

## Systematic Reviews

Four categories of criteria apply to systematic reviews. They are:

1. Comprehensiveness of sources considered/search strategy used.
2. Standard appraisal of included studies.
3. Validity of conclusions.
4. Recency and relevance of the included studies.

The definitions of the three rating categories for these types of studies are as follows:

Good: Recent, relevant review that has comprehensive sources and systematic search strategies; explicit and relevant selection criteria; standard appraisal of studies; and valid conclusions.

Fair: Recent, relevant review that lacks comprehensive sources and systematic search strategies but is not clearly biased and meets the other criteria for a rating of "good."

Poor: Outdated, irrelevant, or biased review that lacks comprehensive sources and/or systematic search strategies, explicit and relevant selection criteria, and/or standard appraisal of studies or that draws invalid conclusions.

## Case-Control Studies

Six categories of criteria apply to case-control studies. They include:

1. Accurate ascertainment of cases.
2. Nonbiased selection of cases and controls with exclusion criteria applied equally to both.
3. Response rate.
4. Diagnostic testing procedures applied equally to each group.
5. Measurement of exposure accurate and applied equally to each group.
6. Appropriate attention to potential confounding variables.

The definitions of the three rating categories for these types of studies are as follows:

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Appropriate ascertainment of cases and controls and exclusion criteria applied equally to cases and controls, and without major apparent selection or diagnostic workup bias; response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic workup biases, response rates less than 50 percent, or inattention to confounding variables.

## Randomized Controlled Trials and Cohort Studies

Seven categories of criteria apply to randomized controlled trials (RCTs) and cohort studies. They include:

1. Initial assembly of comparable groups.
  a. For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  b. For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
2. Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
3. Levels of follow-up: differential loss between groups; overall loss to followup.
4. Measurements: equal, reliable, and valid, and including masking of outcome assessment.
5. Clear definition of interventions.
6. All important outcomes considered.
7. Analysis:
  a. For RCTs: intention-to-treat analysis.
  b. For cohort studies: adjustment for potential confounders.

The definitions of the three rating categories for these types of studies are as follows:

Good: Comparable groups assembled initially and maintained throughout the study; followup least 80 percent; reliable and valid measurement instruments applied equally to the groups; outcome assessment masked; interventions defined clearly; all important outcomes considered; appropriate attention to confounders in analysis; and for RCTs, intention-to-treat analysis.

Fair: Generally comparable groups assembled initially but some question remains whether some (although not major) differences occurred with followup; measurement instruments acceptable (although not the best) and generally applied equally; outcome assessment masked; some, but not all important, outcomes considered; appropriate attention to some, but not all, potential confounders; for RCTs, intention-to-treat analysis.

Poor: Groups assembled initially not close to being comparable or not maintained throughout the study; measurement instruments unreliable or invalid or not applied at all equally among groups; outcome assessment not masked; key confounders given little or no attention; for RCTs, no intention-to-treat analysis.

## Diagnostic Accuracy Studies

Seven categories of criteria apply to diagnostic accuracy studies. They include:

1. Screening test relevant, available for primary care, adequately described.
2. Study uses a credible reference standard, performed regardless of test results.
3. Reference standard interpreted independently of screening test.
4. Indeterminate results handled in a reasonable manner.
5. Spectrum of patients included in study.
6. Sample size.
7. Administration of reliable screening test.

The definitions of the three rating categories for these types of studies are as follows:

Good: Relevant, available screening test; credible reference standard; interpretation of reference standard independent of interpretation of screening test; reliability of test assessed; few indeterminate results, or indeterminate results handled in a reasonable manner; large sample size (more than 100 subjects) and a broad spectrum of patients with and without disease.

Fair: Relevant, available screening test; reasonable although not best reference standard; interpretation of reference standard independent of interpretation of screening test; moderate sample size (50 to 100 subjects) and a "medium" spectrum of patients.

Poor: Inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow spectrum of patients.