# Appendix D. Search results^*^ * Carotid imaging question 3 was answered using published systematic reviews and did not have comprehensive database searches.

[image]