# Appendix C. Search Strategies

## Key to Symbols and Abbreviations

exp = exploded subject heading or MeSH term

.fs = floating subheading

.gw = group name

.kw = keyword

.me = subject heading or MeSH term

.mp = word in title, abstract, registry number word, or subject heading

.pt = publication type

.ti = title word

/ (after a word) = subject heading or MeSH term

$ (as a suffix) = truncation

* (as a suffix) = truncation

* (as a prefix) = major focus subject heading or MeSH term

Note: When possible, MEDLINE citations were excluded when searching HealthSTAR and the Cochrane Controlled Trials Register.

## Carotid Endarterectomy Complications

### Database(s): MEDLINE

1 endarterectomy/ae, mo [adverse effects, mortality]
2 1 and carotid.mp. [mp=title, abstract, registry number word, mesh subject heading]
3 endarterectomy, carotid/ae, mo [adverse effects, mortality]
4 *intraoperative complications/ or *postoperative complications/
5 *endarterectomy/ or *endarterectomy, carotid/
6 4 and 5
7 6 and carotid.mp. [mp=title, abstract, registry number word, mesh subject heading]
8 (endarterectom$ and complicat$).ti. and carotid.mp.
9 2 or 3 or 7 or 8
10 9 not case report/
11 10 not editorial.pt.
12 limit 11 to (human and english language)

## Carotid Endarterectomy

### Database(s): HealthSTAR

1 endarterectomy/ or endarterectomy, carotid/
2 1 and carotid.mp. [mp=title, title continuation, abstract, keywords, mesh subject heading]
3 limit 2 to nonmedline

## Carotid Endarterectomy

### Database(s): Cochrane Controlled Trials Register, Database of Abstracts of Reviews of Effectiveness, Health Technology Assessment

1 endarterectomy
2 carotid
3 1 and 2

## Carotid Endarterectomy Economics

### Database(s): MEDLINE, HealthSTAR

1 endarterectomy/
2 1 and carotid.mp. [mp=title, abstract, registry number word, mesh subject heading]
3 endarterectomy, carotid/
4 2 or 3
5 exp "Costs and Cost Analysis/
6 exp Quality of Life/
7 life expectancy/
8 exp mortality/
9 ec.fs.
10 economic$.mp.
11 cost.mp.
12 costs.mp.
13 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14 4 and 13
15 limit 14 to (human and english language)
16 15 not editorial.pt.
17 16 not case report/

## Carotid Endarterectomy Economics

### Database(s): NHS Economic Evaluation Database

1 endarterectomy

## Cerebral Angiography Complications

### Database(s): MEDLINE, HealthSTAR

1 Cerebral Angiography/ae, mo [Adverse Effects, Mortality]
2 (cerebral and angiogra$ and complicat$).ti.
3 1 or 2
4 3 not editorial.pt.
5 4 not case report/
6 5 and exp child/
7 5 and exp child/ and exp adult/
8 6 not 7
9 5 not 8
10 limit 9 to (human and English language)

## Cerebral Angiography

### Database(s): Database of Abstracts of Reviews of Effectiveness, Cochrane Controlled Trials Register, Health Technology Assessment

1 cerebral
2 angiogra*
3 1 and 2

## Echocardiography and Stroke

### Database(s): MEDLINE, HealthSTAR

1 exp echocardiography/
2 exp cerebrovascular accident/
3 cerebrovascular disorders/
4 exp "intracranial embolism and thrombosis"/
5 exp brain ischemia/
6 2 or 3 or 4 or 5
7 1 and 6
8 echocardiogra$.ti.
9 (stroke or tia or transient isch$).ti.
10 8 and 9
11 7 or 10
12 11 not case report/
13 12 not editorial.pt.
14 13 and exp child/
15 13 and exp child/ and exp adult/
16 14 not 15
17 13 not 16
18 limit 17 to (human and english language)

## Echocardiography and Stroke

### Database(s): Database of Reviews of Effectiveness, Cochrane Controlled Trials Register, Health Technology Assessment

1 cerebrovascular-disorders:me
2 stroke*
3 (#1 or #2)
4 echocardiography:me
5 echocardiogra*
6 (#4 or #5)
7 (#3 and #6)

## Echocardiography and Stroke Economics

### Database(s): MEDLINE, HealthSTAR

1 exp echocardiography/
2 exp cerebrovascular accident/
3 cerebrovascular disorders/
4 exp "intracranial embolism and thrombosis"/
5 exp brain ischemia/
6 2 or 3 or 4 or 5
7 1 and 6
8 echocardiogra$.ti.
9 (stroke or tia or transient isch$).ti.
10 8 and 9
11 7 or 10
12 exp "Costs and Cost Analysis"/
13 exp Quality of Life/
14 Life Expectancy/
15 exp Mortality/
16 ec.fs.
17 economic$.mp.
18 cost.mp.
19 costs.mp.
20 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21 11 and 20
22 (echocardiogra$ and stroke).mp. and 20
23 21 or 22
24 limit 23 to english language

## Echocardiography and Stroke Economics

### Database(s): NHS Economic Evaluation Database

1 echocardiography
2 stroke
3 tia
4 ischem* or ischaem*
5 cerebrovascular
6 exp cerebrovascular disorders.me
7 2 or 3 or 4 or 5 or 6
8 1 and 7

## Stroke Recurrence

### Database(s): MEDLINE, HealthSTAR

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 2 and stroke$.mp. [mp=title, abstract, registry number word, mesh subject heading]
4 1 or 3
5 Recurrence/
6 4 and 5
7 4 and recur$.ti.
8 6 or 7
9 8 not editorial.pt.
10 9 not case report/
11 10 and exp child/
12 10 and exp child/ and exp adult/
13 11 not 12
14 10 not 13
15 limit 14 to (human and english language)

## Stroke Recurrence

### Database(s): Database of Abstracts of Reviews of Effectiveness, Cochrane Controlled Trials Register

1 cerebrovascular-disorders:me
2 stroke*
3 (#1 or #2)
4 recur*
5 (#3 and #4)

## Stroke Recurrence Economics

### Database(s): MEDLINE, HealthSTAR

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 2 and stroke$.mp. [mp=title, abstract, registry number word, mesh subject heading]
4 recur$.mp.
5 (1 or 3) and 4
6 exp "Costs and Cost Analysis"/
7 exp Quality of Life/
8 Life Expectancy/
9 exp Mortality/
10 ec.fs.
11 economic$.mp.
12 cost.mp.
13 costs.mp.
14 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15 5 and 14
16 limit 15 to (human and english language)

## Stroke Recurrence Economics

### Database(s): NHS Economic Evaluation Database

1 exp cerebrovascular-disorders:me
2 stroke
3 (#1 or #2)
4 recur*
5 (#3 and #4)

## Transesophageal Echocardiography Complications

### Database(s): MEDLINE

1 Echocardiography, Transesophageal/ae, mo [Adverse Effects, Mortality]
2 exp ECHOCARDIOGRAPHY/ae, mo [Adverse Effects, Mortality]
3 (transesophageal or transoesophageal or tee or toe).mp. [mp=title, abstract, registry number word, mesh subject heading]
4 2 and 3
5 ((transesophageal or transoesophageal or tee) and complicat$).ti.
6 1 or 4 or 5
7 6 not editorial.pt.
8 7 not case report/
9 8 and exp child/
10 8 and exp child/ and exp adult/
11 9 not 10
12 8 not 11
13 limit 12 to (human and english language)

## Transesophageal Echocardiography

### Database(s): Database of Abstracts of Reviews of Effectiveness, Cochrane Controlled Trials Register

1 tee
2 transesophageal*
3 transoesophageal*
4 (#2 or #3)
5 (#4 and echo*)
6 (#1 or #5)

## Anticoagulation Drugs Group 1 & Stroke & No Atrial Fibrillation

### Database(s): MEDLINE

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 acenocoumarol/ or coumarins/ or dicumarol/ or phenindione/ or phenprocoumon/ or protein c/ or protein s/ or warfarin/
7 5 and 6
8 Atrial Fibrillation/
9 7 not 8
10 9 not case report/
11 10 not editorial.pt.
12 11 and exp child/
13 11 and exp child/ and exp adult/
14 12 not 13
15 11 not 14
16 limit 15 to (human and english language)

## Anticoagulation Drugs Group 2 & Stroke & No Atrial Fibrillation

### Database(s): MEDLINE

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 ancrod/ or dermatan sulfate/ or dextran sulfate/ or enoxaparin/ or heparin/ or heparin, low-molecular-weight/ or heparinoids/ or nadroparin/ or tedelparin/
7 5 and 6
8 Atrial Fibrillation/
9 7 not 8
10 9 not case report/
11 10 not editorial.pt.
12 11 and exp child/
13 11 and exp child/ and exp adult/
14 12 not 13
15 11 not 14
16 limit 15 to (human and english language)

## Anticoagulation Drugs Group 1 & Stroke & Atrial Fibrillation

### Database(s): MEDLINE

1 exp cerebrovascular accident/
2 cerebrovascular disorders/ (35125)
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 acenocoumarol/ or coumarins/ or dicumarol/ or phenindione/ or phenprocoumon/ or protein c/ or protein s/ or warfarin/
7 5 and 6
8 Atrial Fibrillation/
9 7 and 8
10 9 not case report/
11 10 not editorial.pt.
12 11 and exp child/
13 11 and exp child/ and exp adult/
14 limit 11 to (human and english language)

## Anticoagulation Drugs Group 2 & Stroke & Atrial Fibrillation

### Database(s): MEDLINE

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 ancrod/ or dermatan sulfate/ or dextran sulfate/ or enoxaparin/ or heparin/ or heparin, low-molecular-weight/ or heparinoids/ or nadroparin/ or tedelparin/
7 5 and 6
8 Atrial Fibrillation/
9 7 and 8
10 9 not case report/
11 10 not editorial.pt.
12 limit 11 to (human and english language)

## Anticoagulation Drugs Unspecified & Stroke & Atrial Fibrillation

### Database(s): MEDLINE

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 acenocoumarol/ or coumarins/ or dicumarol/ or phenindione/ or phenprocoumon/ or protein c/ or protein s/ or warfarin/
7 5 and 6
8 Atrial Fibrillation/
9 7 and 8
10 9 not case report/
11 10 not editorial.pt.
12 11 and exp child/
13 11 and exp child/ and exp adult/
14 limit 11 to (human and english language)
15 exp cerebrovascular accident/
16 cerebrovascular disorders/
17 exp "intracranial embolism and thrombosis"/
18 exp brain ischemia/
19 15 or 16 or 17 or 18
20 acenocoumarol/ or coumarins/ or dicumarol/ or phenindione/ or phenprocoumon/ or protein c/ or protein s/ or warfarin/
21 19 and 20
22 Atrial Fibrillation/
23 21 not 22
24 23 not case report/
25 24 not editorial.pt.
26 25 and exp child/
27 25 and exp child/ and exp adult/
28 26 not 27
29 25 not 28
30 limit 29 to (human and english language)
31 exp cerebrovascular accident/
32 cerebrovascular disorders/
33 exp "intracranial embolism and thrombosis"/
34 exp brain ischemia/
35 31 or 32 or 33 or 34
36 ancrod/ or dermatan sulfate/ or dextran sulfate/ or enoxaparin/ or heparin/ or heparin, low-molecular-weight/ or heparinoids/ or nadroparin/ or tedelparin/
37 35 and 36
38 Atrial Fibrillation/
39 37 and 38
40 39 not case report/
41 40 not editorial.pt.
42 limit 41 to (human and english language)
43 exp cerebrovascular accident/
44 cerebrovascular disorders/
45 exp "intracranial embolism and thrombosis"/
46 exp brain ischemia/
47 43 or 44 or 45 or 46
48 ancrod/ or dermatan sulfate/ or dextran sulfate/ or enoxaparin/ or heparin/ or heparin, low-molecular-weight/ or heparinoids/ or nadroparin/ or tedelparin/
49 47 and 48
50 Atrial Fibrillation/
51 49 not 50
52 51 not case report/
53 52 not editorial.pt.
54 53 and exp child/
55 53 and exp child/ and exp adult/
56 54 not 55
57 53 not 56
58 limit 57 to (human and english language)
59 14 or 30 or 42 or 58
60 Anticoagulants/
61 5 and 60
62 61 not 59
63 62 not case report/
64 63 not editorial.pt.
65 64 and exp child/
66 64 and exp child/ and exp adult/
67 65 not 66
68 64 not 67
69 limit 68 to (human and english language)
70 69 and 8

## Anticoagulation Drugs Unspecified & Stroke & No Atrial Fibrillation

### Database(s): MEDLINE

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 acenocoumarol/ or coumarins/ or dicumarol/ or phenindione/ or phenprocoumon/ or protein c/ or protein s/ or warfarin/
7 5 and 6
8 Atrial Fibrillation/
9 7 and 8
10 9 not case report/
11 10 not editorial.pt.
12 11 and exp child/
13 11 and exp child/ and exp adult/
14 limit 11 to (human and english language)
15 exp cerebrovascular accident/
16 cerebrovascular disorders/
17 exp "intracranial embolism and thrombosis"/
18 exp brain ischemia/
19 15 or 16 or 17 or 18
20 acenocoumarol/ or coumarins/ or dicumarol/ or phenindione/ or phenprocoumon/ or protein c/ or protein s/ or warfarin/
21 19 and 20
22 Atrial Fibrillation/
23 21 not 22
24 23 not case report/
25 24 not editorial.pt.
26 25 and exp child/
27 25 and exp child/ and exp adult/
28 26 not 27
29 25 not 28
30 limit 29 to (human and english language)
31 exp cerebrovascular accident/
32 cerebrovascular disorders/
33 exp "intracranial embolism and thrombosis"/
34 exp brain ischemia/
35 31 or 32 or 33 or 34
36 ancrod/ or dermatan sulfate/ or dextran sulfate/ or enoxaparin/ or heparin/ or heparin, low-molecular-weight/ or heparinoids/ or nadroparin/ or tedelparin/
37 35 and 36
38 Atrial Fibrillation/
39 37 and 38
40 39 not case report/
41 40 not editorial.pt.
42 limit 41 to (human and english language)
43 exp cerebrovascular accident/
44 cerebrovascular disorders/
45 exp "intracranial embolism and thrombosis"/
46 exp brain ischemia/
47 43 or 44 or 45 or 46
48 ancrod/ or dermatan sulfate/ or dextran sulfate/ or enoxaparin/ or heparin/ or heparin, low-molecular-weight/ or heparinoids/ or nadroparin/ or tedelparin/
49 47 and 48
50 Atrial Fibrillation/
51 49 not 50
52 51 not case report/
53 52 not editorial.pt.
54 53 and exp child/
55 53 and exp child/ and exp adult/
56 54 not 55
57 53 not 56
58 limit 57 to (human and english language)
59 14 or 30 or 42 or 58
60 Anticoagulants/
61 5 and 60
62 61 not 59
63 62 not case report/
64 63 not editorial.pt.
65 64 and exp child/
66 64 and exp child/ and exp adult/
67 65 not 66
68 64 not 67
69 limit 68 to (human and english language)
70 69 not 8

## Anticoagulation and Stroke

### Database(s): HealthSTAR

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 exp Anticoagulants/
7 5 and 6
8 limit 7 to nonmedline

## Anticoagulation and Stroke

### Database(s): Health Technology Assessment

1 exp anticoagulants.me
2 anticoag*
3 1 or 2
4 stroke
5 exp cerebrovascular disorders.me
6 4 or 5
7 3 and 6

## Anticoagulation and Stroke

### Database(s): Database of Abstracts of Reviews of Effectiveness

1 anticoagula*
2 acenocoumarol*
3 coumarin*
4 dicoumarol*
5 phenindione*
6 phenprocoumon*
7 warfarin*
8 protein-c
9 protein-s
10 protein-sancrod*
11 ancrod*
12 (dermatan and sulfate*)
13 (dextran and sulfate*)
14 enoxaparin*
15 heparin*
16 nadroparin*
17 tedelparin*
18 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17
19 stroke*
20 cerebrovascular-disorders:me
21 (transient and isch*)
22 tia
23 #19 or #20 or #21 or #22
24 (#18 and #23)

## Anticoagulation and Stroke, No Atrial Fibrillation

### Database(s): Cochrane Controlled Trials Register

1 anticoagula*
2 acenocoumarol*
3 coumarin*
4 dicoumarol*
5 phenindione
6 phenindione*
7 phenprocoumon*
8 warfarin*
9 protein c
10 protein-c
11 protein-s
12 ancrod*
13 (dermatan and sulfate*)
14 (dextran and sulfate*)
15 enoxaparin*
16 heparin*
17 nadroparin*
18 tedelparin*
19 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18
20 stroke*
21 cerebrovascular-disorders:me
22 (transient and isch*)
23 tia
24 #20 or #21 or #22 or #23
25 (#19 and #24)
26 atrial*
27 (#25 not #26)
28 (#27 and medline*)
29 (#27 not #28) = 116

## Stroke Anticoagulation Economics

### Database(s): MEDLINE, HealthSTAR

1 exp cerebrovascular accident/
2 cerebrovascular disorders/
3 exp "intracranial embolism and thrombosis"/
4 exp brain ischemia/
5 1 or 2 or 3 or 4
6 exp Anticoagulants/
7 5 and 6
8 exp "Costs and Cost Analysis"/
9 exp Quality of Life/
10 life expectancy/
11 exp mortality/
12 ec.fs.
13 economic$.mp.
14 cost.mp.
15 costs.mp.
16 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 7 and 16
18 limit 17 to (human and english language)
19 18 not editorial.pt.
20 19 not case report/

## Anticoagulation and Stroke Economics

### Database(s): NHS Economic Evaluation Database

1 exp anticoagulants.me
2 anticoag*
3 1 or 2
4 stroke
5 exp cerebrovascular disorders.me
6 4 or 5
7 3 and 6

## Diagnostic Testing for Carotid Disease, Sensitivity and Specificity

### Database(s): MEDLINE, HealthSTAR

1 Carotid Artery, Internal/ or Carotid Artery Diseases/ or Carotid Artery thrombosis/ or carotid stenosis/
2 ultrasonography/ or ultrasonography, doppler/ or ultrasonography, doppler, color/ or ultrasonography, doppler, duplex/ or ultrasonography, doppler, pulsed/
3 tomography, x-ray computed/
4 cerebral angiography/
5 magnetic resonance angiography/
6 magnetic resonance imaging/
7 1 and 2
8 1 and 3
9 1 and 4
10 1 and 5
11 1 and 6
12 Carotid Artery, Internal/ra, us
13 carotid artery diseases/ra, us
14 carotid artery thrombosis/ra, us
15 carotid stenosis/ra, us
16 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 exp "Sensitivity and Specificity"/
18 16 and 17
19 18 and exp child/
20 18 and exp child/ and exp adult/
21 19 not 20
22 18 not 21
23 22 not editorial.pt.
24 23 not case report/
25 limit 24 to (human and english language)
26 limit 25 to yr=1993-2001

## Carotid Imaging

### Database(s): Database of Abstracts of Review of Effectiveness, Cochrane Controlled Trials Register

1 exp ultrasonography:me
2 ultraso*
3 tomogra*
4 angiogra*
5 mra
6 #1 or #2 or #3 or #4 or #5
7 carotid*
8 #6 and #7

## Carotid Imaging

### Database(s): Health Technology Assessment

1 carotid
2 ultrasonogra* or ultrasound
3 angiography
4 tomography
5 mra
6 magnetic and resonance
7 2 or 3 or 4 or 5 or 6
8 1 and 7

## Carotid Imaging Economics

### Database(s): MEDLINE, HealthSTAR

1 exp "costs and cost analysis"/
2 exp quality of life/
3 life expectancy/
4 exp mortality/
5 ec.fs.
6 economic$.mp.
7 cost.mp.
8 costs.mp.
9 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10 carotid artery, internal/ or carotid artery diseases/ or carotid artery thrombosis/ or carotid stenosis/
11 ultrasonography/ or ultrasonography, doppler/ or ultrasonography, doppler, color/ or ultrasonography, doppler, duplex/ or ultrasonography, doppler, pulsed/
12 tomography, x-ray computed/
13 cerebral angiography/
14 magnetic resonance angiography/
15 magnetic resonance imaging/
16 10 and 11
17 10 and 12
18 10 and 13
19 10 and 14
20 10 and 15
21 Carotid Artery, Internal/ra, us
22 carotid artery diseases/ra, us
23 carotid artery thrombosis/ra, us
24 carotid stenosis/ra, us
25 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24
26 9 and 25
27 limit 26 to english language
28 27 not editorial.pt.
29 28 not case report/

## Carotid Imaging Economics

### Database(s): NHS Economic Evaluation Database

1 carotid
2 ultrasonogra* or ultrasound
3 angiography
4 tomography
5 mra
6 magnetic and resonance
7 2 or 3 or 4 or 5 or 6
8 1 and 7

## All topics

### Database: Cochrane Database of Systematic Reviews

1 stroke.gw.
2 (cerebrovascular accident or cerebrovascular disorders).kw.
3 stroke.ti.
4 endarterectom$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
5 transient ischaemic attack$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
6 transient ischemic attack$.mp.
7 tia.mp. [mp=title, short title, abstract, full text, keywords, caption text]
8 carotid.mp. [mp=title, short title, abstract, full text, keywords, caption text]
9 anticoagula$.ti.
10 anticoagulants.kw.
11 transesophageal.mp. [mp=title, short title, abstract, full text, keywords, caption text]
12 transoesophageal.mp. [mp=title, short title, abstract, full text, keywords, caption text]
13 cerebral angiogra$.mp. [mp=title, short title, abstract, full text, keywords, caption text]
14 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13