# Appendix B. Research Team, Technical Expert Advisory Group, and Peer Reviewers

## Research Team

- Richard T. Meenan, PhD, MPH, Principal Investigator
- InvestigatorCenter for Health ResearchKaiser Permanente NorthwestPortland, Oregon

- Mark Helfand, MD, MPH
- Director, Evidence-based Practice CenterAssociate Professor of Internal Medicine and Medical Informatics & Outcomes ResearchOregon Health & Science UniversityPortland, Oregon

- Mark C. Hornbrook, PhD
- Associate Director for Health Services ResearchCenter for Health ResearchKaiser Permanente NorthwestPortland, Oregon

- Somnath Saha, MD, MPH
- Assistant Professor of MedicineOregon Health & Science UniversityPortland, Oregon

- Roger Chou, MD
- Assistant Professor of MedicineOregon Health & Science UniversityPortland, Oregon

- Kari Swarztrauber, MD, MPH
- Assistant Professor of NeurologyOregon Health & Science UniversityPortland, Oregon

- Kathryn Pyle Krages, AMLS, MA
- Administrator, OHSU Evidence-based Practice CenterDivision of Medical Informatics & Outcomes ResearchOregon Health & Science UniversityPortland, Oregon

- Benjamin K.S. Chan, MS
- Research AssociateDivision of Medical Informatics & Outcomes ResearchOregon Health & Science UniversityPortland, Oregon

- Maureen O'Keeffe-Rosetti, MS
- Research AssociateCenter for Health ResearchKaiser Permanente NorthwestPortland, Oregon

- Marian McDonagh, PharmD
- Clinical Research PharmacistCenter for Health ResearchKaiser Permanente NorthwestPortland, Oregon

- Daphne Plaut, MLS
- Research Center LibrarianCenter for Health ResearchKaiser Permanente NorthwestPortland, OR

- Martha Swain
- Senior Technical Writer-EditorCenter for Health ResearchKaiser Permanente NorthwestPortland, Oregon

- Susan Wingenfeld
- Administrative AssistantDivision of Medical Informatics & Outcomes ResearchOregon Health & Science UniversityPortland, Oregon

- Carole Reule
- SecretaryCenter for Health ResearchKaiser Permanente NorthwestPortland, Oregon

## Technical Expert Advisory Group

- American Academy of Neurology Representative:
- Philip B. Gorelick, MD, MPH, FACPProfessor of Neurological SciencesRush Medical CollegeChicago, Illinois

- Neurologist/Stroke Center Director:
- Bruce M. Coull, MDProfessor of NeurologyUniversity of Arizona College of MedicineTucson, Arizona

- Cardiologist:
- George D. Giraud, MD, PhDPortland VA Medical CenterPortland, Oregon

- Vascular Surgeon:
- James Edwards, MDPortland VA Medical CenterPortland, Oregon

- HMO Perspective:
- Bruce W. Goldberg, MDMedical Director, CareOregonDepartment of Family MedicineOregon Health & Science UniversityPortland, Oregon

- Patient/Community Perspective:
- Alberta M. SimmonsPortland, Oregon

## Peer Reviewers

- Robert J. Adams, MD
- Presidential Distinguished Chair and Regents' Professor of NeurologyMedical College of GeorgiaAugusta, Georgia

- William Armstrong, MD, FACC
- Representing the American College of CardiologyProfessor of Internal MedicineDirector, Echocardiology LaboratoryUniversity of Michigan HospitalAnn Arbor, Michigan

- Kenneth Brummel-Smith, MD
- Representing the American Geriatric SocietyProvidence Center on AgingPortland, Oregon

- Chris Gibbons, MD, MPH
- Senior Policy FellowOffice of the AdministratorCenters for Medicare and Medicaid ServicesBaltimore, Maryland

- Larry B. Goldstein, MD
- Duke Center for Cerebrovascular DiseaseDuke University Medical CenterDurham, North Carolina

- Phillip B. Gorelick, MD, MPH, FACP
- Representing the American Academy of NeurologyProfessor of Neurologic SciencesRush Medical CollegeChicago, Illinois

- Edward Grant, MD
- Representing the American College of RadiologyProfessor of Radiological SciencesChief of UltrasoundUniversity of California, Los Angeles School of MedicineLos Angeles, California

- Robert G. Hart, MD
- Professor of Medicine and NeurologyUniversity of Texas Health Science CenterSan Antonio, Texas

- Arthur J. Labovitz, MD
- Division of CardiologySt. Louis University School of MedicineSt. Louis, Missouri

- David B. Matchar, MD
- Director, Duke Evidence-based Practice CenterDirector, Duke Center for Clinical Health Policy ResearchDuke University Medical CenterDurham, North Carolina

- Gregory P. Samsa, PhD
- Associate Director, Duke Center for Clinical Health Policy ResearchDuke University Medical CenterDurham, North Carolina

- William B. Schroedter, BS, RVT, FSVT
- Representing the Society of Vascular TechnologyTechnical DirectorQuality Vascular Imaging Inc.Venice, Florida