# Appendix A. Abbreviations

AF | atrial fibrillation
ASA | atrial septal aneurysm
CA | cerebral angiography
CCA | common carotid artery
CE | cost-effectiveness
CEA | carotid endarterectomy
CHF | congestive heart failure
CT | computed tomography
CUS | carotid ultrasound
CVA | cerebrovascular accident
CVD | cerebrovascular disease
DCM | dilated cardiomyopathy
DSA | digital subtraction angiography
ECST | European Carotid Surgery Trial
ED | emergency department
EDV | end-diastolic velocity
GI | gastrointestinal
HMO | health maintenance organization
ICA | internal carotid artery
ICH | intracranial hemorrhage
ICU | intensive care unit
IV DSA | intravenous digital subtraction angiography
LAT | left atrial thrombus
LVA | left ventricular aneurysm
LVT | left ventricular thrombus
MAC | mitral annular calcification
MI | myocardial infarction
MRA | magnetic resonance angiography
MRI | magnetic resonance imaging
MVP | mitral valve prolapse
NASCET | North American Symptomatic Carotid Endarterectomy Trial
NBTE | non-bacterial thrombotic endocarditis
PFO | patent foramen ovale
PSV | peak systolic velocity
QALY | quality-adjusted life year
RCT | randomized controlled trial
RIND | reversible ischemic neurological deficit
SEC | spontaneous echocardiographic contrast
TCD | transcranial Doppler
TEE | transesophageal echocardiography
TIA | transient ischemic attack
TOF | time-of-flight
TTE | transthoracic echocardiography
USPSTF | United States Preventive Services Task Force
VT | ventricular tachycardia