# Appendixes

Appendix A. Abbreviations

Appendix B. Research Team, Technical Expert Advisory Group, and Peer Reviewers

Appendix C. Search Strategies

Appendix D. Search results

Appendix E. Criteria for Grading Individual Studies Developed by the Third US Preventive Services Task Force, 1999

Appendix F. Statistical analysis report for effectiveness and cost-effectiveness of echocardiography and carotid imaging in the management of stroke