# Evidence Table

Glossary for Evidence Table

blkr | blocker
BP | blood pressure
epi | epinephrine
HR | heart rate
hyper, HT | hypertensive
K | Potassium
MI | myocardial infarction
norm, normal | normotensive
nPm | no premedication
nr | not reported
pats | patients
Pm | premedication
post-ex, p-ex | following extraction
post-inj, p-inj | following injection
post-proc | following procedures
pre-inj | before injection
PVC | premature ventricular contraction
Sd | standard deviation

Evidence Table 1

Evidence Table 1

| Author | Study Type | Sample Selection | Group Criteria | Sample Size | BP at Baseline | Mean Age, Range | % Male | Other Cardiac Diagnoses | % Taking HT Medication | Type of Medication | Type of Procedure | Pre-medication | Local Anesthetic | Epi. Conc. | Type of Injection | Solution Quantity | BP Record Method | HR Record Method | BP/HR Record Pattern | Other Outcomes | Quality Score | Experimental Group | Data Source | Max Change in SBP | Max Change in DBP | Max Change in HR | Statistical Summary | Change in Other Indicators
1 | Cheraskin et al., 1958^31^ | comparison of outcomes among two BP groups: high & normal | convenience sample of oral surgery patients at a dental school clinic | high: >136 / >89 normal: <140 / <90 | 66 70 | 167/105 127/76 | 49 18-74 | 26% | nr | nr | nr | max/mand extraction | seco-barbital | 2% lidocaine | 1:100,000 | block or infiltration, aspiration nr | 2-8 cc mean=4.5 | nr | nr | baseline, 2 min. (pre-inj), 5 min. post-inj., 10 min. post-inj. | none | 60 | Hyper, Epi, Pm, n=31 Hyper, Epi, nPm, n=10 Hyper, nEpi, Pm, n=15 Hyper, nEpi, nPm, 10 Norm, Epi, Pm, n=12 Norm, Epi, nPm, n=22 Norm, nEpi, Pm, n=17 Norm, nEpi, nPm. n=19 | table, no sd | 7@5-min 7@5-min 3@5min 7@5-min 2@5-min 1@10 min 5@5-min 1@5-min | -2@10 min -3@10 min 2@10 min -1@10 min -3@5-min -3@10 min 2@10 min -1@10 min | 6@10 min 7@10 min 1@10 min 1@10 min 3@5-min 4@10 min 1@10 min 2@10 min | no sig diff pre-post inj, or pre-post ext; overall change not tested, and. differences by group not tested | nr
2 | Vernale, 1960^32^ | comparison of outcomes among two BP groups: high & normal, each serves as its own control | convenience samples of oral surgery patients from cardiac clinic (high), and dental school clinic (norm) | hyper: >150 / >90 normal: nr | 20 6 | 177/103 126/76 | 47 35-69 hyper only | 60% hyper only | 5 hyper with MI | nr | nr | maxillary extraction | none | 2% lidocaine | 1:100,000 | infiltration, aspiration nr | 2 ml | auscultatory manual | 30 sec. count | baseline, .5, 1, 2, & 5 min. post-injection & post extraction | lead II EKG recorded for peri-inj. period | 60 | Hyper, Epi, n=20 Hyper, nEpi, n=20 Norm, EPI, n=6 Norm, nEPI, n=6 | table, no sd | 28 p-ex 21 p-ex 13 p-ex 12 p-ex | 5 p-ex 3 p-ex 4 p-inj 5 p-ex | 13 p-inj 5 p-ex 6 p-inj -6 p-ex | no sig diff from baseline for BP, HR for any group | PVCs inc. slightly with epi and HT; no RST complex effects
3 | Meyer, 1986^33^ | comparison of outcomes among two BP groups: high & normal (with cardiac disease), each serves as its own control | convenience sample of dental patients receiving extractions | hyper: >140 / >90 normal: nr | 36 39 | ~149/90 ~121/75 | 39 nr | nr | nr | nr | nr | extraction, arch nr | none | 2% lidocaine (results with nor-epi not abstracted) | 1:100,000 | nr, with aspiration | 4 ml | auscultatory, auto cuff and microphone | electrical monitoring | every minute, 5 min. pre-inj. to 15 min. post-ext. | side effects | 70 | Hyper, Epi, n=36 Hyper, nEpi, n=36 Norm, Epi, n=39 Norm, nEpi, n=39 | Figure, (error bars) | 12 (3) p-ex 7 (4) p-ex 1 (1) p-ex 2 (2) p-ex | 5 (3) p-inj 8 (4) p-ex -3 (2) p-ex 8 (2) p-ex | 12 (4) p-ex 8 (3) p-ex 9 (3) p-ex 6 (3) p-ex&inj | HR sig> in epi HTs for first min DBP sig< with epi for all | no side effects noted for epi and no epi.
4 | Abraham-Inpijn, et al, 1988^34^ | comparison of outcomes among three BP groups: high, moderate, & normal | unknown, from among patients admitted to hospital for extractions | hyper: >160 / >95 moderate: 140-160/90-95 normal: <140 / <90 | 7 16 15 | ~175/86 ~140/84 ~107/77 nr | 40 sd=16 | 48% | 1 with MI 2 with left axis dev, 3 with ST-T pathosis | 1 patient on blocker | nr | extraction, arch nr | none | 2% lidocaine, for 2 pats, 3% prilocaine with felypressin 0.54um/mL | 1:80,000 | nr | nr | ausculatory, manual | from EKG | 30 min, pre-inj, to 45 min post. proc, in 5 min. intervals. continuous HR | lead I EKG monitored continuously | 55 | Hyper, Epi n=9 Moderate, Epi, n=16 Norm, Epi, n=15 | table, (sd) for BP. figure for HR | 24 (20) 19 (11) 27 (20) | 20 (13) 11 (7) 16 (10) | nr separately nr separately nr separately overall sig 35 (15) | all BP and HR sig>baseline | PVCs during tx, 10 sec sinus arrest in one norm pat; no other EKG changes
5 | Meechan, 1997^3^ | description of outcomes for one high BP group | convenience sample of patients receiving minor oral surgery procedures | receiving treatment for hypertension | 6 beta blkr 8 diuretic | nr | nr | nr | nr | 100% | 6 beta blkrs 8 diuretics (non K spar) 2 with nifedipine | "minor oral surgery" | none | 2% lidocaine | 1:80,000 | block, and/or infiltration with aspiration | 4.4 ml | nr, automatic recording | nr | pre-inj., 10 min. post-inj. | plasma Potassium concentration | 35 | Hyper with beta blocker, Epi, n=6 Hyper with diuretic, Epi, n=8 | figure, (error bars) | 3 (25) 1 (3) | -3 (9) -12 (3) | -3 (7) 7 (7) | no group BP diff; HR and K sig diff; K sig diff from baseline | K conc. sig< in diuretic group (-3mmol/l)
6 | Miura et al., 2000^35^ | comparison of outcomes among two BP groups: high & normal | convenience sample of hypertensive patients with matched normotensive controls receiving extractions | Hyper: >140 / >90 normal: matched (criteria nr) | 18 18 | 149/85 119/71 | 58 25-74 sd=3 | 39% | none | 10 hyperten. Subjects on control meds | nr | extraction | none | 2% lidocaine | 1:80,000 | nr | nr | oscillometric, automatic | oscillo-metric | every 2 min. from 10 min.pre-inj. To 10 in. post-ext. | 2 channel Holter monitoring, with %HF, LF/HF calculated | 45 | Hyper, Epi, n=18 Norm, Epi, n=18 | figure, (error bars) | 13 (3) p-ex 16 (5) p-ex | 4 (2) p-ex 5 (3) p-ex | 5(1) p-ex&inj 5(2) p-ex | SBP & HT sig> baseline; no sig diff between groups | LF/HF > for HT, not] norm; %HF> for norm, not for HT.