# Bibliography

Abraham-Inpijn L, Borgmeijer-Hoelen A, Gortzak RA. Changes in blood pressure, heart rate, and electrocardiogram during dental treatment with use of local anesthesia. J Am Dent Assoc. 1988;116:531-6. [pmid: 3164019].
Absi EG, Satterthwaite J, Shepherd JP, Thomas DW. The appropriateness of referral of medically compromised dental patients to hospital. Br J Oral Maxillofac Surg. 1997;35:133-6. [pmid: 9146873].
Adriani J, Sundin R. Malignant hyperthermia in dental patients. J Am Dent Assoc. 1984;108:180-4. [pmid: 6584489].
Aellig WH, O'Neil R, Laurence DR, Verrill PJ. Cardiac effects of adrenaline and felypressin as vasoconstrictors in local anaesthesia for oral Surg under diazepam sedation. Br J Anaesth. 1970;42:174-6. [pmid: 5440531].
Agren E, Danielsson K. Conduction block analgesia in the mandible. A comparative investigation of the techniques of Fischer and Gow-Gates. Swed Dent J. 1981;5:81-9. [pmid: 6947470].
Ahlquist M, Franzen O. Pulpal ischemia in man: effects on detection threshold, A-delta neural response and sharp dental pain. Endod Dent Traumatol. 1999;15:6-16. [pmid: 10219148].
Ahlstrom U, Dahl E. The effectivity of Carbocaine and Marcaine in oral Surg. A comparative clinical examination of Carbocaine 1 percent and Marcaine 0.25 percent. Odontol Revy. 1971;22:251-6. [pmid: 4948588].
Al-Ekrish AA, Al-Suroor RM, Haidar ZM. The effect of epinephrine in local anesthetic solutions on the blood pressure of young normotensive females following dental infiltrations. Saudi Med J. 1997;18:504-506.
Alexander JP. Dysrhythmia and oral Surg. Br J Anaesth. 1971;43:773-8. [pmid: 5569132].
Alexander RE. Epinephrine is safe for heart patients. Med Times. 1971;99. passim.
Allen GD, Tolas AG. Dental anaesthesia. Lancet. 1969;2.
Anderson LD, Reagan SE. Local anesthetics and vasoconstrictors in patients with compromised cardiovascular systems. [Review] [23 refs]. Gen Dent. 1993;41:161-4. [pmid: 8330733].
Anonymous. Did anesthetic mismanagement contribute to intraoperative death? [letter]. Anesthesiology. 1984;61:791-2. [pmid: 6507941].
Anonymous. Editorial: Vasoconstrictors in local anesthetic. Aust Dent J. 1973;18:191-2. [pmid: 4518543].
Anonymous. Local anaesthetics containing vasoconstrictors. Br Med J. 1970;4:633-4. [pmid: 5488377]. [pmcid: 1820222].
Anonymous. New Zealand Committee on Adverse Drug Reactions. Eighth annual report. N Z Med J. 1973;79:309-16. [pmid: 4519120].
Argentieri R. Dental care for the hypertensive patient. [Review] [45 refs]. N Y Dent J. 1978;44:55-7.
Ash HL. Complications associated with office anesthesia. Dent Clin North Am. 1973;17:315-27. [pmid: 4511374].
Atabay K, Engin C, Cenetoglu S, Celebi C. Epidermal necrolysis from dental anesthesia. Eur J Plast Surg. 1991;14:141-143.
Atherton GJ, McCaul JA, Williams SA. Medical emergencies in general dental practice in Great Britain. Part 2: Drugs and equipment possessed by GDPs and used in the management of emergencies. Br Dent J. 1999;186:125-30. [pmid: 10101908].
Barclay JK. Unusual responses to drugs: Two case reports. N Z Dent J. 1981;77:69-70. [pmid: 6942274].
Barga JL. How to treat nosebleed. Am Fam Physician. 1973;8:66-73. [pmid: 4578466].
Becker DE. Management of immediate allergic reactions. [Review] [41 refs]. Dent Clin North Am. 1995;39:577-86. [pmid: 7556791].
Beckett HA, Gilmour AG. Resistance to local analgesia -- report of a case treated using 5% lignocaine solution [see comments]. Br Dent J. 1990;169:327-8. [pmid: 2271310].
Beers M, Berkow R; editors. The Merck Man Diagnosis and Ther. 17 ed. Whitehouse Station, NJ: Merck Research Laboratories. 1999. [pmcid: 325679].
Bennett CR. Epinephrine-impregnated retraction cord [letter]. J Am Dent Assoc. 1982;105.
Bennett CR. Jorgensen memorial lecture: Drug interactions. Anesth Prog. 1983;30:106-112. [pmid: 19598658].
Benson BW, Bomberg TJ, Hatch RA, Hoffman WJ. Tissue displacement methods in fixed prosthodontics. [Review] [47 refs]. J Prosthet Dent. 1986;55:175-81. [pmid: 3514852].
Bessette RW, Mohl ND, Bishop B. Contribution of periodontal receptors to the masseteric silent period. J Dent Res. 1974;53:1196-1203. [pmid: 4529463].
Bevan DR, Monks PS, Calne DB. Cardiovascular reactions to anaesthesia during treatment with levodopa. Anaesthesiology. 1973;28:29-31.
Binning R. The surgeon's requirements during intra-oral Surg. Br J Anaesth. 1968;40.
Birchfield J, Rosenberg PA. Role of the anesthetic solution in intrapulpal anesthesia. J Endod. 1975;1:26-7. [pmid: 1061766].
Birnbaum J. Epinephrine and local anesthetics [letter]. J Am Dent Assoc. 1982;105.
Bjorlin G, Malmborg O. Cardiac side-reactions to local anaesthetics containing adrenalin. An electrocardiographic investigation. Odontol Revy. 1968;19:401-12. [pmid: 5257053].
Blaxter PL, Britten MJ. Transient amaurosis after mandibular nerve block. Br Med J. 1967;1.
Blinder D, Manor Y, Shemesh J, Taicher S. Electrocardiographic changes in cardiac patients having dental extractions under a local anesthetic containing a vasopressor. J Oral Maxillofac Surg. 1998;56:1399-402. discussion 1402-3. [pmid: 9846537].
Boakes AJ, Laurence DR, Lovel KW, O'Neil R, Verrill PJ. Adverse reactions to local anaesthetic-vasoconstrictor preparations. A study of the cardiovascular responses to Xylestesin and Hostacain-with-Noradrenaline. Br Dent J. 1972;133:137-40. [pmid: 4507157].
Brand HS, Abraham-Inpijn L. Cardiovascular responses induced by dental treatment. [Review] [89 refs]. Eur J Oral Sci. 1996;104:245-52. [pmid: 8831058].
Branham GB, Gareis FJ, Gill WL, Samuels HS. Oral surgical management of a patient with malignant pheochromocytoma. J Oral Surg. 1974;32:54-6. [pmid: 4519137].
Brennan PA, Langdon JD. A preliminary report using oxethazaine -- a potential new dental local anaesthetic. Br J Oral Maxillofac Surg. 1990;28:26-8. [pmid: 2182107].
Britz-Mckibbin P, Kranack AR, Paprica A, Chen DD. Quantitative assay for epinephrine in dental anesthetic solutions by capillary electrophoresis. Analyst. 1998;123:1461-3. [pmid: 9830160].
Bromage PR. Letter: Death in outpatient dental practice. Deaths following local analgesia: possible pontine anaesthesia. Anaesthesiology. 1975;30:239-40.
Brown G. The influence of adrenaline, noradrenaline vasoconstrictors on the efficiency of lidocaine. J Oral Ther Pharmacol. 1968;4:398-405. [pmid: 5648156].
Brown G, Ward NL. Prilocaine and lignocaine plus adrenaline. A clinical comparison. Br Dent J. 1969;126:557-62. [pmid: 5255796].
Brown RS. Dental management of the patient with major depression [letter; comment]. Oral Surg Oral Med Oral Pathol. 1991;72.
Buchanan WT, Thayer KE. Systemic effects of epinephrine-impregnated retraction cord in fixed partial denture prosthodontics. [Review] [33 refs]. J Am Dent Assoc. 1982;104:482-4. [pmid: 7040526].
Buckley JA, Ciancio SG, McMullen JA. Efficacy of epinephrine concentration in local anesthesia during periodontal Surg. J Periodontol. 1984;55:653-7. [pmid: 6594502].
Burch GE, DePasquale NP. Arterial hypertension and the dental patient. J Am Dent Assoc. 1966;73:102-6. [pmid: 5219638].
Buzik SC. Fatal interaction? Halothane, epinephrine and tooth implant Surg. Can Pharm J. 1990;123:68-69.
Campbell JH, Huizinga PJ, Das SK, Rodriguez JP, Gobetti JP. Incidence and significance of cardiac arrhythmia in geriatric oral Surg patients. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1996;82:42-6. [pmid: 8843453].
Campbell RI, Satterfield SD, Dionne RA, Kelley DE. Post anesthetic morbidity following fentanyl, diazepam and methohexital sedation. Anesth Prog. 1980;27:45-48. [pmid: 6933874].
Campbell RL. Prevention of complications associated with intravenous sedation and general anesthesia. J Oral Maxillofac Surg. 1986;44:289-301. [pmid: 3457124].
Campbell RL, Langston WG. A comparison of cardiac rate-pressure product and pressure-rate quotient in healthy and medically compromised patients. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1995;80:145-52. [pmid: 7552876].
Campbell RL, Langston WG, Ross GA. A comparison of cardiac rate-pressure product and pressure-rate quotient with Holter monitoring in patients with hypertension and cardiovascular disease: a follow-up report. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1997;84:125-8. [pmid: 9269011].
Cannell H. Evidence for safety margins of lignocaine local anaesthetics for peri-oral use. [Review] [43 refs]. Br Dent J. 1996;181:243-9. [pmid: 8917957].
Cannell H, Beckett AH. Peri-oral injections of local anaesthetic into defined sites. Br Dent J. 1975;139:242-4. [pmid: 1057982].
Cannell H, Walters H, Beckett AH, Saunders A. Circulating levels of lignocaine after peri-oral injections. Br Dent J. 1975;138:87-93. [pmid: 1053919].
Cantin RY, Poole A, Ryan JF. Malignant hyperthermia. Oral Surg Oral Med Oral Pathol. 1986;62:389-392. [pmid: 2946013].
Cardwell JE, Cawson RA. A trial of lignocaine with I:250,000 adrenaline. Br J Oral Surg. 1969;7:7-11. [pmid: 5258910].
Cawson RA. Local anesthetic hazards [letter]. Oral Surg Oral Med Oral Pathol. 1986;61.
Cawson RA. Vasoconstrictor preference [letter]. J Am Dent Assoc. 1984;109.
Cawson RA, Curson I, Whittington DR. The hazards of dental local anaesthetics. [Review] [31 refs]. Br Dent J. 1983;154:253-8. [pmid: 6344891].
Chaney MA, Kerby R, Reader A, Beck FM, Meyers WJ, Weaver J. An evaluation of lidocaine hydrocarbonate compared with lidocaine hydrochloride for inferior alveolar nerve block. Anesth Prog. 1991;38:212-6. [pmid: 1842158].
Chapman PJ. Medical emergencies in dental practice and choice of emergency drugs and equipment: a survey of Australian dentists. Aust Dent J. 1997;42:103-8. [pmid: 9153837].
Cheatham BD, Primosch RE, Courts FJ. A survey of local anesthetic usage in pediatric patients by Florida dentists. ASDC J Dent Children. 1992;59:401-7. [pmid: 1491077].
Cheraskin E, Prasertsuntarasai T. Use of epinephrine with local anesthesia in hypertensive patients: III. Effect of epinephrine on blood pressure and pulse rate. J Am Dent Assoc. 1958;57:507-519. [pmid: 13575081].
Chernow B, Balestrieri F, Ferguson CD, Terezhalmy GT, Fletcher JR, Lake CR. Local dental anesthesia with epinephrine. Minimal effects on the sympathetic nervous system or on hemodynamic variables. Arc Intern Med. 1983;143:2141-3.
Chilton NW. Clinical evaluation of prilocaine hydrochloride 4 percent solution with and without epinephrine. J Am Dent Assoc. 1971;83:149-54. [pmid: 5281166].
Chng HS, Pitt Ford TR, McDonald F. Effects of prilocaine local anaesthetic solutions on pulpal blood flow in maxillary canines. Endod Dent Traumatol. 1996;12:89-95. [pmid: 9028203].
Chue PW. Hypertension: implications for dentistry. Dent Surv. 1975;51:25-30. [pmid: 1058808].
Ciancio SG. Drugs in dentistry. Agents for gingival retraction [published erratum appears in Dent Manage 1986 Oct;26(10):63]. Dent Manage. 1986;26:59-61. [pmid: 3525263].
Ciarlone AE. Effects of epinephrine [letter]. J Am Dent Assoc. 1982;105.
Ciarlone AE, Pashley DH. Permeability of root dentin to epinephrine released from gingival retraction cord. Oper Dent. 1992;17:106-11. [pmid: 1437692].
Cintron G, Medina R, Reyes AA, Lyman G. Cardiovascular effects and safety of dental anesthesia and dental interventions in patients with recent uncomplicated myocardial infarction. Arch Intern Med. 1986;146:2203-2204. [pmid: 3778050].
Cioffi GA, Chernow B, Glahn RP, Terezhalmy GT, Lake CR. The hemodynamic and plasma catecholamine responses to routine restorative dental care. J Am Dent Assoc. 1985;111:67-70. [pmid: 3861687].
Cohen L. The dental management of patients with medical problems. N Y State Dent J. 1975;41:470-5. [pmid: 1058401].
Costich E. A study of inferior alveolar nerve block anesthesia in humans comparing 2.0 per cent procaine with 2.0 per cent procaine plus 1:50,000 epinephrine. J Dent Res (?). 1956;35:696-703. [pmid: 13367287].
Cote CJ, Karl HW, Notterman DA, Weinberg JA, McCloskey C. Adverse sedation events in pediatrics: Analysis of medications used for sedation. Pediatrics. 2000;106:633-644. [pmid: 11015502].
Cousin GC. Facial nerve palsy following intra-oral Surg performed with local anaesthesia. J R Coll Surg Edinb. 2000;45:330-3. [pmid: 11077783].
Cowan A. Further clinical evaluation of prilocaine (Citanest), with and without epinephrine. Oral Surg Oral Med Oral Pathol. 1968;26:304-11. [pmid: 4875791].
D'Eramo EM. Morbidity and mortality with outpatient anesthesia: the Massachusetts experience. J Oral Maxillofac Surg. 1992;50:700-4. [pmid: 1607998].
Dagher FB, Yared GM, Machtou P. An evaluation of 2% lidocaine with different concentrations of epinephrine for inferior alveolar nerve block. J Endod. 1997;23:178-80. [pmid: 9594760].
Dahl E, Lindqvist B. The effectivity of two carbocaine solutions of different concentration. A comparative, experimental, and clinical study. Odontol Revy. 1967;18:149-55. [pmid: 5229674].
Damm DD, Fantasia JE. Recurring palatal ulceration. Gen Dent. 1992;40.
Danielsson K, Evers H, Holmlund A, et al. Long-acting local anaesthetics in oral Surg. Clinical evaluation of bupivacaine and etidocaine for mandibular nerve block. Int J Oral Maxillofac Surg. 1986;15:119-126. [pmid: 3083015].
Davenport RE, Porcelli RJ, Iacono VJ, Bonura CF, Mallis GI, Baer PN. Effects of anesthetics containing epinephrine on catecholamine levels during periodontal Surg. J Periodontol. 1990;61:553-8. [pmid: 2213464].
Dionne RA, Goldstein DS, Wirdzek PR. Effects of diazepam premedication and epinephrine-containing local anesthetic on cardiovascular and plasma catecholamine responses to oral Surg. Anesth Analg. 1984;63:640-6. [pmid: 6731889].
Divinyi T, Egervary G, Fejer AG. A new method for measuring the stress effects in minor oral Surg. Int J Oral Surg. 1974;3:147-52. [pmid: 4212890].
Dixon RA, Bennett NR, Harrison MJ, et al. I.V. flunitrazepam an I.V. diazepam in conservative dentistry. A cross-over trial. Br J Anaesth. 1980;52:517-526. [pmid: 6104497].
Donovan TE, Gandara BK, Nemetz H. Review and survey of medicaments used with gingival retraction cords. [Review]. J Prosthet Dent. 1985;53:525-31. [pmid: 3889287].
Dooms-Goossens A, de Alam AG, Degreef H, Kochuyt A. Local anesthetic intolerance due to metabisulfite. Contact Dermatitis. 1989;20:124-6. [pmid: 2706960].
Doring KR. Evaluation of an alphaprodine-hydroxyzine combination as a sedative agent in the treatment of the pediatric dental patient. J Am Dent Assoc. 1985;111:567-76. [pmid: 3863855].
Edmondson HD, Roscoe B, Vickers MD. Biochemical evidence of anxiety in dental patients. Br Med J. 1972;4:7-9. [pmid: 5078436]. [pmcid: 1786121].
Edwards RW, Head TW. A clinical trial of intraligamentary anesthesia. J Dent Res. 1989;68:1210-3. [pmid: 2698894].
Eguchi S, Tomioka S, Masuno M, Kurio T, Takaishi K, Nakajo N. Statistical observations of cases of general anesthesia during a thirteen-year period in the Department of Dental Anesthesiology, Tokushima University Dental Hospital. [Japanese]. J Jpn Dent Soc Anesthesiol. 1998;26:657-664.
Eige S, Pritts EA, Palter SE, Olive DL. Anesthesia for office endoscopy. Obstetr Gynecol Clin North Am. 1999;26:99-108.
Eldirini AH. Effectiveness of epinephrine in local anesthetic solutions on the bacteremia following dental extraction. J Oral Ther Pharmacol. 1968;4:317-26. [pmid: 4384485].
Elliott GD, Stein E. Oral Surg in patients with atherosclerotic heart disease. Benign effect of epinephrine in local anesthesia. JAMA. 1974;227:1403-4. [pmid: 4406023].
Epstein S. Clinical study of prilocaine with varying concentrations of epinephrine. J Am Dent Assoc. 1969;78:85-90. [pmid: 5248313].
Esposito U, Salerno G, Luglio A, Rania M. Anaphylactic shock in dentist's office. [Italian]. Rass Int Clin Ter. 1992;72:647-652.
Evans EO. Safety in outpatient dental anaesthesia [letter]. Anaesthesiology. 1977;32.
Findler M, Mazor D, Galili D, Garfunkel A. Dental treatment in a patient with malignant pheochromocytoma and severe uncontrolled high blood pressure. Oral Surg Oral Medicie Oral Pathol. 1993;75:290-291.
Fiset L, Ramsay D, Milgrom P, Weinstein P. Effects of lidocaine with epinephrine on fear related arousal among dental phobics. Anesth Prog. 1986;33:225-9. [pmid: 3465257].
Fitzpatrick B. Endodontic Surg on posterior teeth. Aust Dent J. 1974;19:236-41. [pmid: 4532502].
Foster RT, Parasiuk BK, Collinson DM. Dental anesthesia and shoplifting: a case study. J Can Dent Assoc. 1992;58.
Frabetti L, Checchi L, Finelli K. Cardiovascular effects of local anesthesia with epinephrine in periodontal treatment. Quintessence Int. 1992;23:19-24. [pmid: 1631266].
Franklin SS, Jacobs MJ, Wong ND, L'Italien GJ, Lapuerta P. Predominance of isolated systolic hypertension among middle-aged and elderly us hypertensives : analysis based on national health and nutrition examination survey (NHANES) III. Hypertension. 2001;37:869-74. [pmid: 11244010].
Fredd SM, Abrams H, Barkmeier WW. A paradoxical reaction subsequent to the injection of local anesthesia. J Indiana Dent Assoc. 1977;56:16-7.
Friedlander AH. The dental management of the depressed patient [letter]. J Geriatr Psychiatry Neurol. 1990;3.
Fritts KW, Thayer KE, Yoder JL. The use of epinephrine impregnated retraction cords. J Acad Gen Dent. 1970;18:17-9.
Fukayama H, Ito H, Shimada M, Kubota Y, Fukunaga AF. Effects of hypotensive anesthesia on endocrine systems in oral Surg. Anesth Prog. 1989;36:175-7. [pmid: 2518754].
Fuller HD. Cyanosis of the hands following the use of alphaprodine in dental anaesthesia. Can Anaesth Soc J. 1986;33:213-215. [pmid: 3697816].
Gangarosa LP, Halik FJ. A clinical evaluation of local anaesthetic solutions containing graded epinephrine concentrations. Arc Oral Biol. 1967;12:611-21.
Gardner AF. Local anesthetics. Ann Dent. 1983;42:6-24. [pmid: 6599440].
Garfunkel AA, Kaufman E, Galili D. Intraligamentary anesthesia (transligamentary anesthesia) for health compromized patients. Gerodontics. 1985;1:62-64.
Garriott JC, Di Maio VJM. Death in the dental chair: Three drug fatalities in dental patients. J Toxicol Clin Toxicol. 1983;19:987-995.
Gazes PC. Noncardiac Surg and dentistry in cardiac patients. Primary Cardiol. 1983;9:52-75.
Gelfman SS, Dionne RA, Driscoll EJ. Prospective study of venous complications following intravenous diazepam in dental outpatients. Anesth Prog. 1981;28:126-128. [pmid: 6950674].
Giovannitti JA, Bennett CR. The effectiveness of 1.5% etidocaine HCl with epinephrine 1:200,000 and 2% lidocaine HCl with epinephrine 1:100,000 in oral Surg: a clinical comparison. J Am Dent Assoc. 1983;107:616-8. [pmid: 6355234].
Glasser SP. The problems of patients with cardiovascular disease undergoing dental treatment. J Am Dent Assoc. 1977;94:1158-62. [pmid: 405407].
Glauda NM, Henefer EP, Super S. Nonfatal anaphylaxis caused by oral penicillin: report of case. J Am Dent Assoc. 1975;90:159-61. [pmid: 1053629].
Glick M. New guidelines for prevention, detection, evaluation and treatment of high blood pressure. J Am Dent Assoc. 1998;129:1588-1594. [pmid: 9818576].
Glover J. Drug incompatibilities. Monoamine oxidase inhibitors. Br Dent J. 1967;123:315-20. [pmid: 5233493].
Go M, Kotani J, Momota Y, et al. The case of restlessness caused by flumazenil administration after intravenous sedation with diazepam. [Japanese]. J Japanese Dent Soc Anesthesiol. 1995;23:594-598.
Gogerty J, Strand H, Ogilvie A, Dille J. Vasopressor effects of topical epinephrine in certain dental procedures. Pharmacol Ther. 1957;10:614-622.
Goldman V, Evers H. Prilocaine-felypressin: a new combination for dental analgesia. Dent Pract Dent Record. 1969;19:225-31.
Goldstein DS, Dionne R, Sweet J, et al. Circulatory, plasma catecholamine, cortisol, lipid, and psychological responses to a real-life stress (third molar extractions): effects of diazepam sedation and of inclusion of epinephrine with the local anesthetic. Psychosom Med. 1982;44:259-72. [pmid: 7134364].
Golia JK, Woo R, Farole A, Seltzer JL. Nitroglycerin-controlled circulation in orthognathic Surg. J Oral Maxillofac Surg. 1985;43:342-5. [pmid: 3921675].
Gortzak RA, Abraham-Inpijn L. Pain-induced hypertensive episode in the dental office. Gen Dent. 1995;43:274-6. [pmid: 8940586].
Gostout CJ. Patient assessment and resuscitation. Gastrointestinal Endosc Clin North Am. 1999;9:175-187.
Goulet JP, Perusse R, Turcotte JY. Contraindications to vasoconstrictors in dentistry: Part III. Pharmacologic interactions [see comments]. [Review] [51 refs]. Oral Surg Oral Med Oral Pathol. 1992;74:692-7. [pmid: 1359489].
Gray RJ, Lomax AM, Rood JP. Periodontal ligament injection: with or without a vasoconstrictor?. Br Dent J. 1987;162:263-5. [pmid: 3472559].
Greengrass SR, Andrzejowski J, Ruiz K. Topical bupivacaine for pain control following simple dental extractions. Br Dent J. 1998;184:354-5. [pmid: 9599891].
Guglielmo A, Reader A, Nist R, Beck M, Weaver J. Anesthetic efficacy and heart rate effects of the supplemental intraosseous injection of 2% mepivacaine with 1:20,000 levonordefrin. Oral Surg Oral Med Oral Patho Oral Radiol Endod. 1999;87:284-93.
Hakkarainen K, Ainamo J. Influence of Xylocain adrenalin and Citanest Octapressin on sulcular fluid flow. Proc Finn Dent Soc. 1981;77:336-9. [pmid: 6461001].
Halse A. Effect on operative blood loss by adding vasoconstrictor to a local anesthetic solution. Acta Odontologica Scandinavica. 1970;28:179-85. [pmid: 5310290].
Handler LE, Albers DD. The effects of the vasoconstrictor epinephrine on the duration of pulpal anesthesia using the intraligamentary injection. J Am Dent Assoc. 1987;114:807-9. [pmid: 3475359].
Hanna MH, Heap DG, Kimberley AP. Cardiac dysrhythmia associated with general anaesthesia for oral Surg. Its prevention by the prophylactic use of an oral beta-adrenergic blocker. Anaesthesiology. 1983;38:1192-4.
Hansen PA, Tira DE, Barlow J. Current methods of finish-line exposure by practicing prosthodontists. J Prosthodont. 1999;8:163-70. [pmid: 10740498].
Harris R. Gingival retraction [editorial]. Aust Dent J. 1978;23:359-60. [pmid: 367342].
Harrison JD. Prevention of failures in making impressions and dies. Dent Clin North Am. 1979;23:13-20. [pmid: 365629].
Haskell R. Side effects of drugs in dentistry. J R Soc Health. 1987;107:161-2. [pmid: 3119837].
Hasse AL, Heng MK, Garrett NR. Blood pressure and electrocardiographic response to dental treatment with use of local anesthesia. J Am Dent Assoc. 1986;113:639-42. [pmid: 2945853].
Hatch CL, Chernow B, Terezhalmy GT, Van Ness M, Hall-Boyer K, Lake CR. Plasma catecholamine and hemodynamic responses to the placement of epinephrine-impregnated gingival retraction cord. Oral Surg Oral Med Oral Pathol. 1984;58:540-4. [pmid: 6392983].
Hecht A, App AR. Blood volume lost during gingivectomy using two different anesthetic techniques. J Periodontol. 1974;45:9-12. [pmid: 4543725].
Hellden L, Blomberg S, Woxberg B, Ohman A. A controlled trial of a long-acting local anaesthetic (Marcaine) in oral Surg for relief of post-operative pain. Sven Tandlak Tidskr. 1974;67:223-8. [pmid: 4606108].
Hempenstall PD, Campbell JP, Bajurnow AT, Reade PC, McGrath B, Harrison LC. Cardiovascular, biochemical, and hormonal responses to intravenous sedation with local analgesia versus general anesthesia in patients undergoing oral Surg. J Oral Maxillofac Surg. 1986;44:441-6. [pmid: 3009759].
Hersh EV, Hermann DG, Lamp CJ, Johnson PD, MacAfee KA. Assessing the duration of mandibular soft tissue anesthesia. J Am Dent Assoc. 1995;126:1531-6. [pmid: 7499650].
Hilley MD, Milam SB, Giescke AHJ, Giovannitti JA. Fatality associated with the combined use of halothane and gingival retraction cord. Anesthesiology. 1984;60:587-8. [pmid: 6731915].
Hinkley SA, Reader A, Beck M, Meyers WJ. An evaluation of 4% prilocaine with 1:200,000 epinephrine and 2% mepivacaine with 1:20,000 levonordefrin compared with 2% lidocaine with:100,000 epinephrine for inferior alveolar nerve block. Anesth Prog. 1991;38:84-9. [pmid: 1814249].
Hirota Y, Hori T, Kai K, Matsuura H. Effects of epinephrine and norepinephrine contained in 2% lidocaine on hemodynamics of the carotid and cerebral circulation in older and younger adults. Anesth Pain Control Dent. 1992;1:143-51. [pmid: 1422288].
Hirota Y, Sugiyama K, Joh S, Kiyomitsu Y. An echocardiographic study of patients with cardiovascular disease during dental treatment using local anesthesia. J Oral Maxillofac Surg. 1986;44:116-121. [pmid: 3456017].
Hirota Y, Sugiyama K, Niwa H, Matsuura H. Systemic management of Marfan's syndrome during dental treatment: a case report. Anesth Pain Control Dent. 1993;2:162-70. [pmid: 8142782].
Hirshom WI, Taylor RG, Sheehan JC. Arrhythmias produced by combinations of halothane and small amounts of vasopressor. Br J Oral Surg. 1964;2:131-6. [pmid: 5214254].
Hodgson TA, Shirlaw PJ, Challacombe SJ. Skin testing after anaphylactoid reactions to dental local anesthetics: A comparison with controls. Oral Surg Oral Med Oral Pathol. 1993;75:706-711. [pmid: 8515983].
Holland IS, Stassen LF. Bilateral block: is it safe and more efficient during removal of third molars? [see comments]. Br J Oral Maxillofac Surg. 1996;34:243-7. [pmid: 8818259].
Hondrum SO. Hypertensive episode in the dental office. Gen Dent. 1985;33:134-9. [pmid: 3858202].
Horowitz LG, Nersasian RR. A review of marijuana in relation to stress-response mechanisms in the dental patient. J Am Dent Assoc. 1978;96:983-6. [pmid: 209072].
Houston JB, Appleby RC, DeCounter L, Callaghan N, Funk DC. Effect of r-epinephrine-impregnated retraction cord on the cardiovascular system. J Prosthet Dent. 1970;24:373-6. [pmid: 4195839].
Hughes CL, Leach JK, Allen RE, Lambson GO. Cardiac arrhythmias during oral Surg with local anesthesia. J Am Dent Assoc. 1966;73:1095-102. [pmid: 5222590].
Hunter AR. Drugs for producing dissociative states. [Review] [80 refs]. Int Anesthesiol Clin. 1973;11:1-14. [pmid: 4578681].
Hyams SW. Oculomotor palsy following dental anesthesia. Arch Ophthalmol. 1976;94:1281-2. [pmid: 949268].
Ichinohe T, Igarashi O, Kaneko Y. The influence of propranolol on the cardiovascular effects and plasma clearance of epinephrine. Anesth Prog. 1991;38:217-20. [pmid: 1842159].
Ichinohe T, Kaneko Y, Nakakuki T, Aida H, Abe H. Systemic management of dental patients with cardiovascular disease. Anesth Prog. 1989;36:219-20. [pmid: 2535176].
Isaksson B, Persson G, Astrand P. A comparative study of Carbocaine Dental, Carbocaine Adrenalin and Citanest Exadrin. Odontologisk Tidskrift. 1966;74:181-8. [pmid: 5222018].
Jacoby J. Personal preferences in anesthesia. Surg Clin North Am. 1973;53:515-28. [pmid: 4574943].
Jage J. Circulatory effects of vasoconstrictors combined with local anesthetics. [Review] [33 refs]. Anesth Pain Control Dent. 1993;2:81-6. [pmid: 8219930].
Jakobs W. The status of dental anesthesia in Germany. Anesth Prog. 1989;36:210-212. [pmid: 2490036].
Jakobs W, Tetsch P, Brisse B. Hemodynamic and metabolic effects of beta-adrenoceptor-blockade in stress due to oral Surg in comparison with effects under nitrous oxide analgesia and local anaesthetics. A clinical experimental study. G Anest Stomatol. 1986;15:11-8.
Jastak JT, Yagiela JA. Vasoconstrictors and local anesthesia: a review and rationale for use. [Review] [75 refs]. J Am Dent Assoc. 1983;107:623-30. [pmid: 6355236].
Jensen OT, Upton LG, Hayward JR, Sweet RB. Advantages of long-acting local anesthesia using etidocaine hydrochloride. J Oral Surg. 1981;39:350-353. [pmid: 6938650].
Johnson CD, Brown RS. How cocaine abuse affects post-extraction bleeding. J Am Dent Assoc. 1993;124:60-2.
Johnson CD, Lewis VA, Faught KS, Brown RS. The relationship between chronic cocaine or alcohol use and blood pressure in black men during uncomplicated tooth extraction. J Oral Maxillofac Surg. 1998;56:323-9. [pmid: 9496844].
Jokstad A. Clinical trial of gingival retraction cords. J Prosthetic Dent. 1999;81:258-61.
Jorkjend L, Skoglund LA. Increase in volume of lignocaine/adrenaline-containing local anaesthetic solution causes increase in acute postoperative pain after gingivectomy. Br J Oral Maxillofac Surg. 2000;38:230-4. [pmid: 10864732].
Jorkjend L, Skoglund LA. Infiltrated lidocaine 2% with epinephrine 1:80,000 causes more postoperative pain than lidocaine 2% after oral soft tissue Surg. Anesth Prog. 1999;46:71-6. [pmid: 10853568].
Jowett NI, Cabot LB. Patients with cardiac disease: considerations for the dental practitioner. [Review] [30 refs]. Br Dent J. 2000;189:297-302. [pmid: 11060950].
Kabambe WM, Rood JP, Sowray JH. A comparison of plain 2 per cent lignocaine and 2 per cent lignocaine with adrenaline in local analgesia for minor oral Surg. J Dent. 1982;10:136-9. [pmid: 6955322].
Kadyrov KS. Electrocardiograms in patients suffering from hypertension in extraction of teeth under mask oxide-fluoroxene oxygenous anesthesia. [Russian]. Zdravookhranenie Tadzhikistana. 1990;3:37-39.
Kallio A, Salonen M, Forssell H, Scheinin H, Scheinin M, Tuominen J. Medetomidine premedication in dental Surg -- a double-blind cross-over study with a new alpha 2-adrenoceptor agonist. Acta Anaesthesiol Scand. 1990;34:171-5. [pmid: 1971472].
Kamekura N, Kitagawa E, Fujisawa T, Fukushima K. Effects of minor oral Surg on myocardial function. Anesth Prog. 1989;36:230-234. [pmid: 2490046].
Kaneko Y. Clinical perspectives on capnography during sedation and general anesthesia in dentistry. Anesth Prog. 1995;42:126-30. [pmid: 8934979].
Kaufman E, LeResche L, Sommers E, Dworkin SF, Truelove EL. Intraligamentary anesthesia: a double-blind comparative study. J Am Dent Assoc. 1984;108:175-8. [pmid: 6584488].
Kaufman E, Solomon V, Rozen L, Peltz R. Pulpal anesthesia efficacy of four lidocaine solutions injected with an intraligamentary syringe. Oral Surg Oral Med Oral Pathol. 1994;78:17-21. [pmid: 8078656].
Kawaai H, Tanaka K, Yamazaki S, Sugita T, Okuaki A. A study of intravenous sedation with propofol for dental treatment and oral Surg; Influences on respiration, circulation, sedation, and the recovery process. [Japanese]. J Jpn Dent Soc Anesthesiol. 1998;26:209-218.
Kellam SA, Smith JR, Scheffel SJ. Epinephrine absorption from commercial gingival retraction cords in clinical patients. J Prosthet Dent. 1992;68:761-5. [pmid: 1432796].
Kimura T, Noguchi I, Ooyama N, Takano K, Amemiya Y. Preventive effects of nitroglycerin buccal tablets to increase of blood pressure during dental treatment. [Japanese]. J Jpn Dent Soc Anesthesiol. 1998;26:389-395.
Kinney WB. Gingival retraction and epinephrine. J Hosp Dent Pract. 1968;11:7-9. [pmid: 5241022].
Kiyomitsu Y, Sugiyama K, Joh S. The effects of catecholamines added to lidocaine on cardiac function. Anesth Prog. 1989;36:198-200. [pmid: 2490032].
Knoll-Kohler E, Fortsch G. Pulpal anesthesia dependent on epinephrine dose in 2% lidocaine. A randomized controlled double-blind crossover study. Oral Surg Oral Med Oral Pathol. 1992;73:537-40. [pmid: 1518636].
Knoll-Kohler E, Frie A, Becker J, Ohlendorf D. Changes in plasma epinephrine concentration after dental infiltration anesthesia with different doses of epinephrine. J Dent Res. 1989;68:1098-101. [pmid: 2808867].
Knoll-Kohler E, Knoller M, Brandt K, Becker J. Cardiohemodynamic and serum catecholamine response to surgical removal of impacted mandibular third molars under local anesthesia: a randomized double-blind parallel group and crossover study. J Oral Maxillofac Surg. 1991;49:957-62. [pmid: 1653313].
Koks CHW. Articaine. [Dutch]. Pharmaceutisch Weekblad. 1990;125.
Kronman JH, Giunta JL. Reflex vasoconstriction following dental injections. Oral Surg Oral Med Oral Pathol. 1987;63:542-544. [pmid: 3473373].
Lambrianidis T, Rood JP, Sowray JH. Dental analgesia by jet injection. Br J Oral Surg. 1979;17:227-231.
Langdon JD. 'Reducing the discomfort of injections' [letter; comment]. Br Dent J. 1991;170.
Larsen R. Anesthesia complications in dental interventions. [German]. Deutsche Medizinische Wochenschrift. 1991;116.
Leviner E, Tzukert AA, Mosseri M, et al. Perioperative hemodynamic changes in ischemic heart disease patients undergoing dental treatment. Spec Care Dent. 1992;12:84-8.
Liebelt EL. Reducing pain during procedures. Curr Opin Pediatr. 1996;8:436-441. [pmid: 8946121].
Lilienthal B. Cardiovascular responses to intraosseous injections of prilocaine containing vasoconstrictors. Oral Surg Oral Med Oral Pathol. 1976;42:552-8. [pmid: 1068411].
Lilienthal B, Reynolds AK. Cardiovascular responses to intraosseous injections containing catecholamines. Oral Surg Oral Med Oral Pathol. 1975;40:574-83. [pmid: 1059057].
Lilienthal B, Reynolds AK, Coffin RD, Archer FE. Comparative circulatory effects of adrenaline and noradrenaline during intra-osseous dental anaesthesia. Int J Clin Pharmacol Biopharm. 1975;11:336-9. [pmid: 1158539].
Lim ZX, Geng WG. Tooth extraction in patients with heart disease. Br Dent J. 1991;170:451-2. [pmid: 1676901].
Ling KC. Peripheral facial nerve paralysis after local dental anesthesia. Oral Surg Oral Med Oral Pathol. 1985;60:23-24. [pmid: 3862008].
Lipp M, Dick W, Daublander M, Fuder H, Stanton-Hicks M. Exogenous and endogenous plasma levels of epinephrine during dental treatment under local anesthesia. Reg Anesth. 1993;18:6-12. [pmid: 8448101].
Lipp MDW. Anesthesia for oral Surg - Special demands on the anesthetists. [German]. Anasthesiol Intensivmed. 1996;37:185-189.
List G, Meinster FJ, Nery EB, Prey JH. Gingival crevicular fluid response to various solutions using the intraligamentary injection. Quintessence Int. 1988;19:559-63. [pmid: 3077685].
Lohr K, Carey T. Assessing "best evidence": issues in grading the quality of studies for systematic reviews. Jt Comm J Qual Improv. 1999;25:470-479. [pmid: 10481816].
Macalister AD. Adverse drug reactions and local anaesthesia. N Z Dent J. 1973;69:31-4. [pmid: 4522666].
Mainous EG, Boyne J. Hepatic coma after multiple dental extractions: report of case. J Oral Surg. 1974;32:682-4. [pmid: 4547627].
Majorana A, Schubert MM, Porta F, Ugazio AG, Sapelli PL. Oral complications of pediatric hematopoietic cell transplantation: Diagnosis and management. Support Care Cancer. 2000;8:353-365. [pmid: 10975684].
Malamed SF. The periodontal ligament (PDL) injection: An alternative to inferior alveolar nerve block. Oral Surg Oral Med Oral Pathol. 1982;53:117-121. [pmid: 6949113].
Malamed SF. Physical evaluation and the prevention of medical emergencies: vital signs. Anesth Pain Control Dent. 1993;2:107-13. [pmid: 8219928].
Malamed SF. The postanesthetic period. Complications. Dent Clin North Am. 1987;31:139-49. [pmid: 3468009].
Malamed SF, Gagnon S, Leblanc D. Efficacy of articaine: a new amide local anesthetic. J Am Dent Assoc. 2000;131:635-42. [pmid: 10832257].
Malden NJ, Beamish D. Bilateral inferior dental blocks [1]. Br J Oral Maxillofac Surg. 1998;36.
Mamiya H, Ichinohe T, Kaneko Y. Effects of block analgesia on attenuating intraoperative stress responses during oral Surg. Anesth Prog. 1997;44:101-5. [pmid: 9481970].
Martone CH, Nagelhout J, Wolf SM. Methohexital: A practical review for outpatient dental anesthesia. Anesth Prog. 1991;38:195-199. [pmid: 1842156].
Massalha R, Valdman S, Farkash P, Merkin L, Herishanu Y. Fatal intracerebral hemorrhage during dental treatment. Isr J Med Sci. 1996;32:774-6. [pmid: 8865836].
Mather LE, Cousins MJ. Local anaesthetics and their current clinical use. Drugs. 1979;18:185-205. [pmid: 40784].
Matsumura K, Miura K, Takata Y, et al. Changes in blood pressure and heart rate variability during dental Surg. Am J Hypertens. 1998;11:1376-80. [pmid: 9832183].
Matsuura H. The systemic management of cardiovascular risk patients in dentistry. [Review] [39 refs]. Anesth Pain Control Dent. 1993;2:49-61. [pmid: 8329905].
Maxymiw WG, Wood RE, Liu FF. Postradiation dental extractions without hyperbaric oxygen [see comments]. Oral Surg Oral Med Oral Pathol. 1991;72:270-4. [pmid: 1923410].
McCleve DE, Goldstein JC. Blindness secondary to injections in the nose, mouth, and face: Cause and prevention. Ear Nose Throat J. 1995;74:182-188. [pmid: 7729344].
McVeigh JB. General anesthetic emergencies. Dent Clin North Am. 1965:601-12.
Meecham JG, Thomson CW, Blair GS. A model for investigating the systemic effects of adrenaline in dental local anaesthetic solutions in patients under surgical stress. SAAD Digest. 1991;8:19-25. [pmid: 1925848].
Meechan JG. The effects of dental local anaesthetics on blood glucose concentration in healthy volunteers and in patients having third molar Surg. Br Dent J. 1991;170:373-6. [pmid: 2064859].
Meechan JG. Epinephrine, magnesium, and dental local anesthetic solutions. Anesth Prog. 1996;43:99-102. [pmid: 10323114].
Meechan JG. Plasma potassium changes in hypertensive patients undergoing oral Surg with local anesthetics containing epinephrine. Anesth Prog. 1997;44:106-9. [pmid: 9481971].
Meechan JG, Blair GS. The effect of two different local anaesthetic solutions on pain experience following apicectomy. Br Dent J. 1993;175:410-3. [pmid: 8274324].
Meechan JG, Gowans AJ, Welbury RR. The use of patient-controlled transcutaneous electronic nerve stimulation (TENS) to decrease the discomfort of regional anaesthesia in dentistry: a randomised controlled clinical trial. J Dent. 1998;26:417-20. [pmid: 9699431].
Meechan JG, Hobson RS, Hare JM, Rogers SN. 'Periodontal ligament anaesthesia: with or without a vasoconstrictor?' [letter]. Br Dent J. 1987;162.
Meechan JG, Jastak JT, Donaldson D. The use of epinephrine in dentistry. [Review] [91 refs]. J Can Dent Assoc. 1994;60:825-8; 831-4. [pmid: 7922803].
Meechan JG, Rawlins MD. The effects of two different dental local anesthetic solutions on plasma potassium levels during third molar Surg. Oral Surg Oral Med Oral Pathol. 1988;66:650-3. [pmid: 3205554].
Meechan JG, Rawlins MD. The effects of two different local anaesthetic solutions administered for oral Surg on plasma potassium levels in patients taking kaliuretic diuretics. Eur J Clin Pharmacol. 1992;42:155-8. [pmid: 1618246].
Meechan JG, Thomson CW, Blair GS, Rawlins MD. The biochemical and haemodynamic effects of adrenaline in lignocaine local anaesthetic solutions in patients having third molar Surg under general anaesthesia. Br J Oral Maxillofac Surg. 1991;29:263-8. [pmid: 1911676].
Meechan JG, Welbury RR. Metabolic responses to oral Surg under local anesthesia and sedation with intravenous midazolam: the effects of two different local anesthetics. Anesth Prog. 1993;39:9-12. [pmid: 8507025].
Meechan JG, Welbury RR, Rawlins MD. Kalaemotropic effect of adrenaline in local anaesthetic solutions in sedated oral Surg patients. Br J Clin Pharmacol. 1992;34.
Meiller TF, Overholser CD, Kutcher MJ, Bennett R. Blood pressure fluctuations in hypertensive patients during oral Surg. J Oral Maxillofac Surg. 1983;41:715-718. [pmid: 6579257].
Mekler-Lupolover Y, Gloor B, Bloch S, Wuthrich R. Neuroparalytic keratitis following dental anesthesia. Neuroophthalmology. 1986;6:299-301.
Mercurio JP. Emergency submental injection. J Am Dent Assoc. 1967;74:717-9. [pmid: 5226282].
Meyer FU. Haemodynamic changes under emotional stress following a minor surgical procedure under local anaesthesia. Int J Oral Maxillofac Surg. 1987;16:688-94. [pmid: 3125267].
Meyer FU. Hemodynamic changes of local dental anesthesia in normotensive and hypertensive subjects. Int J Clin Pharmacol Ther Toxicol. 1986;24:477-81. [pmid: 3781681].
Meyer R, Allen GD. Blood volume studies in oral Surg. I. Operative and postoperative blood losses in relation to vasoconstrictors. J Oral Surg. 1968;26:721-6. [pmid: 5303175].
Middlehurst R, Coulthard P. The effect of midazolam sedation on indicators for myocardial ischemia. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1999;88:400-5. [pmid: 10519745].
Milam SB. Intraoperative anesthetic complications. Dent Clin North Am. 1987;31:97-115. [pmid: 3468015].
Milam SB, Bennett CR. Physostigmine reversal of drug-induced paradoxical excitement. Int J Oral Maxillofac Surg. 1987;16:190-193. [pmid: 3110318].
Mito RS, Yagiela JA. Hypertensive response to levonordefrin in a patient receiving propranolol: report of case. J Am Dent Assoc. 1988;116:55-7. [pmid: 3278028].
Mitome M, Shirakawa T, Kikuiri T, Oguchi H. Salivary catecholamine assay for assessing anxiety in pediatric dental patients. J Clin Pediatric Dent. 1997;21:255-9.
Miura K, Matsumura K, Nakamura Y, Kurokawa H, Kajiyama M, Takata Y. Suppression of cardiac sympathetic nervous system during dental Surg in hypertensive patients. Hypertens Res. 2000;23:207-12. [pmid: 10821128].
Mochizuki M, Yokota S, Murata Y, et al. Changes in heart rate and blood pressure during dental procedures with local anesthesia. Anesth Prog. 1989;36:234-235. [pmid: 2490047].
Moore JR. The surgeon's requirements for intra-oral Surg. Br J Anaesth. 1968;40:152-4. [pmid: 5645155].
Moore KD, Reader A, Meyers WJ, Beck M, Weaver J. A comparison of the periodontal ligament injection using 2% lidocaine with 1:100,000 epinephrine and saline in human mandibular premolars. Anesth Prog. 1987;34:181-6. [pmid: 3479918].
Moore PA, Dunsky JL. Bupivacaine anesthesia. A clinical trial for endodontic therapy. Oral Surg Oral Med Oral Pathol. 1983;55:176-179. [pmid: 6340015].
Mueller WA, Drummond JN, Pribisco TA, Kaplan RF. Pulse oximetry monitoring of sedated pediatric dental patients. Anesth Prog. 1985;32:237-240. [pmid: 3868307].
Munoz RJ. The cardiovascular effects of anxiety and R-epinephrine retraction cord in routine fixed prosthodontic procedures. J Calif Dent Assoc. 1970;46:10-3. [pmid: 4913980].
Murai T, Kyoda N, Misaki T, Takada K, Sawada S, Machida T. Effects of clonidine on intravenous sedation with midazolam. Anesth Prog. 1995;42:135-8. [pmid: 8934981].
Murray C, Sasaki SS, Berg D, Yeung L. Local anesthesia and malignant hyperthermia: Review of the literature and recommendations for the dermatologic surgeon. Dermatol Surg. 1999;25:626-630. [pmid: 10491046].
Musselwhite JM, Klitzman B, Maixner W, Burkes EJJ. Laser Doppler flowmetry: a clinical test of pulpal vitality. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1997;84:411-9. [pmid: 9347507].
Muzyka BC, Glick M. The hypertensive dental patient. J Am Dent Assoc. 1997;128:1109-1120. [pmid: 9260420].
Nakai Y, Milgrom P, Mancl L, Coldwell SE, Domoto PK, Ramsay DS. Effectiveness of local anesthesia in pediatric dental practice. J Am Dent Assoc. 2000;131:1699-705. [pmid: 11143733].
Nakanishi O, Kameyama S, Yamamuro T, et al. A lower concentration of epinephrine is effective in lidocaine induced anesthesia of mucobuccal membranes. [Japanese]. J Jpn Dent Soc Anesthesiol. 1995;23:667-674.
Newcomb GM. Contraindications to the use of catecholamine vasoconstrictors in dental local analgesics. [Review] [32 refs]. N Z Dent J. 1973;69:25-30. [pmid: 4594916].
Newcomb GM, Waite IM. The effectiveness of two local analgesic preparations in reducing haemorrhage during periodontal Surg. J Dent. 1972;1:37-42. [pmid: 4541168].
Nichols C. Dentistry and hypertension. J Am Dent Assoc. 1997;128:1557-62. [pmid: 9368441].
Nishino A, Nabeya T, Moriya K, et al. Investigation of cases of suspected allergy to local anesthetics for dental use. [Japanese]. J Jpn Dent Soc Anesth. 1995;23:570-576.
Niwa H, Hirota Y, Sibutani T, et al. The effects of epinephrine and norepinephrine administered during local anesthesia on left ventricular diastolic function. Anesth Prog. 1991;38:221-6. [pmid: 1842160].
Niwa H, Satoh Y, Matsuura H. Cardiovascular responses to epinephrine-containing local anesthetics for dental use: a comparison of hemodynamic responses to infiltration anesthesia and ergometer-stress testing. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2000;90:171-81. [pmid: 10936836].
Niwa H, Shibutani T, Hori T, Kim Y, Akita M, Matsuura H. The interaction between pindolol and epinephrine contained in local anesthetic solution to the left ventricular diastolic filling velocity in normal subjects. Anesth Prog. 1996;43:78-84. [pmid: 10323111].
Nordenram A, Danielsson K. Local anaesthesia in elderly patients. An experimental study of oral infiltration anaesthesia. Swed Dent J. 1990;14:19-24. [pmid: 2363109].
Nordenram A, Sydnes G. Ornithine-8-vasaopressin, a new vasoconstrictor for local anaesthesia in dentistry. A comparative study with adrenaline. Sven Tandlak Tidskr. 1970;63:773-7. [pmid: 5275106].
O'Connor M, Eustace P. Tonic pupil and lateral rectus palsy following dental anaesthesia. Neuroophthalmol. 1983;3:205-208.
Odor TM, Pitt Ford TR, McDonald F. Adrenaline in local anaesthesia: the effect of concentration on dental pulpal circulation and anaesthesia. Endod Dent Traumatol. 1994;10:167-73. [pmid: 7995247].
Odor TM, Pitt Ford TR, McDonald F. Effect of inferior alveolar nerve block anaesthesia on the lower teeth. Endod Dent Traumatol. 1994;10:144-8. [pmid: 7995244].
Oertel R, Ebert U, Rahn R, Kirch W. The effect of age on pharmacokinetics of the local anesthetic drug articaine. Reg Anesth Pain Med. 1999;24:524-528. [pmid: 10588556].
Oertel R, Oertel A, Feller K. A new method of blood sampling and determination of the local anesthetic agent lidocaine in dentistry. Methods Find Exp Clin Pharmacol. 1993;15:131-136. [pmid: 8487596].
Ogawa A, Oi K. Use of N2O/O2/enflurane anesthesia for dental treatment of the handicapped. J Oral & Maxillofacial Surg. 1991;49:343-7.
Oikarinen VJ, Malmstrom M. Penicillin V concentration in dental alveolar blood after tooth extraction. Scand J Dent Res. 1972;80:279-84. [pmid: 4627004].
Oka S, Shimamoto C, Kyoda N, Misaki T. Comparison of lidocaine with and without bupivacaine for local dental anesthesia. Anesth Prog. 1997;44:83-6. [pmid: 9481966].
Okada Y, Suzuki H, Ishiyama I. Fatal subarachnoid haemorrhage associated with dental local anaesthesia. Aust Dent J. 1989;34:323-5. [pmid: 2775019].
Oliver LP. Local anaesthesia -- a review of practice. Aust Dent J. 1974;19:313-9. [pmid: 4531889].
Papadimitriou P, Harsoulis P, Zamboulis C. Changes of sympathetic activity during tooth extraction. Int J Oral Maxillofac Surg. 1986;15:148-51. [pmid: 3083017].
Peeples GA. Anesthetic and surgical considerations in children with dilantin gingival hyperplasia. J Oral Med. 1980;35:97-98. [pmid: 6937610].
Pelzner RB, Kempler D, Stark MM, Lum LB, Nicholson RJ, Soelberg KB. Human blood pressure and pulse rate response to racemic epinephrine retraction cord. J Prosthetic Dent. 1978;39:287-92.
Pergola SG, Raskin RB. Gingival retraction procedures. N Y State Dent J. 1983;49.
Perovic J, Petrovic V, Obradovic O, Todorovic L. The influence of vasoconstrictor in local anaesthetic solutions and injection sites on blood levels of lidocaine after intraoral application. Bull Group Int Rech Sci Stomatol Odontol. 1980;23:113-7. [pmid: 6934839].
Persson G. General side-effects of local dental anaesthesia with special reference to catecholamines as vasoconstrictors and to the effect of some premedicants. Acta Odontol Scand Suppl. 1969;53:1-141. [pmid: 5291391].
Persson G. Ornithine-vasopressin (POR-8) as a vasoconstrictor in anesthetics used for ordinary dental treatment. Scand J Dent Res. 1971;79:441-8. [pmid: 4942586].
Persson G, Isaksson B, Rosenquist J. Octopressin as a vasoconstrictor in anaesthetics used for oral Surg. Svensk Tandlak Tidskr. 1969;62:571-81.
Perusse R, Goulet JP, Turcotte JY. Contraindications to vasoconstrictors in dentistry: Part I. Cardiovascular diseases [see comments]. [Review] [87 refs]. Oral Surg Oral Med Oral Pathol. 1992;74:679-86. [pmid: 1437073].
Perusse R, Goulet JP, Turcotte JY. Contraindications to vasoconstrictors in dentistry: Part II. Hyperthyroidism, diabetes, sulfite sensitivity, cortico-dependent asthma, and pheochromocytoma [see comments]. [Review] [46 refs]. Oral Surg Oral Med Oral Pathol. 1992;74:687-91. [pmid: 1437074].
Petersen JK. The mandibular foramen block. A radiographic study of the spread of the local analgesic solution. Br J Oral Surg. 1971;9:126-38. [pmid: 5291313].
Petersen JK, Luck H, Kristensen F, Mikkelsen L. A comparison of four commonly used local analgesics. Int J Oral Surg. 1977;6:51-9. [pmid: 402325].
Petrikas Zh A. Clinical and pharmacologic studies of intraseptal spongious lidocain anesthesia of the teeth with and without epinephrine. [Russian]. Stomatologiya. 1990;69:27-29.
Petrikas Zh A, Rumyantsev VA, Shumilova TV. Efficacy of combining trimecaine with adrenalin. [Russian]. Stomatologiya. 1993;72:86-87.
Phatak NM, Lang RL. Systemic hemodynamic effects of R-epinephrine gingival retraction cord in clinic patients. J Oral Ther Pharmacol. 1966;2:393-8. [pmid: 5334252].
Piperno S, Kaim J. Epinephrine in local anesthesia -- effect on the blood pressure of normotensive patients. N Y State Dent J. 1981;47:392-4. [pmid: 6943468].
Pitt Ford TR, Seare MA, McDonald F. Action of adrenaline on the effect of dental local anaesthetic solutions. Endod Dent Traumatol. 1993;9:31-5. [pmid: 8491126].
Pogue WL, Harrison JD. Absorption of epinephrine during tissue retraction. J Prosthet Dent. 1967;18:242-7. [pmid: 5231297].
Pollmann L. Circadian changes in the duration of local anaesthesia. Int J Oral Surg. 1982;11:36-39. [pmid: 6811455].
Pope MR. Epinephrine-free gingival retraction. J Hosp Dent Pract. 1968;11:10-1. [pmid: 5241017].
Poulsom RC. An anaphylactoid reaction to periodontal surgical dressing: report of case. J Am Dent Assoc. 1974;89:895-6. [pmid: 4529314].
Powell SL, Robertson L, Doty BJ. Dental nerve blocks. Postgrad Med. 2000;107:229-245.
Premdas CE, Pitt Ford TR. Effect of palatal injections on pulpal blood flow in premolars. Endod Dent Traumatol. 1995;11:274-8. [pmid: 8617162].
Primosch RE, Robinson L. Pain elicited during intraoral infiltration with buffered lidocaine. Am J Dent. 1996;9:5-10. [pmid: 9002806].
Raab W-M. Anesthesia for oral Surg - Local anesthesia as standard procedure. [German]. Anasthesiol Intensivmed. 1996;37:192-196.
Rafel SS. Electrocardiographic changes during outpatient oral Surg. J Oral Surg. 1972;30:898-9. [pmid: 4508215].
Reiman MB. Exposure of subgingival margins by nonsurgical gingival displacement. J Prosthet Dent. 1976;36:649-54. [pmid: 792433].
Reitz J, Reader A, Nist R, Beck M, Meyers WJ. Anesthetic efficacy of the intraosseous injection of 0.9 mL of 2% lidocaine (1:100,000 epinephrine) to augment an inferior alveolar nerve block. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1998;86:516-23. [pmid: 9830641].
Replogle K, Reader A, Nist R, Beck M, Weaver J, Meyers WJ. Cardiovascular effects of intraosseous injections of 2 percent lidocaine with 1:100,000 epinephrine and 3 percent mepivacaine [see comments]. J Am Dent Assoc. 1999;130:649-57. [pmid: 10332129].
Reynolds C. The use of vasoconstrictors in dental anesthesia of cardiac patients. Appl Ther. 1966;8.
Reynolds F. Vasoconstrictor agents in local-anaesthetic preparations. Lancet. 1972;2:764-5. [pmid: 4116180].
Robiony M, Demitri V, Costa F, Politi M, Cugini U. Truncal anaesthesia of the maxillary nerve for outpatient surgically assisted rapid maxillary expansion. Br J Oral Maxillofac Surg. 1998;36:389-91. [pmid: 9831062].
Rodrigo C. Flumazenil in dentistry. Anesth Prog. 1995;42:121-125. [pmid: 8934978].
Rodrigo MRC, Clark RNW. A study of intravenous sedation with diazepam and midazolam for dentistry in Hong Kong Chinese. Anaesth Intensive Care. 1986;14:404-411. [pmid: 3565727].
Roelofse JA, Shipton EA, de V. Joubert JJ, Luus HG. The cardiovascular response to tracheal intubation during anaesthesia for oral surgical procedures. Effects of labetalol, acebutolol and lignocaine on cardiac rhythm. J Dent Assoc S Afr. 1986;41:707-11. [pmid: 3473752].
Roelofse JA, Shipton EA, Joubert JJ, Grotepass FW. A comparison of labetalol, acebutolol, and lidocaine for controlling the cardiovascular responses to endotracheal intubation for oral surgical procedures. J Oral Maxillofacial Surg. 1987;45:835-41.
Rollason WN, Bennetts FE, Clarke I. Cardiac dysrhythmias during outpatient dental anaesthesia with enflurane. The role of 'beta blockade.'. Acta Anaesth Scand. 1984;28:497-502. [pmid: 6496008].
Rollason WN, Russell JG. Intravenous metoprolol and cardiac dysrhythmias. An evaluation in the management of dysrhythmias in outpatient dental anaesthesia. Anaesthesiology. 1980;35:783-9.
Rood JP. Etidocaine in dentistry. Anesth Prog. 1989;36:190-191. [pmid: 2490028].
Rood JP. Ocular complication of inferior dental nerve block. A case report. Br Dent J. 1972;132:23-4.
Rood JP. Safety of adrenaline [letter; comment]. Br Dent J. 1999;186.
Rosenberg M, Weaver J. General anesthesia. Anesth Prog. 1991;38:172-186. [pmid: 1819969].
Rosenberg PA. Local anesthetic complications: a review and case report. [Review] [8 refs]. N Y J Dent. 1985;55:55-8. [pmid: 3881702].
Rowson JE, Preshaw PM. The use of lignocaine in dental practice: results of a survey of a group of general and hospital dental practitioners. J Dent. 1997;25:431-3. [pmid: 9241962].
Rutter DV. An indication for hypnosis. Anaesthesiology. 1981;36:302-3.
Saadoun AP, Malamed S. Intraseptal anesthesia in periodontal Surg. J Am Dent Assoc. 1985;111:249-56. [pmid: 3876361].
Sack U, Kleemann PP. Intraoral conduction anesthesia with epinephrine-containing local anesthetics and arterial epinephrine plasma concentration. Anesth Pain Control Dent. 1992;1:77-80. [pmid: 1392688].
Sakurai M. Effects of epinephrine in local dental anesthetics on plasma catecholamine concentration and circulation. Dent Jpn. 1990;27:135-9.
Salman I, Schwartz S. Effects of vasoconstrictors used in local anesthetics in patients with diseases of the heart. J Oral Surg. 1955;13:209-213. [pmid: 14392539].
Salonen M, Forssell H, Lehmijoki O, Kaila T, Scheinin M. A comparison of two sedative premedications for minor oral Surg under local anaesthesia. Int J Oral Maxillofac Surg. 1989;18:202-5. [pmid: 2507667].
Salonen M, Forssell H, Scheinin M. Local dental anaesthesia with lidocaine and adrenaline. Effects on plasma catecholamines, heart rate and blood pressure. Int J Oral Maxillofac Surg. 1988;17:392-4. [pmid: 3145958].
Scaramella J, Allen GD, Goebel WM, Donaldson D. Lidocaine as a supplement to general anesthesia for extraction of third molars: Serum levels. Anesth Prog. 1979;26.
Scheutz F. Drug addicts and local analgesia -- effectivity and general side effects. Scandinavian J Dent Res. 1982;90:299-305.
Schleder JR, Reader A, Beck M, Meyers WJ. The periodontal ligament injection: a comparison of 2% lidocaine, 3% mepivacaine, and 1:100,000 epinephrine to 2% lidocaine with 1:100,000 epinephrine in human mandibular premolars. J Endod. 1988;14:397-404. [pmid: 3253404].
Schmitz JP, Holmgreen WC. Outpatient anesthetic management of a patient with Wolff-Parkinson-White syndrome. J Oral Maxillofac Surg. 1997;55:175-9. [pmid: 9024357].
Schwartz HC. Local anesthesia. [Review] [26 refs]. J Am Dent Assoc. 1974;89:157-63. [pmid: 4599144].
Schwartz HJ, Sher TH. Bisulfite sensitivity manifesting as allergy to local dental anesthesia. J Allergy Clin Immunol. 1985;75:525-527. [pmid: 3980886].
Shaw DH, Krejci RF. Change in the drug prescribing preference of dentists over a ten-year period. Northwest Dent. 1993;72:25-8.
Shaw DH, Krejci RF. Epinephrine containing gingival retraction cords -- how safe are they?. J Nebr Dent Assoc. 1976;52:7-9.
Shugailov IA, Finadeev AP, Proskuryakova OV, et al. Combined anesthesia in pregnant women during the out-patient dental interventions. [Russian]. Stomatologiya. 1989;68:25-27.
Sidon MA, Aldrete JA, McMullen RB, Barnes DR. Evaluation of the addition of potassium chloride to lidocaine as an anesthetic in dentistry. J Am Dent Assoc. 1969;78:556-62. [pmid: 4885036].
Siiba S, Nakanishi O, Ishikawa T, Hirakawa T, Kawahara H, Imamura Y. Increase in the threshold of pain and touch sensation in the human face with clonidine plus 30% nitrous oxide. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1999;87:294-8. [pmid: 10102588].
Sisk AL. Comparison of etidocaine and lidocaine for control of intra- and post-operative bleeding and pain. J Oral Maxillofac Surg. 1986;44:16-20. [pmid: 3484524].
Sisk AL. Vasoconstrictors in local anesthesia for dentistry. Anesth Prog. 1993;39:187-193. [pmid: 8250339].
Smith I. Office-based anaesthesia: The UK perspective. Ambul Surg. 1998;6:69-74.
Smith RB, High P, Spatz S, Zubrow H. Effects of levonordefrin injection during enflurane anesthesia. J Oral Surg. 1974;32:506-7. [pmid: 4525418].
Southwell GC. Physiological responses under dental sedation and anaesthesia. Dent Anaesth Sedation. 1976;5:99-101.
Stabile P, Reader A, Gallatin E, Beck M, Weaver J. Anesthetic efficacy and heart rate effects of the intraosseous injection of 1.5% etidocaine (1:200,000 epinephrine) after an inferior alveolar nerve block. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2000;89:407-11. [pmid: 10760722].
Steblay NM, Beaman AL. Reduction of fear during dental treatment through reattribution techniques. J Am Dent Assoc. 1982;105:1006-9. [pmid: 6961142].
Strauss RA, Eschenroeder TA. Hemiplegic migraine following third molar extractions under intravenous sedation: report of a case. J Oral Maxillofac Surg. 1989;47:184-6. [pmid: 2913255].
Sugimura M, Hirota Y, Shibutani T, et al. An echocardiographic study of interactions between pindolol and epinephrine contained in a local anesthetic solution. Anesth Prog. 1995;42:29-35. [pmid: 8934951].
Sugiyama K, Joh S, Hirota Y, et al. Nitroglycerin infusion during dental treatment and minor oral Surg. J Osaka Univ Dent School. 1988;28:9-16.
Summers L. An investigation into the effects of surgical stress on the fit and poor-risk patient including the modifying effect of relative analgesia and beta-blockade. Part I. The effects of surgical stress on fit and poor-risk patients. Br J Oral Surg. 1981;19:3-12. [pmid: 6111336].
Summers L. An investigation into the effects of surgical stress on the fit and poor-risk patient including the modifying effects of relative analgesia and beta-blockade. Part III. The modifying effect of beta-blockade on surgical stress. Br J Oral Surg. 1981;19:81-7. [pmid: 6942883].
Summers L. An investigation into the effects of surgical stress on the fit and poor-risk patient including the modifying effects of relative analgesia and beta-blockade. Part IV. The effect of beta-blockade and relative analgesia on surgical stress. Br J Oral Surg. 1981;19:88-95. [pmid: 6942884].
Sunada K, Nakamura K, Yamashiro M, Sumitomo M, Furuya H. Clinically safe dosage of felypressin for patients with essential hypertension. Anesth Prog. 1996;43:108-15. [pmid: 10323116].
Sutherland KJ. Medical conditions affecting dental treatment planning. Aust Dent J. 1972;17:169-77. [pmid: 4507678].
Sveen K. Effect of the addition of a vasoconstrictor to local anesthetic solution on operative and postoperative bleeding, analgesia and wound healing. Int J Oral Surg. 1979;8:301-6. [pmid: 120334].
Szabo G, Gaspar L, Divinyi T. Recent clinical experiences with Ultracain(™) preparations versus different lidocain. [German]. Z Stomatol. 1988;85:235-238. [pmid: 3268022].
Szappanyos G, Gemperle M, Rifat K. Selective indications for ketamine anaesthesia. Proc R Soc Med. 1971;64:1156-9. [pmid: 4257063]. [pmcid: 1812067].
Taggart P, Hedworth-Whitty R, Carruthers M, Gordon PD. Observations on electrocardiogram and plasma catecholamines during dental procedures: the forgotten vagus. Br Med J. 1976;2:787-9. [pmid: 974610]. [pmcid: 1688634].
Takagi J, Asahi Y, Yoneda T, et al. Systemic management during dental treatment of a patient who is hypersensitive to antihypertensive drugs. [Japanese]. J Jpn Dent Soc Anesthesiol. 1998;26:249-253.
Takano K, Fujii K, Kanri T The application of iontophoresis in dental local anesthesia, 4th report examination of the electrifying conditions and intra electrode tampon pH. [Japanese] J Jpn Dent Soc Anesthesiol 1996 24(3)(pp 461 466) 1996.:461-466
Tartaro S, Vatti M, Galantuso P. Local anesthetics in surgical oral dentistry and in maxillofacial Surg their limits in regard to the cardiovascular system. J Med. 1977;8:435-41. [pmid: 272437].
Teenier TJ, Throckmorton GS, Ellis E3. Effects of local anesthesia on bite force generation and electromyographic activity. J Oral Maxillofac Surg. 1991;49:360-5. [pmid: 2005493].
Thomson PJ, Langton SG. Persistent haemorrhage following dental extractions in patients with liver disease: two cautionary tales [see comments]. Br Dent J. 1996;180:141-4. [pmid: 8850288].
Todorovic L, Stajcic Z, Petrovic V. Mandibular versus inferior dental anaesthesia: clinical assessment of 3 different techniques. Int J Oral Maxillofac Surg. 1986;15:733-8. [pmid: 3100676].
Tolas AG, Allen GD. Propranolol in prevention of cardiac arrhythmia. J Oral Surg. 1970;28:181-3. [pmid: 5263941].
Tolas AG, Pflug AE, Halter JB. Arterial plasma epinephrine concentrations and hemodynamic responses after dental injection of local anesthetic with epinephrine. J Am Dent Assoc. 1982;104:41-3. [pmid: 6948029].
Torabinejad M, Peters DL, Peckham N, Rentchler LR, Richardson J. Electron microscopic changes in human pulps after intraligamental injection. Oral Surg Oral Med Oral Pathol. 1993;76:219-24. [pmid: 8361735].
Tordoff SG, Brossy M, Rowbotham DJ, James JN, James R, Raphael JH. The effect of pre-incisional infiltration with lignocaine on postoperative pain after molar teeth extraction under general anaesthesia. Anaesthesiology. 1996;51:585-7.
Troullos ES, Hargreaves KM, Goldstein DS, Stull R, Dionne RA. Epinephrine suppresses stress-induced increases in plasma immunoreactive beta-endorphin in humans. J Clin Endocrinol Metab. 1989;69:546-51. [pmid: 2527244].
Tsuchihashi T, Takata Y, Kurokawa H, et al. Blood pressure response during dental Surg. Hypertens Res. 1996;19:189-94. [pmid: 8891747].
Tsukamoto A. Effect of nitrous oxide analgesia on pituitary-adrenal function in dental patients. [Japanese]. Jpn J Anesthesiol. 1980;29:423-430.
Tyas M. Cotton pellets and gingival retraction cords. Clinical notes No. 2. Aust Dent J. 1984;29.
Umino M, Ohwatari T, Shimoyama K, Nagao M. Unexpected atrial fibrillation during tooth extraction in a sedated elderly patient. Anesth Prog. 1994;41:77-80. [pmid: 8934964].
Valanne J, Korttila K, Ylikorkala O. Intravenous diclofenac sodium decreases prostaglandin synthesis and postoperative symptoms after general anaesthesia in outpatients undergoing dental Surg. Acta Anaesthesiol Scand. 1987;31:722-7. [pmid: 3324615].
van der Bijl P, Victor AM. Adverse reactions associated with norepinephrine in dental local anesthesia. Anesth Prog. 1992;39:87-9. [pmid: 1308379].
Van Sickels JE, Tiner BD. Cost of a genioplasty under deep intravenous sedation in a private office versus general anesthesia in an outpatient surgical center. J Oral Maxillofacial Surg. 1992;50:687-90.
Vanderheyden PJ, Williams RA, Sims TN. Assessment of ST segment depression in patients with cardiac disease after local anesthesia. J Am Dent Assoc. 1989;119:407-12. [pmid: 2527898].
Vernale C. Cardiovascular responses to local dental anesthesia with epinephrine in normotensive and hypertensive subjects. Anesthesiology. 1960;13:942-952.
Verrill PJ. Adverse reactions to local anaesthetics and vasoconstrictor drugs. Practitioner. 1975;214:380-7. [pmid: 806908].
Vreeland DL, Reader A, Beck M, Meyers W, Weaver J. An evaluation of volumes and concentrations of lidocaine in human inferior alveolar nerve block. J Endod. 1989;15:6-12. [pmid: 2607268].
Waldman HB, Binkley G. Lidocaine hypersensitivity: report of a case. J Am Dent Assoc. 1967;74:747-9. [pmid: 5226287].
Wallenstein S, Fleiss JL, Chilton NW. The logistic analysis of categorical data from dental and oral experiments. Pharmacol Ther Dent. 1981;6:65-78. [pmid: 6953452].
Walton JG, Thompson JW. Pharmacology for the dental practitioner. 6. Systemic disease and dental practice (continued). Br Dent J. 1969;127:281-7. [pmid: 5258050].
Warrington RJ, McPhillips S, Cuesta-Herranz J. Allergic reaction to local anesthetic agents of the amide group [1] (multiple letters). J Allergy Clin Immunol. 1997;100.
Watanabe T, Koshi I, Tsukada K, Ogasawara T, Kasahara H. Analgesic effect of the combination of iontophoresis of lidocaine and a very fine needle for the injection of the oral infiltration anesthesia. [Japanese]. J Jpn Dent Soc Anesthesiol. 1995;23:723-733.
Webb BW. Medical evaluation for outpatient dental procedures. J Fam Pract. 1978;6:971-4. [pmid: 660117].
Weir DJ, Williams BH. Clinical effectiveness of mechanical-chemical tissue displacement methods. J Prosthet Dent. 1984;51:326-9. [pmid: 6368802].
Wessberg G. Role of screening for hypertension in patient management. J Am Dent Assoc. 1978;96:1040-4. [pmid: 276544].
Whitehead MH, Whitmarsh VB, Horton JN. Metoprolol in anaesthesia for oral Surg. The effect of pretreatment on the incidence of cardiac dysrhythmias. Anaesthesiology. 1980;35:779-82.
Wilson CA, Tay WM. Alum solution as an adjunct to gingival retraction. A clinical evaluation. Br Dent J. 1977;142:155-8. [pmid: 320987].
Winther JE, Nathalang B. Effectivity of a new local analgesic Hoe 40 045. Scand J Dent Res. 1972;80:272-8. [pmid: 4560609].
Winther JE, Patirupanusara B. Evaluation of carticaine - a new local analgesic. Int J Oral Surg. 1974;3:422-7. [pmid: 4217318].
Woehrlen Jr AE. Subcutaneous emphysema. Anesth Prog. 1985;32:161-163. [pmid: 3865564].
Woods R. Sedation for dental treatment of infants. I. Physiology and pharmacology. Aust Dent J. 1979;24:213-218. [pmid: 296694].
Woycheshin F. An evaluation of the drugs used for gingival retraction. J Prosth Dent. 1964;14.
Yagiela JA. Local anesthetics. Anesth Prog. 1991;38:128-141. [pmid: 1819966].
Yagiela JA. Vasoconstrictor agents for local anesthesia. [Review] [17 refs]. Anesth Prog. 1995;42:116-20. [pmid: 8934977].
Yamada T, Fukunaga J, Sunaga H, et al. Acceptable dose of epinephrine during sevoflurane anesthesia; I. Hemodynamic changes due to epinephrine. [Japanese]. J Jpn Dent Soc Anesthesiol. 1998;26:202-208.
Ylipaavalniemi P, Sane J. Changes in heart rate during injection of local anaesthetics. Proc Finn Dent Soc. 1981;77:346-9. [pmid: 7335642].
Yoshimura Y. The relation of tooth extraction to anginal attack. J Oral Maxillofac Surg. 1983;41:365-76. [pmid: 6574218].
Yoshimura Y, Sugihara T, Kishimoto H, Fujie K, Yoshida Y. Old myocardial infarction and tooth extractions: retrospective observation of 14 patients. J Osaka Univ Dent School. 1981;21:181-91.
Yoshimura Y, Sugimura M, Kawakatsu K. Hyperdynamic beta-adrenergic circulatory state. A case report. Int J Oral Surg. 1977;6:260-5. [pmid: 201579].
Zhang C, Banting DW, Gelb AW, Hamilton JT. Effect of beta-adrenoreceptor blockade with nadolol on the duration of local anesthesia. J Am Dent Assoc. 1999;130:1773-80. [pmid: 10599182].