# References

1 Franklin SS, Jacobs MJ, Wong ND, L'Italien GJ, Lapuerta P. Predominance of isolated systolic hypertension among middle-aged and elderly us hypertensives: analysis based on national health and nutrition examination survey (NHANES) III. Hypertension. 2001;37:869-74. [pmid: 11244010].
2 Matsuura H. The systemic management of cardiovascular risk patients in dentistry. [Review] [39 refs]. Anesth Pain Control Dent. 1993;2:49-61. [pmid: 8329905].
3 Meechan JG. Plasma potassium changes in hypertensive patients undergoing oral surgery with local anesthetics containing epinephrine. Anesth Prog. 1997;44:106-9. [pmid: 9481971].
4 Goulet JP, Perusse R, Turcotte JY. Contraindications to vasoconstrictors in dentistry: Part III. Pharmacologic interactions [see comments]. [Review] [51 refs]. Oral Surg, Oral Med Oral Pathol. 1992;74:692-7. [pmid: 1359489].
5 Glick M. New guidelines for prevention, detection, evaluation and treatment of high blood pressure. J Am Dent Assoc. 1998;129:1588-1594. [pmid: 9818576].
6 Muzyka BC, Glick M. The hypertensive dental patient. J Am Dent Assoc. 1997;128:1109-1120. [pmid: 9260420].
7 Dionne RA, Goldstein DS, Wirdzek PR. Effects of diazepam premedication and epinephrine-containing local anesthetic on cardiovascular and plasma catecholamine responses to oral surgery. Anesth Analg. 1984;63:640-6. [pmid: 6731889].
8 Lohr K, Carey T. Assessing "best evidence": issues in grading the quality of studies for systematic reviews. Jt Comm J Qual Improv. 1999;25:470-479. [pmid: 10481816].
9 Salman I, Schwartz S. Effects of vasoconstrictors used in local anesthetics in patients with diseases of the heart. J Oral Surg. 1955;13:209-213. [pmid: 14392539].
10 Elliott GD, Stein E. Oral surgery in patients with atherosclerotic heart disease. Benign effect of epinephrine in local anesthesia. JAMA. 1974;227:1403-4. [pmid: 4406023].
11 Meiller TF, Overholser CD, Kutcher MJ, Bennett R. Blood pressure fluctuations in hypertensive patients during oral surgery. J Oral Maxillofac Surg. 1983;41:715-718. [pmid: 6579257].
12 Yoshimura Y. The relation of tooth extraction to anginal attack. J Oral Maxillofac Surg. 1983;41:365-76. [pmid: 6574218].
13 Hasse AL, Heng MK, Garrett NR. Blood pressure and electrocardiographic response to dental treatment with use of local anesthesia. J Am Dent Assoc. 1986;113:639-42. [pmid: 2945853].
14 Hirota Y, Sugiyama K, Joh S, Kiyomitsu Y. An echocardiographic study of patients with cardiovascular disease during dental treatment using local anesthesia. J Oral Maxillofac Surg. 1986;44:116-121. [pmid: 3456017].
15 Salonen M, Forssell H, Scheinin M. Local dental anesthesia with lidocaine and adrenaline. Effects on plasma catecholamines, heart rate and blood pressure. Int J Oral Maxillofac Surg. 1988;17:392-4. [pmid: 3145958].
16 Vanderheyden PJ, Williams RA, Sims TN. Assessment of ST segment depression in patients with cardiac disease after local anesthesia. J Am Dent Assoc. 1989;119:407-12. [pmid: 2527898].
17 Davenport RE, Porcelli RJ, Iacono VJ, Bonura CF, Mallis GI, Baer PN. Effects of anesthetics containing epinephrine on catecholamine levels during periodontal surgery. J Periodontol. 1990;61:553-8. [pmid: 2213464].
18 Meechan JG, Rawlins MD. The effects of two different local anaesthetic solutions administered for oral surgery on plasma potassium levels in patients taking kaliuretic diuretics. Eur J Clin Pharmacol. 1992;42:155-8. [pmid: 1618246].
19 Leviner E, Tzukert AA, Mosseri M, et al. Perioperative hemodynamic changes in ischemic heart disease patients undergoing dental treatment. Spec Care Dentist. 1992;12:84-8. [pmid: 1440125].
20 Findler M, Mazor D, Galili D, Garfunkel A. Dental treatment in a patient with malignant pheochromocytoma and severe uncontrolled high blood pressure. Oral Surg Oral Med Oral Pathol. 1993;75:290-291. [pmid: 8097035].
21 Campbell RL, Langston WG. A comparison of cardiac rate-pressure product and pressure-rate quotient in healthy and medically compromised patients. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1995;80:145-52. [pmid: 7552876].
22 Nichols C. Dentistry and hypertension. J Am Dent Assoc. 1997;128:1557-62. [pmid: 9368441].
23 Blinder D, Manor Y, Shemesh J, Taicher S. Electrocardiographic changes in cardiac patients having dental extractions under a local anesthetic containing a vasopressor. J Oral Maxillofac Surg. 1998;56:1399-402. discussion 1402-3. [pmid: 9846537].
24 Niwa H, Satoh Y, Matsuura H. Cardiovascular responses to epinephrine-containing local anesthetics for dental use: a comparison of hemodynamic responses to infiltration anesthesia and ergometer-stress testing. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2000;90:171-81. [pmid: 10936836].
25 Phatak NM, Lang RL. Systemic hemodynamic effects of R-epinephrine gingival retraction cord in clinic patients. J Oral Ther Pharmacol. 1966;2:393-8. [pmid: 5334252].
26 Fritts KW, Thayer KE, Yoder JL. The use of epinephrine impregnated retraction cords. J Acad Gen Dent. 1970;18:17-9.
27 Houston JB, Appleby RC, DeCounter L, Callaghan N, Funk DC. Effect of r-epinephrine-impregnated retraction cord on the cardiovascular system. J Prosthet Dent. 1970;24:373-6. [pmid: 4195839].
28 Munoz RJ. The cardiovascular effects of anxiety and R-epinephrine retraction cord in routine fixed prosthodontic procedures. J Calif Dent Assoc. 1970;46:10-3. [pmid: 4913980].
29 Pelzner RB, Kempler D, Stark MM, Lum LB, Nicholson RJ, Soelberg KB. Human blood pressure and pulse rate response to racemic epinephrine retraction cord. J Prosthet Dent. 1978;39:287-92. [pmid: 344863].
30 Hatch CL, Chernow B, Terezhalmy GT, Van Ness M, Hall-Boyer K, Lake CR. Plasma catecholamine and hemodynamic responses to the placement of epinephrine-impregnated gingival retraction cord. Oral Surg Oral Med Oral Pathol. 1984;58:540-4. [pmid: 6392983].
31 Cheraskin E, Prasertsuntarasai T. Use of epinephrine with local anesthesia in hypertensive patients: III. Effect of epinephrine on blood pressure and pulse rate. J Am Dent Assoc. 1958;57:507-519. [pmid: 13575081].
32 Vernale C. Cardiovascular responses to local dental anesthesia with epinephrine in normotensive and hypertensive subjects. Anesthesiology. 1960;13:942-952.
33 Meyer FU. Hemodynamic changes of local dental anesthesia in normotensive and hypertensive subjects. Int J Clin Pharmacol, Ther Toxicol. 1986;24:477-81. [pmid: 3781681].
34 Abraham-Inpijn L, Borgmeijer-Hoelen A, Gortzak RA. Changes in blood pressure, heart rate, and electrocardiogram during dental treatment with use of local anesthesia. J Am Dent Assoc. 1988;116:531-6. [pmid: 3164019].
35 Miura K, Matsumura K, Nakamura Y, Kurokawa H, Kajiyama M, Takata Y. Suppression of cardiac sympathetic nervous system during dental surgery in hypertensive patients. Hypertens Res. 2000;23:207-12. [pmid: 10821128].
36 Mito RS, Yagiela JA. Hypertensive response to levonordefrin in a patient receiving propranolol: report of case. J Am Dent Assoc. 1988;116:55-7. [pmid: 3278028].
37 van der Bijl P, Victor AM. Adverse reactions associated with norepinephrine in dental local anesthesia. Anesth Prog. 1992;39:87-9. [pmid: 1308379].
38 Barclay JK. Unusual responses to drugs: Two case reports. N Z Dent J. 1981;77:69-70. [pmid: 6942274].
39 Hilley MD, Milam SB, Giescke AHJ, Giovannitti JA. Fatality associated with the combined use of halothane and gingival retraction cord. Anesthesiology. 1984;60:587-8. [pmid: 6731915].
40 Hondrum SO. Hypertensive episode in the dental office. Gen Dent. 1985;33:134-9. [pmid: 3858202].
41 Kronman JH, Giunta JL. Reflex vasoconstriction following dental injections. Oral Surg Oral Med Oral Pathol. 1987;63:542-544. [pmid: 3473373].
42 Gortzak RA, Abraham-Inpijn L. Pain-induced hypertensive episode in the dental office. Gen Dent. 1995;43:274-6. [pmid: 8940586].
43 Umino M, Ohwatari T, Shimoyama K, Nagao M. Unexpected atrial fibrillation during tooth extraction in a sedated elderly patient. Anesth Prog. 1994;41:77-80. [pmid: 8934964].
44 Sugimura M, Hirota Y, Shibutani T, et al. An echocardiographic study of interactions between pindolol and epinephrine contained in a local anesthetic solution. Anesth Prog. 1995;42:29-35. [pmid: 8934951].