# Future Research

Based on the available evidence concerning the use of epinephrine in local anesthetic solutions, which suggests that adverse outcomes among hypertensive patients are infrequent and that risk indicators reflect only minimal change, replicating existing studies does not represent an efficient method to further our knowledge of the risks for adverse cardiovascular outcomes associated with this use. Rather, a large-scale descriptive study of adverse outcomes of the use of epinephrine-containing local anesthetics would seem to be indicated. Because existing electronic dental data systems do not contain either health history information or adverse outcome data, a retrospective study would be difficult to mount, necessitating a prospective effort. A long-term protocol initiated in one or more large dental clinics that involves electronic capture of pre-existing cardiovascular diagnoses and medication status of all patients, together with information describing all adverse outcomes occurring during treatment could begin to quantify the magnitude of additional risk represented by the use of epinephrine in hypertensives with minimal outlay of effort and expense. Only if the results of such an investigation indicate that the added risk is greater than deemed acceptable would additional trials to develop more sensitive methods for identifying patients at increased risk be justified.

With respect to the use of epinephrine-impregnated gingival retraction cord, studies are needed to quantify the absorption of epinephrine from gingival tissues. The effects of time, tissue condition, cord construction, and epinephrine concentration on plasma concentration of epinephrine should be determined in these studies. Once a better understanding of the possible range of epinephrine concentrations is gained, the risks associated with the use of these cords in hypertensive patients can be evaluated. At present, a single human study reports absorption levels.^30^