# Conclusions

The key question addressed by this review was, "What additional risks of adverse cardiovascular outcomes do epinephrine-containing anesthetic solutions and epinephrine-impregnated gingival retraction cords represent for controlled and uncontrolled hypertensive individuals receiving dental treatment?" The systematic review indicated that the strength of the evidence available for answering this question was poor. No studies examined outcomes of the use of epinephrine-impregnated gingival retraction cord in controlled and uncontrolled hypertensive patients. Only one study was identified that examined outcomes of the use of epinephrine among controlled hypertensives. A larger group of five studies was identified that examined the effects of epinephrine in local anesthetics among uncontrolled hypertensives. Here, the reported risks were judged to be minimal by the authors of the studies, consisting of small increases in heart rate and systolic blood pressure. However, not all risk indicators for adverse cardiovascular events were considered in these studies, and incomplete recording of risk indicators that were examined further weakens the strength of the evidence.