# Results

The systematic review of the literature identified six studies that met the inclusion criteria (see Evidence Table 1). These studies included a total of 325 subjects, of whom 177 were identified as hypertensive. Of these, 14 percent were identified as taking medication for control of hypertension. All of the studies examined effects of epinephrine in local anesthesia; no studies of the effects of epinephrine-impregnated gingival retraction cord were included. In all studies the local anesthetic involved was 2 percent lidocaine, and epinephrine concentrations were divided between 1:100,000 (n=3 studies) and 1:80,000 (n=3 studies). Quantities of anesthetic solution injected were reported in four studies, with means ranging from 2 ml to 4.5 ml. Depth of anesthesia and duration of anesthesia were not reported. The outcomes examined in these studies consisted principally of systolic and diastolic blood pressures and heart rate. The dental procedure involved was tooth extraction in five of the six studies, and "minor oral surgery" in the sixth. The studies are summarized in the following section, followed by our assessment of the strength of the evidence. We then discuss the limitations of the evidence base.

## Summary of the Studies

The first of the included studies^31^ compared eight groups of subjects, four normotensive and four hypertensive. Other cardiac conditions for these subjects were not reported. Within these groups, injections either did or did not contain epinephrine, and subjects either were or were not premedicated. Blood pressure and heart rate were recorded immediately before the injection, 5 minutes post-injection, and 10 minutes post-injection. The timing of the extraction was not indicated. Mean increases in systolic blood pressure were small and occurred principally in the first 5 minutes, with means of 3 to 7 mm Hg among hypertensive groups, and 1 to 5 mm Hg among normotensives. Pressures then declined from 5 to 10 minutes post-injection in all but the nonsedated normotensive group receiving epinephrine. None of the changes were statistically significant from baseline. No between-group changes were tested statistically. Smaller changes in diastolic pressures were observed with decreases in five groups of between 1 and 3 mm Hg, and increases in three groups of between 0 and 2 mm Hg at 5 minutes. Additional small changes were seen in the period 5 to 10 minutes post injection, with maximum changes over 10 minutes never more than 3 mm Hg. Again, changes were not significantly different from baseline, and no intergroup comparisons were reported. Heart rate changes showed much the same pattern as systolic pressure, with mean increases of 1 to 7 bpm among hypertensive groups, and 1 to 4 bpm among normotensive groups for baseline to 5 minutes, with still smaller, mixed changes in the 5 to 10 minute period. The authors concluded that neither epinephrine nor hypertensive status resulted in significantly different mean changes in blood pressure or heart rate following injection with local anesthetic (p>0.05). Medication status among hypertensive patients was not reported.

The second study compared 20 hypertensive patients, many of whom also had other cardiovascular disease, with a small group of six normotensive subjects with no cardiac complications.^32^ Both groups received extractions under local anesthesia with and without epinephrine at separate visits. Here, hypertensive subjects exhibited larger increases in systolic pressure, with means of 28 mm Hg and 21 mm Hg with and without epinephrine, compared to normotensive subjects, with increases of 13 mm Hg and 12 mm Hg with and without epinephrine, respectively. Roughly equal increases were associated in the epinephrine groups with injection and extraction, and these were additive. Diastolic changes were smaller and mixed in direction, and no clear hypertensive or epinephrine patterns emerged. Heart rate changes were most pronounced in hypertensive subjects receiving epinephrine. The authors indicate that changes from baseline and differences in standard deviations among groups were not statistically significant for all comparisons, but the specific comparisons made, tests used, and p values are not described. No alterations in the cardiac complex (S-T segment alteration, T-wave inversion, abnormal QRS complex) were identified. However, premature ventricular contractions (PVCs) were present and reported to be less frequent in the absence of epinephrine.

The third study consisted of two groups, hypertensive subjects and normotensive subjects, each of whom received extractions with three different local anesthetic solutions, one with epinephrine, one with norepinephrine, and one without either.^33^ Other cardiac conditions were not reported. The norepinephrine results are not reported in the evidence table. Among all subjects, changes in blood pressure and heart rate responses were small, but hypertensive responses for systolic blood pressure and heart rate tended to be somewhat greater. Comparison of epinephrine versus no epinephrine anesthetic in both hypertensive and normotensive groups showed that diastolic decreases were greater among epinephrine groups in the period following the extraction procedure (p <0.05). Significant differences in systolic pressure and heart rate occurred in the hypertensive group, and these differences involved isolated readings following extraction. No side effects were attributed to epinephrine.

The fourth study included normotensives (n=15), hypertensives (n=9), and a third group, moderate hypertensives (n=15), who had systolic and diastolic blood pressures ranging between 140 and 160 mm Hg and 90 and 95 mm Hg, respectively.^34^ Ten subjects had previous myocardial infarctions and seven had arrhythmias. One patient was reported to be taking a beta blocker and was excluded from analysis of heart rate. Blood pressure and heart rate were recorded at 5-minute intervals throughout visits for tooth extractions. An EKG was run for the immediate period of the injection and the extraction. Group means for maximum and minimum blood pressures recorded were reported. All patients but two received local anesthetic containing epinephrine. Heart rate changes were not analyzed by hypertensive status. Increases in mean maximum systolic pressure were similar among the three groups, ranging from 19 to 27 mm Hg. Similarly, increases in mean maximum diastolic pressure ranged from 11 to 20 mm Hg across groups. These increases were statistically significant compared to baseline values (p<0.01). Intergroup differences were not tested for significance. EKG disturbances were reported in two subjects, a sinus arrhythmia with multifocal supraventricular premature contractions in a hypertensive subject and a 10-second sinus arrest in a normotensive subject, presumed to be an "extreme vasovagal reaction."

The fifth study included 14 subjects diagnosed as hypertensive and taking control medications, either beta blockers or nonpotassium-sparing diuretics.^3^ Blood pressure and heart rate were recorded twice; once before the injection, and once 10 minutes postinjection. Plasma potassium concentrations were recorded at these same times. Differences between groups in change in blood pressure were not significant, with systolic increasing 1 and 3 mm Hg, while diastolic decreased 3 and 12 mm. Heart rate changes were significantly different (p<0.02), decreasing 3 bpm in the beta blocker group and increasing 7 bpm in the diuretic group. The plasma potassium concentration decreased significantly in the diuretic group compared to baseline (p<0.01) and to the beta blocker group (p<0.05).

The sixth study compared 18 patients with essential hypertension receiving an extraction and an equal number of matched controls, with the matching criteria not identified.^35^ All patients received epinephrine. Of the 18 hypertensives, 10 were receiving antihypertensive treatment (n=2 diuretics; n=5 calcium channel antagonists; n=2 ACE inhibitors; n=1, ACE inhibitor and calcium channel blocker). Blood pressure and heart rate were recorded every two minutes and values averaged for treatment phases. From EKG monitoring, power spectral densities were computed, and the ratio of the low frequency band to the high frequency band was calculated (LF/HF ratio), along with the high frequency band as a proportion of the total frequency band (%HF). The patterns of change in blood pressure were similar for the two groups, with inter-group differences not tested for statistical significance. Changes in systolic pressures were all significantly different than baseline (p<0.05). Only normotensive subjects exhibited a significant increase in diastolic pressure from baseline, and only for the extraction phase of treatment. The LF/HF ratio declined significantly during anesthesia and extraction phases for hypertensives but not normotensives, suggesting suppression of the cardiac sympathetic nervous system. Percent HF declined significantly during anesthesia for normotensives, but not hypertensives.

Table 10 summarizes the mean maximum blood pressure and heart rate changes (from mean baseline values) reported in the three studies of uncontrolled hypertensives where both hypertensives and normotensives received injections with and without epinephrine.^31-33^ Because two of the studies did not report confidence intervals for their observations, meta-analysis was not performed.^31,32^ The unweighted means of the individual study means shown in Table 10 indicate that when dental extractions were performed using local anesthetic with epinephrine, systolic blood pressure was 4 mm Hg higher for hypertensive subjects and no higher for normotensive subjects than when the same procedures were performed using local anesthetic without epinephrine. Heart rate was higher with epinephrine than without for both hypertensives and normotensives (6 bpm and 5.6 bpm, respectively), while diastolic blood pressure was lower (1.0 and 4.7 mm Hg, respectively, for hypertensives and normotensives). The table also indicates that receiving the procedure without epinephrine is also associated with increases in blood pressure and heart rate compared to baseline and that, for systolic blood pressure and heart rates, these increases are greater in hypertensives than in normotensives (11.7 versus 5.0 mm Hg, and 4.7 bpm versus 0.7 bpm). Increases in diastolic pressure were similar at 3.3 and 4.0 mm Hg. The mean maximum changes in blood pressure tended to be greater for both hypertensives and normotensives in the two studies of uncontrolled hypertensives not included in the table.^34,35^ Only one of these studies reported heart rate values, which were lower.^35^

Table 10. Means of Maximum Changes from Baseline for Blood Pressure and Heart Rate^a^

| max Δ SBP (mm) | max Δ DBP (mm) | max Δ HR (bpm)
Hypertensives
anesthesia with epinephrine | 15.3 | 2.3 | 9.3
anesthesia without epinephrine | 11.7 | 3.3 | 4.7
Normotensives
anesthesia with epinephrine | 5.0 | -0.7 | 6.3
anesthesia without epinephrine^a ^ | 5.0 | 4.0 | 0.7

a unweighted mean of subject means reported in three studies

SBP=systolic blood pressure

DBP=diastolic blood pressure

HR=heart rate

Where timing of the maximum reading was reported, it occurred in conjunction with the surgical procedure rather than the injection in almost all instances. However, for both hypertensives and normotensives receiving local anesthetic with epinephrine, smaller increases in systolic blood pressure and heart rate were associated with the injection, whereas these increases were not present for injections without epinephrine.

None of the studies noted any patient-reported adverse events. Examination of EKGs in two studies indicated occurrences of PVCs associated with epinephrine in the local anesthetic, and in one study these PVCs were also associated with hypertensive status.

In addition to examining the studies included in the review for descriptions of adverse outcomes, we also examined several reports of adverse events possibly involving either epinephrine or hypertensive patients among the persons identified in the literature search. Of eight reports of adverse events associated with local anesthesia that we examined, two were associated with vasopressors other than epinephrine,^36,37^ and five concerned putative reactions to epinephrine in normotensive subjects.^38-42^ One report described an episode of atrial fibrillation extending 10 minutes during tooth extraction following injection of 2 percent lidocaine with 1:200,000 epinephrine, 3.6 + 0.9 ml, in a subject with controlled hypertension (nifedipine) and cardiac disease.^43^

Finally, several studies not included in the systematic review reported outcomes associated with one or more hypertensive patients receiving local anesthetics with epinephrine, but these patients were not analyzed as a group.^10,12,13,16,17,21-23^ In none of these studies were adverse outcomes reported that could be associated with groups including hypertensive patients.

In summary, the information from the available studies of uncontrolled hypertensive subjects suggests that hypertensive subjects receiving an extraction experience small increases in systolic blood pressure and heart rate associated with the use of a local anesthetic containing epinephrine (4 mm Hg and 6 bpm). These increases associated with the use of epinephrine occur in addition to increases in systolic and diastolic blood pressure and heart rate associated with undergoing the procedure without epinephrine (11.7 and 3.3 mm Hg and 4.7 bpm) that are larger for hypertensives than for normotensives. No adverse outcomes were reported among any of the subjects in the studies included in the review, and only one report of an adverse event associated with the use of epinephrine in local anesthetic in a hypertensive patient was identified in the literature.

## Strength of the Evidence

For purposes of grading the strength of the evidence, the key question addressed by the systematic review was deconstructed into four separate analysis questions, each addressing a different dimension of the key question. These four questions addressed separately the risks associated with the use of epinephrine in anesthetic solutions and the risk associated with the use of epinephrine in gingival retraction cord; and these two uses of epinephrine were addressed separately for two different populations, hypertensives taking medication to control their blood pressure, and uncontrolled hypertensives with elevated blood pressure. We rated the strength of the evidence as 'poor'for each of these four questions. For three of the questions, use of gingival retraction cord containing epinephrine in controlled and in uncontrolled hypertensives, and the use of epinephrine in local anesthetic solutions in controlled hypertensives, this 'poor' rating results from the number of available studies. One study examined outcomes of the administration of local anesthetic solutions containing epinephrine to patients taking medications for the control of hypertension comprising 14 subjects and two medications. Two other studies included patients taking antihypertensive medications, but outcomes were not reported separately. There were no studies describing outcomes of the use of gingival retraction cord either for hypertensive patients, or for those taking medications for the control of hypertension.

There were five studies addressing the fourth question, outcomes of the use of epinephrine-containing anesthetic solutions in hypertensive patients. These studies included 311 subjects, 163 of whom were hypertensive. The mean quality score for the studies was 54, the median was 58. These aspects of the available evidence meet the criteria for a strength rating of 'fair.' However, the strength of the evidence must be rated as 'poor' because the outcomes considered in these five studies do not represent a reasonably complete assessment of risk indicators. In essence, only changes in blood pressure and heart rate received scrutiny in all five studies, and the comprehensiveness of these assessments was quite varied. Only one study specifically noted the presence or absence of patient-reported side effects. Two studies monitored single-lead EKGs for the detection of arrhythmias. One study used two-lead EKG for analysis of sympathetic and parasympathetic activity. No other outcomes were assessed. Among the blood pressure and heart rate monitoring methods, three studies collected initial epinephrine exposure readings 5 minutes postinjection, and the remaining two collected initial readings at 2 minutes and @@@frac12@@@ minute postinjection, respectively. Thus, transient effects in principal outcomes might have remained undetected in three of five studies.

## Limitations of the Evidence Base

Three principal limitations of the database are clearly 1) the incomplete nature of the evidence describing the effects of intraoral local anesthetics among uncontrolled hypertensives 2) the lack of studies describing the effects of intraoral injection with local anesthetics containing epinephrine on hypertensive subjects taking medications for the control of hypertension, and 3) the lack of studies regarding the effects of epinephrine-impregnated gingival retraction cord in uncontrolled and controlled hypertensive subjects.

Available studies of the use of epinephrine-containing local anesthetics in dental treatment for hypertensive patients are limited due to the narrow range of outcomes examined and the incomplete nature of the assessments within the narrow range of outcomes. While changes in systolic and diastolic blood pressure and heart rate were evaluated, the studies generally failed to assess other important outcomes that may indicate increased cardiovascular risk such as stroke volume, plasma epinephrine concentration, and disturbances in cardiac activity indicative of arrhythmias or transient ischemia. Due to the complex interaction of factors that determine hemodynamic outcomes, potentially adverse cardiovascular system responses to epinephrine contained in local anesthesia solutions may not be detectable through discontinuous recording of blood pressures and heart rate. Discontinuous recording such as that used in most of the studies included in the review may also mask transient changes in these basic outcomes that mark heightened risk.

Our inability to include more than one study examining the effect of epinephrine-containing local anesthetic solutions among controlled hypertensives is also a serious limitation of the evidence base. Hypertensive medications are among the most commonly prescribed medication groups and, among the types of medications prescribed, at least two pose the potential for adverse outcomes. Interaction of nonselective beta blockers and epinephrine can lead to reduction in cardiac output through alpha receptor-induced elevation in blood pressure with concomitant compensatory vagal reflex-mediated reduction in heart rate.^45^ As shown in the study included in the review, when epinephrine is used in patients taking nonpotassium-sparing diuretics, potassium levels can decrease.^3^ Because studies performed in the dental environment of patients taking these medications have not been reported, knowledge of outcomes and possible adverse events must necessarily be inferred from other studies in other environments.

Although we found no studies that examine the effects of epinephrine-impregnated gingival retraction cord in hypertensive subjects, several studies have reported the effect of retraction cord in normotensive subjects.^25,27-30^ In general, mean effects on blood pressure and heart rate were minimal. However, only one of these studies measured plasma epinephrine concentrations, and this study did not evaluate the effect of lacerations in gingival tissue, which are assumed to be associated with increased uptake of epinephrine.^30^ Better quantitative knowledge of plasma concentrations of epinephrine resulting from use of impregnated cord in healthy, lacerated, and inflamed gingival tissue, together with knowledge of associations between plasma concentrations and length of exposure, would be useful in improving our understanding of the possible risks to hypertensive subjects without necessitating extensive trials among this population.

An additional consideration with respect to limitations of the database may reflect more on the restrictions imposed by the key question. Part of the reason for caution in administering epinephrine to patients with hypertension lies in the fact that in middle-aged and older patients, the presence of hypertension increases the likelihood that other cardiovascular disease may also be present, which in turn reduces the resiliency of the system to challenges imposed by exogenous epinephrine. This review did not include studies of patients with cardiovascular disease unless a specific diagnosis of hypertension was included in the description for all subjects of at least one arm of the study. Several of the studies listed in Table 9 examine the effects of epinephrine on patients with other forms of cardiovascular disease. As a general observation, few patients in the included studies were identified as having the cardiac pathology described in the excluded studies.

Only four of the studies identified the range of anesthetic dosages that subjects received, and no dose-response analyses were reported. Dosages were all between 2 and 4.5 ml, or less than three full capsules. This information does not permit any extrapolation to higher doses, which might be attempted to extend time or depth of anesthesia. Thus, the only information available describing the effects of epinephrine administration on hypertensives covers only the most conservative dosing strategy.

Two final limitations of the evidence base are the relatively small number of hypertensive subjects included in the reviewed studies, and the tendency for studies to aggregate individual patient data, often without reporting any measure of variability, let alone assessment of outliers. As suggested by the results of these studies as well as by the paucity of reports of specific adverse outcomes, such adverse outcomes of dental anesthesia among hypertensive patients are uncommon events. Thus detecting changes in indicators that may signal heightened risk for adverse outcomes requires observations of large numbers of subjects and careful evaluation of variability among the observations.