# Methodology

This chapter describes the procedures that the Research Triangle Institute/University of North Carolina Evidence-based Practice Center (RTI/UNC EPC) used to develop this systematic review describing research involving the effect of epinephrine contained in local anesthetics and gingival retraction cord on hypertensive individuals receiving dental treatment. To set the context for the review, we first present the key question and its underlying causal pathway. Then, a detailed description of the literature search process is presented, followed by descriptions of our inclusion and exclusion criteria, our application of those criteria to the articles identified in the search, the rating of the individual studies surviving the review process, and the preparation of evidence tables.

## Key Question and Causal Pathway

The key question for this review focuses on whether there are added risks for adverse effects posed by the hemodynamic effects of the epinephrine found in local anesthetics and in gingival retraction cord among hypertensive individuals receiving dental treatment. The key question is stated as: What additional risks of adverse cardiovascular outcomes do epinephrine-containing anesthetic solutions and epinephrine-impregnated retraction cords represent for controlled and uncontrolled hypertensive individuals receiving dental treatment?

The causal pathway (Figure 1) illustrates the context of the question in the dental practice environment. Epinephrine is used in anesthetic solutions to decrease local blood flow, thereby lengthening the duration and deepening the anesthetic effect while possibly lessening the risk of systemic toxicity due to circulating anesthetic solution. Epinephrine is used in gingival retraction cord to minimize gingival bleeding that can result from tooth preparation, and to cause the free gingiva to shrink away from the tooth surface, which facilitates securing an accurate impression of the prepared tooth. Epinephrine may pose an increased risk of adverse cardiovascular outcomes to individuals with hypertension both through the direct action of epinephrine on cardiovascular physiology (Q1_a_), and through its action on the altered physiology created by various medications prescribed for hypertension control (Q1_b_). Because hypertension is often a marker for other cardiac disease, risk also may be elevated due to decreased ability of the heart to compensate for epinephrine-induced change. Finally, the cardiovascular effects of epinephrine may be enhanced by aspects of the dental environment itself, which may increase plasma concentrations of catecholamines.

Figure 1. Causal Pathway

## Literature Search

Two separate literature searches were conducted for the evidence report, one for local anesthetic solutions and one for gingival retraction cord. In both instances MEDLINE was searched initially, with additional searching conducted in EMBASE and the Cochrane Controlled Trials Register. No attempt was made to search the gray literature, i.e., dissertations, theses, unpublished studies, abstracts, industry reports, and other nontraditional sources. This decision was based on resource limitations and on previous experience at the RTI/UNC EPC indicating that such searches were generally unproductive.

Tables 1 and 2 show the MeSH terms used for searching MEDLINE, the principal databases for both searches, as well as the results of these searches. The searches were run in March 2001. The search terms do not reflect the entirety of the inclusion and exclusion criteria developed for the questions (see next section) as indexing tended to be unreliable and nonspecific through the 1980s, when much of the literature of interest was reported. Only at the broadest level could the search be limited, namely to human studies reported in English. For anesthetic solutions, all papers with keywords associated with local anesthesia and with either epinephrine or hypertension keywords were initially identified. For retraction cords an equally broad strategy was employed, identifying all reports with keywords for hypertension or epinephrine and for various permutations of the term "gingival retraction cord."

Table 1. Strategy and Results of MEDLINE Local Anesthetic Solutions Search

| Search Term | n of Titles
1 | exp anesthesia, dental/ or exp anesthetic, local/ of exp anesthesia local/ | 57,798
2 | exp dentistry/ | 209,852
3 | 1 and 2 | 7,927
4 | exp hypertension/ or exp antihypertensive agents/ or exp epinephrine/ or adrenaline.mp. | 330,034
5 | 3 and 4 | 467
6 | limit 5 to (human and English language) | 280

Table 2. Strategy and Results of MEDLINE Gingival Retraction Cord Search

| Search Term | n of Titles
1 | exp dental impression technique/ or gingival retraction cord.mp | 3,729
2 | gingival retraction.mp or retraction cord.mp | 120
3 | 1 or 2 | 3,781
4 | exp hypertension/ | 145,115
5 | exp antihypertensive agents/ | 148,483
6 | exp epinephrine/ | 88,257
7 | adrenaline.mp. | 11,720
8 | 5 or 6 or 7 | 221,274
9 | 4 and 8 | 36,355
10 | 3 and 9 | 1
11 | 3 and 8 | 40
12 | 10 or 11 | 40
13 | limit 12 to (human and English language) | 29

Tables 3 and 4 show the results of similar searches in EMBASE, using the same search strategy, with more general terms substituted where necessary. All studies not duplicated in the previous MEDLINE search are shown on the last line of these tables. Finally, searches of the Cochrane Controlled Trials Register identified no additional studies.

Table 3. Strategy and Results of EMBASE Local Anesthetic Solutions Search

| Search Term | n of Titles
1 | exp dental anesthesia/ | 403
2 | exp anesthesia/ or exp anesthesia complication/ or exp local anesthesia/ or anesthesia.mp. | 84,939
3 | exp anesthetic agent/ | 71,622
4 | 2 or 3 | 126,776
5 | exp dentistry/ or exp preventive dentistry/ or exp reparative dentistry/ | 6,915
6 | 4 and 5 | 247
7 | 1 or 6 | 623
8 | exp adrenalin/ or epinephrine.mp. | 38,772
9 | exp hypertension/ | 125,294
10 | 8 or 9 | 161,852
11 | 7 and 10 | 99
12 | limit 11 to human and English language | 91
13 | unduplicated in MEDLINE | 80

Table 4. Strategy and Results of EMBASE Gingival Retraction Cord Search

| Search Term | n of Titles
1 | exp reparative dentistry/ | 1,485
2 | cord.mp. | 55,899
3 | 1 and 2 | 7
4 | exp hypertension/ or exp antihypertensive agents/ or exp epinephrine/ or exp adrenaline/ | 221,114
5 | 3 and 4 | 0

A supplemental search strategy involved perusal of the reference listings of studies identified in the searches. This strategy identified two types of additional studies, those published prior to 1966, the earliest date for inclusion of dental studies in MEDLINE, and studies with incorrect or incomplete index terms. This supplementation was fruitful in that two of the studies included in the evidence table were identified in this manner.

## Inclusion and Exclusion Criteria

Table 5 shows the inclusion and exclusion criteria applied to the articles identified in the searches. Essentially identical criteria were used in both reviews, including the inclusion and separate analysis of known hypertensive subjects, exposure to known concentrations of epinephrine, receipt of epinephrine-containing local anesthetic via either intraoral submucosal block or infiltration injection or receipt of epinephrine-impregnated gingival retraction cord, recording of at least one cardiovascular or hemodynamic outcome, and a dental setting with dental treatment provided. Given the nature of the key question, the requirements for hypertensive subjects, epinephrine, and cardiovascular/hemodynamic outcomes are obvious. We accepted a variety of hemodynamic and cardiovascular outcomes due to the broad wording of the key question regarding risk indicators for adverse outcomes. We considered risk indicators to include changes in blood pressure, heart rate, and stroke volume, and plasma epinephrine concentration, and EKG disturbances including transient arrhythmias. We included reports of headache, syncope, angina, hypertensive crisis, longer-term arrhythmia, cerebrovascular accident, and myocardial infarction as adverse events. We imposed the requirement that studies be conducted in a dental environment while dental treatment was provided to ensure that the results of the studies, and hence the review, would have external validity. Because receipt of dental injections and subsequent dental treatment result in increased plasma concentrations of catecholamines in some individuals that may mimic or heighten the effects of exogenous epinephrine,^7^ it is important that this environment be duplicated in studies of epinephrine's effects if the key question is to be addressed directly. Finally, studies reporting on fewer than five hypertensive subjects were excluded to minimize bias resulting from case selection. Such case reports were identified and considered separately in the analysis.

Table 5. Inclusion and Exclusion Criteria

Inclusion criteria
1. | Hypertensive group identified by medical history or blood pressure criteria, all members in group are hypertensive
2. | Results reported separately for hypertensive group
3 | At a minimum, one hemodynamic parameter recorded pre- and post-injection or pre- and post-placement
4. | Intraoral local anesthesia delivered by block or infiltration, or gingival retraction cord applied to gingival sulcus around a minimum of one tooth
5. | Local anesthesia or gingival retraction cord contains epinephrine in known amount
6. | Study conducted in dental environment, including provision of dental procedure
7 | Minimum of five hypertensive subjects in report.
| Exclusion criteria
1. | No confirmation of hypertension status for each member of the hypertension group

## Review of Identified Papers

We performed initial surveys of the titles of the articles included in both searches, identifying those articles for which the title indicated some possibility that the study was relevant and might satisfy the inclusion criteria. These surveys were performed independently by the Clinical and Research Directors of the dental component of the EPC, with all titles identified by either placed on the potentially eligible list. Forty-four percent of articles placed on the local anesthetic list were selected by both Directors, with 27 percent and 29 percent identified by the Clinical and Research Director, respectively. For gingival retraction cord, the percentages were 40 percent by both, and 40 percent and 20 percent by the Clinical and Research Director, respectively.

We then reviewed the abstract and, if needed, the full paper for all articles surviving the title review to develop a refined list of potentially eligible articles. From this refined list, a final review was independently performed by the two Directors to determine eligibility. The agreement between Directors was 100 percent for the final include/exclude decisions for all articles for both reviews. All included articles were identified in the initial survey of titles by both Directors.

Table 6 shows the numbers of articles remaining after each stage in the review process. The final numbers of papers included in the reviews were six and none, respectively, for anesthetic solutions and retraction cord. Reasons for exclusion for the 16 local anesthetic and 6 retraction cord papers excluded in the final review are shown in Tables 7 and 8.

Table 7. Local Anesthetic Articles Excluded in Final Review

Article | Reason for exclusion
Salman and Schwartz, 1955^9^ | no separate analysis of subjects receiving epinephrine
Elliott and Stein, 1974^10^ | hypertensive subjects not analyzed separately
Meiller, 1983^11^ | no indication that epinephrine used in anesthetic
Yoshimura, 1983^12^ | three hypertensive subjects
Hasse et al., 1986^13^ | hypertensive subjects not analyzed separately
Hirota et el., 1986^14^ | two hypertensive subjects
Salonen et al., 1988^15^ | no hypertensive subjects in sample
Vanderheyden et al., 1989^16^ | hypertensive subjects not analyzed separately
Davenport et al., 1990^17^ | hypertensive subjects not analyzed separately
Meechan and Rawlins, 1992^18^ | subjects not identified as hypertensive
Leviner et al., 1992^19^ | no hypertensive subjects identified
Findler et al., 1993^20^ | no epinephrine used
Campbell and Langston, 1995^21^ | hypertensive subjects not analyzed separately
Nichols, 1997^22^ | subjects receiving local anesthetic not analyzed separately
Blinder et al., 1998^23^ | incomplete data for both hypertensive subjects
Niwa et al., 2000^24^ | no dental treatment, no intraoral injection

Table 8. Retraction Cord Articles Excluded in Final Review

Article | Reason for exclusion
Phatak and Lang, 1966^25^ | no hypertensive subjects
Fritz et al., 1970^26^ | no hypertensive subjects
Houston et al., 1970^27^ | no hypertensive subjects
Munoz, 1970^28^ | no hypertensive subjects
Pelzner et al., 1978^29^ | no hypertensive subjects
Hatch et al., 1984^30^ | no hypertensive subjects

Table 6. Search Refinement Results

| Local Anesthetic Solution | Gingival Retraction Cord
Step Acquisition
initial MEDLINE Search | 280 | 29
initial EMBASE search (nonduplicates) | 80 | 0
initial Cochrane Registry search | 0 | 0
review of reference sections | 12 | 4
total articles for review | 372 | 33
Initial Screening for Inclusion
surviving title review | 78 | 12
surviving initial abstract/full paper review | 22 | 6
Final Review for Inclusion
surviving final review | 6 | 0

## Development of the Evidence Table

The evidence table was designed to report the most salient elements of the included studies while remaining manageable in terms of size and complexity. The table was completed by direct abstraction from the included articles without the use of abstraction forms. The research director performed the abstraction, and the Clinical Director reviewed the tables against the individual studies. All discrepancies were resolved by consensus.

The evidence table reports a quality rating for each included article. This rating was developed specifically for the review, but the approach reflects that used in all ratings developed by the RTI/UNC EPC.^8^ A set of quality items was specified that assessed several elements of internal and external validity, including sample size, presence of a comparison group of normotensive subjects, use of control groups (without epinephrine), outcomes reported, measurement methods, statistical testing, determination of hypertensive status, and reporting issues (Table 9). Item weighting was determined empirically, again with reference to assessment instruments previously developed by the EPC. A total of 20 points were available for 13 items, with partial scores possible for multipoint items. Raw scores were rescaled to a 0 to 100 scale. The included studies were assessed by a single rater using a standardized form. The resultant scores were not used as a part of the inclusion/exclusion decision. Rather they represented one of the considerations for grading the available evidence.

Table 9. Quality Rating Form

Study design - non-epinephrine control group(s):
2 | control groups used
0 | no control groups, only epinephrine groups
Study design - normotensive control group(s):
2 | comparison of hypertensive and normal patients
0 | hypertensive only
Sample size:
3 | >50 per group
2 | 20-49 per group
1 | 10-19 per group
0 | <10 per group
Quantity of anesthetic solution used:
1 | quantity noted
0 | quantity not reported
Measures included:
2 | blood pressure, heart rate, and electrocardiogram
1 | blood pressure and heart rate
0 | blood pressure or heart rate
Measurement frequency
2 | continuous pre-injection to post-procedure (max 1 min intervals)
1 | continuous pre-injection to post-procedure (max 5 min intervals)
0 | discontinuous or incomplete intervals
Measurement reliability:
1 | measurement reliability reported
0 | no reliability reported
Statistical testing
2 | between group and versus baseline for all time points
1 | between group or versus baseline for all time points
0 | no statistical testing reported
Determination of hypertensive status
1 | baseline blood pressure criteria or medication status
0 | medical history or other
Description of hypertensive treatment
1 | hypertensive taking medications identified in analysis
0 | no analysis by medication group
Reporting - variation:
1 | variation indicated
0 | no indication of variation
Reporting - results:
1 | tabular presentation of summary values
0 | figures only, all values interpolated
Reporting - complications and adverse outcomes
1 | complications and adverse outcomes described, or notation of none
0 | no mention of complications or adverse outcomes

## Grading the Evidence

The strength of the assembled evidence was graded in terms of the extent to which it answered the key question; that is, the extent to which it identified and quantified any additional risks for hypertensive patients from exposure to epinephrine in dental practice. Three rating categories were possible:

- Good: the numbers of studies and subjects are large (10 or more studies, 500 or more subjects); the quality of the studies is generally high (median 70 or higher); the results of these studies are consistent; and, when taken together, the results are comprehensive with respect to risks examined.
- Fair: the numbers of studies and subjects are adequate overall (5 or more studies, 200 or more subjects); the quality of the studies is generally acceptable (median 55 or higher); the results of these studies are reasonably consistent, with inconsistencies reflected as quantitative rather than qualitative differences; and the principal known risks are adequately examined.
- Poor: the numbers of studies and/or subjects are small (fewer than 5 studies or 200 subjects); or the quality of the studies is generally low (median below 55); or there are substantial inconsistencies in the results or the risks examined among the studies do not represent a reasonably complete assessment of known risks.

The grading criteria are subjective, and they reflect the general approach to grading the evidence used by all EPCs. The evidence was graded independently by the Research and Clinical Directors. Separate grades were assigned to the evidence addressing the use of epinephrine in local anesthesia and gingival retraction cord in uncontrolled and controlled hypertensives. If it had been necessary, agreement on a grade would be achieved by discussion leading to consensus. No discussion was necessary as the Directors' grades were identical for all applications.