# Introduction

Epinephrine, a catecholamine also known as adrenaline, is produced naturally in the body by the adrenal medulla and is important in regulating a variety of bodily functions, particularly during stressful situations. Heightened secretion of epinephrine caused by stress, fear, or anxiety contributes to the reaction popularly referred to as the "fight or flight response." In preparing the body for extreme physical exertion, epinephrine acts on two types of adrenergic receptors, alpha and beta. When alpha receptors are stimulated, the result is an increase in peripheral vasoconstriction with an accompanying increase in blood pressure and a possible vagal-mediated reflex slowing of the heart rate. The increased venous blood return to the heart tends to increase cardiac output. When beta 1 receptors are stimulated, myocardial contractility and heart rate increase, and cardiac output is further augmented. Although stimulation of beta 2 receptors produces vasodilatation that tends to lower blood pressure, it increases blood flow to vital areas such as skeletal muscles to assist in the "fight or flight" response. Therefore the net result of epinephrine during stressful events is to shunt blood away from vasoconstricted subcutaneous and gastrointestinal tract blood vessels and toward vasodilated blood vessels in the skeletal muscles where it is most needed. These vascular effects are further augmented by both the increased cardiac activity resulting from epinephrine's effects on beta receptors and by the beta 2 receptor bronchodilating effects of epinephrine, which facilitate oxygenation of blood during this period of heightened oxygen utilization and carbon dioxide production.

Epinephrine is used medically as a stimulant in cardiovascular collapse and cardiac arrest, as a vasoconstrictor and physiologic antagonist in acute allergic reactions, as a bronchodilator and antispasmodic in bronchial asthma, and to lower intra-ocular pressure in the treatment of glaucoma. In very small amounts, epinephrine is also used as an additive in local anesthetics to improve the depth and extend the duration of the anesthesia, as well as to reduce bleeding in the operative field. Epinephrine counteracts the anesthetic's localized vasodilator effects in subcutaneous and submucosal vessels, thereby reducing the risk of anesthetic toxicity by decreasing the rate of systemic absorption from the site of injection. Despite these benefits, which are important in many dental applications of local anesthetics, the clinical significance of cardiovascular and hemodynamic changes caused by the introduction of exogenous epinephrine makes its inclusion in local anesthetic solutions a controversial subject in dentistry.

Lidocaine is the most widely used dental anesthetic in the United States and is used most frequently with epinephrine 1:100,000 because of the advantages conferred by the combination. Lidocaine is also available without epinephrine, but anesthesia, when achieved, lasts for only a short time, 5 to 15 minutes. Alternative anesthetics available without epinephrine (mepivacaine, prilocaine) are also short acting. Longer duration for these local anesthetics requires the addition of a vasoconstrictor.

Another application of epinephrine in dentistry is in gingival retraction materials. Epinephrine is impregnated in cotton cord that is inserted into the sulcus between a tooth and the surrounding gingiva to separate them. This increased space allows dental impression material to flow more readily into the sulcus to record details of teeth prepared for crowns. The epinephrine will also constrict the blood supply to adjacent tissue, thereby permitting the impression to be secured without contamination by bleeding.

The question addressed by this systematic review is whether there is evidence of added risk of adverse events posed by the hemodynamic and cardiovascular effects of epinephrine when it is used in the dental treatment of hypertensive individuals. Data from the National Health and Nutrition Examination Survey (NHANES) III study indicate that 24 percent of the U.S. adult population is hypertensive, defined as a patient either having a resting systolic blood pressure of 140 mm Hg or greater or a diastolic blood pressure of 90 mm Hg or greater, or taking prescription antihypertensive medication. Of this hypertensive population, 48 percent are untreated, 24 percent are successfully treated, and 28 percent are inadequately treated.^1^ Thus, hypertensive individuals will represent a substantial proportion of a typical dental practice's adult patients.

The added risks attributed to the use of epinephrine in hypertensive patients accrue from several distinct mechanisms.^2^ In patients not taking antihypertensive medication, epinephrine can increase pre-existing elevated systolic blood pressure. Such an increase can possibly cause an acute hypertensive crisis, leading to hypertensive encephalopathy, cerebral hemorrhage, and acute left ventricular failure. Because longstanding hypertension can lead to cardiac hypertrophy and atherosclerotic changes in arteries, angina pectoris and myocardial infarction, as well as cardiac arrthymias, are also more likely if the heart cannot compensate satisfactorily for blood pressure and heart rate changes caused by epinephrine. Beta blockers are often used as first-line antihypertensive medications. Some of these beta blockers selectively reduce the receptivity of beta 1 receptors, thereby limiting the effects of epinephrine on the heart rate and force of contraction. However, nonselective beta blockers also block beta 2 receptors, eliminating epinephrine's vasodilatation action while leaving the alpha receptor-mediated vasoconstrictor activity of epinephrine intact. This unopposed vasoconstriction of epinephrine may result in a hypertensive crisis. Finally, hypertensive patients taking nonpotassium-sparing diuretics and calcium channel-blocker medications who are administered epinephrine may experience hypokalemia, which can lead to arrhythmias.^3^

Recommendations for the use of epinephrine in clinical dental practice are not in full agreement. Most recommendations advise caution in using local anesthetics with epinephrine in hypertensive patients. Some indicate that epinephrine is contraindicated in controlled hypertensive patients taking medications with known epinephrine interactions,^4^ and some indicate that epinephrine use is acceptable with appropriate precautions and monitoring.^5^ Opinion about the use of epinephrine in uncontrolled hypertensives is also divided, with some cautioning against it^6^ and some indicating that it is appropriate in most instances.^2^ Virtually all recommendations discourage the use of gingival retraction cord in uncontrolled hypertensives, including those of manufacturers.