# Appendix C. Selection and Tasks of Peer Reviewers

Not including representatives of government agencies, we selected three organizations to contact to request that they suggest persons to serve as peer reviewers. In addition, the three members of the TEAG were asked to serve as peer reviewers because they played a major role throughout the project in conceptualizing the work and reviewing materials. We contacted all potential peer reviewers to determine their willingness to serve as peer reviewers, alerting them to the fact that this service would require them to prepare formal written reviews according to a checklist developed for this systematic review. Their comments and suggestions will form the basis of our revisions to the draft evidence report.

An important first step in the identification of potential peer reviewers for this systematic review was to determine the appropriate constituencies from which our reviewers should be drawn. We decided to include a representative of a dental education specialty professional organization involved with dental anesthesia (American Dental Education Association). We also chose to include a representative of patients and the public at large from the American Heart Association. Finally, we selected a representative from among dental trade associations and manufacturers (nominated by the Dental Manufacturers Association). The selection of representatives from government agencies rests with AHRQ and its National Institute of Dental and Craniofacial Research (NIDCR) collaborators. Clearly the sponsoring agencies as well as other government agencies providing dental services to a variety of populations are an important constituency, too. We believe that these categories represent a reasonable range of dental care experts, users, and patient groups to be involved in reviewing this report on the cardiovascular effects of epinephrine in hypertensive dental patients.

## Peer Reviewers

- Dr. Stanley F. Malamed
- University of Southern CaliforniaSchool of DentistrySection of Anesthesia and Medicine925 West 34th StreetLos Angeles, California 90089-0641

- Dr. Joel M. Weaver
- The Ohio State UniversityCollege of DentistryDepartment of Oral and Maxillofacial Surgery305 West 12th AvenueColumbus, OH 43210-1241

- Dr. John A. Yagiela
- University of California at Los AngelesSchool of DentistryDivision of Diagnostic and Surgical SciencesThe Center of Health SciencesLos Angeles, CA 90095-1668

- Dr. Alberto Nasjletti
- New York Medical CollegeDepartment of PharmacologyRm. 507 Basic Science BuildingValhalla, NY 10595(Represents the American Heart Association)

- Dr. Ralph Green
- President, Zila Biomedical5227 N 7th StreetPhoenix AZ 85014602-266-6700rgreen@zila.com(Represents the Dental Manufacturers Association)

- Gary E. Jeffers
- University of Detroit MercySchool of Dentistry8200 W. Outer DriveDetroit, MI 48219(Represents the American Dental Education Association)

## Government Peer Reviewers

- Dr. Jay R. Anderson
- Chief Dental Officer4350 East West Highway, 7th FloorBethesda, MD 20814(Represents Health Resources and Services Administration)

- Dr. Eric Broderick
- Principal Dental ConsultantDHHS/HIS/HQE5600 Fishers Lane, Room 6A-30Rockville, MD 20857(Represents Indian Health Service)

- Dr. C. Richard Buchanan
- Department of Veterans AffairsOffice of Dentistry (112D)810 Vermont AvenueN.W., Washington, DC 20420

- Elizabeth Clark
- Policy Analyst5600 Fishers LaneRockville, MD 20857(Represents Food and Drug Administration)

- Dr. William G. Kohn
- Associate Director for ScienceDivision of Oral Health/NCCDPHPCenters for Disease Control and Prevention4770 Buford Highway, Mailstop F-10Atlanta, GA 30341

- Dr. Isabel Garcia
- National Institute of Dental and Craniofacial Research45 Center DriveBuilding 45, Room 4AS, 19EBethesda, MD 20892

- Dr. John Eisenberg †
  † Deceased
- DirectorAgency for Healthcare Research and QualityExecutive Office Center2101 E. JeffersonRoom 600Rockville, MD 20852