# Appendix B. Selection and Role of the Technical Expert Advisory Group

We gratefully acknowledge the involvement of and assistance from the three members of our Technical Expert Advisory Group (TEAG). TEAG members are listed at the end of this Appendix. The TEAG was meant in part to contribute to (a) advancing AHRQ's broader goals of creating and maintaining "science partnerships" and "public-private partnerships" and (b) meeting the needs of a broad array of potential consumers and users of its products. Thus, it was both a substantive resource and a sounding board during the study. The TEAG is the body from whom "expert inputs" were formally sought at several points through the project.

We constituted our TEAG from two types of technical experts. These types are (1) technical/clinical experts and (2) potential users of the systematic review, including explicitly a representative of the primary dental professional organization in the U.S. -- the American Dental Association (A.D.A).

The final decision about TEAG membership was based on the candidates' availability for scheduled conference calls and other input, willingness to review materials and provide advice and assistance within a short turnaround time, and approval by the AHRQ TO Officer.

The RTI-UNC team solicited the views of TEAG members from the start of this systematic review. Among other issues, TEAG members provided insights and reactions to the key clinical question, input to the literature review process by ensuring that we included all known published research meeting our inclusion criteria, and reviewed a preliminary draft of this review.

In keeping with AHRQ's standards for employing a multidisciplinary approach to the development of systematic reviews, we called on our TEAG for inputs at two key points during this task. First, the group was asked to comment on the literature search and to give us feedback on our overall plans at that stage of the analysis, which included our approach to summarizing and synthesizing the evidence about cardiovascular outcomes associated with the use of epinephrine in the management of dental patients who are hypertensive. Second, they were asked to review the draft evidence report for completeness, correctness, and clarity.

## TEAG Members

- Stanley Frederick Malamed, D.D.S.
- University of Southern CaliforniaSchool of DentistrySection of Anesthesia and Medicine925 West 34th StreetLos Angeles, California 90089-0641

- Joel Milton Weaver, II, D.D.S., Ph.D.
- The Ohio State UniversityCollege of DentistryDepartment of Oral and Maxillofacial Surgery305 West 12th AvenueColumbus, Ohio 43218-2357(Representing the American Dental Association)

- John Allen Yagiela, D.D.S., Ph.D.
- University of California at Los AngelesSchool of DentistryDivision of Diagnostic and Surgical SciencesThe Center for Health SciencesLos Angeles, California 90095