# Appendix A. Acknowledgements

This study was supported by Contract No. 290-97-0011 Task Number 6 from the Agency for Healthcare Research and Quality (AHRQ), formerly the Agency for Health Care Policy and Research (AHCPR). We acknowledge the assistance of Jacqueline Besteman, J.D., M.A., the AHRQ Task Order Officer for the Evidence-based Practice Center Program; and Ernestine (Tina) Murray, R.N., M.A.S., the AHRQ Task Order Officer for this task. The cooperation and support of Isabel Garcia, D.D.S., M.P.H., the National Institute of Dental and Craniofacial Research (NIDCR) liaison with AHRQ, has been greatly appreciated. In addition, the investigators appreciate the time and assistance of Ms. Terri Kissiah, Ms. Carrie Roseamelia, and Mr. Christian Evensen of RTI, and Dr. Lynn Whitener of UNC.