# Appendixes

Appendix A. Acknowledgements

Appendix B. Selection and Role of the Technical Expert Advisory Group

Appendix C. Selection and Tasks of Peer Reviewers