# References

1 Lohr KN, Carey TS. Assessing 'best evidence': issues in grading the quality of studies for systematic reviews. Joint Commission J Qual Improvement. 1999;25:470-479.
2 Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282:1054-1060. [pmid: 10493204].
3 Barnes DE, Bero LA. Why review articles on the health effects of passive smoking reach different conclusions. JAMA. 1998;279:1566-1570. [pmid: 9605902].
4 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-1278. [pmid: 1834807].
5 Oxman AD, Guyatt GH, Singer J, et al. Agreement among reviewers of review articles. J Clin Epidemiol. 1991;44:91-98. [pmid: 1824710].
6 Irwig L, Tosteson AN, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. 1994 Apr 15;120:667-676.
7 Sacks HS, Reitman D, Pagano D, Kupelnick B. Meta-analysis: an update. Mt Sinai J Med. 1996;63:216-224. [pmid: 8692168].
8 Auperin A, Pignon JP, Poynard T. Review article: critical review of meta-analyses of randomized clinical trials in hepatogastroenterology. Alimentary Pharmacol Ther. 1997;11:215-225.
9 Beck CT. Use of meta-analysis as a teaching strategy in nursing research courses. J Nurs Educ. 1997;36:87-90. [pmid: 9029423].
10 Smith AF. An analysis of review articles published in four anaesthesia journals. Can J Anaesth. 1997;44:405-409. [pmid: 9104524].
11 Clarke M., Oxman AD. Cochrane Reviewer's Handbook 4.0. The Cochrane Collaboration. 1999.
12 Khan KS, Ter Riet G, Glanville J, Sowden AJ, Kleijnen J. Undertaking Systematic Reviews of Research on Effectiveness. CRD's Guidance for Carrying Out or Commissioning Reviews: York, England: University of York, NHS Centre for Reviews and Dissemination. 2000. [pmcid: 384376].
13 New Zealand Guidelines Group. Tools for Guideline Development & Evaluation. Accessed July 10, 2000. Web Page. Available at: http://www.nzgg.org.nz/.
14 Harbour R, Miller J. A new system [Scottish Intercollegiate Guidelines Network (SIGN)] for grading recommendations in evidence based guidelines. BMJ. 2001;323:334-336. [pmid: 11498496].
15 Oxman AD, Cook DJ, Guyatt GH. Users' guides to the medical literature. VI. How to use an overview. Evidence-Based Medicine Working Group. JAMA. 1994;272:1367-1371. [pmid: 7933399].
16 Cook DJ, Sackett DL, Spitzer WO. Methodologic guidelines for systematic reviews of randomized control trials in health care from the Potsdam Consultation on Meta-Analysis. J Clin Epidemiol. 1995;48:167-171. [pmid: 7853043].
17 Cranney A, Tugwell P, Shea B, Wells G. Implications of OMERACT outcomes in arthritis and osteoporosis for Cochrane metaanalysis. J Rheumatol. 1997;24:1206-1207. [pmid: 9195536].
18 de Vet HCW, de Bie RA, van der Heijden GJMG, Verhagen AP, Sijpkes P, Kipschild PG Systematic reviews on the basis of methodological criteria Physiotherapy June 1997 83(6):284 289
19 Pogue J, Yusuf S. Overcoming the limitations of current meta-analysis of randomised controlled trials. Lancet. 1998;351:47-52. [pmid: 9433436].
20 Sutton AJ, Abrams KR, Jones DR, Sheldon TA, Song F. Systematic reviews of trials and other studies. Health Technol Assess. 1998;2:1-276.
21 Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354:1896-1900. [pmid: 10584742].
22 How to Use the Evidence: Assessment and Application of Scientific Evidence. Canberra, Australia: NHMRC. 2000. [pmcid: 384376].
23 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. 2000;283:2008-2012. [pmid: 10789670].
24 Chalmers TC, Smith H Jr, Blackburn B, et al. A method for assessing the quality of a randomized control trial. Control Clin Trials. 1981;2:31-49. [pmid: 7261638].
25 Evans M, Pollock AV. A score system for evaluating random control clinical trials of prophylaxis of abdominal surgical wound infection. Br J Surg. 1985;72:256-260. [pmid: 3986472].
26 Liberati A, Himel HN, Chalmers TC. A quality assessment of randomized control trials of primary treatment of breast cancer. J Clin Oncol. 1986;4:942-951. [pmid: 3711962].
27 Colditz GA, Miller JN, Mosteller F. How study design affects outcomes in comparisons of therapy. I: Medical. Stat Med. 1989;8:441-454.
28 Gotzsche PC. Methodology and overt and hidden bias in reports of 196 double-blind trials of nonsteroidal antiinflammatory drugs in rheumatoid arthritis. Control Clin Trials. 1989;10:31-56. [pmid: 2702836].
29 Kleijnen J, Knipschild P, ter Riet G. Clinical trials of homoeopathy. BMJ. 1991;302:316-323. [pmid: 1825800]. [pmcid: 1668980].
30 Detsky AS, Naylor CD, O'Rourke K, McGeer AJ, L'Abbe KA. Incorporating variations in the quality of individual randomized trials into meta-analysis. J Clin Epidemiol. 1992;45:255-265. [pmid: 1569422].
31 Cho MK, Bero LA. Instruments for assessing the quality of drug studies published in the medical literature. JAMA. 1994;272:101-104. [pmid: 8015115].
32 Goodman SN, Berlin J, Fletcher SW, Fletcher RH. Manuscript quality before and after peer review and editing at Annals of Internal Medicine. Ann Intern Med. 1994;121:11-21. [pmid: 8198342].
33 Fahey T, Hyde C, Milne R, Thorogood M. The type and quality of randomized controlled trials (RCTs) published in UK public health journals. J Public Health Med. 1995;17:469-474. [pmid: 8639349].
34 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
35 Khan KS, Daya S, Collins JA, Walter SD. Empirical evidence of bias in infertility research: overestimation of treatment effect in crossover trials using pregnancy as the outcome measure. Fertil Steril. 1996;65:939-945. [pmid: 8612853].
36 van der Heijden GJ, van der Windt DA, Kleijnen J, Koes BW, Bouter LM. Steroid injections for shoulder disorders: a systematic review of randomized clinical trials. Brit J Gen Pract. 1996;46:309-316. [pmid: 8762750]. [pmcid: 1239642].
37 Bender JS, Halpern SH, Thangaroopan M, Jadad AR, Ohlsson A. Quality and retrieval of obstetrical anaesthesia randomized controlled trials. Can J Anaesth. 1997;44:14-18. [pmid: 8988818].
38 Sindhu F, Carpenter L, Seers K. Development of a tool to rate the quality assessment of randomized controlled trials using a Delphi technique. J Adv Nurs. 1997;25:1262-1268. [pmid: 9181425].
39 van Tulder MW, Koes BW, Bouter LM. Conservative treatment of acute and chronic nonspecific low back pain. A systematic review of randomized controlled trials of the most common interventions. Spine. 1997;22:2128-2156. [pmid: 9322325].
40 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-384. [pmid: 9764259].
41 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-613. [pmid: 9746022].
42 Turlik MA, Kushner D. Levels of evidence of articles in podiatric medical journals. J Am Podiatr Med Assoc. 2000;90:300-302. [pmid: 10881461].
43 DerSimonian R, Charette LJ, McPeek B, Mosteller F. Reporting on methods in clinical trials. N Engl J Med. 1982;306:1332-1337. [pmid: 7070458].
44 Poynard T, Naveau S, Chaput JC. Methodological quality of randomized clinical trials in treatment of portal hypertension. In Methodology and Reviews of Clinical Trials in Portal Hypertension. Excerpta Medica. 1987:306-311.
45 Reisch JS, Tyson JE, Mize SG. Aid to the evaluation of therapeutic studies. Pediatrics. 1989;84:815-827. [pmid: 2797977].
46 Imperiale TF, McCullough AJ. Do corticosteroids reduce mortality from alcoholic hepatitis? A meta-analysis of the randomized trials. Ann Intern Med. 1990;113:299-307. [pmid: 2142869].
47 Spitzer WO, Lawrence V, Dales R, et al. Links between passive smoking and disease: a best-evidence synthesis. A report of the Working Group on Passive Smoking. Clin Invest Med. 1990;13:17-42. discussion. 43. 46. [pmid: 2138069].
48 Verhagen AP, de Vet HC, de Bie RA, et al. The Delphi list: a criteria list for quality assessment of randomized clinical trials for conducting systematic reviews developed by Delphi consensus. J Clin Epidemiol. 1998;51:1235-1241. [pmid: 10086815].
49 National Health and Medical Research Council (NHMRC). How to Review the Evidence: Systematic Identification and Review of the Scientific Literature. Canberra, Australia : NHMRC. 2000. [pmcid: 384376].
50 Zaza S, Wright-De Aguero LK, Briss PA, et al. Data collection instrument and procedure for systematic reviews in the Guide to Community Preventive Services. Task Force on Community Preventive Services. Am J Prev Med. 2000;18:44-74. [pmid: 10806979].
51 Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-412. [pmid: 7823387].
52 Prendiville W, Elbourne D, Chalmers I. The effects of routine oxytocic administration in the management of the third stage of labour: an overview of the evidence from controlled trials. Br J Obstet Gynaecol. 1988;95:3-16. [pmid: 3277663].
53 Guyatt GH, Sackett DL, Cook DJ. Users' guides to the medical literature. II. How to use an article about therapy or prevention. B. What were the results and will they help me in caring for my patients? Evidence-Based Medicine Working Group. JAMA. 1994;271:59-63. [pmid: 8258890].
54 Guyatt GH, Sackett DL, Cook DJ. Users' guides to the medical literature. II. How to use an article about therapy or prevention. A. Are the results of the study valid? Evidence-Based Medicine Working Group. JAMA. 1993;270:2598-2601. [pmid: 8230645].
55 The Standards of Reporting Trials Group. A proposal for structured reporting of randomized controlled trials. JAMA. 1994;272:1926-1931. [pmid: 7990245].
56 The Asilomar Working Group on Recommendations for Reporting of Clinical Trials in the Biomedical Literature. Checklist of information for inclusion in reports of clinical trials. Ann Intern Med. 1996;124:741-743. [pmid: 8633835].
57 Moher D, Schulz KF, Altman DG, for the CONSORT Group The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomised trials Lancet 2001 357(9263)1191 1194 11323066
58 Aronson N, Seidenfeld J, Samson DJ, et al. Relative Effectiveness and Cost-Effectiveness of Methods of Androgen Suppression in the Treatment of Advanced Prostate Cancer. Evidence Report/Technology Assessment No. 4. Rockville, Md.: Agency for Health Care Policy and Research. AHCPR Publication No.99-E0012. 1999.
59 Lau J, Ioannidis J, Balk E, et al. Evaluating Technologies for Identifying Acute Cardiac Ischemia in Emergency Departments: Evidence Report/Technology Assessment: No. 26. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 01-E006 (Contract 290-97-0019 to the New England Medical Center). 2000.
60 Chestnut RM, Carney N, Maynard H, Patterson P, Mann NC, Helfand M. Rehabilitation for Traumatic Brain Injury. Evidence Report/Technology Assessment No. 2. Rockville, Md.: Agency for Health Care Policy and Research. AHCPR Publication No. 99-E006. 1999.
61 Jadad AR, Boyle M, Cunningham C, Kim M, Schachar R. Treatment of Attention-Deficit/Hyperactivity Disorder. Evidence Report/Technology Assessment No. 11. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 00-E005. 1999.
62 Heidenreich PA, McDonald KM, Hastie T, et al. An Evaluation of Beta-Blockers, Calcium Antagonists, Nitrates, and Alternative Therapies for Stable Angina. Rockville, MD: Agency for Healthcare Research and Quality. AHRQ Publication No. 00-E003. 1999.
63 Mulrow CD, Williams JW, Trivedi M, Chiquette E, Aguilar C, Cornell JE. Treatment of Depression: Newer Pharmacotherapies. Evidence Report/Technology Assessment No. 7. Rockville, Md.: Agency for Health Care Policy and Research. AHRQ Publication No. 00-E003. 1999.
64 Vickrey BG, Shekelle P, Morton S, Clark K, Pathak M, Kamberg C. Prevention and Management of Urinary Tract Infections in Paralyzed Persons. Evidence Report/Technology Assessment No. 6. Rockville, Md.: Agency for Health Care Policy and Research. AHCPR Publication No. 99-E008. 1999.
65 West SL, Garbutt JC, Carey TS, et al. Pharmacotherapy for Alcohol Dependence. Evidence Report/Technology Assessment No. 5. Rockville, Md.: Agency for Health Care Policy and Research. AHCPR Publication No. 99-E004. 1999.
66 McNamara RL, Miller MR, Segal JB, et al. Management of New Onset Atrial Fibrillation. Evidence Report/Technology Assessement No.12. Rockville, Md.: Agency for Health Care Policy and Research; AHRQ Publication No. 01-E026. 2001.
67 Ross S, Eston R, Chopra S, French J. Management of Newly Diagnosed Patients With Epilepsy: A Systematic Review of the Literature. Evidence Report/Technology Assessment No. 39. Rockville, Md: Agency for Healthcare Research and Quality. AHRQ Publication No. 01-E-029. 2001.
68 Goudas L, Carr DB, Bloch R, et al. Management of Cancer Pain. Evidence Report/Technology Assessment. No. 35. (Contract 290-97-0019 to the New England Medical Center). Rockville, Md.: Agency for Health Care Policy and Research. AHCPR Publication No. 99-E004. 2000.
69 Corrao G, Bagnardi V, Zambon A, Arico S. Exploring the dose-response relationship between alcohol consumption and the risk of several alcohol-related conditions: a meta-analysis. Addiction. 1999;94:1551-1573. [pmid: 10790907].
70 Ariens GA, van Mechelen W, Bongers PM, Bouter LM, van der Wal G. Physical risk factors for neck pain. Scand J Work, Environ Health. 2000;26:7-19. [pmid: 10744172].
71 Carruthers SG, Larochelle P, Haynes RB, Petrasovits A, Schiffrin EL. Report of the Canadian Hypertension Society Consensus Conference: 1. Introduction. Can Med Assoc J. 1993;149:289-293. [pmid: 8339174]. [pmcid: 1485500].
72 Laupacis A, Wells G, Richardson WS, Tugwell P. Users' guides to the medical literature. V. How to use an article about prognosis. Evidence-Based Medicine Working Group. JAMA. 1994;272:234-237. [pmid: 8022043].
73 Levine M, Walter S, Lee H, Haines T, Holbrook A, Moyer V. Users' guides to the medical literature. IV. How to use an article about harm. Evidence-Based Medicine Working Group. JAMA. 1994;271:1615-1619. [pmid: 8182815].
74 Angelillo IF, Villari P. Residential exposure to electromagnetic fields and childhood leukaemia: a meta-analysis. Bulletin of the World Health Organization. 1999;77:906-915. [pmid: 10612886].
75 Sheps SB, Schechter MT. The assessment of diagnostic tests. A survey of current medical research. JAMA. 1984;252:2418-2422. [pmid: 6481928].
76 Arroll B, Schechter MT, Sheps SB. The assessment of diagnostic tests: a comparison of medical literature in 1982 and 1985. J Gen Intern Med. 1988;3:443-447. [pmid: 3049967].
77 Recommended Methods. 1996.
78 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-1066. [pmid: 10493205].
79 McCrory DC, Matchar DB, Bastian L, et al. Evaluation of Cervical Cytology. Rockville, Md.: Agency for Health Care Policy and Research. AHCPR Publication No.99-E010. 1999. [pmcid: 325679].
80 Ross SD, Allen IE, Harrison KJ, Kvasz M, Connelly J, Sheinhait IA. Systematic Review of the Literature Regarding the Diagnosis of Sleep Apnea. Rockville, Md.:Agency for Health Care Policy and Research. 1999. [pmcid: 325679].
81 Gyorkos TW, Tannenbaum TN, Abrahamowicz M, et al An approach to the development of practice guidelines for community health interventions Can J Public Health. Revue Canadienne De Sante Publique 1994 85Suppl 1:S8 13
82 Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services -- methods. The Task Force on Community Preventive Services. Am J Prev Med. 2000;18:35-43. [pmid: 10806978].
83 Greer N, Mosser G, Logan G, Halaas GW. A practical approach to evidence grading. Joint Commission J Qual Improv. 2000;26:700-712.
84 Guyatt GH, Haynes RB, Jaeschke RZ, et al. Users' Guides to the Medical Literature: XXV. Evidence-based medicine: principles for applying the Users' Guides to patient care. Evidence- Based Medicine Working Group. JAMA. 2000;284:1290-1296. [pmid: 10979117].
85 Levels of Evidence. Accessed January 12, 2001. Web Page. Available at: http://cebm.jr2.ox.ac.uk.
86 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20:21-35.
87 How to read clinical journals: IV. To determine etiology or causation. Can Med Assoc J. 1981;124:985-990. [pmid: 7260801]. [pmcid: 1705401].
88 Guyatt GH, Cook DJ, Sackett DL, Eckman M, Pauker S. Grades of recommendation for antithrombotic agents. Chest. 1998;114:441S-444S. [pmid: 9822056].
89 Guyatt GH, Sackett DL, Sinclair JC, Hayward R, Cook DJ, Cook RJ. Users' guides to the medical literature. IX. A method for grading health care recommendations. Evidence-Based Medicine Working Group. JAMA. 1995;274:1800-1804. [pmid: 7500513].
90 Hoogendoorn WE, van Poppel MN, Bongers PM, Koes BW, Bouter LM. Physical load during work and leisure time as risk factors for back pain. Scand J Work, Environ Health. 1999;25:387-403. [pmid: 10569458].
91 Sackett DL, Straus SE, Richardson WS, et al. Evidence-Based Medicine: How to Practice and Teach EBM. London: Churchill Livingstone. 2000. [pmcid: 384376].
92 Lohr KN. Grading Articles and Evidence: Issues and Options. Final Guidance Paper. Final report submitted to the Agency for Health Care Policy and Research for Contract No. 290-97-0011, Task 2. Research Triangle Park, N.C.: Research Triangle Institute; 1998.
93 Cook DJ, Mulrow CD, Haynes RB. Systematic reviews: synthesis of best evidence for clinical decisions. Ann Intern Med. 1997;126:376-380. [pmid: 9054282].
94 Mulrow CD. The medical review article: state of the science. Ann Intern Med. 1987;106:485-488. [pmid: 3813259].
95 Clark HD, Wells GA, Huet C, et al. Assessing the quality of randomized trials: reliability of the Jadad scale. Control Clin Trials. 1999;20:448-452. [pmid: 10503804].
96 Hemminki E. Quality of reports of clinical trials submitted by the drug industry to the Finnish and Swedish control authorities. Eur J Clin Pharmacol. 1981;19:157-165. [pmid: 7215412].
97 Khan KS, Daya S, Jadad A. The importance of quality of primary studies in producing unbiased systematic reviews. Arch Intern Med. 1996;156:661-666. [pmid: 8629879].
98 Field MJ, Lohr KN, eds. Guidelines for Clinical Practice: From Development to Use. Institute of Medicine. Washington, D.C.: National Academy Press; 1992.
99 Lohr KN, Aaronson NK, Burnam MA, Patrick DL, Perrin EB, Roberts JS. Evaluating quality-of-life and health status instruments: development of scientific review criteria. Clin Ther. 1996;18:979-991. [pmid: 8930436].
100 Last JM. A Dictionary of Epidemiology. New York: Oxford University Press; 1995.
101 Moher D, Jadad A, Tugwell P. Assessing the quality of randomized controlled trials. Int J Technol Assess Health Care. 1996;12:195-208. [pmid: 8707495].
102 Olkin I. Statistical and theoretical considerations in meta-analysis. J Clin Epidemiol. 1995;48:133-147. [pmid: 7853039].
103 Tritchler D. Modelling study quality in meta-analysis. Stat Med. 1999;18:2135-2145. [pmid: 10441769].
104 Greenland S. Invited commentary: a critical look at some popular meta-analytic methods. Am J Epidemiol. 1994;140:290-296. [pmid: 8030632].
105 Chalmers TC, Celano P, Sacks HS, Smith HJ. Bias in treatment assignment in controlled clinical trials. N Engl J Med. 1983;309:1358-1361. [pmid: 6633598].
106 Kunz R, Oxman AD. The unpredictability paradox: review of empirical comparisons of randomised and non-randomised clinical trials. BMJ. 1998;317:1185-1190. [pmcid: 28700]. [pmid: 9794851].
107 Moher D, Jadad AR, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. 1995;16:62-73. [pmid: 7743790].
108 Fox JP, Hall CE, Elveback LR. Epidemiology; Man and Disease. New York: Macmillan; 1970.
109 Hill AB. The environment and disease: Association or causation?. Proc R Soc Med. 1965;58.
110 Stelfox HT, Chua G, O'Rourke K, Detsky AS. Conflict of interest in the debate over calcium-channel antagonists. N Engl J Med. 1998;338:101-106. [pmid: 9420342].
111 Hoffman RM, Kent DL, Deyo RA. Diagnostic accuracy and clinical utility of thermography for lumbar radiculopathy. A meta-analysis. Spine. 1991;16:623-628.
112 Canadian Task Force on the Periodic Health Examination. The periodic health examination. Can Med Assoc J. 1979;121:1193-1254. [pmid: 115569]. [pmcid: 1704686].
113 Sackett DL. Rules of evidence and clinical recommendations on the use of antithrombotic agents. Chest. 1989;95:2S-4S. [pmid: 2914516].
114 Cook DJ, Guyatt GH, Laupacis A, Sackett DL. Rules of evidence and clinical recommendations on the use of antithrombotic agents. Chest. 1992;102:305S-311S. [pmid: 1395818].
115 Ogilvie RI, Burgess ED, Cusson JR, Feldman RD, Leiter LA, Myers MG. Report of the Canadian Hypertension Society Consensus Conference: 3. Pharmacologic treatment of essential hypertension. Can Med Assoc J. 1993;149:575-584. [pmid: 8364814]. [pmcid: 1485999].
116 Evans WK, Newman T, Graham I, et al. Lung cancer practice guidelines: lessons learned and issues addressed by the Ontario Lung Cancer Disease Site Group. J Clin Oncol. 1997;15:3049-3059. [pmid: 9294467].
117 Granados A, Jonsson E, Banta HD, et al. EUR-ASSESS Project Subgroup Report on Dissemination and Impact. Int J Technol Assess Health Care. 1997;13:220-286. [pmid: 9194353].
118 Bartlett JG, Breiman RF, Mandell LA, File TMJ. Community-acquired pneumonia in adults: guidelines for management. The Infectious Diseases Society of America. Clin Infect Dis. 1998;26:811-838. [pmid: 9564457].
119 Bril V, Allenby K, Midroni G, O'Connor PW, Vajsar J. IGIV in neurology -- evidence and recommendations. Can J Neurol Sci. 1999;26:139-152. [pmid: 10352875].
120 Working Party for Guidelines for the Management of Heavy Menstrual Bleeding. An evidence-based guideline for the management of heavy menstrual bleeding. N Z Med J. 1999;112:174-177. [pmid: 10391640].
121 Shekelle PG, Woolf SH, Eccles M, Grimshaw J. Clinical guidelines: developing guidelines. BMJ. 1999;318:593-596. [pmid: 10037645]. [pmcid: 1115034].
122 Guide to Clinical Preventive Services, 2nd Ed. Alexandria, Va.: International Medical Publishing, Inc.; 1996.
123 Gross PA, Barrett TL, Dellinger EP, et al. Purpose of quality standards for infectious diseases. Infectious Diseases Society of America. Clin Infect Dis. 1994;18.
124 Gray JAM. Evidence-Based Healthcare. London: Churchill Livingstone;1997.
125 Djulbegovic B, Hadley T. Evaluating the quality of clinical guidelines. Linking decisions to medical evidence. Oncology. 1998 Nov;12:310-314. [pmid: 10028514].
126 Edwards AG, Russell IT, Stott NC. Signal versus noise in the evidence base for medicine: an alternative to hierarchies of evidence?. Fam Pract. 1998;15:319-322. [pmid: 9792346].
127 Chesson ALJ, Wise M, Davila D, et al. Practice parameters for the treatment of restless legs syndrome and periodic limb movement disorder. An American Academy of Sleep Medicine Report. Standards of Practice Committee of the American Academy of Sleep Medicine. Sleep. 1999;22:961-968. [pmid: 10566915].
128 Wilkinson CP. Evidence-based medicine regarding the prevention of retinal detachment. Transactions Am Ophthalmol Society. 1999;97:397-406.
129 Garbutt JC, West SL, Carey TS, Lohr KN, Crews FT. Pharmacological treatment of alcohol dependence: a review of the evidence. JAMA. 1999;281:1318-1325. [pmid: 10208148].
130 Berlin JA, Rennie D. Measuring the quality of trials: the quality of quality scales. JAMA. 1999;282:1083-1085. [pmid: 10493209].
131 Herrington DM, Reboussin DM, Brosnihan KB, et al. Effects of estrogen replacement on the progression of coronary-artery atherosclerosis. N Engl J Med. 2000;343:522-529. [pmid: 10954759].
132 Angerer P, Stork S, Kothny W, Schmitt P, von Schacky C. Effect of oral postmenopausal hormone replacement on progression of atherosclerosis: a randomized, controlled trial. Arterioscler Thromb Vasc Biol. 2001;21:262-268. [pmid: 11156863].
133 Hulley S, Grady D, Bush T, et al. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998;280:605-613. [pmid: 9718051].
134 Veterans and Agent Orange. Washington, D.C.: National Academy Press; 1994.
135 Dans AL, Dans LF, Guyatt GH, Richard S. Users' guides to the medical literature: XIV. How to decide on the applicability of clinical trial results to your patient. JAMA. 1998;279:545-549. [pmid: 9480367].
136 Barratt A, Irwig L, Glasziou P, et al. Users' guides to the medical literature: XVII. How to use guidelines and recommendations about screening. Evidence-Based Medicine Working Group. JAMA. 1999;281:2029-2034. [pmid: 10359392].
137 Sacks HS, Berrier J, Reitman D, Anocaon-Berk VA, Chalmers TC. Meta-analyses of randomized controlled trials. N Engl J Med. 1987;316:450-455. [pmid: 3807986].
138 Victor N. "The challenge of meta-analysis":discussion. Indications and contra-indications for meta-analysis. J Clin Epidemiol. 1995;48:5-8. [pmid: 7853048].
139 Longnecker MP, Berlin JA, Orza MJ, Chalmers TC. A meta-analysis of alcohol consumption in relation to risk of breast cancer. JAMA. 1988;260:652-656. [pmid: 3392790].
140 Begg CB. Biases in the assessment of diagnostic tests. Stat Med. 1987;6:411-423. [pmid: 3114858].
141 Working group on methods for prognosis and decision making. Memorandum for the Evaluation of Diagnostic Measures. Journal of Clinical Chemistry and Clinical Biochemistry. 1990;28:873-879.
142 Pinson AG, Becker DM, Philbrick JT, Parekh JS. Technetium-99m-RBC venography in the diagnosis of deep venous thrombosis of the lower extremity: a systematic review of the literature. J Nucl Med. 1991;32:2324-2328. [pmid: 1836023].
143 Jaeschke R, Guyatt G, Sackett DL. Users' guides to the medical literature. III. How to use an article about a diagnostic test. A. Are the results of the study valid? Evidence-Based Medicine Working Group. JAMA. 1994;271:389-391. [pmid: 8283589].
144 Reid MC, Lachs MS, Feinstein AR. Use of methodological standards in diagnostic test research. Getting better but still not good. JAMA. 1995;274:645-651. [pmid: 7637146].
145 Bruns DE Reporting Diagnostic Accuracy Clinical Chemistry 1997 43(11):
146 Becker DM, Philbrick JT, Abbitt PL, Real-time ultrasonography for the diagnosis of lower extremity deep venous thrombosis. The wave of the future?. Arch Intern Med. 1989;149:1731-1734. [pmid: 2669660].
147 Levine C, Armstrong K, Chopra S, Estok R, Zhang S, Ross S. Diagnosis and Management of Breast Disease: A Systematic Review of the Literature. Rockville, Md.: Agency for Healthcare Research and Quality; 2000.
148 United States Surgeon General's Advisory Committee on Smoking and Health. Smoking and health: report of the advisory committee to the Surgeon General of the Public Health Service. Washington DC: U.S. Dept. of Health, Education, and Welfare, Public Health Service, U.S Government Printing Office; 1964.
149 Dickersin K, Scherer R, Lefebvre C. Identifying relevant studies for systematic reviews. BMJ. 1994;309:1286-1291. [pmid: 7718048].
150 Simes RJ. Publication bias: the case for an international registry of clinical trials. J Clin Oncol. 1986;4:1529-1541. [pmid: 3760920].
151 Easterbrook PJ, Berlin JA, Gopalan R, Matthews DR. Publication bias in clinical research. Lancet. 1991;337:867-872. [pmid: 1672966].
152 Jeng GT, Scott JR, Burmeister LF. A comparison of meta-analytic results using literature vs individual patient data. Paternal cell immunization for recurrent miscarriage. JAMA. 1995;274:830-836. [pmid: 7650808].
153 Moher D, Fortin P, Jadad AR, et al. Completeness of reporting of trials published in languages other than English: implications for conduct and reporting of systematic reviews. Lancet. 1996;347:363-366. [pmid: 8598702].
154 Moher D, Pham, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. 2000;53:964-972. [pmid: 11004423].
155 Vickers A, Goyal N, Harland R, Rees R. Do certain countries produce only positive results? A systematic review of controlled trials. Control Clin Trials. 1998;19:159-166. [pmid: 9551280].
156 Verhagen AP, de Vet HC, de Bie RA, Kessels AG, Boers M, Knipschild PG. Balneotherapy and quality assessment: interobserver reliability of the Maastricht criteria list and the need for blinded quality assessment. J Clin Epidemiol. 1998;51:335-341. [pmid: 9539890].
157 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350:185-186. [pmid: 9250191].
158 Emerson JD, Burdick E, Hoaglin DC, Mosteller F, Chalmers TC. An empirical study of the possible relation of treatment differences to quality scores in controlled randomized clinical trials. Controlled Clinical Trials. 1990;11:339-352. [pmid: 1963128].
159 Thompson SG. Why sources of heterogeneity in meta-analysis should be investigated. BMJ. 1994;309:1351-1355. [pmid: 7866085].
160 Chalmers TC, Matta RJ, Smith H Jr, Kunzler AM. Evidence favoring the use of anticoagulants in the hospital phase of acute myocardial infarction. N Engl J Med. 1977;297:1091-1096. [pmid: 909566].
161 Schulz KF, Chalmers I, Grimes DA, Altman DG. Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals. JAMA. 1994;272:125-128. [pmid: 8015122].
162 Grimes DA, Schulz KF. Methodology citations and the quality of randomized controlled trials in obstetrics and gynecology. American Journal of Obstetrics & Gynecology. 1996;174:1312-1315. [pmid: 8623862].
163 Chene G, Morlat P, Leport C, et al. Intention-to-treat vs. on-treatment analyses of clinical trial data: experience from a study of pyrimethamine in the primary prophylaxis of toxoplasmosis in HIV-infected patients. ANRS 005/ACTG 154 Trial Group. Control Clin Trials. 1998;19:233-248. [pmid: 9620807].
164 Lachin JM. Statistical considerations in the intent-to-treat principle. Control Clin Trials. 2000;21:167-189. [pmid: 10822117].
165 Djulbegovic B, Lacevic M, Cantor A, et al. The uncertainty principle and industry-sponsored research. Lancet. 2000;356:635-638. [pmid: 10968436].
166 Dong BJ, Hauck WW, Gambertoglio JG, et al. Bioequivalence of generic and brand-name levothyroxine products in the treatment of hypothyroidism. JAMA. 1997;277:1205-1213. [pmid: 9103344].
167 Rennie D. Thyroid storm. JAMA. 1997;277:1238-1243. [pmid: 9103350].
168 Cho MK, Bero LA. The quality of drug studies published in symposium proceedings. Ann Intern Med. 1996;124:485-489. [pmid: 8602706].
169 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342:1887-1892. [pmid: 10861325]. [pmcid: 1557642].
170 Barnes DE, Bero LA. Scientific quality of original research articles on environmental tobacco smoke. Tob Control. 1997;6:19-26. [pmid: 9176982].
171 Lachs MS, Nachamkin I, Edelstein PH, Goldman J, Feinstein AR, Schwartz JS. Spectrum bias in the evaluation of diagnostic tests: lessons from the rapid dipstick test for urinary tract infection. Ann Intern Med. 1992;117:135-140. [pmid: 1605428].