# Discussion

This chapter examines several discrete topics pertinent to the field of evidence-based practice and to efforts to develop rigorous reviews of the clinical and scientific knowledge on important health care issues. We first reflect on our data collection efforts for identifying the relevant literature because the challenges we encountered are instructive for others embarking on the development of systematic reviews and technology assessments. A second topic concerns how our results flow directly from how we conceptualized this project, giving due attention to the (perhaps conflicting) needs of policymakers, researchers, clinicians, and experts in evidence-based practice and to the implications of decisions about the empirical and epidemiologic analytic framework we used to structure our evaluations. Third, in earlier chapters we discussed our findings related to study quality independently of those for grading the strength of a body of evidence, and this strategy posed some issues that may influence our findings and conclusions. Finally, we offer our advice concerning directions for future research, noting that the challenges, gaps, and deficiencies in current rating or grading systems demand attention if the evidence-based practice field is to move forward with confidence and scientific rigor.

## Data Collection Challenges

As noted in previous chapters, we identified 1,602 articles, reports, and other materials from our literature searches, web searches, referrals from our technical expert advisory group, and suggestions from independent peer reviewers of an earlier version of this report, and from a previous project conducted by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center (EPC) on behalf of the Agency for Healthcare Research and Quality (AHRQ). In the end, our formal literature searches were the least productive source of systems for this report. Of the more than 120 systems we eventually reviewed that dealt with either quality of individual articles or strength of bodies of evidence, the searches per se generated a total of 30 systems that we could review, describe, and evaluate. Many articles from the search(es) related to study quality were essentially reports of primary studies or reviews that discussed "the quality of the data"; few addressed evaluating study quality itself.

We caution that those involved in evidence-based practice and research may not find it productive simply to search for quality rating schemes through standard (systematic) literature searches. This is one reason that we are comfortable with identifying (as in Chapter 3) a set of instruments or systems that meet reasonably rigorous standards for use in rating study quality. Little is to be gained by directing teams seeking to produce systematic reviews or technology assessments (or clinical practice guidelines) to initiate wholly new literatures searches in this area.

At the moment, we cannot provide concrete suggestions for how to search the literature on this topic most efficiently. Some advances must simply await expanded options for coding the peer-reviewed literature. Meanwhile, investigators wishing to build on our efforts might well consider tactics involving citation analysis and extensive contact with researchers and guideline developers to identify the systems they are presently using to assess the quality of studies in systematic reviews. In this regard, the efforts of at least some AHRQ-supported EPCs will be instructive.

Our literature search was most problematic for systems oriented toward grading the strength of a body of evidence. We found that the Medical Subject Headings (MeSH) terms were not very sensitive for identifying evidence grading systems. We attribute this phenomenon to the lag in development of MeSH terms specific for the evidence-based practice field.

To overcome this problem, we resorted to a text word search using "evidence," "strength," "rigor," "grading," and "ranking." This approach yielded nearly 700 articles, many of which reported the results of primary randomized controlled trials (RCTs). Our search yielded these articles because of a very common phrase: "no evidence that this treatment..." In other words, the trigger of the term "evidence" did not yield material concerned with grading the strength of a body of literature.

As a result, the systems we discussed in Chapter 3 (i.e., specifically those related to the entries in Grid 5 [Appendix C]) were identified primarily by reviewing the evidence grading schemes used by the authors of clinical guidelines and practice recommendations. Reliance on literature searches for finding instruments to assess bodies of evidence will likely prove disappointing, and we suggest that users, researchers, or policymakers wishing to explore this area today will need to rely on published materials cited in this report and contact with experts in the field for work in progress.

## Conceptualization of the Project

### Quality of Individual Articles

#### Types of Studies

We decided early on that comparing and contrasting study quality systems without differentiating among study types was likely to be less revealing or productive than assessing quality for systematic reviews, RCTs, observational studies, and studies of diagnostic tests individually. In the worst case, in fact, combining all such systems into a single evaluation framework risked nontrivial confusion and misleading conclusions, and we were not willing to take the chance that users of this report would conclude that "a single system" would suit all purposes. That is clearly not the case.

The scope of the project also dictated that we limit ourselves to the study designs most commonly encountered in clinical research. Other types of study designs do exist for which one might wish to evaluate study quality; among them are, for example, cost-effectiveness analysis and clinical prediction rules. However, the four designs we chose cover the vast majority of clinically relevant research and currently have a larger publication base from which to evaluate quality.

#### Domains and Elements Specific to Study Types

For these reasons, we developed separate assessments (as reflected in the grids in Appendix B and the tables in Chapter 3) to reflect this decision. Of necessity, each grid has its own set of domains for comparison. Grid 1 has 11 domains for evaluating the quality of systematic reviews, Grid 2 has 11 domains for RCTs, Grid 3 has nine domains for observational studies, and Grid 4 has five domains for studies evaluating diagnostic tests.

The domains for each type of study comprised one or more elements. Some were based directly on empirical results. As the literature highlighted in Appendix D shows, several empirical studies confirmed that bias can arise when certain design elements are not met. Thus, we considered these factors as critical elements for our study quality domains. Other domains or elements were based on best practices in the design and conduct of research studies. They are widely accepted methodologic standards, and investigators (especially for RCTs and observational studies) would probably be regarded as remiss if they did not observe them.

The important implication of these points is that, because we chose the critical domains on which to judge systems, our results and recommendations are directly and inextricably linked to our definition of these domains (i.e., our conceptualization of the project). We believe that selecting such domains on the basis, mostly, of empirical work and, secondarily, on the grounds of long-standing best practices in epidemiology and clinical research is sound. Nonetheless, we note that other evaluators might opt to focus on different domains and, thus, come to different evaluations and conclusions.

For this reason, we emphasize that the "full" information on our assessments of all types of systems for the different study designs can be found in the grids in Appendix B, and we draw attention to both parts of those grids. (The first part provides our assessment of the degree to which the system dealt with all domains; the second part gives important descriptive information.) The tables in Chapter 3 then distill this information to highlight, for scales and checklists, the extent to which they cover all domains and then, the extent to which they cover domains we identified as crucial. We then focus on those systems that do an acceptable job of covering this latter set of domains.

In selecting among alternative systems, potential users of such systems may elect to return to the full grids to find information that they regard as critical to their decisionmaking. We also emphasize that the scope of our work did not permit our own application or testing of these instruments. Thus, at the moment, we must advise that potential users of any approaches identified in this report ought to give direct consideration to feasibility and ease of use and likely applicability to their own particular projects or topics.

#### Types of Systems

Although the project is focused on issues related to study quality, we also contrasted the systems in Grids 1-4 on descriptive factors such as whether the system was a scale, checklist, or guidance document, how rigorously it was developed, whether instructions were provided for its use, and similar factors. This approach enabled us to home in on scales and checklists as the more likely methods for rating articles that might be adopted more or less as is.

In some cases, guidance documents contained similar content but had not been devised for evaluative applications. We noted that a few of the guidance documents could, with relatively minimal effort, be reconstructed into a scale or checklist. In so doing, however, we would recommend that developers carry out some reliability and validity testing, as the lack of such testing for the scales and checklists we reviewed is a major gap in this field that ought not be perpetuated.

### Strength of a Body of Evidence

Similarly, our grid concerning systems for grading the strength of bodies of evidence (Appendix C) is tied directly to our conceptual framework. As discussed in Chapter 2, we focused on three domains -- quality, quantity, and consistency -- because they combine important aspects of the collective design, conduct, and analysis of studies that address a given topic. Quality here links back to the summation of the quality of individual articles. Quantity involves the magnitude of the estimated (observed) effect, the potential statistical power of the body of knowledge as reflected in the aggregate sizes of studies (i.e., their sample sizes), and the sheer number of studies bearing on the clinical or technology question under consideration. The accepted wisdom is that, all other things equal, a larger effect is better because a good deal of bias would have to be present to invalidate the likelihood of an association. Finally, consistency reflects the extent to which the results of included studies tell the same story and comport with known facts about the natural history of disease. These are well-established variables for characterizing how confidently we can conclude that a body of knowledge provides information on which clinicians or policymakers can act.

We did not include generalizability as a separate domain because we believed that our definition of consistency needed to focus only on concepts appropriate to grading the strength of a body of evidence. (In the evidence-based practice community, this idea is sometimes rendered as grading the strength of separate linkages in a comprehensive analytic framework or causal pathway.) In our view, generalizability (as it has typically been used in the clinical practice guideline arena) addresses whether the findings, aggregated across multiple studies, are relevant to particular populations, settings of care, types of clinicians, or other factors.

As we approached the tasks in this project, with the legislative mandate and AHRQ's history in mind, we concluded that our study ought to stop short of advising on the development or implementation of practice guidelines per se. Had we incorporated generalizability into our evaluative framework (as some peer reviewers suggested), our results and recommendations concerning systems for grading the strength of a body of evidence might have been very different.

Furthermore, including generalizability as a domain would have increased the complexity of our evaluations and added to the burden of applying them. Moreover, generalizability can be addressed only in the context of the clinical or technology question at hand -- that is, to whom (e.g., patients, clinical specialties) or what settings is one interested in generalizing? In that sense, generalizability might be said to lie downstream of issues relating to study quality or strength of evidence, as we depicted in Figure 2. Finding generic grading systems that could deal clearly with different answers to that downstream question struck us as improbable, meaning that we might in the end have had fewer grading systems to suggest than we in fact identified in our results chapter.

## Study Quality

### Growth in Numbers of Systems

We identified at least three times as many scales and checklists for rating the quality of RCTs (n = 32) as we did for observational studies (n = 12), systematic reviews (n = 11), or diagnostic test studies (n = 6). We expect that ongoing methodological work addressing the quality of observational and diagnostic studies will over time affect both the number and the sophistication of these systems. Thus, our findings and conclusions with respect at least to observational and diagnostic studies may need to be readdressed once results from more methodological studies in these areas are available.

### Development of Systems Appropriate for Observational Studies

As indicated in Appendix D, some empirical research is related to the design, conduct, and analysis of systematic reviews, RCTs, and studies evaluating diagnostic tests; much less information is presently available about the factors influencing the quality of observational studies. Many systems that we evaluated for observational studies (Grid 3) were ones that we also evaluated for RCTs (Grid 2). Reviewing the systems that apply to both types of study designs led us to conclude that the likely original intent of several of these systems was to evaluate the quality of RCTs and that the developers added questions to address observational studies as well.

Thus, abstracting information from and assessing these "one size fits all" systems against the two sets of relevant domains proved difficult (especially for the observational study grid). We see this as additional support for the view that a "single system" across all study types will not likely be achieved and, in fact, might be counterproductive.

The absence of systems specific to observational studies may be explained in part by the complexities involved in observational study design (a fact that can be appreciated from the flow diagram offered in Figure 1). RCTs improve the comparability between study and control groups using randomization to allocate treatments (preferably double-blinded randomization), and trialists attempt to maintain comparability of these groups by avoiding differential attrition or assessment.

By contrast, an observational study by its very nature "observes" what happens to individuals. Thus, to prevent selection bias, the comparison groups in an observation study are supposed to be as similar as possible except for the factors under study. For investigators to derive a valid result from their observational studies, they must achieve this comparability between study groups (and, for some types of prospective studies, maintain it by minimizing differential attrition). Because of the difficulty in ensuring adequate comparability between study groups in an observational study -- both when the project is being designed or upon review after the work has been published -- we wonder whether nonmethodologically trained researchers can identify when potential selection bias or other biases more common with observational studies have occurred.

### Longer or Shorter Instruments

When comparing across all the quality rating scales and checklists that we evaluated, we noted that the older ones tended to be most inclusive for the quality domains we chose to assess.^24,45^ However, these systems also tended to be very long and potentially cumbersome to complete. As factors critical to good study design have been identified -- that is, the empirical criteria we invoked in our assessments -- we saw that the more recent systems are shorter and focus mainly on these empirical criteria for rating study quality.

Shorter instruments have the obvious advantage of brevity, and some data suggest that they will provide sufficient information on study quality. Jadad and colleagues reported that simply asking about three domains (randomization, blinding, and withdrawals [a form of attrition]) serves to differentiate between higher- and lower-quality RCTs that evaluate drug efficacy.^ 34 ^ However, the Jadad scale is not applicable to study designs other than RCTs of therapies, and it is not very useful for health services interventions where randomization or double blinding cannot occur. The Jadad team also omitted elements such as allocation concealment and use of intention-to-treat statistical analysis. We judged that these two elements have an empirical basis, but we acknowledge that the information supporting them has emerged since the publication of their scale.

The movement from longer, more inclusive instruments to shorter ones is a pattern observed throughout the health services research world for at least 25 years, particularly in areas relating to the assessment of health status and health-related quality of life. Thus, this model is not surprising in the field of evidence-based practice and measurement. However, the lesson to be drawn from efforts to derive shorter, but equivalently reliable and valid, instruments from longer ones (with proven reliability and validity) is that substantial empirical work is needed to ensure that the shorter forms operate as intended. More generally, we are not convinced that shorter instruments per se will always be better, unless demonstrated in future empirical studies.

### Reporting Guidelines

Several authors of the QUOROM and CONSORT statements served on our technical expert panel.^21,57^ They strongly emphasized that such reporting guidelines are not to be used for assessing the quality of either RCTs or systematic reviews, respectively. We believe this is an appropriate caution, and so we considered these consensus works only as guidance documents in our review.

We applaud these consensus guidelines for reporting RCTs and systematic reviews. If these guidelines are used (and they are currently required by certain journals) they will lead to better reporting and two downstream benefits. First, this may diminish the unavoidable tension (when assessing study quality) between the actual study design, conduct, and analysis and the reporting of these study characteristics. Second, if researchers follow these guidelines when designing their studies, they are likely to have better designed studies that will then be more transparent when published.

## Strength of a Body of Evidence

### Interaction Among Domains

Our comparison of systems for assessing the strength of a body of evidence uses three domains (Grid 5). We did not try to unravel the interrelationships among quality, quantity, and consistency for this project. As the body of literature grows, additional studies (i.e., quantity) increase the likelihood of a large range of quality scores and heterogeneity with respect to population settings, outcomes measured, and results. When these factors are similar across studies, consistency (and thus, strength of evidence) is enhanced. When they are not, this heterogeneity will reduce consistency and presumably detract from the overall strength of the evidence. Alternatively, heterogeneity may provide clues that indicate important treatment differences across subpopulations under study.^ 130 ^

### Conflict Among Domains When Bodies of Evidence Contain Different Types of Studies

Adding to the complexities of evaluating interactive domains for one type of study design is the challenge of evaluating a body of knowledge comprising observational and RCT data. As our peer reviewers pointed out, a contemporary case in point is the association between hormone replacement therapy (HRT) and cardiovascular risk.

Several observational studies, but only one large trial and two small RCTs, have examined the association between HRT and secondary prevention of cardiovascular disease for older women with preexisting heart disease.^131-133^ In terms of quality, much of the observational work is considered good and the RCTs are considered very good. In terms of quantity, both the numbers of reports and individuals evaluated in these reports are high for observational studies and modest for RCTs. Results are fairly consistent across the observational studies and across the RCTs, but between the two types of studies the results conflict. Observational studies show a treatment benefit. All three RCTs showed no evidence that hormone therapy was beneficial for women with established cardiovascular disease, and one RCT^ 133 ^ found an increased risk of coronary events during the first year of HRT use.

Most experts would agree that RCTs minimize an important potential bias in the observational studies, namely selection bias. However, experts also prefer more studies with larger aggregate samples and/or with samples that address more diverse patient populations and practice settings -- often the hallmark of observational studies. The inherent tension between these factors is clear. The lesson we draw is that a system for grading strength of evidence, in and of itself and no matter how good it is, may not completely resolve the tension. Users, practitioners, and policymakers may need to consider these issues in light of the broader clinical or policy questions they are trying to solve.

### Systems Related or Not Related to Development Of Clinical Practice Guidelines

Of the 34 non-EPC systems we evaluated for their performance in rating overall bodies of evidence, 23 addressed issues related to grading the strength of an evidence base for the development of clinical practice guidelines or treatment recommendations. The remaining 11 had not been derived directly from guideline development efforts per se. Interestingly, the first authors of all 11 of the non-guideline-derived systems are from outside the United States.^11,12,39,70,84,85,87,90,117,124,126^

Based on the results of this project, it appears that the only U.S. investigators who currently grade the strength of the evidence, apart from those developing clinical practice guidelines or practice-related recommendations, are those affiliated with AHRQ's EPCs. We believe a useful follow-on to the present study might be to evaluate more directly all the strength-of-evidence approaches now being used in guideline development as well as non-guideline development activities. Such an effort might well entail review of considerable collections of gray literature -- for example, from the professional society's technical bulletins -- rather than purely peer-reviewed publications.

### Emerging Uses of Grading Systems

Two of the 11 non-guideline-derived systems graded the strength of the evidence for a systematic review of risk factors for back and neck pain.^70,90^ Narrative and quantitative systematic reviews are typically done for therapies, preventive services, or diagnostic technologies -- that is, to amass data that will inform clinical practice or reimbursement and coverage (policy) decisions. Traditional reviews are common for disease risk factors or health-related behaviors; evidence-based systematic reviews would be a likely next step as we move towards a greater reliance on evidence-based products for clinical or policy decisionmaking. Nonetheless, we are intrigued with this novel use of evidence grading for a systematic review on risk factors; it may foretell broader applications for systems of assessing study quality and evidence strength than has been seen to this point. Whether domains covered by extant rating and grading systems would need to be modified to take account of the types of research done to clarify risk factors is a matter of speculation and future research.

An example from the gray literature indicates that grading the strength of the evidence apart from the development of guidelines had been occurring even before the two risk evaluation studies^70,90^ were published in the late 1990s. In 1994, the Institute of Medicine convened an expert panel to review the literature on the health effects of Agent Orange.^ 134 ^ This team developed their own categorization system for grading the strength of this body of literature that also incorporated quality, quantity, and consistency.

As Guyatt and colleagues point out in their users' guides, summarizing the literature on treatment effects can (1) assist clinicians in treating their patients,^53,135^ (2) help develop prevention strategies,^ 136 ^ (3) resolve issues arising from conflicting studies of disease risk factors,^ 90 ^ and (4) determine whether new treatments are worth their cost. Countries that have a national health service must identify ways to curb and prioritize health care spending, and many are turning to evidence-based practice to help them do so.

In the United States, we are beginning to see a rising emphasis on evidence-based practice and evidence-based policymaking. Like our foreign counterparts whose countries have national health plans, we may begin to see policymakers in public programs such as Medicare and Medicaid placing a greater reliance on systematic reviews -- and specifically systematic reviews that provide grades for the strength of evidence -- documenting the benefits (and harms) of preventive, diagnostic, and therapeutic interventions relevant to those beneficiary populations. The same may prove to be true for administrative leaders of integrated health systems and managed care organizations. Certainly, study quality and evidence grading will be important issues when comparisons need to be made of diagnostic or therapeutic options for a given disorder using cost-effectiveness methodologies.

## Limitations of the Research

Several limitations of the current research should be understood. The most important caveat is that the project team defined the quality and strength of the evidence domains for evaluation based on our review of the literature. We did so as objectively as possible and relied on well-respected work and the advice of our technical expert advisors. For our review of quality ratings, we included whatever quality domains the systems as a whole addressed, using as much detail as possible. However, our findings for all the grids are derived directly from our definitions and the way we structured this project.

Although our literature search was thorough and rigorous, it cannot be described as wholly systematic. Our two searches, one for identifying articles addressing study quality and the second for grading the strength of a body of evidence, dated from 1995 through June 2000. We searched only MEDLINE and restricted the articles to English language.

We did expand our search by viewing web sites known to contain publications prepared by groups from the United Kingdom, Canada, Australia, and New Zealand that focus on evidence-based medicine or guideline development. Moreover, our peer reviewers made suggestions for literature (e.g., on empirical bases for certain domains or for background and contextual materials) that had not surfaced as part of our formal literature searches. In addition, we did review several older articles that had been published as early as 1979. The more recent articles we identified as part of our literature search had cited the earlier publications as seminal pieces of work, and we would have been remiss in not including them in this project. All these additions, however, do make the formal data collection somewhat less "systematic" (but more comprehensive) than it might otherwise have been.

Finally, the time and resource constraints for this project led us to focus on generic study quality scales, checklists, and component systems. Although we included systems developed for narrow, specific clinical topics (e.g., pain; childhood leukemia; smoking-related diseases; drugs to treat alcohol dependence) that we encountered during the data collection phase, we did not actively seek them in our search. We see this gap as one that might profitably be filled by a second project to evaluate "specific" systems against the same types of criteria as applied here to "generic" instruments. Doing so would provide a more complete picture for potential users, investigators, or policymakers of the state of the science (and art) of rating the quality of articles and the strength of evidence today, and it will make clearer the contributions of those EPCs that have developed or adapted topic-specific approaches.

## Selecting Systems for Use Today: A "Best Practices" Orientation

### Rating Article Quality

In reviewing Grids 1-4 (Appendix B), we can see that many systems cover many of the domains that we considered generally informative for assessing study quality. However, we did not believe this range of information provided sufficient practical guidance for users who want to know, today, where to start. Thus, we condensed the information to identify systems that fully or at least partially addressed what we regarded as key domains, and these systems -- largely scales and checklists -- are the ones that appear in the tables of Chapter 3.

More specifically, we identified five systems for evaluating the quality of systematic reviews, eight for RCTs, six for observational studies, and three for studies of diagnostic tests (see Tables 14, 17, 19, and 21, respectively). Summing across these sets, we arrived at a total of 19 unduplicated systems that fully address our critical quality domains (with the exception of funding or sponsorship for several systems).^6-8,12,14,18,24,26,32,36,38,40,45,47,49,50,77,78^Three systems were used for both RCTs and observational studies.^14,40,45^

Based on this iterative analysis, we feel comfortable recommending that those who plan to incorporate study quality into a systematic review or evidence report can use one or more of these 19 systems as a starting point, being sure to take into account the types of study designs occurring in the articles under review and the key methodological issues specific to the topic under study. We caution that systems ostensibly intended to be used to rate the quality of both RCTs and observational studies -- what we refer to as "one size fits all" quality assessments -- may prove to be difficult to use and, in the end, may measure study quality less precisely than desired.

We encourage those who will be incorporating study quality into a systematic review to examine many different quality instruments to determine which items will best suit their needs. We acknowledge that the resulting instrument will not be developed according to rigorous standards, but it will encompass domains that are important for the topic under evaluation. Other considerations for the selection and development of study quality systems include the topic to be reviewed, the available time for completing the review (some systems seem rather complex to complete), and whether the preference is for a scale or a checklist.

### Rating Strength of Evidence

Systems for grading the strength of a body of evidence are much less uniform than those for rating study quality. This variability complicates the job of selecting one or more systems that might be put into use today. In addition, approaches for characterizing the strength of evidence seem to be getting longer or more complex with time. This trend stands in some contrast to that for systems related to assessing study quality, where the trend is for a reduction in the number of critical domains over time. This pattern may also reflect the fact that this effort is earlier on the development and diffusion curve.

Two other properties of these systems stand out. As discussed in Chapter 3, consistency has only recently become an integral part of the systems we reviewed in this area. We see this as a useful advance. Also continuing is the habit of using an older study design hierarchy to define study quality as an element of grading overall strength of evidence. As recently noted in methodologic work done for the U.S. Preventive Services Task Force, however, reliance on such a hierarchy without consideration of the domains we have discussed throughout this report is increasingly seen as unacceptable. We would expect, therefore, that systems for grading strength of bodies of evidence will increasingly call for quality rating approaches like those identified above.

Table 23 in Chapter 3 provides the seven systems that fully addressed all three domains for grading the strength of a body of evidence. The earliest system was published in 1994;^ 81 ^ the remaining systems were published in 1999^ 11 ^ and 2000,^82-84^ indicating that this is a rapidly evolving field.

As with the study quality systems, selecting among the evidence grading systems will depend on the reason for measuring evidence strength, the type of studies that are being summarized, and the structure of the review panel. Some systems appear to be rather cumbersome to use and may require sufficient staff, time, and financial resources. Again, for users, researchers, and policymakers uncertain about which among these seven might best suit their needs, we suggest also applying descriptive information from Grid 5B in the decisionmaking.

## Epc Systems

Although several EPCs used methods that met our criteria at least in part, these tended to be topic-specific applications (or modifications) of generic parent instruments. The same is generally true of efforts to grade the overall strength of evidence. For users interested in systems deliberately focused on a specific clinical condition or technology, we refer readers to the citations given earlier in this report.

## Recommendations for Future Research

More than 30 empirical studies address design elements for systematic reviews, RCTs, observational studies, and studies to assess diagnostic tests (Appendix D). As can be inferred from our discussion throughout this report, insufficient information is available for identifying design elements proven to be critical for trials and other investigations (although this is less true for RCTs). Thus, as a general proposition, the information base for understanding how best to rate the quality of such studies remains incomplete. Until this research gap is bridged, those wishing to produce authoritative systematic reviews or technology assessments will be somewhat hindered in this aspect of their work.

In addition, most of the empirical work on study design issues at present pertains to systematic reviews and RCTs. Thus, more empirical research should be targeted to identify and resolve issues relevant to the quality of observational studies. Some information may arise shortly from the Cochrane Non-Randomised Studies Methods Group, which is drafting guidelines for using nonrandomized studies in Cochrane reviews. Our technical advisors also noted the work of the STARD (STAndards for Reporting Diagnostic accuracy) group, which will be providing a guideline for reporting of diagnostic test studies in the very near future.

The importance of inter-rater reliability for producing defensible systematic reviews and technology assessments should not be underestimated, especially in circumstances in which several reviewers (who may or may not be methodologically trained, as contrasted with clinically trained) are contributing simultaneously to the review. Thus, another avenue for future research is to evaluate inter-rater reliability among the same and different quality systems as they may be applied for an evidence report or technology assessment of a given topic. This would be similar to the work done by Juni and colleagues, where they evaluated study quality using 25 different scales among publications addressing low molecular weight heparin and standard heparin post-surgery for prevention of deep vein thrombosis.^ 2 ^

Moreover, as implied above, rating study quality according to one of the "acceptable" systems that we have identified may be demonstrably easier and more reliable than grading strength of evidence according to systems examined for this project. For that reason, we emphasize the need for comparative work that uses several grading systems to evaluate the strength of the evidence on one topic as well as some reliability testing to determine whether several different reviews arrive at the same evidence grades.

We are encouraged that the U.S. Congress mandated this study from AHRQ in the first place. Nonetheless, our discussion in this chapter and earlier should make clear that a "one-shot" overview project could not and did not address all the significant issues in relating to methods or systems to assess health care research results.

We did not, for instance, give much attention to topic-specific approaches that may be somewhat more common in EPC work. In our judgment, one useful follow-up to the current project would assess whether the study quality grids that we developed are useful for discriminating among studies of varying quality -- that is, as another set of study-specific quality systems. If they are useful for differentiation, a likely next step is to refine and test the systems further using typical instrument development techniques. Further valuable work would be to test the study quality grids against the instruments we have called out as meeting our final evaluation criteria. To assist such work, we have included (Appendix F) a reproduction of the data extraction forms used in this study.

Many of these systems have been developed abroad, and it seems clear that much of the activity in this area rests outside the United States. As evidence-based practice activities take even stronger hold in this country, through development of evidence reports, technology assessments, and clinical practice or health policy guidelines, we believe a more in-depth comparison and contrast might be made of how this work is done here and elsewhere. In particular, we believe that U.S. investigators should make strong efforts to ascertain what advances are taking place in the international community in efforts to develop systems for assessing study quality and evidence strength and to determine where these are relevant to the U.S. scene.

We noted the more common uses for such rating schemes as being for studies of therapies, preventive services, and diagnostic technologies. Further applications should be tested. As already mentioned, use of such approaches in studies of disease risk factors is one area of potentially fruitful research. Another is the extent to which existing approaches can be applied to the types of studies used to evaluate purely screening tests (as contrasted with tests used primarily for diagnosis). Finally, a significant emerging area concerns the efficacy or effectiveness of counseling interventions (whether for preventive or therapeutic purposes); such studies are often far more complex, heterogeneous, or multi-faceted than typical RCTs or observational studies, and we are not at all certain that existing rating and grading methods will apply. Therefore, examining the utility of the systems identified in this report for these "less traditional" bodies of evidence will be important in the future.

Many experts in this field point to the appreciable lack of proven elements and domains in these types of assessment instruments. Perusal of the tables in Chapter 2 that define domains and elements will indicate the extent to which we needed to rely on accepted practices in health services, clinical, and epidemiological research to populate the criteria by which we evaluated systems. Thus, a key item for the research agenda lies simply in extending the empirical work on these systems. Such work would show what factors used in rating study quality, for example, actually make a difference in final scores for individual articles or a difference in how quality is judged for bodies of evidence as a whole. In addition, we discussed earlier the contrasts between short and long forms of these rating and grading systems. All other things equal, shorter will be better because of the reduced burden on evaluators. Nonetheless, some form of "psychometric testing" of shorter forms in terms of reliability, reproducibility, and validity needs to be done, either of the shortened instrument itself or against its parent instrument.

A broader concern is the need to clarify techniques to make systematic reviews and technology assessments more efficient and cost-effective. Although that is not directly a matter solely for rating study quality and evidence strength, the potential link is that better methods for those tasks might enable investigators and evidence-based practice experts to arrive more easily at reviews in which the nature and merit of the knowledge base is clear to all.

Finally, we encourage greater experimentation and collaboration between U.S. and international professionals in commissioning and conducting systematic reviews and technology assessments. The AHRQ EPC program, with one EPC in Canada, is a good start, and collaboration does exist between two AHRQ EPCs (at Research Triangle Institute-University of North Carolina and at Oregon Health Sciences University) and their work or the U.S. Preventive Services Task Force and the equivalent Task Force in Canada. Moreover, AHRQ EPCs do examine reviews from the Cochrane Collaboration review groups in amassing literature on given issues.

Nonetheless, having multiple groups around the globe commissioning exhaustive reviews on essentially the same clinical or technology topics has obvious inefficiencies. Collaboration on the refinement of quality rating and evidence strength grading systems is one appealing step toward decreasing duplication, and broader coordination of work in the evidence-based arena may be desirable. The issue of generalizability or applicability of the evidence will certainly arise, but the literature base will basically be the same for all but highly country-specific health interventions and technologies.

## Summary and Conclusion

To answer significant questions posed to AHRQ by the U.S. Congress, we reviewed more than 30 empirical studies to determine the critical domains for addressing study quality in each of four study designs: systematic reviews, RCTs, observational studies, and studies of diagnostic tests. Regardless of when this work was done, either recently or as long as 20 years ago, many investigators included most of the quality rating domains that we chose to assess.

We identified and reviewed, abstracted data from, and summarized more than 100 sources of information for the current study. Applying evaluative criteria based on key domains to the systems reported on in these articles, we identified 19 study quality and seven strength-of-evidence grading systems that those conducting narrative or quantitative systematic reviews and technology assessment can use as starting points. In making this information available to the Congress and disseminating information about these generic systems and the project as a whole more widely, AHRQ can meet the congressional expectations outlined at the outset of the report. The broader agenda to be met is for those producing systematic reviews and technology assessments to apply these rating and grading schemes in ways that can be made transparent for other groups developing clinical practice guidelines and other health-related policy advice. We have also offered a rich agenda for future research in this area, noting that the Congress can enable pursuit of this body of research through AHRQ and its EPC program. Thus, we are confident that the work and recommendations contained in this report will move the evidence-based practice field ahead in ways that will bring benefit to the entire health care system and the people it serves.