# Introduction

Throughout the 1990s and into the 21st century, the Agency for Healthcare Research and Quality (AHRQ, previously the Agency for Health Care Policy and Research [AHCPR]) has been the foremost federal agency providing research support and policy guidance in health services research. In this role, it gives particular emphasis to quality of care, clinical practice guidelines, and evidence-based practice. One special program has involved creating and funding a group of 12 Evidence-based Practice Centers (EPCs) in North America that specialize in producing systematic reviews (evidence reports and technology assessments) of the world's scientific and clinical literature and in enhancing the methods by which such work is done in a rigorous, yet efficient, manner. This report documents work done in 2000-2001 as part of the latter element of the Agency's mission -- namely, advancing the field's understanding of how best to ensure that systematic reviews are scientifically and clinically robust.

## Motivation for and Goals of the Present Study

In 1998, the Research Triangle Institute-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) prepared a report at the Agency's request to identify issues involved in assessing the quality of the published evidence.^1,92^ The aim then was to provide AHRQ with information that would help all 12 EPCs ensure that the strength of the knowledge base about a given EPC topic was properly and adequately reflected in their final evidence reports. Lohr and Carey (1999) focused on ways to assess the quality of individual studies in systematic reviews; they found that many checklists, scales, and other similar tools were available for rating the quality of studies and that these tools varied widely.^ 1 ^ They also reported that many tools were based on expert opinion, not grounded in empirical research; few scales used rigorous scale development techniques.

AHRQ asked the RTI-UNC EPC to undertake the present study, which extends and builds on the earlier report, for two reasons. The primary reason relates to a mandate from the Congress of the United States as part of the Healthcare Research and Quality Act of 1999, which created the Agency for Healthcare Research and Quality (AHRQ). This Act reauthorized the former AHCPR and extended many of its programs in quality of care, evidence-based practice, and technology assessment. Section 911(a) of Part B, Title IX, requires AHRQ, in collaboration with experts from the public and private sectors, to identify methods or systems to assess health care research results, particularly "methods or systems to rate the strength of the scientific evidence underlying health care practice, recommendations in the research literature, and technology assessments." The second reason for the current work relates to AHRQ's mission to support research that will improve the outcomes and quality of health care through research and dissemination. AHRQ's mission is being realized in part through its EPC program, the focus of which is "to improve the quality, effectiveness, and appropriateness of clinical care by facilitating the translation of evidence-based research findings into clinical practice." Thus, the research described in this report supports AHRQ's mission by providing information that EPCs and others can use to enhance research methods in the process of translating knowledge into practice.

The overarching goal of this project was to describe systems to rate the strength of scientific evidence focusing on methods used to conduct systematic reviews. The two specific aims were to:

- Conduct a rigorous review of quality scales, quality checklists, and study design characteristics (components) for rating the quality of individual articles.
- Identify and review methodologies for grading the strength of a body of scientific evidence -- that is, an accumulation of many individual articles that address a common scientific issue.

We addressed these specific aims by conducting two focused literature searches, one for each specific aim, to identify published research related to these two issues. We then developed and completed descriptive tables or matrices -- hereafter referred to as "grids" -- to compare and characterize existing systems for assessing the quality of individual articles and rating the strength of bodies of evidence. In these preliminary stages, we solicited the advice and assistance of international experts. The grids and accompanying discussion form the results of this project. Drawing on the results of our analysis, we identified existing quality rating scales or checklists that in our view can be used in the production of systematic evidence reviews and technology assessments, along with a discussion of the reasons for highlighting these specific instruments. The mission of AHRQ's EPC program is carried out through the development of evidence reports and technology assessments -- which collectively can be termed systematic reviews (as they are often known in the evidence-based practice field). For many in the clinical and policymaking communities, the products, indeed the lexicon, of evidence-based practice are unfamiliar, and one particular distinction may often be missed. This is the difference between a systematic review and the more familiar and more common narrative review. The next section of this chapter explicates the contrast between systematic and narrative reviews, with the aim of clarifying the significant role that systems for rating study quality and grading strength of evidence play in contemporary scientific endeavors of this sort.

## Systematic Reviews of Scientific Evidence

What is a systematic review? According to Cook and colleagues (1997),^ 93 ^ a systematic review is a type of scientific investigation of the literature on a given topic in which the "subjects" are the articles being evaluated. Thus, before a research team conducts a systematic review, it develops a well-designed protocol that lists: (1) a focused study question, (2) a specific search strategy, including the databases to be searched, and how studies will be identified and selected for the review according to inclusion and exclusion criteria, (3) the types of data to be abstracted from each article, and (4) how the data will be synthesized, either as a text summary or as some type of quantitative aggregation or meta-analysis. These steps are taken to protect the work against various forms of unintended bias in the identification, selection, and use of published work in these reviews.

In contrast, what is a narrative review? A narrative review is similar to a systematic review but without all the safeguards to control against bias. Table 1 (adapted from Cook et al.^ 95 ^) depicts the differences between systematic and narrative reviews. The major difference between these two approaches to synthesizing the clinical or scientific literature is that a systematic review attempts to minimize bias by the comprehensiveness and reproducibility of the search for and selection of articles for review.

Table 1. Key Distinctions Between Narrative and Systematic Reviews, by Core Features of Such Reviews

Core Feature | Narrative Review | Systematic Review
Study question | Often broad in scope. | Often a focused clinical question.
Data sources and search strategy | Which databases were searched and search strategy are not typically provided. | Comprehensive search of many databases as well as the so-called gray literature. Explicit search strategy provided.
Selection of articles for study | Not usually specified, potentially biased. | Criterion-based selection, uniformly applied.
Article review or appraisal | Variable, depending on who is conducting the review. | Rigorous critical appraisal, typically using a data extraction form.
Study quality | If assessed, may not use formal quality assessment. | Some assessment of quality is almost always included as part of the data extraction process.
Synthesis | Often a qualitative summary. | Quantitative summary (meta-analysis) if the data can be appropriately pooled; qualitative otherwise.
Inferences | Sometimes evidence-based. | Usually evidence-based.

93 Source: Adapted from Cook et al., 1997.

The biases that can occur in systematic reviews are similar to those that are possible in clinical studies. For example, good study design for randomized controlled trials (RCTs) requires that allocation to treatment or control be randomized with the investigator "masked" (or "blinded") to the subsequently assigned treatment (allocation concealment). This helps to ensure comparability of study groups and minimizes selection bias. By extension, in systematic reviews, if the literature search is not broad enough or the reasons for inclusion and exclusion of articles are not clearly specified, selection bias can arise in the choice of articles that are reviewed.^94,95^ Another important difference between narrative reviews and systematic reviews is that systematic reviews typically assess how well the study was designed, conducted, and analyzed. That is, systematic reviews provide a measure of quality for each study (sometimes regarded as each article or publication) in the review. When research teams assemble the literature for a systematic review, it is important that they place more emphasis on the results from studies of higher rather than lower quality; this is an additional analytic step that does not typically occur in the conduct of narrative reviews. In addition, compared with traditional reviews, systematic reviews more typically provide explicit grading of the strength of the body of evidence in question.

The importance of taking a direct and explicit approach to assessing the quality of articles and strength of evidence lies, in part, in the need to be able to take account of differences in study quality and the impact of those differences on inferences that can be drawn about the scientific evidence. Empirical evidence indicates that the combined result or effect measure of interest in a review may be biased if studies of varying quality are summarized together.^ 51 ^

## Quality Assessments in Systematic Reviews

The concern about study quality first arose in the early 1980s with the publication of a landmark paper by Chalmers and colleagues^ 24 ^ and another extensive work by Hemminki, who evaluated the quality of trials done in 1965 through 1975 that were used to support the licensing of drugs in Finland and Sweden.^ 96 ^ Since that time, numerous studies have provided evidence that study quality is important when producing systematic reviews.^51,97^

Thus, as this report will document, many quality scales and quality checklists have been developed in the past two decades or so for these evaluative purposes. In addition, several studies have appeared showing the importance of certain study design attributes or components, including randomization and double-blinding in the conduct of RCTs. These points are elaborated below and in Chapters 2 and 3. At this juncture, we note that the type of research being addressed in systematic reviews plays a major role in the conduct of those reviews and thus in the creation of systems for grading the evidence. Because of the significance of study design in this work, we present in Figure 1 a study design flow chart or algorithm (modified from Zaza et al.^ 50 ^) that discriminates among the various types of research published in the medical literature -- RCTs, cross-sectional studies, case-control studies, and other so-called observational investigations.

Figure 1. Study Design Algorithm

^50^ Modified from Zaza et al. 2000.

### Defining Quality

Critical to this discussion is the definition of quality, which authors of quality ratings often do not specify. In the previous AHRQ project, Lohr and Carey defined "methodologic quality" as "the extent to which all aspects of a study's design and conduct can be shown to protect against systematic bias, nonsystematic bias, and inferential error"; "nonmethodologic quality" refers to "the extent to which the information from a study has significant clinical or policy relevance." (Ref. 1, p. 472.)

We focus in this report on methodologic quality -- that is, the extent to which a study's design, conduct, and analysis has minimized selection, measurement, and confounding biases. Our definition of quality refers to the internal validity of a study, not its external validity or generalizability. Although not all experts in the evidence-based practice field would take this approach, we consider issues of generalizability more relevant for developing clinical practice guidelines than for producing rigorous systematic reviews per se, in that guideline development is a step that occurs after a body of evidence on a clinical topic has been assembled and the overall strength of that evidence assessed.^ 98 ^

### Developing Quality Assessments

Our project's first specific aim was to identify and compare tools to conduct quality assessment, which includes quality scales and checklists but also individual components of study quality. As part of the comparison among quality assessment instruments, it is important to understand proper scale development techniques.

Measurement scales, which in this context would include quality rating instruments, are developed in a stepwise fashion. The first steps involve defining the quality constructs or issues to be measured and the scope and purpose of the quality review, after which the actual questions are developed. The final steps require testing the instrument's reliability and validity and making such modifications as seem appropriate to meet conventional standards (for example, for internal consistency or test-retest reliability).^ 99 ^

Typically, instrument developers examine three types of validity: face, content, and criterion validity. Asking whether the instrument appears to measure what it was intended to measure assesses face validity. The extent to which the quality domain of interest -- for example, randomization -- is comprehensively assessed measures content validity. Criterion validity is defined as the extent to which the measurement correlates with an external criterion variable (a "gold standard"),^ 100 ^ preferably one that can be measured objectively and independently. Khan and colleagues suggest that the last step in this iterative process is to determine the measurement properties of the quality instrument.^ 12 ^ For many types of instruments, researchers measure criterion validity if an acceptable gold standard is available. Quality assessment tools of the type under consideration in this report have no true, "objective" gold standard that lies outside the domain of subjective assessment of the "goodness" of the study or article at hand. Because criterion validity cannot be assessed, some scale developers assess the instrument's reliability -- that is, measuring whether a similar quality assessment score can be derived on the same study using either different scales or assessors (inter-rater reliability).^ 12 ^ The rigorousness with which a scale is developed may influence its measurement properties.

### Using Quality Ratings

No consensus exists on how study quality should be used in a systematic review. Moher, Jadad, and Tugwell (1996) describe four ways that quality assessment of RCTs may be used in systematic reviews and meta-analyses.^ 101 ^ The most basic approach is to use quality as an inclusion threshold. Many reviewers, for example, admit only RCTs into a systematic review and eliminate other study designs from further consideration. Others have used a numeric quality score as a statistical weight when conducting meta-analyses (i.e., quantitative systematic reviews) to calculate a summary estimate of effect. A third method involves conducting a cumulative meta-analysis that is initiated by including only the higher quality studies and then adding studies of lesser quality sequentially. Finally, some have recommended that quality be examined visually in a plot.

Experts also disagree about whether quality should be formally scored, used as a threshold for inclusion or exclusion, employed in sensitivity analysis, applied in some other analytic framework, simply described, or not considered at all. Each approach has some potential advantages or some serious problems. If quality is to be used as a threshold for inclusion or exclusion, how quality is determined matters.^ 2 ^ In systematic reviews of treatment, for instance, including a very poor quality study, regardless of its size, can profoundly influence summary estimates of the effects of that treatment.^41,97^

Complex statistical challenges arise when reviewers are attempting to arrive at a quantitative summary rather than attempting to conduct a more narrative review. Work by Detsky et al., Olkin, Moher et al., Sutton et al., and Tritchler is particularly helpful in guiding reviewers about the salient issues and statistical techniques involved.^20,30,101-103^

## Concepts of Study Quality and Strength of Evidence

### Study Quality

Systematic reviews comprise evidence based on research papers from the published literature and, whenever possible, from the "gray" or unpublished literature as well. Although much of the material identified and used for systematic reviews is from the peer-reviewed literature, the process and thoroughness of review conducted by journal reviewers and by those doing systematic reviews may not be the same. Thus, the literature compiled for systematic reviews may be of varying quality, which can lead to conflicting summary estimates between systematic reviews on the same topic.

For example, Juni and colleagues evaluated study quality of 17 RCTs comparing low molecular weight heparin with standard heparin for preventing post-operative thrombosis using 25 different quality scales. Among the scales, both the indicators of study quality and their corresponding weights differed such that a study considered to be high quality on one scale was deemed low quality on another. Thus, summarizing the high quality articles according to one scale produced different relative risks than summarizing high quality studies using another scale.^ 2 ^ Juni et al. found that an important predictor of summary relative risk was one particular component of study quality, whether the assessor of the outcome (risk of thrombosis) was masked to treatment allocation. This suggests that evaluating study quality is dependent on particular study design issues relevant to the topic under study. Their finding that a focus on methodologic components rather than summary scores to measure quality supports other work and editorial comment in the field.^ 104 ^

As discussed in more detail below, several published studies provide empirical evidence that inadequate description of certain elements of experimental study design -- namely randomization procedures, allocation concealment (in which investigators do not know which drug will be assigned next), and outcome masking -- have been associated with biased results.^2,51,105,106^Failure to mask the randomization procedures or outcome assessment was associated with elevated estimates of treatment effect compared with studies that reported using adequate masking procedures.

Whether potential design deficiencies in the published studies are the result of poor study design or poor reporting of study design is difficult to evaluate because reviewers typically see only the study report. Several collaborative efforts have put forth "statements" to standardize reporting; these include publishing guidelines for systematic reviews (QUOROM),^ 21 ^ RCTs (CONSORT),^ 57 ^ and observational studies (MOOSE).^ 23 ^ These guidelines appear as checklists that authors can use to ensure that they have adequately addressed all the necessary components of a systematic review or publication on a given clinical or health services research project. Because of the evidence that poor quality studies may bias summary estimates from systematic reviews, researchers have developed and incorporated study quality assessment into their procedures for abstracting information from the literature and then describing and evaluating that literature. Numerous quality rating checklists and scales exist for RCTs.^101,107^ Few instruments have been developed specifically for systematic reviews, observational studies, or investigations of diagnostic tests; however, most of those pertinent for observational studies of treatment effects are general enough to evaluate RCTs. Among existing instruments, even fewer scales and checklists have been developed using rigorous scale development techniques.

In this project, we compared and contrasted quality rating approaches using the definition of quality offered above, which is based on study design characteristics indicative of methodologic rigor. As explained in Chapter 2, Methods, we developed the grids for evaluating study quality using domains or specific items from various sources that described study quality or that discussed epidemiologic design standards. Some domains include explicit case definition specification, treatment allocation, control of confounding, extensiveness of follow-up, standardized and reproducible outcome assessment methods, and appropriate statistical analysis. Because design standards differ by study types (e.g., RCTs, observational studies, systematic reviews, and diagnostic studies), we developed one grid for each of these design types.

### Strength of a Body of Evidence

In conceptualizing this project, we contended that a continuum exists from rating study quality to grading the strength of a body of evidence. Grading the strength of a body of evidence incorporates judgments of study quality, but it also includes how confident one is that a finding is true and whether the same finding has been detected by others using different studies or different people. Thus, grading evidence strength stops at the dashed line in Figure 2. Only by incorporating population-specific information such as regional, racial, and clinical setting differences (akin to generalizability) does one derive a clinical or treatment guideline. We extensively searched the literature to identify ways to grade the strength of a body of evidence. In the end, we determined that judging evidence strength does not typically appear to be a separate endeavor but rather is usually incorporated into the development of clinical practice guidelines and clinical recommendations within them. We thus limited our review of the guideline literature to the elements that address grading the strength of the evidence for a given topic per se and disregarded information addressing recommendation development. In a manner analogous to the development of study quality grids, we created one additional matrix -- an "evidence strength grid" -- to capture the information concerning grading the strength of a body of scientific knowledge. In developing this grid, we posited that evaluating the strength of a body of evidence is similar to distinguishing between causal and noncausal associations in epidemiology.

Figure 2. Continuum from Study Quality Through Strength of Evidence to Guideline Development

The dashed line is the theoretical dividing line between summarizing the scientific literature and developing a clinical practice guideline. Below the dashed line, guideline developers would decide whether the evidence represents all the relevant subsets of the populations (or settings, or types of clinicians) for whom the guideline is being developed.

Since the appearance of the Surgeon General's Report on Smoking and Health in 1964,^148,108^ epidemiologists have been using five criteria for assessing causal relationships.^ 109 ^ Two criteria, consistency and strength, are of particular relevance. Consistency is the extent to which diverse approaches, such as different study designs or populations, for studying a relationship or link between a factor and an outcome will yield similar conclusions. Strength is the size of the estimated risk (of disease due to a factor) and its accompanying confidence intervals. Both of these concepts are directly related to grading the strength of a body of evidence.

Other epidemiologic criteria such as coherence, which examines whether the cause-and-effect interpretation for an association conflicts with what is known of the natural history and biology of the disease, are more relevant for developing clinical recommendations. The remaining two causality criteria typically used in epidemiology, specificity and temporality, are more appropriate for measuring risk than for conducting technology assessments.

Based on these epidemiologic principles, the literature, and prior RTI-UNC EPC work, we concluded that grading the strength of a body of evidence should take three domains into account: quality, quantity, and consistency. Quality is defined as above, but in this case we are concerned with the quality of all relevant studies for a given topic. Quantity encompasses several aspects such as the number of studies that have evaluated the question, the overall sample size across all of the studies, and the magnitude of the treatment effect. Quantity is along the lines of "strength" from causality assessment and is typically reported in a comparative sense as a mean difference, relative risk, or odds ratio. Consistency -- that is, whether investigations with both similar and different study designs report similar findings -- can be assessed only if numerous studies are done. Thus, consistency is an important consideration when comparing one study with many individuals to several smaller studies with few individuals. We contend that one needs to address all three factors -- quality, quantity, and consistency -- when grading the strength of the evidence.

## Organization of This Report

Chapter 2 of this report describes our technical approach, including methods for literature searches, interactions with outside experts and other EPCs, development of Study Quality and Evidence Strength Grids, and other steps. Appendix A describes our initial input from the EPCs. In Chapter 3 we present our results, including a detailed examination of the rating and grading systems we reviewed according to the domains that we regarded as significant for such systems to cover. Appendices B and C provide the actual completed grids by which to compare and contrast existing systems for assessing the quality of individual articles and grading the strength of bodies of evidence. Chapter 4 discusses our results in greater detail and provides a listing of several rating systems that, in our judgment, can be used for quality assessment purposes; it also offers our suggestions for future research. Appendix D gives an annotated bibliography of studies that provide empirical evidence on domains for rating study quality. The references include only studies cited in the body of this report; Appendix E cites excluded studies with the reason for exclusion. Appendix F contains an example of the electronic data abstraction tool we developed for this task. Appendix G provides a glossary of some of the terms we use in the context of this report.