# Diagnostic Studies

The domains and elements we used to compare tools to evaluate the quality of diagnostic studies were meant to be supplemental to those considered for RCTs and observational studies, as these are the two designs typically employed to evaluate diagnostic tests. The domains that we derived for diagnostic studies are unique; all have some empirical basis as a result of the work of Lijmer and colleagues.^ 78 ^ They evaluated whether certain design factors perceived as "good practice" influenced the risk of bias. Of the five study design factors to be associated with bias, studies that evaluated the test in persons with known disease status showed more biased results than if the test had been evaluated in a population with a full spectrum of disease. Studies that used a different reference standard for confirmation of positive and negative test results and those that interpreted the reference standard with full knowledge of the test result were also subject to substantial bias. The work of Lachs and colleagues supported that of Lijmer et al. in that the key test characteristics of sensitivity and specificity were affected by the spectrum of disease in the population tested.^ 171 ^

Exhibit D-1. Empirical Evidence Used to Derive Study Quality Domains

Source | Methodologic Issue Studied | Study Design Addressed | Summary of Findings
Chalmers et al., 1977^ 160 ^ | RCTs vs. nonrandomized controlled trials using historical controls | Controlled trials | Use of historical controls in nonrandomized controlled trials of the use of anticoagulants for myocardial infarction led to exaggerated estimates of mortality reduction compared with RCT study designs.
Chalmers et al., 1983^ 105 ^ | Randomization blinding (i.e., allocation concealment) in therapeutic trials of treatment for acute myocardial infarction | RCT | Case fatality differences were 8.8% in blinded randomization studies, 24.4% in unblinded randomized studies, and 58.1% in non-randomized studies. Evidence to support randomized study designs with double-blinding to minimize bias.
Simes, 1986^ 150 ^ | Publication bias in clinical oncology | Systematic review* | Analysis of all published trials yielded increased estimates of effect for "new" therapies compared with analysis of trials registered in advance of conduct with an international registry.
Colditz et al., 1989^ 27 ^ | Randomized versus non-randomized and double-blinded versus non-blinded trials in cardiology, neurology, respiratory medicine, and psychiatry. | RCT | Non-randomized sequential studies found larger therapeutic gains for the innovation compared to standard therapy (p = 0.004). RCTs that did not employ double-blinding had a higher likelihood of showing a positive effect of the innovation (p = 0.02). Evidence to support randomized study designs with double-blinding to minimize bias.
Emerson et al., 1990^ 158 ^ | Relationship between study quality using the Chalmers scale and treatment differences in RCTs (primarily in various meta-analyses of cardiovascular trials, but with one dataset each of progesterone therapy in pregnancy, nicotine chewing gum for smoking cessation, and antibiotic therapy for GI surgery) | Systematic review* | No relationship between quality scores (using the entire scale) and treatment differences or variation in treatment difference was found. Using a component approach, inclusion of randomization blinding and/or handling of withdrawals was not associated with treatment differences either.
Easterbrook et al., 1991^ 151 ^ | Publication bias | Systematic review | Study of research projects approved by a central ethics committee between 1984 and 1987 found that studies with significant results, non-randomized trials, observational studies, and laboratory-based trials were significantly more likely to be published. Studies funded by the pharmaceutical industry were less likely to be published than studies with other types of funding.
Lachs et al.^ 171 ^ | Spectrum bias in diagnostic tests | Diagnostic tests | Sensitivity and specificity of urine dip stick for diagnosis of UTI differed markedly between groups of patients at high and low pre-test risk for UTI. The spectrum of disease in the patient population affects test characteristics and thus is important when evaluating a diagnostic test.
Dickersin et al., 1994^ 149 ^ | Searching for RCTs in ophthalmology | Systematic review * | Medline^®^ searches are not sufficiently sensitive to obtain all RCTs in field secondary to inadequate indexing, incomplete coverage of medical literature by Medline, skill level of searcher, and unpublished trials.
Thompson, 1994^ 159 ^ | Heterogeneity in meta-analyses of cardiac, cancer outcomes, and cholesterol lowering | Systematic review | Conclusions of meta-analyses may differ if heterogeneity among studies exists (due to issues such as age of subjects, duration of therapy, extent of cholesterol reduction, and confounding due to tobacco use).
Jeng et al., 1995^ 152 ^ | Meta-analysis using individual patient data versus summary data from published and unpublished | Systematic review | The effect of treatment for infertility using paternal white blood cell immunization for recurrent miscarriage was statistically significant for pooled summary data from published studies with diminishing estimates of effect for meta-analysis using individual patient data or meta-analysis using unpublished data.
Cho and Bero, 1996^ 168 ^ | Drug studies published in symposium proceedings | RCT, Observational | Studies sponsored by pharmaceutical companies and published in symposium proceedings were more likely to report favorable effects of the drug of interest than were studies published under peer review.
Schulz et al., 1994^ 161 ^ | Randomization sequence generation, allocation concealment, and baseline characteristics in obstetrics and gynecology trials | RCT | Only about a third (32%) of trials reported an adequate method of sequence generation, and nearly half (48%) did not report methods used to conceal allocation. Only 9% reported adequate techniques for both. Differences in baseline characteristics among study groups in unrestricted trials were smaller than what would be statistically expected if randomization had been done properly.
Grimes and Schulz, 1996^ 162 ^ | Reporting of randomization sequence generation and allocation concealment for RCTs in obstetrics and gynecology | RCT | Failure to report an adequate approach to sequence generation was highly associated with failure to report adequate allocation concealment (p <0.001).
Jadad et al., 1996^ 34 ^ | Need for blinded quality assessment of studies in systematic reviews. Quality assessment included items on randomization, double-blinding, and handling of withdrawals/dropouts | Systematic review * | Blind assessment resulted in lower and more consistent quality assessments.
Khan et al., 1996^ 35 ^ | Crossover trials versus parallel group design in infertility research | RCT | Crossover trials overestimated odds ratios(ORs) by 74% (95% Confidence Interval [CI]: 2% to 197%) compared with parallel study designs evaluating the same interventions.
Khan et al., 1996^ 97 ^ | Study quality and bias in systematic reviews of antiestrogen therapy for oliospermia | Systematic review | High quality studies did not find evidence of effectiveness, while low quality studies did. The overall summary OR for all studies had a positive OR, but a CI that crossed 1.
Moher et al., 1996^ 153 ^ | Non-English language trials | Systematic review* | No significant differences for completeness of reporting of key study elements (randomization, double-blinding, withdrawals) for trials published in English versus other languages
Vickers et al., 1998^ 155 ^ | Positive trial results and country of origin of study | Systematic review* | Trials of acupuncture originating in China, Japan, Hong Kong, Taiwan, and Russia/USSR had positive findings in all but one case. For trials of interventions other than acupuncture, publication of positive results occurred 99%, 89%, 97%, and 95% for studies originating in China, Japan, Russia/USSR, and Taiwan, respectively. No trial published in China or Russia/USSR found a treatment to be ineffective.
Barnes and Bero, 1997^ 170 ^ | Quality of peer-reviewed original research publications versus non-peer-reviewed articles published in symposium proceedings Funding/Support | Primarily observational | Symposium articles on the health effects of environmental tobacco smoke exposure were found to be of poorer quality than peer-reviewed articles using a multivariate model which controlled for study design, article conclusion, article conclusion, article topic, and whether the source of funding was acknowledged. Symposium articles were significantly more likely to have tobacco industry funding or to have no source of funding acknowledged and less likely to have government funding. However, in multivariate modeling, funding source per se was not found to be significant.
Berlin, 1997^ 157 ^ | Blinding of reviewers to journal, author, institution, and treatment group for meta-analysis of RCTs | Systematic review* | Blinding of reviewers during study selection and data extraction, using document scanning and editing, had neither a clinically nor a statistically significant effect on the summary odds ratios for meta-analyses of five different medical interventions.
Barnes and Bero, 1998^ 3 ^ | Author affiliation and conclusions of reviews of effects of passive smoke exposure | Systematic review† | Reviews that found passive smoke exposure not to be associated with adverse health effects largely had authors with tobacco industry affiliation.
Chene et al., 1998^ 163 ^ | Intention-to-treat (ITT) statistical analysis | RCT | A significant interaction between compliance and treatment outcome was found in this study of pyrimethamine prophylaxis of cerebral toxoplasmosis in HIV-infected patients. The ITT analysis did not show a significant treatment effect, while the on-treatment efficacy analysis did show a positive effect of the drug. The authors firmly believe that ITT analysis provides the only interpretable analysis of RCTs based on the following rationale: (1) randomization is maintained by an ITT analysis, (2) bias may result in an efficacy analysis when noncompliant patients have poorer outcomes and an interaction exists between compliance and treatment group, (3) prognostic factors affect compliance and treatment effect cannot be taken into account in an efficacy analysis, and (4) generalization is impossible without an ITT analysis.
Moher et al, 1998^ 41 ^ | Masked versus unmasked RCT study quality assessment Allocation concealment | Systematic review* RCT | Masked study quality assessment resulted in study quality scores were higher and statistically different (3.8% difference, p=0.005) compared with open assessment. Trials with inadequate reporting of allocation concealment had statistically exaggerated estimates of treatment effect, where the ratio of odds ratios was: 0.63, [95% CI 0.45, 0.88].
Moher et al, 1998^ 41 ^ | Incorporation of study quality into meta-analyses | Systematic review* | Meta-analysis using only low quality trails had significantly greater estimate of treatment effect compared with meta-analysis of only high quality trials. Use of a quality weight in meta-regression rather than analyzing only low or high quality studies independently resulted in an estimate that had the least statistical heterogeneity and that was similar to the average treatment benefit of all trials, regardless of quality.
Stelfox et al., 1998^ 110 ^ | Industry funding/sponsorship of research | Various | This study examined 5 original research articles, 32 review articles, and 33 letters to the editor published between March 1995 and September 1996 that had information about the safety of calcium-channel antagonists. 96% of authors supportive of calcium-channel antagonist safety had financial relationships with manufacturers compared with 60% of authors with neutral positions and 37% of authors who were critical of the safety of these agents (p <0.001). Supportive and neutral authors were also more likely than critical authors to have financial interactions with manufacturers of competing products. 100% of supportive, 67% of neutral, and 43% of critical authors had financial interactions with any pharmaceutical manufacturers (p <0.001).
Verhagen et al., 1998^ 156 ^ | Blinding of balneotherapy study quality assessment using the Maastricht criteria | Systematic review * | Quality scores assessed using blinded versus nonblinded reviewers did not differ significantly.
Clark et al., 1999^ 95 ^ | Reviewer blinding and use of the Jadad scale to rate the quality of studies on technologies to reduce perioperative allogenic blood transfusions | Systematic review* | Reviewer blinding did not result in a consistently significant effect on quality assessment. Found considerable interrater variability when using the Jadad scale, largely because of disagreements on the withdrawal item.
Juni et al., 1999^ 2 ^ | Relationship of quality assessment using 25 different scales to treatment effects in a meta-analysis of 17 RCTs comparing standard to low molecular weight heparin (LMWH) for prevention of postoperative thrombosis | Systematic review* | 6 scales found LMWH superior to standard heparin only in low quality trials; 7 scales found LMWH superior only in high quality trials; and the summary quality scores using the remaining 12 scales found similar estimates of effect in both high and low quality study strata. Using component approaches only found no significant association of treatment effect and allocation concealment or handling of withdrawals. However, open outcome assessment was associated with exaggerated treatment estimates (35% on average).
Lijmer et al., 1999^ 78 ^ | Design of diagnostic test studies and risk of bias | Diagnostic tests | Evidence of exaggerated performance of diagnostic tests was found for studies with the following design flaws:; 1. Evaluating the test in a diseased population and a separate control group (relative diagnostic odds ratios ([RDOR]: 3.0 [95% CI 2.0, 4.5]);; 2. Use of a different reference standard for confirmation of positive and negative results of the test under study (RDOR: 2.2 [1.5, 3.3]);; 3. Interpretation of the reference standard with knowledge of the test result (RDOR: 1.3 [1.0, 1.9]);; 4. Lack of description of the test (RDOR: 1.7 [1.1, 2.5]); and; 5. No description of the study population (RDOR: 1.4 [1.1, 1.7]).
Concato et al., 2000^ 169 ^ | Comparison of RCTs and well-designed observational studies using concurrent controls for five clinical topics (BCG vaccine for TB, mammography and mortality from breast cancer, cholesterol levels and trauma mortality, hypertension treatment and stroke, hypertension treatment and coronary disease) | Observational ‡ | Estimates of effect were similar for RCTs and observational studies that used concurrent controls for each of the five clinical areas studied. All measures of effect had overlapping 95% CIs. For these clinical topics and cohort studies using concurrent controls it appears that meta-analyses of these types of rigorous observational studies come to the same conclusion as meta-analyses of RCTs.
Djulbegovic et al., 2000^ 165 ^ | Pharmaceutical company sponsorship of RCTs | RCT | Biases toward new treatments were found in for-profit pharmaceutical industry-sponsored research may be due to violations of principles of equipoise (e.g., choice of an inappropriate comparative control).
Lachin, 2000^ 164 ^ | Intent-to-treat (ITT) versus efficacy statistical analysis | RCT | This article compared an intention-to-treat (ITT) analysis with an efficacy analysis for an Alzheimer's disease drug trial where there were substantial drop-outs due to hepatotoxicity of the drug. Complete follow-up was available for 92% of the participants. While both the ITT and the efficacy analyses supported drug efficacy, the ITT analysis supported efficacy only at higher doses. The efficacy analysis introduced selection bias based on tolerance of and compliance with the drug.
Moher et al., 2000^ 154 ^ | Non-English language trials | Systematic Review* | No evidence was found that language-restricted meta-analyses lead to biased estimates of treatment efficacy in 79 meta-analyses covering a wide variety of disease areas. The average difference between meta-analyses including and excluding non-English trials was 2% (ratio of odds ratios: 0.98, 95% CI 0.81, 1.17). Sensitivity analyses indicated that these findings were robust. Inclusion of non-English trials did result in more precise estimates of treatment efficacy, with CI averaging 16% narrower.

* Applies to systematic reviews of trials

† Applies to observational studies that are prospective cohort studies that use concurrent controls

‡ Applies to systematic reviews of observational studies

Note: For complete reference information, see reference list