# Appendix D: An Annotated Bibliography of Empiric Evidence Used in Grid Development

We use the term "empiric evidence" in this report to mean aspects of study design, conduct, and analysis that have been shown, via methodological studies, to be related to risk of bias. When these aspects are not addressed or are poorly addressed in a study, it is more likely that the results from this study will give false or misleading results. For Tables 7-10 in this report (Chapter 2, Methods) we have designated particular domains and elements as empirically based. Exhibit D-1 (at the end of this appendix) catalogs the empirical evidence that we have used to arrive at these designations.

We acknowledge that there is disagreement between respected methodological experts, epidemiologists, and statisticians on some of these issues; we have attempted to take a moderate approach. Where empirical evidence was available but contradictory on a given domain or element topic, we elected not to define an empiric position on that topic. Where evidence was scant but clear, we included it as empiric but emphasize that future research may alter our conclusion.

A thorough assessment of underlying empiric evidence was not among the objectives of this project. Rather, this appendix arose from our need to categorize and make sense of the relevant research base. Although the information is fairly comprehensive, we have not undertaken the steps necessary to assure that it is exhaustive.