# Appendix C: Strength of Eviendce Grids Acronyms

ACRONYM | DESCRIPTION
CC | Case-control study
CI | Confidence interval
EB | Evidence-based
MA | Meta-analysis
N | Number
NA | Not available
NNT | Number needed to treat
OR | Odds ratio
RCT | Randomized controlled trial
SR | Systematic review

Grid 5A. Summary Evaluation of Systems for Grading by Three Domains

| Domain
| Quality | Quantity | Consistency
Source
Canadian Task Force, 1979^ 112 ^ | [image] | [image] | [image]
Anonymous, 1981^ 87 ^ | [image] | [image] | [image]
Cook et al., 1992^ 114 ^; Sackett, 1989^ 113 ^ | [image] | [image] | [image]
U.S. Preventive Services Task Force, 1996^ 122 ^ | [image] | [image] | [image]
Ogilvie et al., 1993^ 115 ^ | [image] | [image] | [image]
Gross et al., 1994^ 123 ^ | [image] | [image] | [image]
Gyorkos et al., 1994^ 81 ^ | [image] | [image] | [image]
Guyatt et al., 1998^ 88 ^ | [image] | [image] | [image]
Guyatt et al., 1995^ 89 ^ | [image] | [image] | [image]
Evans et al., 1997^ 116 ^ | [image] | [image] | [image]
Granados et al., 1997^ 117 ^ | [image] | [image] | [image]
Gray, 1997^ 124 ^ | [image] | [image] | [image]
van Tulder et al., 1997^ 39 ^ | [image] | [image] | [image]
Bartlett et al., 1998^ 118 ^ | [image] | [image] | [image]
Djulbegovic and Hadley, 1998^ 125 ^ | [image] | [image] | [image]
Edwards et al., 1998^ 126 ^ | [image] | [image] | [image]
Bril et al., 1999^ 119 ^ | [image] | [image] | [image]
Chesson et al., 1999^ 127 ^ | [image] | [image] | [image]
Clarke and Oxman, 1999^ 11 ^ | [image] | [image] | [image]
Hoogendoorn et al., 1999^ 90 ^ | [image] | [image] | [image]
Working Party, 1999^ 120 ^ | [image] | [image] | [image]
Shekelle et al., 1999^ 121 ^ | [image] | [image] | [image]
Wilkinson, 1999^ 128 ^ | [image] | [image] | [image]
Ariens et al., 2000^ 70 ^ | [image] | [image] | [image]
Briss et al., 2000^ 82 ^ | [image] | [image] | [image]
Greer et al., 2000^ 83 ^ | [image] | [image] | [image]
Guyatt et al., 2000^ 84 ^ | [image] | [image] | [image]
Khan et al., 2000^ 12 ^ | [image] | [image] | [image]
NHMRC, 2000^ 49 ^ | [image] | [image] | [image]
NHS, 2001^ 85 ^ | [image] | [image] | [image]
New Zealand Guidelines Group, 2000^ 13 ^ | [image] | [image] | [image]
Sackett et al., 2000^ 91 ^ | [image] | [image] | [image]
Harbour and Miller, 2001^ 14 ^ | [image] | [image] | [image]
Harris et al., 2001^ 86 ^ | [image] | [image] | [image]
EPC Quality Assessments
Chestnut et al., 1999^ 60 ^ | [image] | [image] | [image]
West et al., 1999^ 65 ^ | [image] | [image] | [image]
McNamara et al., 1999^ 66 ^ | [image] | [image] | [image]
Ross et al., 2000^ 67 ^ | [image] | [image] | [image]
Levine et al., 2000^ 147 ^ | [image] | [image] | [image]
Goudas et al., 2000,^ 68 ^ and Lau et al., 2000^ 59 ^ | [image] | [image] | [image]

Note: For complete reference information, see reference list Legend:

Yes

Partial

No information

Grid 5B. Overall Description of Systems to Grade Strength of Evidence

| Domain
| Quality | Quantity | Consistency | Other | Strength of Evidence Grading System | Comments
Test | Test consistent with causation | Test neutral or inconclusive | Test opposes causation
Source
Canadian Task Force on the Periodic Health Examination, 1979, 1997^ 112 ^ (This is the methodology section from the Web site www.ctfphc.org/Methodology (http://www.ctfphc.org) accessed on 1-24-01) | Based on hierarchy of research design | Number of studies | NA | | Quality of published evidence hierarchy:
  I | Evidence from at least 1 properly randomized controlled trial
  II-1 | Evidence from well-designed controlled trials without randomization
  II-2 | Evidence from well-designed cohort or case-control analytic studies, preferably from more than 1 center or research group
  II-3 | Evidence from comparisons between times or places with or without the intervention. Dramatic results in uncontrolled experiments could also be included here.
  III | Opinions of respected authorities, based on clinical experience, descriptive studies or reports of expert committees.
Cook et al., 1992^ 114 ^ Sackett et al., 1989^ 113 ^ | Based on hierarchy of research design | Sample size | NA | | Levels of evidence:; 1. Randomized trials with low false-positive (α) and low false-negative (β) errors; 2. Randomized trials with high false-positive (α) and/or high false-negative (β) errors; 3. Nonrandomized concurrent cohort comparisons between contemporaneous patients who did and did not receive therapy; 4. Nonrandomized historical cohort comparisons between current patients who did receive therapy and former patients who did not; 5. Case series without controls
U. S. Preventive Services Task Force, 1996^ 122 ^ | Based on hierarchy of research design, conduct of study, and risk of bias | Number of studies and statistical power to measure differences in effect | NA | | Levels of evidence:
  I | Evidence from at least one properly randomized controlled trial
  II-1 | Well-designed controlled trial without randomization
  II-2 | Well-designed cohort or CC analytic studies, preferably from more than one center or group
  II-3 | Multiple time series with or without the intervention (also includes dramatic results in uncontrolled experiments)
  III | Opinions of respected authorities, descriptive studies and case reports, reports of expert committees
Ogilvie et al., 1993^ 115 ^ | Based on hierarchy of research design | Considers statistical significance, sample size, and power | NA | | Levels of evidence for rating studies of treatment:; 1. An RCT that demonstrates a statistically significant difference in at least one important outcome. Alternatively, if the difference is not statistically significant, an RCT of adequate sample size to exclude a 25% difference in relative risk with 80% power, given the observed results.; 2. An RCT that does not meet the level I criteria; 3. A non-randomized trial with contemporaneous controls selected by some systematic method (i.e., not selected by perceived suitability for one of the treatment options for individual patients). Alternatively, subgroup analysis of an RCT.; 4. A before-after study or case series (of at least 10 patients) with historical controls or controls drawn from other studies.; 5. Case series (at least 10 patients) without controls; 6. Case report (fewer than 10 patients)
Gross et al., 1994^ 123 ^ | Based on hierarchy of research design and conduct of study | Number of studies | NA | | Levels of evidence:; 1. Evidence from at least 1 properly randomized controlled trial; 2. Evidence from at least 1 well-designed clinical trial without randomization, from cohort or case-controlled experiments (preferably from more than one center), multiple time-series studies, or dramatic results from uncontrolled studies; 3. Opinions of the panel or respected authorities based on clinical judgment or descriptive studies; 4. Other: - Unanimous agreement - General, not unanimous
Gyorkos et al., 1994^ 81 ^ | Validity of studies | Strength of association and precision of estimate | Variability in findings from independent studies | | Overall assessment of level of evidence based on four elements:; 1. Validity of individual studies; 2. Strength of association between intervention and outcomes of interest; 3. Precision of the estimate of strength of association; 4. Variability in findings from independent studies of the same or similar interventions; For each element a qualitative assessment of whether there is strong, moderate or weak support for a causal association.
Guyatt et al., 1998^ 88 ^ | Based on hierarchy of research design | Multiplicity of studies, and precision of estimate relative to a treatment threshold | Consistency of study result considered | | Levels of Evidence: Level I (Grade A) | From Fifth ACCP Consensus Conference on Antithrombotic Therapy "...the more balanced the trade-off between benefits and risks the greater the influence of individual patient values in decision-making."
  I | Results come from a single RCT in which the lower limit of the CI for the treatment effect exceeds the minimal clinically important benefit
  I+ | Results come from a meta-analysis of RCTs in which the treatment effects from individual studies are consistent, and the lower limit of the CI for the treatment effect exceeds the minimal clinically important benefit
  I− | Results come from a meta-analysis of RCTs in which the treatment effects from individual studies are widely disparate, but the lower limit of the CI for the treatment effect still exceeds the minimal clinically important benefit
  Level II (Grade B)
  II | Results come from a single RCT in which the CI for the treatment effect overlaps the minimal clinically important benefit
  II+ | Results come from a meta-analysis of RCTs in which the treatment effects from individual studies are consistent and the CI for the treatment effect overlaps the minimal clinically benefit
  II− | Results comefrom a meta-analysis of RCTs in which the treatment effects from individual studies are widely disparate and the CI for the treatment effect overlaps the minimal clinically important benefit
  Level III (Grade C)
  III | Results come from nonrandomized concurrent cohort studies
  Level IV (Grade C)
  IV | Results come from nonrandomized historic cohort studies
  Level V (Grade C)
  V | Results come from case series
Guyatt et al., 1995^ 89 ^ | Based on hierarchy of research design | Number of studies and precision of estimate | Heterogeneity of studies and differences in estimates of effect considered | | | Authors define 2 criteria for what constitutes important heterogeneity among RCTs:; 1. Difference in the estimate of RR reduction between the two most disparate studies is greater than 20%, and; 2. The difference between the boundaries of the CIs between the two most disparate studies is greater than 5%.; Their system uses 3 components to grade recommendations: strength of evidence, whether the impact of treatment warrants use and how effective the treatment is relative to a threshold number needed to treat (NNT). The grades range from A1 to C2 and are based on these three factors. For this strength of evidence grid we have abstracted only the A through C grades, which pertain most strongly to strength of evidence.
  A1 | RCTs, no heterogeneity, CIs all on one side of the threshold NNT
  A2 | RCTS, no heterogeneity, CIs overlap threshold NNT
  B1 | RCTs, heterogeneity, CIs all on one side of the threshold NNT
  B2 | RCTs, heterogeneity, CIs overlap threshold NNT
  C1 | Observational studies, CIs all on one side of the threshold NNT
  C2 | Observational studies, CIs overlap threshold NNT
Evans et al., 1997^ 116 ^ | Based on hierarchy of research design | Adequacy of sample size to minimize false-positive or false-negative conclusions | NA | | Levels:; 1. Randomized controlled trials that are big enough to be either: - Positive with small risk of false-positive conclusions - Negative with small risk of false-negative conclusions - Meta-analysis; 2. Randomized controlled trials that are too small, so that they show either: - Positive trends that are not statistically significant, with big risks of false-positive conclusions - No impressive trends but large risks of false-negative conclusions; 3. Formal comparisons with non-randomized contemporaneous controls; 4. Formal comparisons with historic controls; 5. Case-series
Granados et al., 1997^ 117 ^ | Based on hierarchy of research design | NA | NA | | Level/strength of evidence upon which to base conclusions about the dissemination of technology assessments:; 1. Strong; based on empirical evidence, including experimental and quasi-experimental data; 2. Moderate; clear consensus among committee members; 3. Weak; insufficient evidence, but viewed as worth considering by committee members
Gray, 1997^ 124 ^ | Based on hierarchy of research design and execution | Number of studies and power | NA | | Strength of evidence:; 1. Strong evidence from at least one systematic review of multiple, well-designed randomized controlled trials; 2. Strong evidence from at least one properly designed randomized controlled trial of appropriate size; 3. Evidence from well-designed trials without randomization, single group pre-post, cohort, time series, or matched case-control studies; 4. Evidence from well-designed non-experimental studies from more than one center or research group; 5. Opinions of respected authorities, based on clinical evidence, descriptive studies or reports of expert committees
van Tulder et al., 1997^ 39 ^ | Based on hierarchy of research design and conduct of study | Number of studies | Contradictory findings rated as Level 4 evidence | | Levels of evidence:; 1. Strong evidence -- multiple relevant, high quality RCTs; 2. Moderate evidence -- one relevant, high quality RCT and one or more relevant, low quality RCTs; 3. Limited evidence -- one relevant, high quality RCT or multiple relevant, low quality RCTs; 4. No evidence -- only one relevant, low quality study, no relevant RCTs or contradictory outcomes | Based on rating system used for the U.S. Clinical Practice Guideline for Acute Low Back Problems in Adults.
Bartlett et al., 1998^ 118 ^ | Based on hierarchy of research design | Number of studies | NA | | Evidence grade:; 1. Evidence from at least one RCT; 2. Evidence from at least one well-designed clinical trial without randomization; 3. Evidence from opinions of respected authorities, based on clinical experience, descriptive studies, or reports of expert committees
Djulbegovic et al., 1998^ 125 ^ | Based on hierarchy of research design | Based partially on error rate Error rate Low: acceptable false-positive rate 5%; acceptable false-negative rate 20% Intermediate: false-positive rate cannot be computed Highest: hints of efficacy only | NA | | Levels:; 1. Well-designed prospective randomized controlled trials with a low error rate.*; 2. A single arm, prospective study, intermediate error rate.*; 3. Retrospective/anecdotal date with the highest error rate.*; *See quality column for definition of error rate. | Considers error rate and research design for grading the strength of the evidence
Edwards et al., 1998^ 126 ^ | Methodological quality | Effect size | NA | | Concept of Signal-to-Noise Ratio: The authors suggest that the weight of evidence be assessed by comparing "signal" to "noise." Signal depends largely on effect size, but is assessed in the light of relevance and applicability to a particular situation. Noise refers to design deficiencies or methodological weaknesses.
Bril et al., 1999^ 119 ^ | Based on hierarchy of research design | NA | NA | | A+ Randomized controlled, double-blind trials; 1. Randomized controlled trials; 2. Controlled trials; 3. Open trials; 4. Retrospective audits; 5. Case-reports, expert opinion
Chesson et al., 1999^ 127 ^ | Based on hierarchy of research design | Considers alpha and beta error | NA | | 1. Randomized well-designed trials with low alpha and low beta errors; 2. Randomized trials with high beta errors; 3. Nonrandomized controlled or concurrent cohort studies; 4. Nonrandomized historical cohort studies; 5. Case series | Adapted from Sackett^ 113 ^
Clarke and Oxman (Cochrane Collaboration Handbook) 1999^ 11 ^ | Based on hierarchy of research design, validity and risk of bias | Magnitude of effect | Consistency of effect across studies | 1. Dose-response relationship; 2. Supporting indirect evidence; 3. No other plausible explanation | Questions to consider regarding the strength of inference about the effectiveness of an intervention in the context of a systematic review of clinical trials:; - How good is the quality of the included trials?; - How large and significant are the observed effects?; - How consistent are the effects across trials?; - Is there a clear dose-response relationship?; - Is there indirect evidence that supports the inference?; - Have other plausible competing explanations of the observed effects (e.g., bias or cointervention) been ruled out?
Hoogendoorn et al., 1999^ 90 ^ | High quality: methodological quality score 50% of the maximum score Low quality: methodological quality score <50% of the maximum score | Number of studies | Inconsistent: if <75% of the available studies reported the same conclusion | | Evidence based on quality, number, and the outcome of studies:
  Strong | provided by generally consistent findings in multiple high-quality studies
  Moderate | generally consistent findings in 1 high-quality study and 1 low-quality study, or in multiple low-quality studies
  No evidence | only 1 study available or inconsistent findings in multiple studies.
Working Party for Guidelines for the Management of Heavy Menstrual Bleeding, 1999^ 120 ^ | Based on hierarchy of research design | NA | NA | | | Adapted from the National Health Service, United Kingdom. Grading is for quality of evidence and is based primarily on research design.
  Grade A | Evidence based on randomized controlled trials
  Grade B | Evidence based on robust experimental or observational studies
  Grade C | Evidence based on more limited evidence but the advice relies on expert opinion and has the endorsement of respected authorities
Shekelle et al., 1999^ 121 ^ | Based on hierarchy of research design | Multiplicity of studies | NA | | Category of evidence:
  IA | Evidence from meta-analysis of RCTs
  IB | Evidence from at least one randomized controlled trial
  IIA | Evidence from at least one controlled study without randomization
  IIB | Evidence from at least one other type of quasi-experimental study
  III | Evidence from non-experimental descriptive studies, such as comparative studies, correlation studies, and case-control studies
  IV | Evidence from expert committee reports or opinions or clinical experience of respected authorities, or both
Wilkinson, 1999^ 128 ^ | Based on design, execution, and analysis | Typically one study | NA | | Levels:; 1. Strong evidence, i.e., study design addressed the issue in question, study was performed in the population of interest, and was executed to ensure accurate and reliable data with appropriate statistical analysis; 2. Substantial evidence, i.e., study had some of the Level I attributes but not all of the attributes; 3. Consensus of expert opinion without Level I or Level II evidence.
Ariens et al., 2000^ 70 ^ | Based on hierarchy of research design | Multiplicity of studies | Consistency of findings | | Levels of evidence:; 1. Strong evidence: consistent findings in multiple high-quality cohort or case-referent studies; 2. Moderate evidence: consistent findings in multiple cohort or case-referent studies, of which only one study was high quality; 3. Some evidence: findings of one cohort or case-referent study, or consistent findings in multiple cross sectional studies, of which at least one study was high quality; 4. Inconclusive evidence: all other cases (i.e., consistent findings in multiple low quality cross-sectional studies, or inconsistent findings in multiple studies) | Applied to the question of physical risk factors for neck pain, hence only observational studies available for analysis.
Briss et al., 2000^ 82 ^ | Threats to validity: - study description - sampling - measurement - data analysis - interpretation of results - other Quality of execution: Good (0-1 threats) Fair (2-4 threats) Limited (5+ threats) Design suitability: Greatest- concurrent comparison groups and prospective measurement Moderate- all retrospective designs or multiple pre or post measurements; no concurrent comparison group Least- single pre and post-measurements; no concurrent comparison group or exposure and outcome measured in a single group at the same point in time. | Effect size - sufficient - large - small Larger effect sizes (absolute or relative risk) are considered to represent stronger evidence of effectiveness than smaller effect sizes with judgments made on an individual basis | Consistency as yes or no. | | Evidence of effectiveness is based on execution, design suitability, number of studies, consistency, and effect size Expert opinion: sufficient effect size Insufficient: insufficient design, too few studies, inconsistent, small effect size *See description under Quality column
  Strong:
  Strong: | | Good and greatest,* at least 2 studies, consistent, sufficient
  Strong: | | Good/fair and great/mod,* at least 5 studies consistent, sufficient
  Strong: | | Good/fair* and any design, at least 5 studies consistent, sufficient
  Sufficient:
  Sufficient: | | Good and greatest,* one study, consistency unknown, sufficient Good/fair and great/mod,* at least 3 studies consistent, sufficient
  Sufficient: | | Good/fair* and any design, at least 5 studies consistent, sufficient
Greer et al., 2000^ 83 ^ | Strong design not defined but includes issues of bias and research flaws | System incorporates number of studies and adequacy of sample size | Incorporates consistency | | Grade:; 1. Evidence from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizabiltiy, bias, and flaws in research design. Studies with negative results have sufficiently larded samples to have adequate statistical power.; 2. Evidence from studies of strong design but there is some uncertainty due to inconsistencies or concern about generalizabiltiy, bias, research design flaws, or adequate sample size. Or, evidence consistent from studies of weaker designs.; 3. The evidence is from a limited number of studies of weaker design. Studies with strong design either haven't been done or are inconclusive.; 4. Support solely from informed medical commentators based on clinical experience without substantiation from the published literature. | Does not require a systematic review of the literature -- only six "important" research papers.
Guyatt et al., 2000^ 84 ^ | Based on hierarchy of research design, with some attention to size and consistency of effect | Multiplicity of studies, with some attention to magnitude of treatment effects | Consistency of effect considered | | Hierarchy of evidence for application to patient care:; - N of 1 randomized trial; - Systematic reviews of randomized trials; - Single randomized trials; - Systematic review of observational studies addressing patient-important outcomes; - Single observational studies addressing patient-important outcomes; - Physiologic studies; - Unsystematic clinical observations; Authors also discuss a hierarchy of preprocessed evidence that can be used to guide the care of patients:; - Primary studies -- by selecting studies that are both highly relevant and with study designs that minimize bias, permitting a high strength of inference; - Summaries -- systematic reviews; - Synopses -- of individual studies or systematic reviews; - Systems -- practice guidelines, clinical pathways, or EB textbook summaries | Evidence defined broadly as any empirical observation about the apparent relationship between events. "The hierarchy is not absolute. If treatment effects are sufficiently large and consistent, for instance, observational studies may provide more compelling evidence than most RCTs."
Khan et al., 2000^ 12 ^ | Based on hierarchy of research design | Sample size and power for providing precise estimates | Referred to as heterogeneity among studies | | Level of evidence:
  1 | High quality experimental studies without heterogeneity and with precise results
  2/3 | Low quality experimental studies, high quality controlled observational studies
  4 | Low quality controlled observational studies, case series
  5 | Expert opinion
National Health and Medical Research Council, 2000^ 22 ^ | Did the study design eliminate bias? How well were the studies done? Were appropriate and relevant outcomes measured? | How big was the effect? Does the p-value or confidence interval reasonably exclude chance? | NA | | Levels of evidence: | In the guidelines process NHMRC asks other questions to assess the evidence: Were appropriate and relevant outcomes measured? Was the effect clinically important? Levels of evidence now exclude expert opinion and consensus from an expert committee, although such forms of evidence were admitted in the 1995 guidance.
  I | Evidence obtained from a SR of all relevant RCTs
  II | Evidence obtained from at least one properly designed RCT
  III-1 | Evidence obtained from well-designed pseudorandomized controlled trial
  III-2 | Evidence obtained from comparative studies (including SR of such studies) with concurrent controls and allocation not randomized, cohort studies, case-control studies, in interrupted time series with a control group
  III-3 | Evidence obtained from comparative studies with historical control, two or more single arm studies, or interrupted time series without a parallel control group
  IV | Evidence obtained from case series, either post-test or pretest/post-test
NHS Centre for Evidence Based Medicine, (http://cebm.jr2.ox.ac.uk) (accessed 12-2001)^ 85 ^ | Based on hierarchy of research design with some attention to risk of bias | Multiplicity of studies, and precision of estimate | Homogeneity of studies considered | | Criteria to rate levels of evidence vary by one of four areas under consideration (Therapy/Prevention or Etiology/Harm; Prognosis; Diagnosis; and Economic analysis). For example, for the first area (Therapy/Prevention or Etiology/Harm) the levels of evidence are as follows:
  1A | SR with homogeneity of RCTs
  1B | Individual RCT with narrow CI
  1C | All or none (this criteria met when all patients died prior to the treatment becoming available and now some survive or some died previously and now none die)
  2A | SR with homogeneity of cohort studies
  2B | Individual cohort study (including low quality RCT; e.g. <80% follow-up)
  2C | "Outcomes" research
  3A | SR with homogeneity of case-control studies
  3B | Individual case-control study
  4 | Case-series and poor quality cohort and case-control studies
  5 | Expert opinion without explicit critical appraisal or based on physiology, bench research or "first principles."
New Zealand Guidelines Group, 2000^ 13 ^ | Based on hierarchy of research design and validity | Multiplicity of studies, magnitude of effect and range of certainty | NA | | Evidence:; 1. Randomized controlled trials; 2. Non-randomized controlled studies; 3. Non-experimental designs: - Cohort studies - Case control; 4. Case series; 5. Expert opinion | Evidence grades 1 through 5 appear to be based on study type, but text also discusses the importance of evaluating the actual study validity. This system is designed for application to questions of effectiveness. They distinguish between grading evidence and critical appraisal -- for purposes of this summary we've merged these functions.
Sackett et al., 2000^ 91 ^ | Based on hierarchy of research design | Considers narrowness of CI which relates to sample size and extent of follow-up | Homogeneity exhibited in systematic reviews | | Level of evidence:
  1A | SR (with homogeneity) of RCTs
  1B | Individual RCT (with narrow CI)
  1C | All or none -- prior to availability of new therapy, all died, now with therapy some survive
  2A | SR (with homogeneity of cohort studies
  2B | Individual cohort study (including low-quality RCT; e.g. <80% follow-up
  2C | "Outcomes" research
  3A | SR (with homogeneity of case-control studies
  3B | Individual case-control study
  4 | Case series (and poor-quality cohort and case-control studies)
  5 | Expert opinion without explicit critical appraisal or based on physiology, bench research or "first principles"
Harbour and Miller, 2001^ 14 ^ | Based on hierarchy of research design and risk of bias in conduct of study | Multiplicity of studies | Consistency of evidence considered in guidelines development process | | SIGN's 1 through 4 level of evidence grading system is based on type of study, quality of study and risk of bias:
  1++ | High quality meta-anal, SR of RCTs or RCTs with very low risk of bias
  1+ | Well conducted meta-anal, SR of RCTs or RCTs with low risk of bias
  1− | Meta-analysis, SR of RCTs or RCTs with high risk of bias
  2++ | High quality SR of CC or cohort studies with very low risk of confounding or bias, and a high probability that relationship is causal
  2+ | Well conducted CC or cohort studies with a low risk of confounding or bias and a moderate probability that the relationship is causal
  2− | CC or cohort studies with a high risk of confounding or bias and a significant risk that the relationship is not causal
  3 | Non-analytic studies (e.g. case series)
  4 | Expert opinion
Harris et al., 2001^ 86 ^ Work for the U.S. Preventive Services Task Force | Based on hierarchy of research design and methodologic quality (good, fair, poor) within research design | Magnitude of effect (Numbers of studies or sizes of study samples are typically discussed by the USPSTF as part of this domain) | Consistency (Consistency is not required by the Task Force but if present, contributes to both coherence and quality of the body of evidence) | Coherence (Coherence implies that the evidence fits the underlying biologic model.) | Levels of evidence:; - Aggregate internal validity is the degree to which the study(ies) provides valid evidence for the population and setting in which it was conducted; - Aggregate external validity is the extent to which the evidence is relevant and generalizable to the population and conditions of typical primary care practice; - Coherence/consistency
  I | Evidence from at least one properly randomized controlled trial
  II-1 | Well-designed controlled trial without randomization
  II-2 | Well-designed cohort or CC analytic studies, preferably from more than one center or group
  II-3 | Multiple time series with or without the intervention (also includes dramatic results in uncontrolled experiments)
  III | Opinions of respected authorities, based on clinical experience, descriptive studies and case reports, or reports of expert committees
EPC Quality Assessments
Chestnut et al., 1999^ 60 ^ | Based on hierarchy of research design considered design and execution as well | Typically more than one | NA | | | Grading is for quality of evidence and is based primarily on research design.
  Class I :
  | Properly designed randomized controlled trials
  Class II:
  IIA | Randomized controlled trials that contain design flaws preventing a specification of Class I
  IIA | Multicenter or population-based longitudinal (cohort) studies
  IIB | Controlled trials that were not randomized
  IIB | Case-control studies
  IIB | Case series with adequate description of the patient population, interventions, and outcomes measured.
  Class III:
  - | Descriptive studies (uncontrolled case series)
  - | Expert opinion
  - | Case reports
  - | Clinical experience
West et al., 1999^ 65 ^ Pharmacological Treatment of Alcohol Dependence (RTI-UNC EPC) | Based on methodology, conduct, and analysis | Considers sample size and magnitude of difference in efficacy between intervention and placebo | Incorporates consistency among studies | | Grades: | Note: Primarily concerns RCTs because only one non-RCT was included in the analysis
  A (good) | Sufficient data for evaluating efficacy; sample size is adequate; data are consistent and indicate that the key drug is clearly superior to placebo for treatment of alcohol dependence.
  B (fair) | Sufficient data for evaluating efficacy; sample size is adequate; data indicate inconsistencies in findings for alcohol outcomes between the drug and placebo such that efficacy of the key drug for treatment of alcohol dependence is not clearly established.
  C (poor) | Sufficient and consistent evidence that the key drug is no more efficacious for treating alcohol dependence than placebo; sample size is adequate.
McNamara et al., 2001^ 66 ^ Management of New Onset Atrial Fibrillation (JHU EPC) | NA | Strength of evidence depends on estimated magnitude of effect, precision of estimate, and confidence that there is a true effect | NA | | System of grading dependent upon OR and CI: Evidence of efficacy:
  Strong | OR>1.0, 99% CI does not include 1.0
  Moderate | >OR>1.0, 95% CI does not include 1.0, but 99% CI does
  Suggestive | 95% CI includes 1.0 in the lower tail (0.05<p<0.2-0.3) and the OR is in a clinically meaningful range
  Inconclusive | 95% CI widely distributed around 1.0
  Evidence of Lack of Efficacy:
  Strong | OR near 1.0, 95% CI is narrow
Ross et al., 2001^ 67 ^ Management of Newly Diagnosed Patients with Epilepsy (Metaworks, Inc) | Based on hierarchy of research design | Number of studies and power of studies | NA | | Levels of evidence:; 1. Evidence obtained from meta-analysis of multiple, well-designed, controlled studies or from high-power RCTs; 2. Evidence obtained from at least one well-designed experimental study or low power RCT; 3. Evidence obtained from well-designed, quasi-experimental studies such as nonrandomized, controlled single group, pre-post, cohort, time, or matched case-control series; 4. Evidence from well-designed, nonexperimental studies, such as comparative and correlational descriptive and case studies; 5. Evidence from case reports and clinical examples | Evidence scores for individual studies were computed by dividing the Jadad score by the level of evidence.
Levine et al., 2000^ 147 ^ Diagnosis and Management of Breast Disease (Metaworks, Inc) | Based on hierarchy of research design | Number of studies and power of studies | NA | | 1. Evidence based on RCTs (or MA of RCT) of adequate size to ensure a low risk of incorporating false-positive or false-negative results; 2. Evidence based on RCTs that are too small to provide level I evidence. These may show either positive trends that are not statistically significant or no trends and are associated with a high risk of false-negative results.; 3. Evidence based on nonrandomized, controlled or cohort studies, case series, case-controlled studies or cross-sectional studies; 4. Evidence based on the opinion of respected authorities or that of expert committees as indicated in published consensus conferences or guidelines; 5. Evidence which expresses the opinion of those individuals who have written and reviewed these guidelines, based on their experience, knowledge of the relevant literature and discussion with their peers
Goudas et al, "Chapter 2. Methods." Management of Cancer Pain, 2000^ 68 ^ and Lau et al., "Chapter 2. Methods." Evaluating Technologies for Identifying ACI in ED, 2000^ 59 ^ | Internal validity graded on a 4 category system based on design and likelihood of bias (see details under system column) | Study size and magnitude of treatment effect | NA | Applicability of the evidence from study populations to the population at large | Internal validity of RCTs:; 1. Double-blinded, well-concealed randomization, few drop outs, and no (or only minor reporting problem of the trial that is likely to cause significant bias; 2. Single-blinded only, unclear concealment of randomization, or has some inconsistency in the reporting of the trial but is unlikely to result in major bias; 3. Unblinded study, inadequate concealment of random allocation, high drop out rate, or has substantial inconsistencies in the reporting of the trial such that it may result in large bias; 4. Inadequately reported (very often trials do not report certain data; this may occur by intent or due to oversight); Internal validity of non-randomized studies graded on study design and adequacy of reporting:; 1. Prospective controlled trial; 2. Cohort; 3. Case-series