# Appendix B: Quality of Evidence Grids

Quality Grid 1A. Evaluation of Quality Rating Systems for Systematic Reviews

Instrument | Domains
Instrument | Study Question | Search Strategy | Inclusion/Exclusion | Interventions | Outcomes | Data Extraction | Study Quality/Validity | Data Synthesis & Analysis | Results | Discussion | Funding/Support
Oxman and Guyett, 1991^ 4 ^; Oxman et al., 1991^ 5 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Irwig et al., 1994^ 6 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Oxman et al., 1994^ 15 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Cook et al., 1995^ 16 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Sacks et al., 1996^ 7 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Auperin et al., 1997^ 8 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Beck, 1997^ 9 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Cranney et al., 1997^ 17 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
de Vet et al., 1997^ 18 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Smith, 1997^ 10 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Barnes and Bero, 1998^ 3 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Pogue and Yusuf, 1998^ 19 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Sutton et al., 1998^ 20 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Clarke and Oxman, 1999^ 11 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Moher et al., 1999^ 21 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Khan et al., 2000^ 12 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
New Zealand Guidelines Group, 2000^ 13 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
NHMRC, 2000^ 22 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Harbour and Miller 2001^ 14 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Stroup et al., 2000^ 23 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]

Note: For complete reference information, see reference list

Quality Grid 1B. Description of Quality Rating Systems for Systematic Reviews

Instrument | Description of Instrument to Assess Study Quality
Instrument | Generic or specific instrument | Type of instrument? | Quality concept discussed | Method used to select items | Rigorous development process | Inter-rater reliability reported | Instructions provided for instrument use?
Oxman and Guyatt 1991^ 4 ^; Oxman et al., 1991^ 5 ^ | Generic | Checklist | No | Accepted | No | ICC=0.71 (95%CI:0.59-0.81) | Yes
Irwig et al., 1994^ 6 ^ | Generic | Checklist | No | Accepted | No | No | Partial
Oxman et al., 1994^ 15 ^ | Generic | Guidance | Partial | Accepted | No | No | Partial
Cook et al., 1995^ 16 ^ | Generic | Guidance | Partial | Both | Partial | No | Yes
Sacks et al., 1996^ 7 ^ | Generic | Checklist | No | Modified Sacks, et al., 1987^ 137 ^ | No | No | Yes
Auperin et al., 1997^ 8 ^ | Generic | Checklist | No | Modified Sacks, et al., 1987^ 137 ^ | No | ICC = 0.89-0.96 | Partial
Beck, 1997^ 9 ^ | Generic | Checklist | No | Modified multiple sources | No | % Agreement 87-89% | No
Cranney et al., 1997^ 17 ^ | Generic | Guidance | No | Modified Victor, 1995^ 138 ^ and Cook, 1995^ 16 ^ | Partial | No | No
de Vet et al., 1997^ 18 ^ | Specific | Guidance | Partial | Accepted | No | No | Partial
Smith, 1997^ 10 ^ | Generic | Checklist | No | Modified Mulrow 1987^ 94 ^ and Oxman, et al., 1994^ 15 ^ | No | No | Partial
Barnes and Bero, 1998^ 3 ^ | Generic | Scale | Partial | Modified Oxman, et al., 1994^ 15 ^ | No | r = 0.87 | No
Pogue and Yusuf, 1998^ 19 ^ | Generic | Guidance | Partial | Accepted | No | No | Partial
Sutton et al., 1998^ 20 ^ | Generic | Guidance | Yes | Modified multiple sources | No | No | Partial
Clarke and Oxman, 1999^ 11 ^ | Generic | Checklist | No | Both | Partial | No | Partial
Moher et al., 1999^ 21 ^ | Generic | Guidance | Yes | Both | Partial | No | Partial
Khan et al., 2000^ 12 ^ | Generic | Checklist | Yes | Both | No | No | Partial
New Zealand Guidelines Group, 2000^ 13 ^ | Generic | Checklist | No | Both | No | No | Partial
NHMRC, 2000^ 22 ^ | Generic | Guidance | Yes | Modified Clarke and Oxman (1999)^ 11 ^ | No | No | Partial
Harbour and Miller 2001^ 14 ^ | Generic | Checklist | Yes | Both | Partial | No | Yes
Stroup et al, 2000^ 23 ^ | Generic | Guidance | Partial | Both | No | No | Partial

Note: For complete reference information, see reference list ICC = intraclass correlation coefficient k = kappa R = correlation coefficient

Quality Grid 2A. Evaluation of Quality Rating Systems for Randomized Controlled Trails

Instrument | Domains
Instrument | Study Question | Study Population | Randomization | Blinding | Interventions | Outcomes | Statistical Analysis | Results | Discussion | Funding/Support
Chalmers et al., 1981^ 24 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
DerSimonian et al., 1982^ 43 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Evans and Pollock, 1985^ 25 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Liberati et al., 1986^ 26 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Poynard et al., 1987^ 44 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Prendiville et al., 1988^ 52 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Colditz et al., 1989^ 27 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Gotzsche, 1989^ 28 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Reisch et al., 1989^ 45 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Imperiale and McCullough, 1990^ 46 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Spitzer et al., 1990^ 47 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Kleijnen et al., 1991^ 29 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Detsky et al., 1992^ 30 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Guyatt et al., 1993^ 54 ^; Guyatt et al., 1994^ 53 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Cho and Bero, 1994^ 31 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Goodman et al., 1994^ 32 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Standards of Reporting Trials Group, 1994^ 55 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Fahey et al., 1995^ 33 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Schulz et al., 1995^ 51 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Asilomar Working Group on Recommendations for Reporting of Clinical Trials in the Biomedical Literature, 1996^ 56 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Moher et al., 2001^ 57 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Jadad et al., 1996^ 34 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Khan et al., 1996^ 35 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
van der Heijden et al., 1996^ 36 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Bender and Halpern, 1997^ 37 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
de Vet et al., 1997^ 18 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Sindhu et al., 1997^ 38 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
van Tulder et al., 1997^ 39 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Downs and Black, 1998^ 40 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Moher et al., 1998^ 41 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Verhagen et al., 1998^ 48 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Clarke and Oxman, 1999^ 11 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Lohr and Carey, 1999^ 1 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Khan et al., 2000^ 12 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
New Zealand Guidelines Group, 2000^ 13 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
NHMRC, 2000^ 49 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Harbour and Miller 2001^ 14 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Turlik and Kushner, 2000^ 42 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Zaza et al., 2000^ 50 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
EPC Quality Assessments
Aronson et al., 1999^ 58 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Chestnut et al., 1999^ 60 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Jadad et al., 1999^ 61 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Heidenreich et al., 1999^ 62 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Mulrow et al., 1999^ 63 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Vickrey et al., 1999^ 64 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
West et al., 1999^ 65 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
McNamara et al., 2001^ 66 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Ross et al., 2000^ 67 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Goudas et al., 2000^ 68 ^ Lau et al., 2000^ 59 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]

Note: For complete reference information, see reference list

Quality Grid 2B. Description of Quality Rating Systems for Randomized Controlled Trails

Instrument | Description of Instrument to Assess Study Quality
Instrument | Generic or specific instrument | Type of instrument? | Quality concept discussed | Method used to select items | Rigorous development process | Inter-rater reliability reported | Instructions provided for instrument use
Chalmers et al., 1981^ 24 ^ | Generic | Scale | Yes | Accepted | No | No | Yes
DerSimonian et al., 1982^ 43 ^ | Generic | Checklist | Partial | Accepted | No | % Agreement 51-82% | Partial
Evans and Pollock, 1985^ 25 ^ | Generic | Scale | No | Accepted | No | No | Yes
Liberati et al., 1986^ 26 ^ | Generic | Scale | Yes | Modified Chalmers et al., 1981^ 24 ^ | No | No | Partial
Poynard et al., 1987^ 44 ^ | Generic | Checklist | No | Modified Chalmers 1981^ 24 ^ | No | No | No
Prendiville et al., 1988^ 52 ^ | Generic | Guidance | Yes | Accepted | No | No | Yes
Colditz et al., 1989^ 27 ^ | Generic | Scale | Yes | Modified DerSimonian et al., 1982^ 43 ^ | Partial | No | Partial
Gotzsche, 1989^ 28 ^ | Specific | Scale | No | Accepted | No | No | Yes
Reisch et al., 1989^ 45 ^ | Generic | Checklist | Partial | Accepted | No | Partial | Yes
Imperiale et al., 1990^ 46 ^ | Generic | Checklist | Yes | Accepted | No | k = 0.79 | No
Spitzer et al., 1990^ 47 ^ | Generic | Checklist | Partial | Accepted | No | No | No
Kleijnen et al., 1991^ 29 ^ | Generic | Scale | Partial | Accepted | No | Partial | Partial
Detsky et al., 1992^ 30 ^ | Generic | Scale | Yes | Accepted | Partial | ICC = 0.92 | Partial
Guyatt et al., 1993^ 54 ^; Guyatt et al., 1994^ 53 ^ | Generic | Guidance | No | Accepted | No | No | Partial
Cho and Bero, 1994^ 31 ^ | Generic | Scale | Yes | Modified Spitzer et al., 1990^ 47 ^ | Partial | r = 0.60 ± 0.13 | Partial
Goodman et al., 1994^ 32 ^ | Generic | Scale | Yes | Both | Partial | ICC = 0.25 | Yes
Standards of Reporting Trials Group, 1994^ 55 ^ | Generic | Guidance | Yes | Both | Partial | No | Yes
Fahey et al., 1995^ 33 ^ | Generic | Scale | Partial | Modified Clarke and Oxman (1999)^ 11 ^ | No | No | No
Schulz et al., 1995^ 51 ^ | Generic | Component | Yes | Accepted | Yes | Partial | Yes
Asilomar Working Group, 1996^ 56 ^ | Generic | Guidance | No | Both | Partial | No | No
Moher et al., 2001^ 57 ^ | Generic | Guidance | Yes | Both | Partial | No | Yes
Jadad et al., 1996^ 34 ^ | Generic | Scale | Yes | Empiric | Yes | ICC = 0.66 (95% CI: 0.53-0.79) | Yes
Khan et al., 1996^ 35 ^ | Generic | Scale | Yes | Modified Jadad et al., 1996^ 34 ^ | Yes | k = 0.70-0.94 | Yes
van der Heijden et al., 1996^ 36 ^ | Specific | Scale | Partial | Accepted | No | No | Yes
Bender et al., 1997^ 37 ^ | Generic | Scale | Partial | Modified Jadad et al., 1996^ 34 ^ | Yes | ICC = 0.85 | Partial
de Vet et al., 1997^ 18 ^ | Generic | Scale | Partial | Accepted | No | No | No
Sindhu et al., 1997^ 38 ^ | Generic | Scale | No | Both | Yes | R = 0.90-0.99 | Partial
van Tulder et al., 1997^ 39 ^ | Generic | Scale | No | Accepted | No | No | No
Downs and Black, 1998^ 40 ^ | Generic | Scale | Partial | Both | Yes | r = 0.75 | Yes
Moher et al., 1998^ 41 ^ | Generic | Scale | Yes | Modified Jadad et al., 1996,^ 34 ^ and Schulz et al., 1995^ 51 ^ | Yes | No | Partial
Verhagen et al., 1998^ 48 ^ | Generic | Checklist | Yes | Both | Partial | No | No
Clarke and Oxman, 1999^ 11 ^ | Generic | Guidance | Yes | Both | No | No | Partial
Lohr and Carey, 1999^ 1 ^ | Generic | Guidance | Yes | Accepted | No | No | No
Khan et al., 2000^ 12 ^ | Generic | Checklist | Yes | Both | No | No | Partial
New Zealand Guidelines Group, 2000^ 13 ^ | Generic | Checklist | No | Both | No | No | Partial
NHMRC, 2000^ 49 ^ | Generic | Checklist | Yes | Both | No | No | No
Harbour and Miller 2001^ 14 ^ | Generic | Checklist | Yes | Both | Partial | No | Yes
Turlik and Kushner, 2000^ 42 ^ | Specific | Scale | No | Both | No | No | No
Zaza et al., 2000^ 50 ^ | Generic | Checklist | No | Accepted | No | % Agreement 65.2-85.6 % (Median= 79.5%) | Yes
EPC Quality Assessments
Aronson et al., 1999^ 58 ^ | Specific | Checklist | No | Both | No | No | Partial
Chestnut et al., 1999^ 60 ^ | Specific | Checklist | No | Both | No | No | Partial
Jadad et al., 1999^ 61 ^ | Specific | Scale | Yes | Both | No | No | Partial
Heidenreich et al., 1999^ 62 ^ | Specific | Checklist | No | Both | No | No | No
Mulrow et al., 1999^ 63 ^ | Specific | Scale | No | Both | No | No | Yes
Vickrey et al., 1999^ 64 ^ | Generic | Scale | Yes | Empiric | Yes | No | Yes
West et al., 1999^ 65 ^ | Specific | Scale | Yes | Accepted | Partial | k=0.66-0.88 | Yes
McNamara et al., 2001^ 66 ^ | Specific | Scale | Partial | Modified Detsky et al., (1992)^ 30 ^ and Clarke and Oxman (1999)^ 11 ^ | No | Partial | Partial
Ross et al., 2000^ 67 ^ | Generic | Scale | Yes | Modified Jadad et al., 1996^ 34 ^ | No | Partial | Yes
Goudas et al., 2000^ 68 ^ Lau et al., 2000^ 59 ^ | Generic | Component | Yes | Accepted | No | No | Partial

Note: For complete reference information, see reference list ICC = intraclass correlation coefficient k = kappa R = correlation coefficient

Quality Grid 3A. Evaluation of Quality Rating Systems for Observational Studies

Instrument | Domains
Instrument | Study Question | Study Population | Comparability Of Subjects | Exposure/Intervention | Outcome Measure | Statistical Analysis | Results | Discussion | Funding
Reisch et al., 1989^ 45 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Spitzer et al., 1990^ 47 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Carruthers et al., 1993^ 71 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Cho and Bero, 1994^ 31 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Goodman et al., 1994^ 32 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Laupacis et al., 1994^ 72 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Levine et al., 1994^ 73 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Downs and Black, 1998^ 40 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Angelillo and Villari, 1999^ 74 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Corrao et al., 1999^ 69 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Lohr and Carey, 1999^ 1 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Ariens et al., 2000^ 70 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Khan et al., 2000^ 12 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
New Zealand Guidelines, 2000^ 13 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
NHMRC, 2000^ 49 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Harbour and Miller 2001^ 14 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Zaza et al., 2000^ 50 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
EPC Quality Assessments
Chestnut et al., 1999^ 60 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]
Vickrey et al., 1999^ 64 ^ | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image] | [image]

Note: For complete reference information, see reference list

Quality Grid 3B. Description of Quality Rating Systems for Observational Studies

Instrument | Description of Instrument to Assess Study Quality
Instrument | Generic or specific instrument | Type of instrument? | Quality concept discussed | Method used to select items | Rigorous development process | Inter-rater reliability reported | Instructions provided for instrument use?
Reisch et al., 1989^ 45 ^ | Generic | Checklist | Partial | Accepted | No | Partial | Yes
Spitzer et al., 1990^ 47 ^ | Generic | Checklist | Partial | Accepted | No | No | No
Carruthers et al., 1993^ 71 ^ | Generic | Guidance | No | Accepted | No | No | No
Cho and Bero, 1994^ 31 ^ | Generic | Scale | Yes | Modified Spitzer et al., 1990^ 47 ^ | Partial | r = 0.60 ± 0.13 | Yes
Goodman et al., 1994^ 32 ^ | Generic | Scale | Yes | Both | Partial | ICC = 0.25 | Yes
Laupacis et al., 1994^ 72 ^ | Generic | Guidance | No | Accepted | No | No | Partial
Levine et al., 1994^ 73 ^ | Generic | Guidance | No | Accepted | No | No | Partial
Downs et al., 1998^ 40 ^ | Generic | Scale | Partial | Both | Yes | r = 0.75 | Yes
Angelillo and Villari, 1999^ 74 ^ | Specific | Guidance | Partial | Modified Chalmers et al., 1981,^ 24 ^ and Longnecker, 1988^ 139 ^ | No | No | No
Corrao et al., 1999^ 69 ^ | Specific | Scale | No | Accepted | No | No | No
Lohr and Carey, 1999^ 1 ^ | Generic | Guidance | Yes | Accepted | No | No | No
Ariens et al., 2000^ 70 ^ | Specific | Checklist | Yes | Accepted | Partial | % Agreement between 2 reviewers = 84% | Partial
Khan et al., 2000^ 12 ^ | Generic | Checklist | Yes | Accepted | No | No | Partial
New Zealand Guidelines Group, 2000^ 13 ^ | Generic | Checklist | No | Both | No | No | Partial
NHMRC, 2000^ 49 ^ | Generic | Checklist | Yes | Both | No | No | Partial
Harbour and Miller 2001^ 14 ^ | Generic | Checklist | Yes | Both | Partial | No | Yes
Zaza et al., 2000^ 50 ^ | Generic | Checklist | No | Accepted | No | % Agreement 65.2-85.6% (Median = 79.5%) | Yes
EPC Quality Assessments
Chestnut et al., 1999^ 60 ^ | Specific | Checklist | No | Both | No | No | Partial
Vickrey et al., 1999^ 64 ^ | Generic | Scale | No | Accepted | No | No | Partial

Note: For complete reference information, see reference list ICC = intraclass correlation coefficient k = kappa R = correlation coefficient

Quality Grid 4A. Evaluation of Quality Rating Systems for Diagnostic Studies

Instrument | Domains
Instrument | Study Population | Adequate Description of Test | Appropriate Reference Standard | Blinded Comparison of Test and Reference | Avoidance of Verification Bias
Sheps and Schechter, 1984^ 75 ^; Arroll et al., 1988^ 76 ^ | [image] | [image] | [image] | [image] | [image]
Begg, 1987^ 140 ^ | [image] | [image] | [image] | [image] | [image]
Working Group on methods for prognosis and decision making, 1990^ 141 ^ | [image] | [image] | [image] | [image] | [image]
Hoffman et al., 1991^ 111 ^ | [image] | [image] | [image] | [image] | [image]
Pinson et al., 1991^ 142 ^ | [image] | [image] | [image] | [image] | [image]
Carruthers et al., 1993^ 71 ^ | [image] | [image] | [image] | [image] | [image]
Jaeschke et al., 1994^ 143 ^ | [image] | [image] | [image] | [image] | [image]
Irwig et al., 1994^ 6 ^ | [image] | [image] | [image] | [image] | [image]
Reid et al., 1995^ 144 ^ | [image] | [image] | [image] | [image] | [image]
Cochrane Methods Working Group, 1996^ 77 ^ | [image] | [image] | [image] | [image] | [image]
Bruns, 1997^ 145 ^ | [image] | [image] | [image] | [image] | [image]
Lijmer et al., 1999^ 78 ^ | [image] | [image] | [image] | [image] | [image]
Khan et al., 2000^ 12 ^ | [image] | [image] | [image] | [image] | [image]
NHMRC, 2000^ 49 ^ | [image] | [image] | [image] | [image] | [image]
Harbour and Miller, 2001^ 14 ^ | [image] | [image] | [image] | [image] | [image]
EPC Quality Assessments
McCrory et al., 1999^ 79 ^ | [image] | [image] | [image] | [image] | [image]
Ross et al., 1999^ 80 ^ | [image] | [image] | [image] | [image] | [image]
Goudas et al., 2000;^ 68 ^ Lau et al., 2000^ 59 ^ | [image] | [image] | [image] | [image] | [image]

Note: For complete reference information, see reference list

Quality Grid 4B. Description of Quality Rating Systems for Diagnostic Studies

Instrument | Description of Instrument to Assess Study Quality
Instrument | Generic or specific instrument | Type of instrument? | Quality concept discussed | Method used to select items | Rigorous development process | Inter-rater reliability reported | Instructions provided for instrument use?
Sheps and Schechter, 1984^ 75 ^; Arroll et al., 1988^ 76 ^ | Generic | Checklist | No | Accepted | No | k = 0.81-1.0 | Partial
Begg, 1987^ 140 ^ | Generic | Guidance | Partial | Accepted | No | No | Partial
Working Group, 1990^ 141 ^ | Generic | Guidance | No | Accepted | Partial | No | Partial
Hoffman et al., 1991^ 111 ^ | Specific | Checklist | Partial | Based on multiple other systems | No | k = 0.61 | Yes
Pinson et al., 1991^ 142 ^ | Specific | Guidance | No | Modified Becker, 1989^ 146 ^ | No | No | Yes
Carruthers et al., 1993^ 71 ^ | Generic | Guidance | No | Accepted | No | No | no
Jaeschke et al., 1994^ 143 ^ | Generic | Guidance | No | Accepted | No | No | Partial
Irwig et al., 1994^ 6 ^ | Generic | Guidance | Yes | Accepted | No | No | Partial
Reid et al., 1995^ 144 ^ | Generic | Guidance | Yes | Accepted | No | No | Yes
Cochrane Methods Working Group, 1996^ 77 ^ | Generic | Checklist | Partial | Accepted | No | No | Yes
Bruns, 1997^ 145 ^ | Generic | Guidance | Partial | Accepted | Partial | No | Partial
Lijmer et al., 1999^ 78 ^ | Generic | Checklist | Yes | Both | Partial | No | Partial
Khan et al., 2000^ 12 ^ | Generic | Checklist | Yes | Both | No | No | Partial
NHMRC, 2000^ 49 ^ | Generic | Checklist | Yes | Modified Clarke and Oxman, 1999^ 11 ^ | No | No | Partial
Harbour and Miller 2001^ 14 ^ | Generic | Checklist | Yes | Both | Partial | No | Yes
EPC Quality Assessments
McCrory et al., 1999^ 79 ^ | Generic | Scale | No | Accepted | No | No | Partial
Ross et al., 1999^ 80 ^ | Specific | Scale | Yes | Accepted | Partial | No | Partial
Goudas et al., 2000^ 68 ^, Lau et al., 2000^ 59 ^ | Generic | Component | Yes | Accepted | No | No | Partial

Note: For complete reference information, see reference list ICC = intraclass correlation coefficient k = kappa R = correlation coefficient