# Appendix A: Approaches to Grading Quality and Rating Strength of Evidence Used by Evidence-based Practice Centers

## Introduction

An important element of this project was to summarize how the 12 evidence-based practice centers (EPCs) supported by the Agency for Healthcare Research and Quality (AHRQ) rated individual study quality and graded the strength of a body of evidence for their various evidence reports and technology assessments. The initial step in gathering information was for the AHRQ EPC Program Officer to ask the EPCs, on behalf of the team from the Research Triangle Institute-University of North Carolina (RTI-UNC) EPC, to identify the methods they used in these steps, assuming they did them at all. To assist in this process, RTI-UNC EPC staff reviewed the methods sections and appendices of all published evidence reports done by the EPCs for relevant information and then included this information with the form from the AHRQ Program Officer (Exhibit A-1) that asked the EPCs to specify how they handled quality ratings and evidence strength grading for their initial, subsequent, and current evidence reports and technology assessments. Several EPCs chose to summarize their procedures for us in a memorandum. We compiled the information (see Tables A-1 and A-2) and incorporated it into the appropriate grids (Appendices B and C).

## Findings

Of the 12 EPCs, 10 did formally evaluate quality of articles in some fashion. Those that did applied numerous different techniques (Table A-1), and some based their quality assessments on study design only. Those that formally evaluated quality and developed a quality score employed several key study design components either as part of their inclusion/exclusion criteria or as components in their meta-analyses.

EPCs used quality ratings in several different ways:

1. As a factor in sensitivity or meta-analyses (Blue Cross and Blue Shield Association, Johns Hopkins University, New England Medical Center, Duke University, University of California at San Francisco-Stanford, University of Texas at San Antonio);
2. Descriptively in the evidence tables, results, and/or discussion section of their evidence reports (ECRI, McMaster University, Oregon Health Sciences University, RAND-Southern California, RTI-UNC); and
3. As inclusion/exclusion criteria for the literature searches of their evidence reports (MetaWorks, Inc.).

The data provided in Table A-2 are based on the completed surveys we received from each of the EPCs. Little changed over time with respect to whether and how the EPCs rated study quality. Five EPCs graded the strength of bodies of evidence in their first EPC projects, and the same five currently grade evidence strength.

Exhibit A-1. Information Requisition Letter to EPCs

July 7, 2000

Dear EPC Directors and staff:

Thank you so very much for participating in our phone call with all the EPCs on May 22. As was discussed during the call, the RTI-UNC EPC has a very exciting but somewhat daunting task ahead of them and they need as much help from their fellow EPCs as they can possibly get!

The RTI-UNC EPC has organized an absolutely wonderful expert panel for this project. They include:

- Doug Altman
- Lisa Bero
- Alan Garber
- Steven Goodman
- Jeremy Grimshaw
- Alejandro Jadad
- Joseph Lau
- David Moher
- Cynthia Mulrow
- Andy Oxman
- Paul Shekelle

As Sue West indicated on the call, she has already reviewed the published AHRQ evidence reports (ERs) to identify the rating scales and methodologies for grading the evidence that were used by each EPC for their first ER (please see attached spreadsheet indicating which reports were reviewed). If information was available on rating scales or grading classifications from your ER(s), we are including a copy of the specific pages from your report with this letter. Please review this attached information to make sure that it accurately reflects the procedures you used at that time. Also, several of you very graciously provided Kathleen Lohr with information for her earlier project on the issues involved in grading articles and evidence so you certainly do not need to re-send this to the RTI-UNC EPC!

As the spreadsheet indicates, all of the EPCs have been funded to develop additional ERs. Your procedures may have changed somewhat as you worked on subsequent ERs. We would appreciate if you would share your procedures and full documentation that indicates how you are currently rating the quality of studies and grading the evidence so that the RTI-UNC EPC can document this in their report to AHRQ.

This information can be sent directly to Sue West at the following address: Suzanne L. West, Ph.D., M.P.H. Cecil G. Sheps Center for Health Services Research 725 Airport Road CB# 7590 University of North Carolina Chapel Hill, NC 27599-7590

Alternatively, you can email to Sue_West@med.unc.edu or fax to 919-966-5764.

If you have suggestions for other scales or grading schemes or people to contact for this information, please provide this to Sue as well.

In their first ER, Pharmacotherapy for Alcohol Dependence, the RTI-UNC EPC did grade the evidence for their 5 key questions. With this letter, we have included copied pages from their evidence report that give their procedures as an example of what is meant by "grading the evidence" in the context of the current project, "Systems to Rate the Strength of the Scientific Evidence."

If you have any questions or need further guidance regarding your contributions to the RTI-UNC project, please don't hesitate to call Sue at 919-843-7662. Because of the timeline for this project, it would be great if you could send your information to Sue West by Friday, July 21. In replying to Sue, please include this letter and check the appropriate box indicating which information you are sending (or not sending!) to UNC. We (AHRQ and the RTI-UNC EPC) really appreciate your assisting the RTI-UNC EPC with this project.

- 1997 ER (first ER) for AHRQ

### Rating study quality

[image] | Contained forms and description for rating the quality of individual studies | [image] | [image] Rating and description is being sent to the RTI-UNC EPC [image] This info is not available to send
[image] | Did not contain information on rating the quality of individual studies

### Grading the evidence for key questions

[image] | Contained information on grading the evidence | [image] | [image] This info is being sent to the RTI-UNC EPC [image] This info is not available to send
[image] | Did not contain information on grading the evidence
- Subsequent ERs for AHRQ or other funding sources

### Rating study quality

[image] | Contained forms and description for rating the quality of individual studies | [image] | [image] Rating and description is being sent to the RTI-UNC EPC [image] This info is not available to send
[image] | Did not contain information on rating the quality of individual studies

### Grading the evidence for key questions

[image] | Contained information on grading the evidence | [image] | [image] This info is being sent to the RTI-UNC EPC [image] This info is not available to send
[image] | Did not contain information on grading the evidence
- Are you currently:

### Rating study quality?

[image] Yes
[image] No

### Grading the evidence for key questions?

[image] Yes
[image] No

Legend:

Yes

Partial

No

Thank you, in advance, for your help! Sincerely, Jacqueline Besteman

cc: Kathleen N. Lohr, PhD Valerie King, MD Suzanne L. West, PhD, MPH

encl: EPC-specific pages from first evidence report Pages from RTI-UNC Alcohol Pharmacotherapies evidence report Spreadsheet with all projects 4-page project summary

Topic and Nominators and Partners by EPC | How Was Quality Measured in the Report? | How Was Quality Used in the Report?
Blue Cross and Blue Shield Association Technology Evaluation Center (TEC)
Relative Effectiveness and Cost-Effectiveness of Methods of Androgen Suppression Treatment in the Treatment of Advanced Prostatic Cancer Health Care Financing Administration | Assessed the quality of methods and reporting to determine whether the studies could be grouped into categories by grade of methodologic quality. Factors assessed included: Formal quality rating was not given, component approach provided on evidence tables. | Quality used for sensitivity analyses. Meta-analysis combined hazard ratios for studies of "high" quality but "high" was not defined.
  Random sequence generation
  Blinding of randomization process during recruitment
  Blinding of investigator and patient to treatment
  Study withdrawals
  Intent to treat
  Power
  Compliance with treatment
  Description of treatment protocols
Duke University
Evaluation of cervical cytology American College of Obstetricians and Gynecologists | Quality criteria for diagnostic tests; - Test and reference measured independently; - Test compared to valid reference standard; - Choice of patients for reference standard independent of test results; - Sample selection addressed; - Location of publication; - Funding source; Consensus on the seven quality points, weight determined by consensus and averaging | Evaluated the effect of study quality on summary effectiveness scores using individual components of the score, then using the total score both as a continuous and dichotomous (cutpoint 7).
ECRI
Diagnosis and treatment of dysphagia/swallowing problems in elderly Health Care Financing Administration | Quality measured by study design. | Study design reported in evidence tables and discussed in the results section of the evidence report.
Johns Hopkins University
Evaluation and treatment of new onset atrial fibrillation, in the elderly American Academy of Family Physicians | 22 questions, major domains listed below: | The EPC noted that it would have used study quality in a sensitivity analysis but there were too few studies.
  Thoroughness of population description
  Bias and confounding (description of randomization and blinding
  Standard protocol, other therapies received
  Outcomes and follow-up
  Statistical quality and interpretation
McMaster University
Treatment of attention deficit/hyperactivity disorder American Academy of Pediatrics, American Psychiatric Association | Quality was based on the Jadad scale for randomized controlled trials | Authors used quality to describe results and conclusions.
  Randomization
  Blinding
  Withdrawals
  Industry support
MetaWorks, Inc.
Diagnosis of sleep apnea Blue Cross/Blue Shield of Massachusetts, Sleep Disorder Center of Metro Toronto | Diagnostic studies rated by Irwig instrument before data abstraction | Quality score ranged from 0-44; papers with a quality score of <16 were not abstracted.
  Random order of assignment
  Use of a gold standard
  Blinded reading of test and gold standard
New England Medical Center
Diagnosis and treatment of acute bacterial rhinosinusitis American Academy of Otolaryngology, American Academy of Family Practice, American Academy of Pediatrics, American College of Physicians | Quality was based on the Jadad scale for randomized controlled trials | Quality was used for sensitivity measure in meta-analysis
  Randomization
  Blinding
  Withdrawals
  Use of a composite quality score
  Use of factor(s) that relate to systematic bias
Oregon Health Sciences University
Rehabilitation of persons with traumatic brain injury National Institute of Child Health and Human Development Brain Injury Association | Levels of quality | Quality levels were used descriptively in the results and conclusions section of the report.
  Class I: properly designed RCTs
  Class II a: RCTs with design flaws or multicenter or population-based longitudinal (cohort) studies b: Controlled trials that were not randomized, case-control studies, case series with adequate description of population, intervention, outcomes
  Class III: descriptive studies, expert opinion, case reports, clinical experience
RAND-Southern California Evidence-based Practice Center
Prevention and management of urinary complications in paralyzed persons Paralyzed Veterans of America, American Association of Spinal Cord Injury Psychologists, American Congress of Rehabilitation Medicine, American Paraplegia Society, Association of Rehabilitation Nurses, Consortium for Spinal Cord Medicine | Quality was based on the Jadad scale for randomized controlled trials Cohort studies: | Quality grades were reported in evidence tables.
  Randomization
  Blinding
  Withdrawals
  Comparability at baseline or whether adjustments made during analysis
  Masked measurement of outcomes and risk factors
Research Triangle Institute -- University of North Carolina, Chapel Hill
Pharmacotherapy for alcohol dependence American Society of Addiction Medicine | Quality rating score adapted from scoring for spinal cord clinical guideline. | Authors reported quality scores in evidence tables and used them descriptively for results and conclusions.
University of California at San Francisco/Stanford University
Management of stable angina American College of Cardiology/American Heart Association Task Force on Practice Guidelines/American College of Physicians | Four indicators: | Authors used quality ratings in subgroup analyses.
  Randomization
  Blinding
  Description of randomization method
  Mention of exclusions
University of Texas at San Antonio EPC
Depression treatment with new drugs National Institute of Mental Health, American Psychiatric Association, American Pharmaceutical Association Vermont Department of Mental Health/Mental Retardation Blue Cross/Blue Shield of Massachusetts, American College of Physicians, Kaiser Permanente of Northern California | Internal validity used instead of quality | Authors used the dropout rate in meta-analysis looking at response rates.
  Randomization (method and concealment)
  Blinding
  Co-interventions
  Dropouts

Refer to Table

EPC | Subsequent Evidence Reports for AHRQ or Others | | Current Practice
EPC | Rating Study Quality | Grading the Evidence for Key Questions | Rating Study Quality | Grading the Evidence for Key Questions
Blue Cross and Blue Shield | [image] | [image] | [image] | [image]
Duke University | [image] | [image] | [image] | [image]
ECRI | [image] | [image] | [image] | [image]
Johns Hopkins University | [image] | [image] | [image] | [image]
McMaster University | [image] | [image] | [image] | [image]
MetaWorks, Inc. | [image] | [image] | [image] | [image]
New England Medical Center | [image] | [image] | [image] | [image]
Oregon Health Sciences University | [image] | [image] | [image] | [image]
Southern California Evidence-based Practice Center-RAND | [image] | [image] | [image] | [image]
RTI-UNC | [image] | [image] | [image] | [image]
UCSF-Stanford | [image] | [image] | [image] | [image]
UT-San Antonio | [image] | [image] | [image] | [image]

Legend:

Yes

Partial

No