# Appendixes

Appendix A: Approaches to Grading Quality and Rating Strength of Evidence Used by Evidence-based Practice Centers

Appendix B: Quality of Evidence Grids

Appendix C: Strength of Eviendce Grids Acronyms

Appendix D: An Annotated Bibliography of Empiric Evidence Used in Grid Development

Systematic Reviews and Meta-Analyses

Randomized Controlled Trials

Observational Studies

Diagnostic Studies

Appendix E: Excluded Articles

Appendix F: Abstraction Forms

Appendix G: Glossary