# Evidence Tables

Studies of Development of Decision Aids

Evidence Table 4.1a. Schapira (1997) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Schapira M, 1997 Country: USA RefMan ID: 123 Study purpose: To develop and evaluate a decision aid (DA) to help patients understand therapy options and enhance the process of informed patient decision-making | Study design: One group pre-post intervention Duration of the study: NR Validity: Content, consensus | Setting: Out-patient Type of cancer: Prostate Type of decision: Treatment (primary) Model of decisionmaking:; - Informed as stated by authors and determined by reviewers; Phase of decision:; - Information transfer; Context of decision: Radiation therapy vs. radical prostatectomy vs. watchful waiting | Description: Videotape ^a^ Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Researcher Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 32 Characteristics: Primary care outpatients without prostate cancer Age: Mean: NR; SD: NR; range: 50 to 85 years Education: reading level < 6 grade: 5 subjects (16%); > 6 and < 12: 12 (37%); > 12: 15 (47%). Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Face psychometric properties of DA; - Clarity of DA; - Comprehensiveness of DA; - Knowledge; - Attitudes toward decisionmaking; - Satisfaction; Outcomes measured:; - before and after the intervention

a 20-minute videotape. Contained a description of the anatomy of the prostate gland, epidemiology of prostate cancer, treatment options and outcomes, efficacy of treatment, and management of possible side effects. The video portion of the script was designed to complement the audio portion by the use of role modeling; reinforcement of quantitative data with visual presentations; and footage of the operating room, radiation suites, and other medical and community settings. Excerpts from interviews with physicians (i.e., radiation oncologist) were used to describe the three-option treatment process with patients who described personal treatment experiences. Long-term side effects associated with radiation therapy and radical prostatectomy were presented as numerical outcomes, while survival outcomes were presented qualitatively.

Studies of Development of Decision Aids

Evidence Table 4.1b. Shapira (1997) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Schapira M, 1997 Country: USA RefMan ID: 123 | n = 32 Videotape | comprehensiveness and clarity of DA | | - 31/32 felt the information presented in the video was clear and easy to understand:
Schapira M, 1997 Country: USA RefMan ID: 123 | n = 32 Videotape | Knowledge ^a^ | - mean percentage correct answers ^b^ : 46.2 | - mean percentage correct answers ^b^ : 73.9; - authors report: "Subjects generally demonstrated improvement in qualitative knowledge of therapy side effects" (p.123) | Differences between pre- and post-test were statistically significant in 10/14 items (p < 0.05) (McNemars' test for matched pairs)
Schapira M, 1997 Country: USA RefMan ID: 123 | n = 32 Videotape | attitudes toward decisionmaking ^a^ | a) Defer the decision to the physician: 9/32 (28%) b) Would pursue behaviors of information seeking, such as asking a second opinion: 3/32 (9%) c) Joint decisionmaking discussion between the physician and the patient: 1/32 (3%) d) Family advice: 4/32 (13%) e) Consideration of treatment side effects: 1/32 (3%) | a) Defer the decision to the physician: 5/32 (16%) b) Would pursue behaviors of information seeking, such as asking a second opinion: 10/32 (31%) c) Joint decisionmaking discussion between the physician and the patient: 7/32 (22%) d) Family advice: 2/32 (5%) e) Consideration of treatment side effects: 6/32 (19%) | No statistical analyses were performed
Schapira M, 1997 Country: USA RefMan ID: 123 | n = 32 Videotape | satisfaction | | "Subjects expressed satisfaction with this format of education" (page 124)

Outcomes were measured at baseline and after the intervention (timing not specified).

a "The knowledge assessment instrument included 20 multiple choice questions developed by the investigator and based on the videotape content. Topics covered by the questions included anatomy and physiology of the prostate, risk factors and epidemiology of prostate cancer, common short-term and long-term side effects of radiation and radical prostatectomy, the definition and indications for watchful waiting, and the relative efficacy of surgery and radiation." (p. 122)

b Mean of percentages was obtained from Table 2 results. We added up the percentage of each of the 14 questions reported, then divided by 14.

c This outcome was measured by responses to three open-ended questions: 1) Describe how you would go about making a decision about treating your prostate cancer; 2) What role do you want your doctor to play when making a decision about prostate cancer treatment? and 3) Who (in addition to your doctor) would you want to help you in making the decision about treatment? The responses were grouped by major themes and then coded.

Studies of Development of Decision Aids

Evidence Table 4.2a. Gustafson (1993, Study 1) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Gustafson D, 1993; Gustafson, D, 1993; Taylor, JO, 1994; Owens, BH, 1996 Study 1 Country: USA RefMan ID: 1196, 5048, 5047, 4219 Study purpose: To evaluate ("field testing") the use of a computer based program in breast cancer patients | Study design: Case series Duration of the study: Total duration of the study: Not clear Duration for an individual patient: 7 weeks Validity: Content Readability: Grade level: 8 | Setting: Home Type of cancer: Breast Type of decision: Treatment Model of decision-making:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Not clear | Description: Computer-based program that uses a modem to connect to a central computer (CHESS) ^a^ Purpose:; - Help people experiencing a health crisis; - Increase knowledge; - Help make a decision; Intervention administered by: Researcher Timing of the intervention:; - after the decision was made | Number of subjects enrolled: 10 Characteristics:; - Women with breast cancer; - Treatment choice: mastectomy: 7 subjects, lumpectomy: 3.; - Mean time since diagnosis: 31.7 months; Age: Mean: NR; SD: NR; Median: 51 years Education: Completed college: 10 subjects; - Computer experience: 6 subjects; Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Acceptability of DA; - Feasibility; - Would recommend DA to other patients; - "Emotions"; Outcomes measured:; - after the intervention

a CHESS: Comprehensive Health Enhancement Support System: "The interface is interactive and easy to use and utilizes color and graphics on a personal computer with a VGA monitor and modem" (RefMan ID 1196, p.75). The program has 9 components that can be tailored to any topic: "Questions and answers," "Instant Library," "Getting help/support," "Personal stories," "Ask an expert," "Discussion group," "Decision aid," "Action plan," "Assessment." In the Decision Aid component, suggestions by experts and other patients help the subject in making difficult decisions. In the case of breast cancer, the patients are helped to decide about surgery, adjuvant hormonal therapy, or chemotherapy and joining clinical trials. The Decision Aid "does not tell users what they should do; it shows users how the computer used their input to predict the choice they might make" (RefMan ID 1196, p. 74).

Studies of Development of Decision Aids

Evidence Table 4.2b. Gustafson (1993, Study 1) Results

Author | Intervention | Outcome(s) | Postintervention Results ^a^ | Notes
Gustafson D, 1993; Gustafson D, 1993; Taylor JO, 1994; Owens BH, 1996 Study 1 Country: USA RefMan ID: 1196, 5048, 5047, 4219 | n = 10 Computer-based program that uses a modem to connect to a central computer (CHESS) | acceptability of DA ^b^ | Mean scores for each component of the Intervention: ***; - Discussion Group: > 4; - Instant Library: > 4; - Ask an Expert:; - Questions and Answers: > 4; - Decision Aid: 4; - Getting Help/Support: > 4.5; - Action Plan: > 3 | *** 7/9 components of the intervention were evaluated. Personal Stories in this study was part of Instant Library.
Gustafson D, 1993; Gustafson D, 1993; Taylor JO, 1994; Owens BH, 1996 Study 1 Country: USA RefMan ID: 1196, 5048, 5047, 4219 | n = 10 Computer-based program that uses a modem to connect to a central computer (CHESS) | Feasibility ^c^ | - Discussion Group: 46.3%; - Instant Library: 15.9%; - Ask an Expert: 14.8%; - Questions and Answers: 11.6%; - Decision Aid: 5.7%; - Getting Help/Support: 2.9%; - Action Plan: 2.8% | subjects used CHESS 546 times (more than 1 minute of use) during the 50-day trial.
Gustafson D, 1993; Gustafson D, 1993; Taylor JO, 1994; Owens BH, 1996 Study 1 Country: USA RefMan ID: 1196, 5048, 5047, 4219 | n = 10 Computer-based program that uses a modem to connect to a central computer (CHESS) | would recommend DA to other patients ^d^ | - Perceived value for breast cancer patients at diagnosis: mean: 4.2; SD: NR; - Perceived value for breast cancer patients during therapy: mean: 4.7; SD: NR; - Perceived value for breast cancer patients after treatment: mean: 3.5; SD: NR
Gustafson D, 1993; Gustafson D, 1993; Taylor JO, 1994; Owens BH, 1996 Study 1 Country: USA RefMan ID: 1196, 5048, 5047, 4219 | n = 10 Computer-based program that uses a modem to connect to a central computer (CHESS) | "emotions" ^e^ | - Positive emotions mean score: * Range: 4.0 to 6.2; - Negative emotions mean score: ** Range: 1.1 to 4.0 | ^*^ "Relief" was not assessed ^**^ "Frustration" was not assessed

Outcomes measured postintervention only.

a Results for Emotions and Acceptability of DA were extracted from the figures presented in the paper. Raw data are not reported.

b Mean feeling score: perceived value of Decision Aid. Value score 1 = not at all to 5 = very.

c Frequency of usage was defined as one entry into a CHESS service that lasted 1 minute; the authors reported the percentage of total uses per service

d This outcome was measured on a 5-point scale with 1 = not valuable and 5 = very valuable.

e The authors list a series of states that they define as positive emotions (understanding, support, empathy, acceptance, motivation, relief, empowerment, elation) and negative emotions (sadness, anxiety, stress, pity, worry, frustration, anger, fear, helplessness, indifference, boredom). The women were asked to rate these emotions on a 7-point scale, with 1 = never, and 7 = very much.

Studies of Development of Decision Aids

Evidence Table 4.3a. Gustafson (1993, Study 2) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Gustafson D, 1993; Gustafson, D, 1993; Taylor, JO, 1994; Owens, BH, 1996 Study 2 Country: USA RefMan ID: 7538, 5048, 5047, 4219 Study purpose: To evaluate ("field testing") the use of a computer-based program in breast cancer patients | Study design: Case series Duration of the study: Total duration of the study: Not clear Duration for an individual patient: 10 weeks Validity: Content, consensus Readability: Grade level: 8 | Setting: Home Type of cancer: Breast Type of decision: Treatment Model of decision-making:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Not clear | Description: Computer-based program that uses a modem to connect to a central computer (CHESS) ^a^ Purpose:; - Help people experiencing a health crisis; - Increase knowledge; - Help make a decision; Intervention administered by: Researcher Timing of the intervention:; - after the decision was made | Number of subjects enrolled: 20 Characteristics:; - Women with breast cancer; - Treatment choice: mastectomy: 13 subjects, lumpectomy: 7.; - Mean time since diagnosis: 14.6 months; Age: Mean: NR; SD: NR; Median: 56 years Education: Completed college: 8 subjects; - Computer experience: 8 subjects; Ethnicity: NR SES: NR | Primary outcome measures:; - Acceptability of DA; - Feasibility; - Would recommend DA to other patients; - "Emotions"; - Satisfaction; Outcomes measured:; - after the intervention

a CHESS: Comprehensive Health Enhancement Support System: "The interface is interactive and easy to use and utilizes color and graphics on a personal computer with a VGA monitor and modem" (RefMan ID 1196, p.75). The program has 9 components that can be tailored to any topic: "Questions and answers", "Instant Library," "Getting help/support," "Personal stories," "Ask an expert," "Discussion group," "Decision aid," "Action plan," "Assessment." In the Decision Aid component, suggestions by experts and other patients help the subject in making difficult decisions. In the case of breast cancer, the patients are helped to decide about surgery, adjuvant hormonal therapy, or chemotherapy and joining clinical trials. The Decision Aid "does not tell users what they should do; it shows users how the computer used their input to predict the choice they might make" (RefMan ID 1196, p. 74).

Studies of Development of Decision Aids

Evidence Table 4.3b. Gustafson (1993, Study 2) Results

Author | Intervention | Outcome(s) | Postintervention Results ^a^ | Notes
Gustafson D, 1993; Gustafson, D, 1993; Taylor, JO, 1994; Owens, BH, 1996 Study 2 Country: USA RefMan ID: 7538, 5048, 5047, 4219 | n = 20 Computer-based program that uses a modem to connect to a central computer (CHESS) | acceptability of DA ^b^ | Mean scores for each component of the Intervention:; - Questions and Answers: > 4; - Discussion Group: > 4; - Instant Library: > 4; - Ask an Expert: > 4; - Getting Help/Support: > 4; - Personal Stories: > 4; - Decision Aid: > 4; - Action Plan: > 3
Gustafson D, 1993; Gustafson, D, 1993; Taylor, JO, 1994; Owens, BH, 1996 Study 2 Country: USA RefMan ID: 7538, 5048, 5047, 4219 | n = 20 Computer-based program that uses a modem to connect to a central computer (CHESS) | feasibility ^c^ | - Discussion Group: 63.5%; - Instant Library: 8.1%%; - Ask an Expert: 10.2%; - Questions and Answers: 9.9%; - Decision Aid: 0.9%; - Getting Help/Support: 2.6%; - Action Plan: 1.2%; - Personal stories: 2.7%; - Bulletin board: 0.9% | subjects used CHESS 1,131 times (more than 1 minute of use) during the 70-day trial.
Gustafson D, 1993; Gustafson, D, 1993; Taylor, JO, 1994; Owens, BH, 1996 Study 2 Country: USA RefMan ID: 7538, 5048, 5047, 4219 | n = 20 Computer-based program that uses a modem to connect to a central computer (CHESS) | would recommend DA to other patients ^d^ | - Perceived value for breast cancer patients at diagnosis: Mean: 4.94; SD: NR; - Perceived value for breast cancer patients during therapy: Mean: 4.89; SD: NR; - Perceived value for breast cancer patients after treatment: Mean: 4.17; SD: NR
Gustafson D, 1993; Gustafson, D, 1993; Taylor, JO, 1994; Owens, BH, 1996 Study 2 Country: USA RefMan ID: 7538, 5048, 5047, 4219 | n = 20 Computer-based program that uses a modem to connect to a central computer (CHESS) | satisfaction with decision support ^e^ | - Preferred intervention vs. 10 hours with visiting nurse in their home: 15/17* (88%); - Preferred intervention vs. 10 hours talking with a cancer survivor: 12/16* (75%) | * Six women who preferred talking to a nurse or a cancer survivor cited that they wanted rapid and precise answers to their questions.
Gustafson D, 1993; Gustafson, D, 1993; Taylor, JO, 1994; Owens, BH, 1996 Study 2 Country: USA RefMan ID: 7538, 5048, 5047, 4219 | n = 20 Computer-based program that uses a modem to connect to a central computer (CHESS) | "emotions" ^f^ | - Positive emotions mean score: Range: 5.1 to 6.5; - Negative emotions mean score: Range: 1.1 to 3.2

Outcomes measured 10 weeks after the intervention.

a Results for Emotions and Acceptability of DA were extracted from the figures presented in the paper. Raw data are not reported.

b Mean feeling score: perceived value of Decision Aid. Value score: 1 = not at all to 5 = very.

c Frequency of usage was defined as one entry into a CHESS service that lasted 1 minute; Percentage of total usage per service

d This outcome was measured on a 5-point scale with 1 = not valuable and 5 = very valuable.

e The authors asked the patients if they preferred another kind of support vs. the intervention.

f The authors list a series of states that they define as positive emotions (understanding, support, empathy, acceptance, motivation, relief, empowerment, elation) and negative emotions (sadness, anxiety, stress, pity, worry, frustration, anger, fear, helplessness, indifference, boredom). The women were asked to rate these emotions on a 7-point scale, with 1 = never, and 7 = very much.

Studies of Development of Decision Aids

Evidence Table 4.4a. McTavish (1995) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
McTavish F, 1995; Taylor, JO, 1994; Owens, BH, 1996, Gustafson, DH, 1993 Country: USA RefMan ID: 5045, 5047, 4219, 5048 Study purpose: To evaluate the results in a pilot study of a computer-based program for women with breast cancer among impoverished, poorly educated "women of color" | Study design: Case series Duration of the study: Total duration of the study: NR Duration for an individual patient: 4.5 months Validity: Content, consensus Readability: Grade level: 8 | Setting: Home Type of cancer: Breast Type of decision: Treatment Model of decision-making:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Not clear | Description: Computer-based program that uses a modem to connect to a central computer (CHESS) ^a^ Purpose:; - Help people experiencing a health crisis; - Increase knowledge; - Help make a decision; Intervention administered by: "Staff member" Timing of the intervention:; - before and after the decision was made | Number of subjects enrolled: 8 Characteristics:; - African-American women in impoverished neighborhoods of inner-city Chicago; - Stage I or II breast cancer; - After choosing treatment: mastectomy: 2 subjects, lumpectomy: 5 subjects; - One woman had not decided what surgery to have; Age: Mean: NR; SD: NR; range: 36 - 66 years; > 50 years: 6 subjects Education: < 12 years: 4 subjects; - Computer experience: 3 subjects; Ethnicity: African-American SES: NR Religion: NR | Primary outcome measures:; - Acceptability of DA; - Feasibility; - "Emotions"; - Decision; Outcomes measured:; - after the intervention

a CHESS: Comprehensive Health Enhancement Support System: "The interface is interactive and easy to use and utilizes color and graphics on a personal computer with a VGA monitor and modem" (RefMan ID 1196, p.75). The program has 9 components that can be tailored to any topic: "Questions and answers", "Instant Library," "Getting help/support," "Personal stories," "Ask an expert," "Discussion group," "Decision aid," "Action plan," "Assessment." In the Decision Aid component, suggestions by experts and other patients help the subject in making difficult decisions. In the case of breast cancer, the patients are helped to decide about surgery, adjuvant hormonal therapy, or chemotherapy and joining clinical trials. The Decision Aid "does not tell users what they should do; it shows users how the computer used their input to predict the choice they might make" (RefMan ID 1196, p. 74).

Studies of Development of Decision Aids

Evidence Table 4.4b. McTavish (1995) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
McTavish F, 1995; Taylor, JO, 1994; Owens, BH, 1996, Gustafson, DH, 1993 Country: USA RefMan ID: 5045, 5047, 4219, 5048 | n = 8 Computer-based program that uses a modem to connect to a central computer (CHESS) | acceptability of DA | | Not clear if these scores are reported as means.
  Component | Ease of use^a^ | Value^b^
  CHESS overall | 5.8 | 7.0
  Questions and Answers | 6.75 | 7.0
  Instant Library | 6.75 | 7.0
  Getting Help/Support | 6.0 | 6.75
  Personal stories | 6.6 | 7.0
  Ask an Expert | 7.0 | 7.0
  Discussion Groups | 5.25 | 7.0
  Decisions and Conflicts | 6.75 | 7.0
  Action Plan | 4.8 | 6.5
McTavish F, 1995; Taylor, JO, 1994; Owens, BH, 1996, Gustafson, DH, 1993 Country: USA RefMan ID: 5045, 5047, 4219, 5048 | n = 8 Computer-based program that uses a modem to connect to a central computer (CHESS) | Feasibility ^c^ | | Authors reported: CHESS was used 886 times for more than a minute, within 15-week access period. On average each woman used CHESS 7 times per week and on the system for more than 1 hour per week.
  Component | Number of uses | Minutes
  Questions and Answers | 83 | 617
  Instant Library | 48 | 341
  Getting Help/Support | 18 | 76
  Personal stories | 43 | 504
  Ask an Expert | 227 | 1,487
  Discussion Groups | 442 | 5,046
  Decisions and Conflicts | 20 | 208
  Action Plan | 5 | 48
McTavish F, 1995; Taylor, JO, 1994; Owens, BH, 1996, Gustafson, DH, 1993 Country: USA RefMan ID: 5045, 5047, 4219, 5048 | n = 8 Computer-based program that uses a modem to connect to a central computer (CHESS) | "emotions" ^d^ | Positive emotions mean score: Range: 2.2 to 6.5 Negative emotions mean score: Range: 2.0 to 4.5
McTavish F, 1995; Taylor, JO, 1994; Owens, BH, 1996, Gustafson, DH, 1993 Country: USA RefMan ID: 5045, 5047, 4219, 5048 | n = 8 Computer-based program that uses a modem to connect to a central computer (CHESS) | decision | 1/8 decided to have surgery

Outcomes were measured after the intervention (time period not specified).

a This outcome was measured on a 7-point scale with 7 = very easy to use.

b This outcome was measured on a 7-point scale with 7 = very valuable.

c Frequency of usage ("uses") was defined as an entry lasting at least 1 minute in a CHESS service.

d The authors list a series of states that they define as positive emotions (understanding, support, empathy, acceptance, motivation, relief, empowerment, elation) and negative emotions (sadness, anxiety, stress, pity, worry, frustration, anger, fear, helplessness, indifference, boredom). The women were asked to rate these emotions on a 7-point scale, with 1 = never, and 7 = very much.

Studies of Development of Decision Aids

Evidence Table 4.5a. Rolnick (1999) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Rolnick F, 1999; Owens, BH, 1996 Country: USA RefMan ID: 386, 4219 Study purpose: To discuss patient use and impressions of the CHESS ^a^ | Study design: RCT Method of Randomization: NR Baseline comparability: NR Blinding of outcome assessment: NR Duration of the study: Total duration of the study: 9 months Duration for an individual patient: 22 months | Setting: Home Type of cancer: Breast Type of decision: Treatment Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Not clear | Description: Intervention Group (IG): Computer-based program that uses a modem to connect to a central computer (CHESS) ^a^ Control Group (CG): Book ^b^ Purpose:; - Help people experiencing a health crisis; - Increase knowledge; - Help make a decision; Intervention administered by: NR Timing of the intervention: NR | Number of subjects enrolled: 36 IG: 19 CG: 17 Characteristics:; - Newly diagnosed breast cancer patients; - Stage 0-II breast cancer; Age: Mean, SD: NR: range: 32 - 78 years Education: "mean education was college level"; - Computer experience: 3 subjects; Ethnicity: NR SES: "family income was between $30,000 and $40,000" Religion: NR | Primary outcome measures:; - Acceptability of DA; - Feasibility; Outcomes measured:; - baseline; - after the intervention

a CHESS: Comprehensive Health Enhancement Support System: "The interface is interactive and easy to use and utilizes color and graphics on a personal computer with a VGA monitor and modem" (RefMan ID 1196, p.75). The program has 9 components that can be tailored to any topic: "Questions and answers", "Instant Library," "Getting help/support," "Personal stories," "Ask an expert," "Discussion group," "Decision aid," "Action plan," "Assessment." In the Decision Aid component, suggestions by experts and other patients help the subject in making difficult decisions. In the case of breast cancer the patients are helped to decide about surgery, adjuvant hormonal therapy or chemotherapy and joining clinical trials. The Decision Aid "does not tell users what they should do; it shows users how the computer used their input to predict the choice they might make" (RefMan ID 1196, p. 74). Discussion group section monitored by a trained facilitator.

b Dr. Susan Love's Breast Book, by Susan M. Love and Karen Lindsey.

Studies of Development of Decision Aids

Evidence Table 4.5b. Rolnick (1995) Results

Author | Intervention | Outcome(s) | Postintervention Results ^a^ | Notes
Rolnick F, 1995; Owens, BH, 1996 Country: USA RefMan ID: 386, 4219 | n = 36 Intervention Group (IG): n = 19; - computer-based program that uses a modem to connect to a central computer (CHESS); Control Group (CG): n = 17; - book | acceptability of DA | Authors reported:; - "subjects considered that having the CHESS was adequate"; - "50% of the subjects reported interested in borrowing computers or software"
Rolnick F, 1995; Owens, BH, 1996 Country: USA RefMan ID: 386, 4219 | n = 36 Intervention Group (IG): n = 19; - computer-based program that uses a modem to connect to a central computer (CHESS); Control Group (CG): n = 17; - book | feasibility ^b^ | | Authors reported: average use was 62 "hits" per subject. The use decreased to an average of twice per week between the 3^rd^ and 7^th^ week and to an average of once per week over 3 months.
  Component | % Patients using | Average # uses | Average time used
  Questions and Answers | 100 | 28 | 4:55
  Instant Library | 100 | 9 | 1:26
  Getting Help/Support | 82 | 8 | 1:08
  Personal stories | 88 | 4 | 1:04
  Ask an Expert | 94 | 7 | 0:33
  Discussion Groups | 100 | 13 | 0:13
  Tailored Decision Aid | 88 | 1 | 0:10
  Action Plan | 88 | 1 | 0:05
  Referral Directory | 24 | 1 | 0:01

a Outcomes were measured after the intervention (time period not specified); the authors did not report any outcome from the control group.

b The CHESS software was programmed to collect information about subject use, which included frequency of use, time of day, and components used.

Studies of Development of Decision Aids

Evidence Table 4.6a. Dolan (1995) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Dolan J, 1995 Country: USA RefMan ID: 4933 Study purpose: To determine if ambulatory patients were capable of completing a realistically complex analytic hierarchy process (AHP) ^a^ analysis to help them decide about their care | Study design: Case series Duration of the study: Total duration of the study: NR Duration for an individual patient: 1 day | Setting: Out-patient Type of cancer: Colon cancer Type of decision: Screening Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Five alternatives for colon cancer screening: careful followup, sigmoidoscopy every 3 years, annual stool tests every 3 years, barium enema every 5 years, colonoscopy every 5 years ^d^ | Description:; - Structured interview ^b^; - Interactive computer program ^c^; Purpose: Help make a decision Intervention administered by: Researcher Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 20 Characteristics:; - Healthy volunteers; - Without history of colon cancer; - Normal mental status; - Fluent in English; Age: Mean: 41 years, SD: NR; Range: 18-63 years Education: > 12 years: 11 Ethnicity: Caucasian: 13; African-American: 6 Hispanic: 1 SES: NR | Primary outcome measures:; - Feasibility; - Acceptability of DA; - Decision; - Reasons for patients' choice of treatment; Outcomes measured: After the intervention (same day)

a AHP is a user-friendly technique that enables a decisionmaker to elicit subjective values and combine them with more objective data in an explicit, unbiased manner (p. 76).

b "After a brief introduction to the study, participants were asked to imagine that they were 50 years old, had a first-degree relative with colon cancer, and were making a decision about a colon cancer screening program for the next 25 years. The decision was then explained to the participants using an AHP model and the definitions for the criteria contained in appendix B." (p. 77)

c "After the participants indicated that they understood the problem, they completed a guided AHP analysis using Expert Choice, a standard AHP software package, running on a laptop computer. The analysis consisted of pair-wise comparisons among the alternatives relative to each of the criteria based on the data shown in appendix A and pair-wise comparisons among the criteria relative to the goal." (p. 77)

d The authors reported that the decision used for the study was based on Eddy's "balance sheet" that describes the pros and cons of alternative approaches to colon cancer screening of 50-year-old men who have a family history of colon cancer in a first-degree relative. At the top of the AHP model was the goal of the decision: "maintain my health and well-being". The five decisions criteria located on the middle level of the model represented the potential risks and benefits of screening. The five alternatives on the bottom level provide a spectrum of risk-benefit profiles from "careful follow-up", which was the least likely to decrease cancer risk but the best in terms of the other four criteria, to "colonoscopy every 5 years", which provided the biggest reduction in cancer risk but was the worst alternative in every other way.

Studies of Development of Decision Aids

Evidence Table 4.6b. Dolan (1995) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
Dolan J, 1995 Country: USA RefMan ID: 4933 | n = 20; - Structured interview; - Interactive computer indent program | Feasibility ^a^ | - All subjects were able to complete the analysis; - The mean time required to complete the analysis was 35 minutes.; - 19/20 (95%) finished the analysis in 45 minutes or less; - 18/20 (90%) met the criteria for being able and willing to use the AHP.* | * The authors reported: "one responded negatively to question number 3 and the other completed the analysis in 46 minutes."^2^
Dolan J, 1995 Country: USA RefMan ID: 4933 | n = 20; - Structured interview; - Interactive computer indent program | acceptability of DA ^c^ | - "Was it hard to understand what you had to do?": 3/20 (15%); - "By going through the analysis, did you learn any useful information about colon cancer screening?": 19/20 (95%); - "If you had a close relative with colon cancer would you prefer to go through this type of analysis before making a decision about how to minimize your own chances of developing colon cancer?": 19/20 (95%); - "If you had a close relative with colon cancer and had to decide on a plan to minimize your own chances of developing colon cancer today, would you choose the option that came out best on your analysis?": 20/20 (100%); - "If you could, would you use this type of analysis to help you and your doctor make other health care decisions?": 18/20 (90%)
Dolan J, 1995 Country: USA RefMan ID: 4933 | n = 20; - Structured interview; - Interactive computer indent program | decision ^d^ | Best option; - colonoscopy every year: 10/20 (50%); - careful followup: 9/20 (45%); - barium enema every 5 years: 1/20 (5%)
Dolan J, 1995 Country: USA RefMan ID: 4933 | n = 20; - Structured interview; - Interactive computer indent program | reasons for patients' choice of treatment ^e^ | Minimizing the chances of developing colon cancer ranked the most important criterion: 15/20 (75%); 5/20 (25%) ranked this as the second most important criterion Avoiding the side effects was ranked the most important criterion: 4/20* (20%) Avoiding cost was ranked the most important criterion: 1/20* (5%)

Outcomes were measured after the intervention (timing not specified).

a Feasibility was assessed according to whether subjects would be capable of using and willing to use the Analytic Hierarchy Process (AHP). Participants were categorized as capable of using the AHP if they completed their analysis in 45 minutes or less, and as willing if they answered yes to the following question: If you had a close relative with colon cancer would you prefer to go through this type of analysis before making a decision about how to minimize your own chances of developing colon cancer?"

b Question number 3: "If you had a close relative with colon cancer would you prefer to go through this type of analysis before making a decision about how to minimize your own chances of developing colon cancer?"

c This outcome was measured by an evaluation questionnaire that the patients completed following the discussion; the results presented are only from those people who answered yes to each question. (p. 77)

d According to subjects' individual AHP analysis

e Priorities assigned to decision criteria by the participants.

Studies of Development of Decision Aids

Evidence Table 4.7a. Chapman (1995) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Chapman GB, 1995 Country: USA RefMan ID: 116 Study purpose: To examine the effects of materials for educating patients about treatment options for breast cancer | Study design: Nonrandomized controlled trial Duration of the study: NR | Setting: University (classroom) Type of cancer: Breast Type of decision: Treatment (primary) Model of decision-making:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision: Breast-sparing surgery vs. mastectomy with reconstruction vs. mastectomy with prosthesis | Description: Intervention group 1 (IG1); - videotape based on a videodisk ^a^; Intervention Group 2 (IG2); - booklet with similar information as the video ^b^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Researcher Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 82 IG1: 40: 23 were psychology students and 17 were nursing students; IG2: 42: 24 were psychology students and 18 were nursing students Characteristics; - Women; - Without breast cancer; Age: Mean: 21.8; SD: NR range: 18 - 46 (both groups) Education: NR Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Knowledge; - Preference; Outcomes measured:; - before and after the intervention

a A videotaped version of a shared decision making program (SDP) called "Treating Your Breast Cancer," produced by the Foundation for Informed Medical Decision Making. The SDP is an interactive videodisk composed of two sections. This study was based on the core part of the SDP; it was narrated by a female physician and contained four sections. The first section presented general information about the breast and breast cancer. A short second section presented an overview of the choice of surgical treatments available to many women. A lengthy third section presented details about the breast sparing option. The final section presented details about the mastectomy option, including material about prostheses and breast reconstruction. The advantages and disadvantages of each surgical procedure were discussed in these last two sections. Interspersed throughout the narration were interview clips with five breast cancer survivors; each discussed the decision she made. The authors reported that the majority of subjects were satisfied with their decisions, conveying the message that the viewer could choose a treatment for herself and that whatever option she chose would be right for her. One woman interviewed had chosen breast-sparing surgery with radiation treatment; a second, mastectomy followed by reconstructive surgery; a third had elected to have mastectomy and used breast prosthesis. The fourth and fifth interviewees provided additional information about breast reconstruction. One was unhappy using a breast prosthesis and decided to have subsequent breast reconstruction; another woman was unhappy with the results of her breast reconstruction.

b The booklet text was produced from the video script. Transcripts of patient interviews were omitted because the authors thought that they would be an unnatural component of a written presentation. In addition, visual aids included in the video, such as cartoon drawings, were not reproduced in the booklet. The booklet did contain photos selected to closely match those presented in the video.

Studies of Development of Decision Aids

Evidence Table 4.7b. Chapman (1995) Results

Author | Intervention | Outcome(s) | Baseline Results IG1 vs. IG2 | Postintervention Results IG1 vs. IG2 | Notes
Chapman GB, 1995 Country: USA RefMan ID: 116 | n = 82 Intervention group 1 (IG1): n = 40 videotape Intervention group 2 (IG2): n = 42 booklet with same information as video, but without patient interviews | Knowledge ^a^ | - mean: 11.4; vs. 11.6; SD: NR | - mean: 13.8 vs. 13.3; SD: NR; - mean difference from baseline: 2.4 vs. 1.6; SD: NR | - in both groups, there were differences from baseline, p < 0.0001; - in both groups, nursing students had higher pre- and postscores, p < 0.0001
Chapman GB, 1995 Country: USA RefMan ID: 116 | n = 82 Intervention group 1 (IG1): n = 40 videotape Intervention group 2 (IG2): n = 42 booklet with same information as video, but without patient interviews | Decision ^b^ | - breast sparing surgery: mean: 41.2 vs. 44.5; SD: NR; - mastectomy with reconstruction: mean 38.9 vs. 31.5; SD: NR; - mastectomy with prosthesis: mean 19.8 vs. 23.9; SD: NR | - breast sparing surgery: mean: 54.3 vs. 46.0; SD: NR*; - mastectomy with reconstruction: mean 29.1 vs.29.2; SD: NR; - mastectomy with prosthesis: mean 16.5 vs. 24.7**; - mean difference for preference for breast sparing: mean 2.4 vs.1.5; SD: NR | *nursing students rated breast-sparing higher than psychology students, p < 0.01 (p 235) **nursing students rated this option lower than psychology students, p < 0.01 (p. 236) booklet group rated mastectomy + reconstruction higher than video group, p < 0.05
Chapman GB, 1995 Country: USA RefMan ID: 116 | n = 82 Intervention group 1 (IG1): n = 40 videotape Intervention group 2 (IG2): n = 42 booklet with same information as video, but without patient interviews | acceptability of DA ^c^ | | Mean ratings (SD: NR): ***; - Woman dissatisfied with her reconstruction: 3.3; - Woman dissatisfied with her prosthesis: 3.6; - Narrator: 3.9; - Three women who were happy with their choices: 3.9, 4.1 and 4.0, respectively. | ***The authors reported that the interviewed women who were dissatisfied with their choices were rated lower than the four other women, p < 0.0001 (ANOVA)

Outcomes were measured before and after the intervention (timing not clear).

a Ward and Griffin's Breast Cancer Information Test-R (18-item true/false questionnaire)

b Expressed by dividing 100 points among the three options.

c Women in the video group rated how much they liked the five women and the narrator on a 5-point scale.

Studies of Development of Decision Aids

Evidence Table 4.8a. Jenkinson (1998) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Jenkinson J, 1998 Country: Canada RefMan ID: 814 Study purpose: To develop a hypermedia program to help patients with localized prostate cancer in making treatment decisions | Study design: Case series Duration of the study: Total duration of the study: Not clear Duration for an individual patient: not clear Validity: Content, consensus | Setting: Outpatient Type of cancer: Prostate Type of decision: Treatment Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision: Radical prostatectomy, radiation therapy, watchful waiting | Description:; - Hypermedia program integrating CD-ROM and Internet ^a^; Purpose:; - Help make a decision; Intervention administered by: NR Timing of the intervention: NR | Number of subjects enrolled: 5 Characteristics:; - Patients from Toronto Hospital-General Division; Age: NR Education: NR Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Acceptability of DA; Outcomes measured:; - after the intervention

a "The Prostate Center" was assembled using mTropolis version 1.1; the screen interface panels and buttons were designed in Adobe Photoshop 4.0. The opening segment of narration was recorded onto a digital audiotape; other audio effects used throughout the program were created in SoundEdit 16. A patient video segment of the program was filmed with a digital video camera; the video was edited in Adobe Premiere and compressed into a Cinepak Quicktime movie. Rudimentary Internet links were developed in mTropolis that would launch a WWW browser and connect directly to pre-existing Web sites. The prototype incorporates text, graphics, and a 5-minute video interview with a patient role model. The patient related to the viewer his reaction to diagnosis of localized prostate cancer, his treatment choice (surgery), and his subsequent recovery from surgery. The authors reported that their original intention was to create videotaped interviews describing each of the three major treatment options (surgery, radiation, and observation); however, due to time constraints, only the interview describing surgical treatment of prostate cancer was completed.

Studies of Development of Decision Aids

Evidence Table 4.8b. Jenkinson (1998) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
Jenkinson J, 1998 Country: Canada RefMan ID: 814 | n = 5 Hypermedia program integrating CD-ROM and Internet | acceptability of DA ^a^ | The authors reported: "testing the prototype has met with a positive response from interviewers who described the program as relevant, useful, and navigable." | No additional details were provided by authors

a Pilot testing of the prototype involved direct observation and a written record of the actions of the patient using the program and a semistructured, one-on-one interview with the patient after his session with the computer.

Studies of Development of Decision Aids

Evidence Table 4.9a. Ravdin (2001) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Ravdin P, 2001 Country: USA RefMan ID: 7852 Study purpose: To develop a decision aid that provides estimates of the net benefit to be expected from adjuvant systemic treatment for individual breast cancer patients | Study design: Case series Duration of the study: NR Validity: NR | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment Model of decision-making:; - NR by authors; - Not clear as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Adjuvant treatment (chemotherapy or endocrine therapy) versus none | Description: Computer program with printed output ^a^ Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: NR Timing of the intervention:; - before the decision was made | Number of patients enrolled: 24 Characteristics:; - diagnosed with breast cancer; - currently undergoing adjuvant treatment or followup care; Age: Mean: NR, SD: NR range: 47 to 74 years Education: Reported as "wide range of education levels" Ethnicity: Reported as "racially diverse" SES: NR | Primary outcome measures:; - acceptability of format and graphic presentation of the printed output; Outcomes measured:; - after the intervention

a The DA intervention consisted of a computer program called Adjuvant, which estimates the net survival benefit to be expected for systemic adjuvant treatment (chemotherapy or endocrine therapy) for an individual breast cancer patient. The program requires that the physician input: patient age, estrogen receptor status, tumor size, number of positive lymph nodes. The program generates overall and disease-free survival estimates and displays the data on the computer screen for physician use and in a printed output format for patient use.

Studies of Development of Decision Aids

Evidence Table 4.9b. Ravdin (2001)Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Ravdin P, 2001 Country: USA RefMan ID: 7852 | n = 24 Computer program with printed output | Acceptability of DA^a,b^ | | - raw data was not reported | Authors cite examples of the type of changes that were made to the printed output for patient use based on the results of the survey. The changes included: (1) use of the term "additional" instead of "adjuvant" (2) use of the phrase "the cancer coming back" instead of the term "relapse" (3) replacement of the term "percent" with the phrase "number of women out of 100" (4) bar charts were used instead of pie charts

a The authors report that subjects were asked to evaluate: (1) wording, (2) layout, (3) use of bar or pie graphs, and (4) the amount and order of information to be presented.

b Authors note that, after assessing the acceptability of the DA intervention with the 24 participants described above, the authors revised the format of the DA intervention output to reflect participants' suggestions. The acceptability of the revised DA intervention format was then tested with a different group of patients (n=25, no data provided).

Studies of Development of Decision Aids

Evidence Table 4.10a. Brundage (1997) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Brundage M, 1997 Country: Canada RefMan ID: 149, 873 Study purpose: To evaluate a treatment trade-off method for its potential in helping lung cancer patients make treatment decisions | Study design: Test-retest ^a^ Duration of the study: Total duration of the study: 9 months Duration for an individual patient: 8 weeks | Setting: Outpatient Type of cancer: Locally advanced non-small-cell lung cancer (NSCLC) and small-cell lung cancer (SCLC) Type of decision: Treatment Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - High-dose radiotherapy vs. low-dose radiotherapy, and; - Combination treatment chemoradiotherapy vs. high-dose radiotherapy | Description:; - Treatment trade-off interview method ^b^; Purpose: Help make a decision Intervention administered by: Researcher Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 76, Group 1: 56 patients: 22 lung cancer, 34 prostate cancer Group 2: 20 staff: 11 nurses, 9 radiation therapy technologists Characteristics; - Patients with NSCLC, SCLC, and prostate cancer who had already received treatment; - Minimum interval between treatment and interview: for NSCLC patients 2 to 4 weeks, for SCLC 6 weeks, and for prostate cancer patients 6 weeks; - Patients could attend a 1-hour interview; Age: Mean: 69 years (prostate cancer patients), 65 years (lung cancer patients), and 37 years (staff group); SD: NR; range: NR Gender: 11 women, 11 men among lung cancer group; 19 women, 1 man among staff group. Education: NR Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Psychometric properties of DA: construct validity reliability; - Feasibility; - Decision; - Desired level of involvement in decisions; Outcomes measured: ^c^; - after the intervention; - retest: 6 weeks after the intervention

a 20/76 subjects (11 patients and nine staff) were included for the second interview (Retest).

b "The participant was asked to imagine being in a health state that represented the typical condition of someone with stage IIIB NSCLC, just after diagnosis. We then assessed his or her preferences for treatments. Two comparisons were used: a) high-dose radiotherapy versus low-dose radiotherapy, and b) combination treatment with chemo-radiotherapy versus high-dose radiotherapy. For each comparison, treatment description cards were laid out so that two treatments could be viewed side-by-side. The description components were: details of the actual treatment regimen, early side effects, late side effects, and effects of the treatment on personal functioning, emotional state, social interaction, and disease symptoms. Survival information was expressed as a percentage (explained and displayed as frequencies indicating the numbers of people out of 100 who would be alive six months, one year, and three years after treatment). Survival data were displayed using a time line that indicated time from treatment and a sliding bar instrument that indicated percentage alive and percentage dead at a given time." (p. 258) (Ref Man ID 873)

c Desired level of involvement in decisions was assessed before the intervention only.

Studies of Development of Decision Aids

Evidence Table 4.10b. Brundage (1998) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results Group 1 vs. Group 2
Brundage M, 1998 Country: Canada Ref Man ID: 149, 873 | n = 76 Group 1: n = 56 Cancer patients Treatment trade-off interview method Group 2: n = 20 Staff Treatment trade-off interview method | Construct validity ^a^ | | - 1^st^ decision: 6-month survival advantage of more toxic treatment (high dose): chose high-dose treatment under certain survival conditions: 45/56 (80%) vs. 16/20 (80%) 1-year survival advantage of more toxic treatment (high dose): chose high-dose treatment under certain survival conditions: 46/56 (82%) vs. 17/20 (85%) 3-year survival advantage of more toxic treatment (high dose): chose high-dose treatment under certain survival conditions: 48/56 (86%) vs. 20/20 (100%); - 2^nd^ decision:^b^ 6-month survival advantage of more toxic treatment (high dose): chose combination treatment under certain survival conditions: 34/56 (61%) vs. 12/20 (60%) 1-year survival advantage of more toxic treatment (high dose): chose combination treatment under certain survival conditions: 42/56 (75%) vs. 15/20 (75%) 3-year survival advantage of more toxic treatment (high dose): chose combination treatment under certain survival conditions: 47/56 (84%) vs. 20/20 (100%)
Brundage M, 1998 Country: Canada Ref Man ID: 149, 873 | n = 76 Group 1: n = 56 Cancer patients Treatment trade-off interview method Group 2: n = 20 Staff Treatment trade-off interview method | Reliability ^b^ | | 6-month survival advantage of more toxic treatment (high dose):low-dose vs. high-dose tradeoff: 0.87* (0.06), 0.94** (0.04), 60%** high-dose vs. combination tradeoff: 0.75 (0.07), 0.87 (0.05), 70% 1-year survival advantage of more toxic treatment (high dose): low-dose vs. high tradeoff: 0.80 (0.06), 0.92 (0.03), 55% high-dose vs. combination tradeoff: 0.79 (0.04), 0.91(0.03), 70% 3-year survival advantage of more toxic treatment (high dose): low-dose vs. high tradeoff: 0.70 (0.12), 0.87 (0.08), 65% high-dose vs. combination tradeoff: 0.70 (0.10), 0.82 (0.08), 85%
Brundage M, 1998 Country: Canada Ref Man ID: 149, 873 | n = 76 Group 1: n = 56 Cancer patients Treatment trade-off interview method Group 2: n = 20 Staff Treatment trade-off interview method | Feasibility | | All but three participants competed the tradeoff exercises. Three additional patients understood the exercise but were unable to provide responses.
Brundage M, 1998 Country: Canada Ref Man ID: 149, 873 | n = 76 Group 1: n = 56 Cancer patients Treatment trade-off interview method Group 2: n = 20 Staff Treatment trade-off interview method | Desired level of involvement in decisions ^c^ | Active role: 17 vs. 15 Equal role: 23 vs. 5 Passive role: 16 vs. 0

a There were three different outcomes in each endpoint: (a) could not answer or declined both treatments, (b) declined high-dose treatment even when it offered 100% probability of survival, and (c) chose high-dose treatment under certain survival conditions. We considered that the last one we are reporting shows a broad picture of the results.

b 20/76 subjects (11 patients and nine staff) were included for the second interview (Retest). Authors assessed consistency with survival-advantage threshold (SAT) scores; SAT = desired survival percentage - baseline survival percentage. The authors reported the correlation results with * Kendall's tau, ** Spearman's rho, and as *** percentage agreement within 5%. Results are displayed as means; numbers between brackets = standard error (SE).

c Authors used a questionnaire similar to Degner's Control Preference Scale.

Studies of Development of Decision Aids

Evidence Table 4.11a. Levine (1992) General Characteristics

Author/ Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Levine M, 1992 Country: Canada RefMan ID: 7117 Study purpose: To test the validity and reliability of a Decision Board in a group of healthy volunteers | Study design: Test-retest Duration of the study: Total duration of the study: NR For each individual patient: 2 weeks Validity: Content Clarity: Pretested | Setting: NR Type of cancer: Breast Type of decision: Treatment, adjuvant Model of decisionmaking:; - Shared as reported by authors; - Informed determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Adjuvant chemotherapy vs. none | Description:; - Decision board ^a^; Purpose:; - Increase knowledge; - Help make a decision; - Improve communication between clinician and patient; Intervention administered by: Oncology nurse Timing of the intervention:; - before and after the decision was made | Number of patients enrolled: 30 Characteristics: Healthy volunteers Age: Mean: 41 years; SD: NR; range: 34 to 59 years Ethnicity: NR SES: NR Religion: NR Education: NR | Primary outcome measures:; - Psychometric properties of DA: construct validity, reliability; - Decision; Outcomes measured:; - after the intervention,; - retest: 2 weeks after the intervention

a A visual aid designed to present the information about treatment options, chance of outcome resulting from the treatment choice and quality of life associated with the choice in a standardized manner. The board was designed to present information regarding treatment choices (no chemotherapy compared with chemotherapy), chance of outcome resulting from the treatment choice, outcomes (cancer-free or no recurrence and cancer returns or recurrence), and quality of life associated with choices and outcomes in a systematic and balanced way. The authors used probabilistic language to describe the potential morbidity. Treatment scenarios were described with the potential side effects. The authors chose to use verbal descriptions of the uncertainty (i.e, likely) rather than numeric ones (i.e., 0.8). The Decision Board had three subtitles: "treatment choice," "chance of outcome," and "outcome." Except for these titles, the board was empty when the interview began. Information cards were held by the patient while the interviewer read aloud. The plastic-laminated card was then attached to the decision board with Velcro. By the end of the discussion, all the information cards were on the board. The cards were color-coded by treatment options.

Studies of Development of Decision Aids

Evidence Table 4.11b. Levine (1992) Results

Author | Intervention | Outcome(s) | Afterintervention Results | Retest Intervention Results | Notes
Levine M, 1992 Study 2 Country: Canada RefMan ID: 7117 | n = 30 Decision board | Construct validity | - 14/17 (82%) who chose chemotherapy switched preference when benefit was reduced; - 16/17 (94%) who chose chemotherapy switched preference when toxicity was increased; - 12/13 (92%) who chose no chemotherapy switched preference when benefit was increased; - 13/13 (100%) who chose no chemotherapy switched preference when toxicity was eliminated
Levine M, 1992 Study 2 Country: Canada RefMan ID: 7117 | n = 30 Decision board | Reliability ^a^ (Decision) | - 17/30 (57%) chose chemotherapy; - 13/30 (43%) chose no chemotherapy | Authors report: 28/30 (93%) had the same preference* | * No data provided about the actual preference, but authors report that the agreement between the two responses, expressed as a kappa statistic, was 0.86.

Outcomes were measured just after the intervention and retested 2 weeks after the intervention.

a Reliability was measured with the actual choice as well as with the strength of preference. Authors report that the strength of preference was assessed on a 6-point Likert scale.

Studies of Development of Decision Aids

Evidence Table 4.12a. Whelan (1995) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Whelan T, 1995 Country: Canada RefMan ID: 7535 Study purpose: To pretest a method to assist women in deciding whether to receive breast irradiation post-lumpectomy | Study design: Survey Duration of the study: NR Validity: Content Clarity: Pretested | Setting: NR Type of cancer: Breast Type of decision: treatment, adjuvant Model of decisionmaking:; - Shared as reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: radiation vs. no radiation | Description: decision board ^a^ Purpose:; - to increase knowledge; - to help make a decision; Intervention administered by: Radiation oncologist and oncology nurse Timing of the intervention: NA | Number of subjects enrolled: 26 Characteristics:; - Healthy volunteers: 10; - Node-negative patients who had been treated with breast irradiation post-lumpectomy: 16; Age: NR Education: NR Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Comprehensibility of DA; Outcomes measured:; - after the intervention

a The decision board was composed of an introduction and scenarios: the introduction covered background information about the disease, prognosis, and the purpose of the board. The scenarios described the treatment options of radiation therapy vs. none and the subsequent outcomes of recurrence of cancer in the breast for women with node-negative breast cancer treated by lumpectomy and axillary dissection. Probability wheels were used to describe the risk of recurrence of cancer with or without radiation therapy. Side effects of the therapy were described. The decision board measured 100 x 70 cm and was designed for administration in a physician's office. The decision board had two subtitles: "treatment choice" and "results of treatment choice." Except for the titles, the board was empty at the onset of the interview. The patient and clinician read each information card and attached it to the board with Velcro. At the end of the discussion, all of the information cards were on the board. (p. 848).

Studies of Development of Decision Aids

Evidence Table 4.12b. Whelan (1995) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
Whelan T, 1995 Country: Canada RefMan ID: 7535 | n = 26 Decision board | comprehensibility | - 26/26 (100%) found the decision aid easy to read; - authors reported that some words were found to be potentially upsetting *; - subjects appeared to have a good understanding of most issues concerning breast radiation *; - subjects had some difficulty understanding that breast irradiation was not associated with survival benefit * | * No additional details were provided by authors.

Outcomes measured after the intervention (time period not specified).

Studies of Development of Decision Aids

Evidence Table 4.13a. Sebban (1995) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Sebban C, 1995 Country: France RefMan ID: 117 Study purpose: To design an instrument to help clinicians inform patients with chronic myeloid leukemia of the risks and benefits of two alternative treatments: Bone marrow transplant (BMT) and chemotherapy (Chemo) | Study design: 2 phases: 1) RCT 2) Test-Retest ^a^ Duration of the study: NR Validity: Content, consensus | Setting: Not clear Type of cancer: Chronic myeloid leukemia Type of decision: Treatment, advanced Model of decisionmaking:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:BMT vs. chemotherapy | Description: Intervention Group 1 (IG1) Short version of Decision Board (DB) ^b^ followed by DB ^c^ Intervention Group 2 (IG2) DB ^c^ Purpose:; - increase knowledge; - help make a decision; - satisfaction with choice; Intervention administered by:Researcher Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 42 IG1: 20; IG2: 22 Characteristics:; - Healthy volunteers: individuals working at the hospital and individuals recruited from a small rural blood donor clinic; - Able to read; Age: Median: 36 years, Range: 23 - 61 years (both groups) Gender: 29 female, 13 male Education: NR Ethnicity: NR SES: NR | Primary outcome measures:; - Psychometric properties of the intervention: construct validity and reliability; - Feasibility of DA; - Clarity of DA; - Decision (hypothetical); - Knowledge; - Satisfaction with choice; Outcomes measured:; - RCT: after the intervention; - Retest: 2 weeks after the first evaluation.

a Subjects enrolled in this phase were a subsample of 16/42 who participated in the RCT.

b "Short version of the instrument displaying only the survival probabilities without details about the procedures and their outcomes." (p. 224)

c "The decision board was designed to present the information regarding treatment choices (BTM compared with Chemo), chances of survival at different points in time [3 months, 2 years and 5 years] (both favorable and unfavorable), and quality of life associated with choices and outcomes. We used a white board made of light cardboard large enough to permit the respondent to read the display. The final dimensions were 70 cm in width and 60 cm in height. The board is empty when the interview begins. Information card are held by the respondent while the interviewer reads aloud. When finished, the card is attached to the board with Velcro. By the end of the discussion all the information cards are on the board. The cards are color-coded. The board is easy to carry around and to store." (p. 223)

Studies of Development of Decision Aids

Evidence Table 4.13b. Sebban (1995) Results

Author | Intervention | Outcome(s) | Postintervention Results IG1 vs. CG2 | Notes
Sebban C, 1995 Country: France RefMan ID: 117 | n = 42 Intervention Group 1 (IG1): n = 20 Short version of Decision board (DB) followed by DB Intervention Group 2 (IG2): n = 22 DB | construct validity ^a^ | - in 16/42 subjects systematic changes of information were presented, all 16 subjects shifted in the predicted direction (p. 225)*; - the correlation between the two elicited preferences (with both DB versions) score was 0.7**; - the correlation between age and choice was - 0.17 | * Statistical analysis not provided ** Authors report that this correlation suggests, "that choices elicited by the two instruments differ"
Sebban C, 1995 Country: France RefMan ID: 117 | n = 42 Intervention Group 1 (IG1): n = 20 Short version of Decision board (DB) followed by DB Intervention Group 2 (IG2): n = 22 DB | Reliability ^b^ | - authors report that only 1/16 subjects shifted the direction of preference on the second application of the instrument*** (p. 225) | *** Intraclass correlation coefficient was 0.87
Sebban C, 1995 Country: France RefMan ID: 117 | n = 42 Intervention Group 1 (IG1): n = 20 Short version of Decision board (DB) followed by DB Intervention Group 2 (IG2): n = 22 DB | feasibility | The authors reported all the subjects approached agreed to participate. Each interview lasted from 20 to 30 minutes.
Sebban C, 1995 Country: France RefMan ID: 117 | n = 42 Intervention Group 1 (IG1): n = 20 Short version of Decision board (DB) followed by DB Intervention Group 2 (IG2): n = 22 DB | acceptability of DA | Authors reported that subjects rated:; - instrument: "very clear": 26/42 (62%) and "clear enough": 16/42(38%); - amount of information: "about right": 32/42 (76%), and "not sufficient": 10/42 (24%)
Sebban C, 1995 Country: France RefMan ID: 117 | n = 42 Intervention Group 1 (IG1): n = 20 Short version of Decision board (DB) followed by DB Intervention Group 2 (IG2): n = 22 DB | decision | - chose bone marrow transplant (BMT): 13/20 (65%) vs. 10/22 (45%); - chose chemotherapy (CHEMO): 7/20 (35%) vs. 11/22 (50%); - chose no treatment: 0/20 vs. 1/22 (5%); - mean: 3.7; SD 1.7 vs. mean 4.8; SD: 2.0 **** | **** Between intervention groups p = 0.07 (Statistical analysis not provided)
Sebban C, 1995 Country: France RefMan ID: 117 | n = 42 Intervention Group 1 (IG1): n = 20 Short version of Decision board (DB) followed by DB Intervention Group 2 (IG2): n = 22 DB | satisfaction with choice ^d^ | - mean: 3.7; SD: 1.06 vs. mean: 2.95; SD: 0.67 | Between intervention groups p < 0.01 (ANOVA)

Outcomes were measured postintervention and retested 2 weeks after the intervention in a subsample.

a This outcome was measured with four constructs: (1) Systematic manipulations of scenarios (content and survival) should shift expressed choices. (2) DB short and complete versions were evaluated for whether they would shift subjects' choices. (3) Correlation with choice and age of respondent. (4) The two DB versions would lead to different levels of satisfaction.

b Test-retest was assessed in 16/42 (38%) participants.

c This outcome was measured on a 7-point Likert scale with 1 = "I definitely prefer BMT" and 7 = "I definitely prefer CHEMO."

d This outcome was measured with a 5-point Likert scale with 5 = very satisfied.

Studies of Development of Decision Aids

Evidence Table 4.14a. Elit (1996, Study 1) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 Study purpose: To determine a decision board's (DB) psychometric properties and to identify if choice of therapy was influenced by the manner in which survival information was given | Study design: test-retest Duration of the study: Total duration of the study: NR Duration for an individual patient: 3 weeks Validity: Content | Setting: Not clear Type of cancer: Epithelial ovarian (advanced) Type of decision: Treatment, adjuvant Model of decision-making:; - Informed as stated by authors and as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Cyclophosphamide + Cisplatin (Plan A) vs. Paclitaxel + Cisplatin (Plan B) | Description: DB ^a^ Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Physician or research assistant Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 48 Characteristics:; - 37 healthy volunteers (HV); - 11 women who had completed firstline chemotherapy for epithelial ovarian cancer (OCP); Age: HV = Mean: 45.9; SD: 10.7. OCP = Mean: 61.2; SD: 14.6 Education: NR Ethnicity: NR SES: NR Religion: NR | Readability: DB was written in a readability index to a grade 7 level ^b^ Primary outcome measures:; - Psychometric characteristics of DA: construct validity, reliability; - Feasibility of DA; - Acceptability of DA; - Knowledge; - Anxiety; - Decision; Outcomes measured:; - before and after the intervention

a "The Board was made from light 'foam core' and was divided so that each part measured 60 x 37 cm. The parts were labeled Introduction, Treatment choices, Side Effects, Outcome, and Description of the Outcome (Fig. 1). The Introduction reiterated for the patient that she had recently undergone "surgery for a cancer that started in the ovary." The cancer was found to have "spread to other areas in the abdomen," and to kill the remaining cancer cells, she would 'require a treatment called chemotherapy.' The Treatment Choices section described the administration of Plan A (cisplatin-cyclophophamide) and Plan B (cisplatin-paclitaxel). Bar graphs were used to portray the rates of the most common side effects. The Outcomes "Cancer-free" and "Cancer does not go away or cancer comes back" were presented as probabilities on a wheel. These outcomes were described by narrative material. "[...] the Board was empty at the onset of the interview. The respondent and interviewer read each information card. When completed, the card was attached to the board with Velcro. Once the cards for the Introduction, Treatment choices and Side Effects were reviewed, the respondent was asked if she would like further information concerning long-term effects of treatment prior to making her treatment choice. If the answer was yes, the descriptions and associated probability wheels for the outcomes (cancer-free and cancer comes back) were presented." (page 331)

b According to Right Writer version 3.1, right Soft Inc.

Studies of Development of Decision Aids

Evidence Table 4.14b. Elit (1996, Study 1) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 | n = 48 Decision Board (DB) | construct validity | - authors report that the predicted shifts in treatment choice occurred 95% of the time. Strength of preference for Plan B: 98.1%; for Plan A: 37.5%*; - 11 volunteers and 11 patients participated in a subsequent interview ^a^; - choice for Plan B was more likely when survival was presented in percentage (76%) compared with median (62%) | * Outcome assessed in 25 of the 37 healthy volunteers. p < 0.001 (Authors did not provide information on how this percentage was obtained or the statistics used)
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 | n = 48 Decision Board (DB) | reliability (decision) ^b^ | - same responses in test and retest evaluations 1/10 (10%) chose Plan A, 9/10 (90%) chose Plan B ^c^ | Kappa = 1.0
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 | n = 48 Decision Board (DB) | feasibility | The authors reported that respondents took 20 to 30 minutes to review the DB
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 | n = 48 Decision Board (DB) | acceptability of DA | - 42/48 (88%) found DB easy or very easy to understand; - 43/48 (90%) would not change information on DB
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 | n = 48 Decision Board (DB) | knowledge ^d^ | - 33/37 (89%) of the healthy volunteers correctly answered the questionnaire; - 10/11 (91%) of the patients correctly answered the questionnaire
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 | n = 48 Decision Board (DB) | anxiety ^e^ | - anxiety did not change appreciably before and after the application of the DB in the women who had completed first-line chemotherapy** | ** p > 0.05 (no data or statistics provided by authors)
Elit L, 1996 Study 1 Country: Canada RefMan ID: 119 | n = 48 Decision Board (DB) | Other ^f^

a During this phase, authors gave participants two forms of survival information: as a median and as a percentage.

b Reliability was assessed with the treatment decision in 10/37 (27%) of the included participants.

c Plan A (cisplatin - cyclophophamide): poorer survival but superior quality of life; Plan B (cisplatin-paclitaxel): superior survival but poorer quality of life.

d The authors assessed comprehension with a 10-item true-false questionnaire regarding information on the two treatment options.

e Changes in anxiety during the course of the interview were measured with the state portion of the State Trait Anxiety Inventory.

f Impact survival information on treatment choice, authors report "Only survival information (median versus percentage) significantly affected choice (p = 0.042)."

Studies of Development of Decision Aids

Evidence Table 4.15a. Elit (1996, Study 2) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Elit L, 1996 Study 2 Country: Canada RefMan ID: 7539 Study purpose: To present therapy alternatives and outcomes to patients in an unbiased fashion, thereby enabling patients to make an informed choice | Study design: Case series Duration of the study: Total duration of the study: 9 months Duration for an individual patient: 1 day Reliability: Intrarater Validity: Content, consensus, construct Readability: Tested Comprehensibility: Tested Clarity: Tested | Setting: Inpatient Type of cancer: Epithelial ovarian (advanced) Type of decision: Treatment, adjuvant Model of decisionmaking:; - Informed as stated by authors and as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Cisplatin + Cyclophosphamide (Plan A) vs. Paclitaxel + Cisplatin (Plan B) | Description: Decision board ^a^ Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Physician or research assistant Timing of the intervention:; - at the point of decision-making | Number of subjects enrolled: 13 Characteristics:; - Newly diagnosed ovarian cancer patients; - Stage III or IV epithelial ovarian cancer; - 4 to 9 days after their operation; Age: NR Education: NR Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Feasibility of DA; - Acceptability of DA; - Knowledge; - Anxiety; - Decision (hypothetical); Outcomes measured:; - before the intervention; - 1 day after the intervention

a "The Board was made from light 'foamcore' and was divided so that each part measured 60 x 37 cm. The parts were labeled Introduction, Treatment choices, Side Effects, Outcome, and Description of the Outcome (Fig. 1). The Introduction reiterated for the patient that she had recently undergone "surgery for a cancer that started in the ovary." The cancer was found to have "spread to other areas in the abdomen," and to kill the remaining cancer cells, she would 'require a treatment called chemotherapy.' The Treatment Choices section described the administration of Plan A (cisplatin-cyclophophamide) and Plan B (cisplatin-paclitaxel). Bar graphs were used to portray the rates of the most common side effects. The Outcomes "Cancer-free" and "Cancer does not go away or cancer comes back" were presented as probabilities on a wheel. These outcomes were described by narrative material. "[...] the Board was empty at the onset of the interview. The respondent and interviewer read each information card. When completed, the card was attached to the board with Velcro. Once the cards for the Introduction, Treatment choices and Side Effects were reviewed, the respondent was asked if she would like further information concerning long-term effects of treatment prior to making her treatment choice. If the answer was yes, the descriptions and associated probability wheels for the outcomes (cancer-free and cancer comes back) were presented." (p. 331)

Studies of Development of Decision Aids

Evidence Table 4.15b. Elit (1996, Study 2) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
Elit L, 1996 Study 2 Country: Canada RefMan ID: 7539 | n = 13 Decision board | feasibility of DA | The authors reported that 1 of the 13 patients enrolled was not interested in reviewing the survival information.
Elit L, 1996 Study 2 Country: Canada RefMan ID: 7539 | n = 13 Decision board | acceptability of DA | 9/11 (82%) recommended using the board with other patients like themselves.
Elit L, 1996 Study 2 Country: Canada RefMan ID: 7539 | n = 13 Decision board | knowledge ^a^ | Authors reported 86% of the questions were answered correctly.* | * No raw data provided.
Elit L, 1996 Study 2 Country: Canada RefMan ID: 7539 | n = 13 Decision board | anxiety ^b^ | Authors report anxiety scores did not change appreciably before and after administration of the Decision Board.** | ** Raw data and statistics not provided.
Elit L, 1996 Study 2 Country: Canada RefMan ID: 7539 | n = 13 Decision board | decision (hypothetical) | Chose cisplatin + cyclophosphamide (Plan A): 4/12 (33%) Chose cisplatin + paclitaxel (Plan B): 8/12 (67%)

Outcomes measured before and 1 day after the intervention.

a The authors assessed comprehension with a 10-item true-false questionnaire regarding information about the two treatment options.

b Changes in anxiety during the course of the interview were measured with the state portion of the State Trait Anxiety Inventory.

Studies of Development of Decision Aids

Evidence Table 4.16a. Whelan (1999) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Whelan T, 1999 Study 2 Country: Canada RefMan ID: 7536 Study purpose: To determine the validity and reliability of an instrument to help clinicians inform their patients about surgical treatment options for the therapy of breast cancer | Study design: Test-retest Duration of the study: Total duration of the study: NR Duration for an individual patient: 4 weeks | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment, primary Model of decisionmaking:; - Shared as stated by authors; - Not clear as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Lumpectomy + radiation vs. mastectomy | Description: Decision Board ^a^ Purpose:; - Increase knowledge; - Help make a decision; - Improve communication between clinician and patients; Intervention administered by: "Skilled interviewer" Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 30 Characteristics:; - Healthy female volunteers; Age: Mean: 57.3 years; SD: NR; Range: NR Education: > 12 years: 16 (53%) Ethnicity: NR SES: NR | Outcome measures:; - Psychometric characteristics of DA: construct validity, reliability; - Acceptability of DA; - Decision; Outcomes measured:; - after the intervention; - retest: 3 or 4 weeks after the intervention

a The decision board was made of foam core 25 x 20 inches large. It had four subtitles: Treatment choice, Side effects, Results of Treatment Choice for the Breast, and Results of Treatment Choice for Survival. Each subtitle corresponded with two explanatory panels; one for mastectomy and one for lumpectomy plus radiation. The instrument was designed to be used by a surgeon. Initially, each panel was covered by a sliding door. The panels were opened to reveal information in a sequential fashion. The patient and the surgeon read each panel together. The patient was encouraged to ask questions during the presentation and afterward. At the end of the presentation, the patient was faced with an overall visual representation of her two options and the possible outcomes associated with each choice. There were three additional cards about breast cancer and the purpose of the board, another card asked the patient to reflect on how the treatment would affect her as an individual, and the third card was available for providing further details regarding breast reconstruction. Upon completion of the decision board presentation, the patient was given a take-home version to review and discuss with others if she so desired.

Studies of Development of Decision Aids

Evidence Table 4.16b. Whelan (1999) Results

Author | Intervention | Outcome(s) | Afterintervention Results | Retest Intervention Results | Notes
Whelan T, 1999 Country: Canada RefMan ID: 7536 | n = 30 Decision board | Construct validity | - 17/19 (89%) who chose lumpectomy + radiation switched preference when survival was decreased; - 9/11 (82%) who chose mastectomy switched preference when survival was reduced
Whelan T, 1999 Country: Canada RefMan ID: 7536 | n = 30 Decision board | Reliability (decision) | - 19/30 (63%) chose lumpectomy + radiation; - 11/30 (37%) chose mastectomy | Authors report 28/30 (93%) had the same preference.* | * No data provided about actual preference. Kappa statistic = 0.86
Whelan T, 1999 Country: Canada RefMan ID: 7536 | n = 30 Decision board | Acceptability of DA | - 30/30 (100%) considered that DB was easy to understand; - 29/30 (97%) recommended that DB should be used for breast cancer patients; - 24/30 (80%) found DB helpful in making a decision

Outcomes measured after the intervention (same day) and retested 3-4 weeks after the intervention.

Studies of Development of Decision Aids

Evidence Table 4.17a. Lawrence (2000) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Lawrence V, 2000 Country: USA RefMan ID: 5012 Study purpose: To develop an evidence-based cross-cultural mammography decision aid for European-American and Mexican-American women ^a^ | Study design: Test-Retest Intervention Group 1 (IG1) Case series Intervention Group 2 (IG2) Duration of the study: Total duration of the study: NR Duration for an individual patient: 2 weeks | Setting: Outpatient Type of cancer: Breast Type of decision: Screening Model of decision-making:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Mammography vs. self-examination vs. examination by health professional vs. none | Description: Decision Board (DB) ^b^ Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Trained administrator Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 56 Mainly monolingual English (IG1): 28 Mainly Spanish speaking Mexican-American women (IG2): 28 Characteristics: Convenience samples recruited among secretarial and administrative staff of a medical school, the waiting area of a primary care clinic for the indigent, and a community center. Age: IG1: range: 50 to 81 years IG2: range: 49 to 89 years Education (IG1 vs. IG2): > 12 years: 28 vs. 0 Ethnicity (IG1 vs. IG2): European-American: 26 vs. 6 Mexican-American: 2 vs. 22 SES: NR Religion: NR | Primary outcome measures:; - Psychometric properties of the decision aid: construct, reliability, validity; - Knowledge; - Decision; Outcomes measured:; - after the intervention; - retest: 1 to 2 weeks after the intervention

a The decision board was developed by a multidisciplinary team and involved an iterative process aimed at verbal and graphic simplicity and comprehensibility. The team included bilingual physicians, biostatisticians, a social scientist, and lay subjects. Lay women evaluated the DA in interactive focus groups with trained facilitators, providing feedback on comprehensibility, relevance, positive/negative balance, framing, and value-laden terminology.

b "The MDA [mammography decision aid] is a visual aid (decision board) comprising graphics and written material describing clinical alternatives, outcomes, and probabilities. The decision board is initially empty and then interactively assembled by a trained administrator with one or more subjects. The interaction is integral to the decision aid and includes probes to ensure comprehension and encourage spontaneous questions from participants. When completed, the team has built a board which visually summarizes the choices, outcomes, and probabilities." (p. 201). One of the probes was, "Why did you change/not change your mind when I changed the chance of benefiting from mammography?" (p. 202)

Studies of Development of Decision Aids

Evidence Table 4.17b. Lawrence (2000) Results

Author | Intervention | Outcome(s) | Afterintervention Results IG1 vs. IG2 ^a^ | Retest Intervention Results IG1 vs. IG2 | Notes
Lawrence V, 2000 Country: USA RefMan ID: 5012 | n = 56 Decision board (DB) | Construct validity ^b^ | - 12/26 who chose mammography reversed preference when subsequently presented with no mortality. Authors report that the remaining nine subjects that still chose mammography felt less strongly; *mean score fell from 4.9, SD: 0.3 to 3.40; SD: 0.5**; - 1/2 of the women who initially preferred not having mammography reversed preference when subsequently presented probability of 80% relative mortality reduction; - 22/28 (89%) changed preference when scenarios were changed *** | | * It is not clear how this number was obtained. ** p < 0.0001 (no statistics provided) *** Authors reported 48% explicitly, 32% implicitly by decreased confidence score (no data reported).
Lawrence V, 2000 Country: USA RefMan ID: 5012 | n = 56 Decision board (DB) | Reliability (Decision) | - chose mammography: 26/28 vs. 26/28; - chose no mammography: 2/28 vs. 2/28 | - chose mammography: 26/28 vs. 26/28; - chose no mammography: 2/28 vs. 2/28
Lawrence V, 2000 Country: USA RefMan ID: 5012 | n = 56 Decision board (DB) | Knowledge ^c^ | - authors reported that qualitative evidence of comprehension was excellent in IG1 women. As well, "After cross-cultural adaptation, comprehensibility was confirmed qualitatively for English and Spanish versions...." (p. 204)

a IG1: Mainly monolingual English; IG2: mainly Spanish-speaking Mexican-American women

b This outcome was measured with a 5-item confidence score: 5 = very strong; 1 = I don't care; only IG1 was included.

c Comprehension was assessed. A qualitative testing was performed with different standardized probes, such as (1) What do you think this means? Or What do you think I meant here? (2) Why did you change/not change your mind when I changed the chance of benefiting from mammography? and (3) What information from our session seems important to you?

Studies of Development of Decision Aids

Evidence Table 4.18a. Carrère (2000) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Carrère M, 2000 Country: France RefMan ID: 5013 Study purpose: To develop and test the acceptability of a decision aid that would allow doctors to transfer clear and comprehensible information to patients so they could make a decision | Study design: Test-retest Duration of the study: Total duration of the study: NR Duration for an individual patient: 2 weeks | Setting: Not clear Type of cancer: Breast Type of decision: Treatment, adjuvant Model of decision-making:; - Shared and Informed as stated by authors; - Not clear as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Chemotherapy vs. none | Description:; - Decision board (DB) ^a^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Researcher Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 40 Characteristics:; - Healthy volunteers; - > 50 years old; - Had never experienced cancer; Age: Mean: 61 years; SD: NR Education: NR Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Psychometric properties of DA: construct validity reliability; - Knowledge; - Decision; Outcomes measured:; - after the intervention; - retest: 2 weeks after the intervention

a Information about the two treatment options was conveyed to the patient orally by the researcher and with cards attached with Velcro on a board 35 cm wide and 50 cm high. The visual aid was empty at the beginning of the interview and, each time a piece of information was provided to the patient, a corresponding card with written information was attached to the board. By the end of the interview, all the information cards were on the board and all the information included in the written material had been transferred. The authors decided to present the two options simultaneously in eight successive points: (1) results of cancer surgery, (2) presentation of mandatory treatments (tamoxifen and radiation treatment), (3) formulation of therapeutic choice, (4) description of chemotherapy treatment, (5) presentation of the risks of relapse induced by the two options, (6) information about overall survival, (7) presentation of chemotherapy side effects, (8) treatment schedules. The two treatment options were both presented in the visual aid by colors: pale yellow for chemotherapy and pale orange for no chemotherapy. Information concerning relapse rates was provided using bar charts. At the end of the interview, a paper take-home version of the DB was given to the subject.

Studies of Development of Decision Aids

Evidence Table 4.18b. Carrère (2000) Results

Author | Intervention | Outcome(s) | Afterintervention Results | Retest Intervention Results | Notes
Carrère M, 2000 Country: France RefMan ID: 5013 | n = 40 Decision board (DB) | Construct validity | - 17/18 (95%) who chose chemo changed to no chemotherapy when percentages of relapse were both equal to 40%; - 14/22 (65%) who chose no chemo changed to chemotherapy when percentage of relapsed rose 50%; - 18/22 (45%) who chose no chemo, changed to chemo when 5-year relapse rate reached 100% | | Authors reported the choice of chemotherapy was not very sensitive to increasing side effects. The choice of no chemotherapy was sensitive to change in the conditions of administration and side effects of chemotherapy.
Carrère M, 2000 Country: France RefMan ID: 5013 | n = 40 Decision board (DB) | Reliability (Decision) | - chose chemotherapy: 18/40 (45%); strength of this preference: ^a^ mean: 7.8; SD: 2.6; range 3.0 to 10.0; - chose no chemotherapy: 22/40 (55%); strength of this preference: ^a^ mean: 8.3: SD: 2.1; range 3.4 to 10.0 | - chose chemotherapy: 18/40 (45%); strength of this preference: ^a^ : mean: 8.1: SD: 2.7; range 2.1 to 10.0; - chose no chemotherapy: 22/40 (55%); strength of this preference ^a^ : mean: 9.4: SD: 1.0; range 6.9 to 10.0 | Intraclass correlation coefficient = 0.97
Carrère M, 2000 Country: France RefMan ID: 5013 | n = 40 Decision board (DB) | Knowledge ^b^ | Proportion of right answers for each of the 13 questions: range: 87.5% to 100% | | Authors report that none of the questions were randomly answered, p < 0.000005 (X ^2^ test).

Outcomes were measured after the intervention and retested 2 weeks after the intervention.

a This outcome was measured with a visual analog scale (0 = indifference between the two options to 10 = absolute preference for the chosen option).

b The women were asked to answer 13 true or false statements about basic information: three items about general postoperative information, five items about chemotherapy treatment, and five items about chemotherapy side effects.

Studies of Development of Decision Aids

Evidence Table 4.19a. Sawka (1998, Study 1) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Sawka C, 1998 Study 1 Country: Canada RefMan ID: 199 Study purpose: To evaluate the revised draft version of a patient decision aid (DA) for the surgical therapy of early stage breast cancer | Study design: Case series Duration of the study: NR | Setting: Outpatient Type of cancer: Breast (stage I and II) Type of decision: Treatment, primary Model of decisionmaking:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision: Lumpectomy + breast radiation vs. mastectomy | Description:; - Usual care ^a^; - Workbook ^b^; - Audiotape ^c^; - Counseling ^d^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Not clear Timing of the intervention: NR | Number of subjects enrolled: 18 Characteristics:; - Newly diagnosed breast cancer patients; - Stage I or II; - Fluency in English; Age: Mean: 55 years; SD: NR; range: 37 to 74 years Education:> 12 years: 18 (100%) Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Face psychometric properties of DA; - Clarity of DA; - Acceptability of DA; - Satisfaction with DA; - Anxiety; - Knowledge; - Decisional conflict; Outcomes measured:; - after the intervention

a Consultation with the surgeon, during which there was a discussion about the diagnosis and treatment options, provided the surgeon believed that both mastectomy and breast-conserving therapy were appropriate.

b The workbook presents color photographs of lumpectomy, acute and long-term radiation reactions, and mastectomy with and without reconstruction. The likelihood of events is described in graphical form to provide quantitative information. The booklet contained a values clarification exercise. This was a three-step process that used the analogy of a 'balance scale' where lumpectomy and mastectomy were on opposite sides. The woman was asked to review the advantages and disadvantages of both lumpectomy with radiation and mastectomy as provided, and to list additional ones. The woman considered the value of each of the advantages and disadvantages by shading each box according to its personal importance (no shading = not important to me; complete shading = extremely important to me). The user examined her worksheet to identify whether she was 'leaning' toward lumpectomy followed by radiation or toward mastectomy. Before the woman completed her own worksheet, several examples were provided. The authors reported that these hypothetical cases would reinforce the notion that there is no right or wrong choice and that the decision is based on a woman's personal values.

c The audiotape is 26 minutes long and supplements the workbook.

d The patient reviewed the decision aid in the presence of a research nurse who answered questions.

Studies of Development of Decision Aids

Evidence Table 4.19b. Sawka (1998, Study 1) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
Sawka C, 1998 Study 1 Country: Canada RefMan ID: 199 | n = 18; - Usual care; - Workbook; - Audiotape; - Counseling | Clarity of DA | 10/18 (56%) found no areas that were unclear Three subjects thought the discussion of adjuvant systemic treatment was unclear
Sawka C, 1998 Study 1 Country: Canada RefMan ID: 199 | n = 18; - Usual care; - Workbook; - Audiotape; - Counseling | Acceptability of DA | - photos "scary but real": 2/18 (11%); - photos were useful in decisionmaking: 6/18 (33%); - 5/18 felt that DA raised new questions about what surgeon first explained; - felt the DA helped clarify information given by surgeon 18/18 (100%); - positive reaction to DA: 17/18 (94%)
Sawka C, 1998 Study 1 Country: Canada RefMan ID: 199 | n = 18; - Usual care; - Workbook; - Audiotape; - Counseling | Satisfaction with DA | - very satisfied or satisfied with DA: 17/18 (94%)
Sawka C, 1998 Study 1 Country: Canada RefMan ID: 199 | n = 18; - Usual care; - Workbook; - Audiotape; - Counseling | Anxiety ^a^ | - unaffected after use of DA: 13/18 (72%); - relieved after use of DA: 4/18 (22%)
Sawka C, 1998 Study 1 Country: Canada RefMan ID: 199 | n = 18; - Usual care; - Workbook; - Audiotape; - Counseling | Knowledge ^b^ | 12/18 (66%) answered the questionnaire. Total number of incorrect responses: 50 (incorrect responses range 0-10, for each item)
Sawka C, 1998 Study 1 Country: Canada RefMan ID: 199 | n = 18; - Usual care; - Workbook; - Audiotape; - Counseling | Decisional conflict ^c^ | mean overall score: 1.81; SD: 0.31

Outcomes were measured after the intervention (timing not specified).

a Self report

b An 18-item questionnaire, the Breast Cancer Information Test (BCIT). The topics covered in the DA were more likely to be answered correctly.

c Decisional Conflict Scale (DCS). It is composed of 16 questions with an overall score and subscales addressing uncertainty, modifiable factors contributing to uncertainty, clarity of values, inadequate social support, and perceived effective decisionmaking. The overall score can range from 1 (low decisional conflict) to 5 (high decisional conflict). In this study, the DCS was administered to eight subjects.

Studies of Development of Decision Aids

Evidence Table 4.20a. Sawka (1998, Study 2) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Sawka C, 1998 Study 2 Country: Canada RefMan ID: 7537 Study purpose: To evaluate the final version of a decision aid (DA) for the surgical therapy of early stage breast cancer in a pilot study | Study design: Case series Duration of the study: NR | Setting: Outpatient Type of cancer: Breast (stage I and II) Type of decision: Treatment, primary Model of decisionmaking:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision: Information transfer Context of decision: Lumpectomy + breast radiation vs. mastectomy | Description:; - Usual care ^a^; - Workbook ^b^; - Audiotape ^c^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Not clear Timing of the intervention: NR | Number of subjects enrolled: 10 Characteristics:; - Newly diagnosed breast cancer patients; - Stage I or II; - Fluency in English; Age: Mean: 52 years; SD: NR; range: 34 years to 78 years Education:> 12 years: 7 (70%) Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Knowledge; - Decisional conflict; Outcomes measured:; - after the intervention

a Consultation with the surgeon during which there was a discussion about the diagnosis and treatment options, provided the surgeon believed that both mastectomy and breast conserving therapy were appropriate.

b The workbook presents color photographs of lumpectomy, acute and long-term radiation reactions, and mastectomy with and without reconstruction. The likelihood of events is described in graphical form to provide quantitative information. The booklet contained a values clarification exercise. This was a three-step process that used the analogy of a 'balance scale' where lumpectomy and mastectomy were on opposite sides. The woman was asked to review the advantages and disadvantages of both lumpectomy with radiation and mastectomy as provided, and to list additional ones. The woman considered the value of each of the advantages and disadvantages by shading each box according to its personal importance (no shading = not important to me; complete shading = extremely important to me). The user examined her worksheet to identify whether she was 'leaning' toward lumpectomy followed by radiation or toward mastectomy. Before the woman completed her own worksheet, several examples were provided. The authors reported that these hypothetical cases would reinforce the notion that there is no right or wrong choice and that the decision is based on a woman's personal values.

c The audiotape is 26 minutes long and supplements the workbook.

Studies of Development of Decision Aids

Evidence Table 4.20b. Sawka (1998, Study 2) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Sawka C, 1998 Study 2 Country: Canada RefMan ID: 7537 | n = 10; - Usual care; - Workbook; - Audiotape | Knowledge ^a^ | | Total number of incorrect responses: 18 (incorrect responses range 0-8, for each item)
Sawka C, 1998 Study 2 Country: Canada RefMan ID: 7537 | n = 10; - Usual care; - Workbook; - Audiotape | Decisional conflict ^b^ | | Overall mean: 2.2; SD: 0.37

Outcomes measured after the intervention (timing not specified).

a Subjects were asked to fill out an 18-item questionnaire, the Breast Cancer Information Test (BCIT). The topics covered in the DA were more likely to be answered correctly.

b Decisional Conflict Scale (DCS) is composed of 16 questions with an overall score and subscales addressing uncertainty, modifiable factors contributing to uncertainty, clarity of values, inadequate social support, and perceived effective decisionmaking. The overall score can range from 1 (low decisional conflict) to 5 (high decisional conflict). In this study, the DCS was administered to all subjects.

Studies of Development of Decision Aids

Evidence Table 4.21a. Fiset (2000) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Fiset V, 2000 Country: Canada RefMan ID: 7894 Study purpose: To develop a decision aid that incorporates patients' values in deciding whether to undergo chemotherapy for stage IV lung cancer | Study design: Case series (patients) Survey (physicians) Duration of the study: Case series: NR Physician survey: 3 months Validity: Content; Face | Setting: Outpatient Type of cancer: Lung Type of decision: Treatment Model of decision-making:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - information transfer; - deliberation; Context of decision: Supportive care/radiation therapy plus chemotherapy versus supportive care/radiation therapy | Description: Audiotape workbook ^a^ Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: NR Timing of the intervention:; - before the decision was made | Number of patients enrolled: 6 Number of physicians: 29 Characteristics: Patients:; - diagnosed with stage IV lung cancer; - had already made the decision about chemotherapy (2 declined and 4 accepted chemotherapy) Physicians:; - thoracic surgeons and respirologists currently treating lung cancer patients ^b^; Age: Mean, SD, range: NR Education: NR Ethnicity: NR SES: NR | Primary outcome measures:; - acceptability of DA; - usefulness of DA; Outcomes measured:; - after the intervention

a DA intervention consisted of an audiotape and accompanying booklet plus a worksheet. The audiotape is 35 minutes in length and explains lung cancer and its stages, the functional impact of this disease, the available treatment options of supportive care, radiation therapy, and chemotherapy. It details the risks and benefits of chemotherapy as well as the side effects.

b A cross-sectional mail survey of thoracic surgeons and respirologists. Survey was sent to all eligible physicians listed by the Ontario Medical Association (sent to 84 thoracic surgeons and 111 respirologists; 15 surgeons and 14 respirologists reviewed the intervention).

Studies of Development of Decision Aids

Evidence Table 4.21b. Fiset (2000) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Fiset V, 2000 Country: Canada RefMan ID: 7894 | n = 6 patients; n = 29 physicians Audiotape booklet with worksheet | Acceptability of DA ^a^ | | Patients:; - all of the patients (6/6) found the intervention acceptable in terms of amount, length, clarity, and appropriateness; - 3/6 (50%) found the absolute survival benefit of chemotherapy upsetting (all three were on chemotherapy) Physicians:; - 25/29 agreed with the clinical practice guideline on which the intervention was based; - greater than 66% of physicians found the information in the intervention sufficient, accurate, and balanced; - greater than 66% felt the intervention would help patients consider personal values, participate in making the decision, and make a more informed decision; - 19/29 would be comfortable giving the DA to their patients; 6/29 were neutral; and 4/29 would be uncomfortable.
Fiset V, 2000 Country: Canada RefMan ID: 7894 | n = 6 patients; n = 29 physicians Audiotape booklet with worksheet | Usefulness of DA ^a^ | | Patients:; - all of the patients (6/6) responded that the intervention would be useful for patients faced with this decision; Physicians: (number who strongly or somewhat agree); - DA will be easy to use in my practice: 14/28 (50%); - DA will complement my usual approach: 17/28 (61%); - DA will help patient make better decisions: 16/28 (57%); - DA will do more good than harm: 15/28 (54%); - DA will save me time: 8/28 (29%); - DA will help streamline my counselling: 10/28 (36%); - Very likely, likely, or somewhat likely to use DA in the future: 21/28 (75%)

a Physician responded to 18 items regarding the acceptability and usefulness of the DA intervention; each item was scored on a 5-point Likert-type scale from strongly agree to strongly disagree.

Studies of Development of Decision Aids

Evidence Table 4.22a. Unic (1998) General Characteristics

Author/Study purpose | Design | Clinical situation | Intervention | Sample | Outcomes
Unic I, 1998 Stalmaeir P, 1999 Unic I, 2000 Country: The Netherlands RefMan ID: 872, 127, 7388 Study purpose: To evaluate the feasibility and reliability of Time tradeoff (TTO) ^a^ for assessing preferences for prophylactic mastectomy (PM) or breast cancer screening (BCS) | Study design: Test-retest Duration of the study: Total duration of the study: 30 months Duration for an individual patient: not clear | Setting: Outpatient Type of cancer: Breast Type of decision: Prevention and screening Model of decision-making:; - Shared as stated by authors; - Components of both paternalistic and informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; - Making the decision; Context of decision: Prophylactic mastectomy vs. BCS | Description:; - Time tradeoff ^b^; - Videotape ^c^; - Pamphlet ^d^; Purpose:; - Help make a decision; Intervention administered by: Physician Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 54 Characteristics:; - Healthy women with family history of breast cancer; - Referred for BCS and genetic counseling; Age: Mean: 38 years; SD: 11; Minimum 25 years Education:< 12 years: 7; > 12 years: 47 Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Psychometric properties of DA: reliability, construct validity; - Feasibility; - Preference; Outcomes measured:; - after the intervention

a As part of the "Shared Decision Making Program" (SDMP) (p. 269)

b The TTO offered the women two alternatives: inferior health for a certain number of life years t (duration), followed by death; and the best-ranked health state for a number of life years x, followed by death. The authors reported an example: What do you prefer: x years with BCS (alternative A) or t years living after PM (alternative B)? The authors started by setting x equal to t to check for understanding the TTO question. Next, x was set equal to zero. Then, x was varied via bisection until the woman was indifferent between the two alternatives. For instance, if a woman were indifferent between 37.5 years with BCS and 50 years after PM, the value for PM would be 75% of the values for BCS (37.5/50 = 0.75). Four tradeoffs were done for different values of t, depending on the woman's age. (p. 270)

c Thirty-two minute videotape called "Breast Cancer in the Family. In this video,"high risk women and their partners, sisters, and daughters talk about physical and psychosocial aspects of PM and BCS." (p. 270)

d Take-home brochure with general information about breast cancer, risk factors for the disease, genetic testing, estimates of the risk of breast cancer for BRCA1/2 mutation carriers, BCS and PM. (p. 270)

Studies of Development of Decision Aids

Evidence Table 4.22b. Unic (1998) Results

Author | Intervention | Outcome(s) | Afterintervention Results | Retest Intervention Results | Notes
Unic I, 1998 Country: The Netherlands RefMan ID: 872 | n = 54; - Time-tradeoff; - Videotape; - Pamphlet | Construct validity | | - TTO values: Mean: 0.6; SD: 0.2;; - RS values: Mean: 0.4; SD: 0.2 **** | **** Comparison between TTO and RS values: p = < 0.001. Correlation coefficient was 0.5 (95%CI = 0.47 - 0.80)
Unic I, 1998 Country: The Netherlands RefMan ID: 872 | n = 54; - Time-tradeoff; - Videotape; - Pamphlet | Reliability (Preference ^a^ ) | Rating Scale (RS) values: Mean: 0.50; SD: 0.27 TTO values: Mean: 0.77; SD 0.25 | - RS values: Mean: 0.4; SD: 0.2 *; - TTO values: Mean: 0.6; SD: 0.2 **; - Women who were proven carriers: N = 11: TTO values: Mean: 0.7; SD: 0.3 ***; - Women with unknown genetic test: N = 39 TTO values: Mean: 0.7; SD: 0.2 *** | * pre- and posttest: p = 0.18 ** pre- and posttest: p = 0.003 (Wilcoxon matched-pairs signed rank test) *** Retest TTO mean values between proven carriers and women with unknown genetic results: p = 0.19 (Mann-Whitney U test) (p. 272) r-Pearson correlation between the averaged TTO values: 0.76 (95% CI = 0.58-0.87) for the two evaluations (N = 46). Meanwhile, the correlation in RS values was 0.67 (95%CI = 0.47 - 0.80, N = 47)
Unic I, 1998 Country: The Netherlands RefMan ID: 872 | n = 54; - Time-tradeoff; - Videotape; - Pamphlet | Feasibility | | - Completed TTO and RS evaluations: 42/54 (78%); - RS rated "rather easy" ^b^ : Mean: 5.0; SD: 1.23; - TTO rated "rather difficult": Mean: 3.39; SD: 1.56; - Ability to express own values ^c^ in both (TTO, RS) was "very sufficient": Mean: 7.1; SD: 1.0 vs. 7.31; 1.2; - "Feeling relaxed during preference assessment" ^d^ in both was "very sufficient": Mean: 7.2; SD: 1.2 vs. 7.4; 0.9 | "Difficulty" RS vs. TTO: p < 0.001 "Ability to express own values": RS vs. TTO: p = 0.25 "Feeling relaxed during preference assessment" RS vs. TTO: p = 0.07 (p. 273)

Outcomes measured after the intervention. Retesting completed at an unspecified time.

a Patient preferences were measured with a rating scale (RS) and with the Time Tradeoff (TTO). In the RS, the patients were asked to rate health states using a 10-point scale from 0 (corresponding to death) to 10 (corresponding to the best ranked health state). In the TTO, the women were offered two alternatives: "inferior health for a number of life years (duration) t, followed by death; and the best-ranked health state for a number of life years x, followed by death" (p. 270) The authors started with setting x = t, then x was set = 0, then x varied until the women were indifferent between the two choices. RS values were rescaled from 0 to 1 for comparison with TTO values.

b Difficulty of RS and TTO was measured on a 7-point scale (1 = very difficult; 7 = very easy).

c The ability of expressing own values was measured on a 10-point scale (1 = very bad; 10 = excellent).

d This outcome was measured on a 10-point scale (1 = very bad; 10 = excellent).

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.1a: Shapira (2000) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Schapira MM 2000 Country: USA RefMan ID: 201 Study purpose: To test the effect of a prostate cancer screening decision aid on patient's knowledge, beliefs, and use of prostate cancer screening tests | Study design: Randomized Controlled Trial Method of Randomization: Not reported Allocation concealment: Adequate Baseline comparability: Characteristics among groups were similar Blinding of outcome assessment: NR Follow-up: NR Duration of the study: Total duration of the study: 6 years Duration for one patient: 2 weeks | Setting: Outpatient Type of cancer: Prostate Type of decision: Screening/detection Model of decisionmaking:; - Informed as stated by authors and as assessed by reviewers; Phase of decision:; - Information transfer; Context of decision: Prostate Specific Antigen (PSA) test + Digital Rectal Examination (DRE) vs. none | Description Control Group (CG):; - Information pamphlet ^a^; - Research assistant available to answer questions ^b^; - Follow-up visit ^c^; Intervention Group (IG):; - DA brochure ^d^; - Research assistant available to answer questions ^b^; - Followup visit ^c^; Purpose:; - Increase knowledge; - Make a decision/state a preference; Intervention administered by: Research assistant Timing of the intervention: Before the decision was made | Number of subjects enrolled: 257 IG: 122; CG: 135 Eligibility criteria: Inclusion:; - 50 to 80 years of age; - having an outpatient encounter in the years 1990 to 1995; Exclusion:; - history of previous cancer; - history of prostate or genitourinary disease; - poor mental status; - active employee at the medical center; Age IG: mean 69.4 years; SD 7.3 CG: mean 70.4 years; SD 6.4 Education: NR Ethnicity: Caucasian: IG: 116, CG: 122; African American: IG:1, CG: 6; Hispanic: IG: 0, CG: 1 Other: IG: 5; CG: 5 SES: NR | Outcome measures:; - Decision; - Knowledge/ beliefs; Outcomes measured:; - Before intervention (same day); - 2 weeks after intervention

a This 5-page pamphlet contained basic prostate cancer information (epidemiology, symptoms of prostate cancer, prostate cancer screening methods, and the potential benefits of screening), without the quantitative and qualitative outcomes regarding risks and benefits of screening.

b A research assistant was present when the subject reviewed the pamphlet and was available to answer any questions.

c A followup visit was scheduled with the subject's primary care physician or one of the research investigators approximately 2 weeks after the initial study visit. During this visit, the subject was asked if he wanted to undergo prostate cancer screening with PSA and a DRE. When subjects asked for the physician's opinion, a script response was provided. The response emphasized the toss-up nature of the decision and encouraged the patient to make up his own mind about cancer screening.

d This 8-page long pamphlet with visual graphs included quantitative information on operating characteristics (sensitivity and specificity) of a combined screening strategy of DRE and PSA and a description of followup tests (transrectal ultrasound and prostate biopsy). The authors reported that they tried to present prostate cancer screening outcomes in a balanced manner. The graphic design used to convey the sensitivity and specificity of a prostate screening strategy consisted of human figure representations. An illustration presented 100 male human figures. A subset of figures was highlighted to represent the frequency of abnormal screening test results. The authors also included a statement on the uncertain efficacy of treatment for earlystage prostate cancer.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.1b: Shapira (2000) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Schapira MM, 2000 RefMan ID: 201 | n = 257 Control Group (CG) n=135:; - information pamphlet; - research assistant available to answer questions; - followup visit; Intervention Group (IG) n=122:; - DA brochure; - research assistant available to answer questions; - followup visit | Knowledge/beliefs ^a^ | mean: 11.7; SD 2.4 vs. mean: 11.4; SD 2.4* | mean: 15.0; SD 2.3 vs. mean: 14.1; SD 2.7** | * between-group difference at baseline: NS; p = 0.32 ** between-group difference p < 0.01 (Wilcoxon-Mann-Whitney test)
Schapira MM, 2000 RefMan ID: 201 | | Decision ^b^ (patient had Prostate Specific Antigen [PSA] + Digital Rectal Examination [DRE]) | | At 2 week followup: 100/122 (82%) vs. 113/135 (84%)*** | *** between-group difference p = 0.60 (Chi-square test)
Schapira MM, 2000 RefMan ID: 201 | | Beliefs ("most men with prostate cancer die of something else") | | Postintervention: 82/122 (67%) vs. 62/135 (46%)**** | **** between-group difference post-intervention: p = 0.01 (Chi-square test)
Schapira MM, 2000 RefMan ID: 201 | | Other results ^c^

Outcomes were measured before intervention (same day) and 2 weeks after the intervention.

a Prostate cancer screening knowledge: 18-item questionnaire; higher scores meaning higher knowledge

b Outcome was measured at baseline as pooled data: i) Subjects said that they were very likely to have DRE test (p. 421). Pooled data at baseline: 224/257 (84%). ii) Subjects said that they were very likely to have PSA test (p. 421). Pooled data at baseline: 216/257 (87%).

c "Subjects felt well informed enough to make a decision about prostate cancer screening." (p. 422) Pooled data: at baseline 198/257 (77%); postintervention: 239/257 (93%); 98% of subjects stated that they would have screening for prostate cancer if their physician recommended it.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.2a: Iglehart (1998) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Iglehart J, 1998 Bluman L, 1999 Miron A., 2000 Country: USA Language of publication: English RefMan ID: 2917, 364, 4382 Study purpose: To evaluate two types of pre-counseling educational material for women at high risk of carrying a BRCA1 or BRCA2 mutation in deciding whether to undergo genetic testing | Study design: Randomized Controlled Trial Method of randomization: NR Allocation concealment: NR Baseline comparibility: NR Blinding of outcome assessment: NR Followup: Not clear ^d^ Duration of the study: Total duration of the study: Not clear Duration for one subject: NR | Setting: Outpatient Type of cancer: Breast and ovarian Type of decision: Genetic testing Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Genetic testing for BRCA1 and BRCA2 mutations versus no genetic testing | Description: Intervention group (IG1):; - DA brochure ^b^; - genetic counseling ^a^ Intervention group (IG2):; - individualized DA brochure ^c^; - genetic counseling ^a^; Purpose:; - To increase knowledge; - Help to make a decision; Intervention administered by: NR Timing of the intervention:; - Before the decision was made | Number of subjects enrolled:; - Baseline: 420 (total);; - Number for IG1 and IG2: NR; - Genetic testing offered: 221 (total); Eligibility criteria:; - Diagnosed with breast cancer before the age of 31; - Jewish women diagnosed with breast cancer before 41 years of age; - Diagnosed with breast cancer before the age of 56 or ovarian cancer at any age and has at least one first-degree relative who was diagnosed with ovarian cancer or breast cancer before age 56; - Diagnosed with breast cancer before age 56 or ovarian cancer at any age and has three or more relatives with ovarian cancer or earlyonset breast cancer (< 56 years); Demographics ^d^ Age: Mean: 49 years; SD: NR; range: 28 to 88 year Education:> 12 years 213 (100%) Ethnicity: Caucasian: 202 (95%) Black 8 (4%); Other 3 (6%) SES: NR | Outcome measures:; - Decision; - Perceived risk; - Knowledge; - Interest in genetic testing; - Interest in prophylactic surgery; Outcomes measured: Before and after the intervention (measured after intervention, after genetic counseling, after testing decision, and then after receiving genetic testing results)

a After reading the DA brochures, participants were offered genetic counselling sessions that were nondirective, neither encouraging nor discouraging women to undergo genetic testing. All of the study participants received an estimation of the risk of carrying a mutation in a uniform manner.

b IG1, DA brochure: standard printed material regarding breast and ovarian cancer genetics and genetic testing; nondirective in nature

c IG2, individualized DA brochure: printed educational material regarding breast and ovarian cancer genetics and genetic testing that were tailored to each participant using data collected during the baseline survey. The individualized variables included: level of education, preference for quantitative or qualitative risk estimates or both, and carrier probability.

d This is a preliminary report that was based on the 213 subjects who completed genetic testing by the cutoff time.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.2b: Iglehart (1998) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Inlgehart J, 1998 Bluman L, 1999 Miron A., 2000 RefMan ID: 2917, 364, and 4382 | Intervention group (IG1): DA brochure before genetic counseling Intervention group (IG2): Individualized DA brochure before genetic counseling | | Note: None of the results were reported by intervention. | Note: None of the results were reported by intervention. | Results are based on a preliminary interim analysis. Data collection is still in process.
Inlgehart J, 1998 Bluman L, 1999 Miron A., 2000 RefMan ID: 2917, 364, and 4382 | Intervention group (IG1): DA brochure before genetic counseling Intervention group (IG2): Individualized DA brochure before genetic counseling | Decision ^a^ | | 213/221 (96%) women offered testing decided to be tested.
Inlgehart J, 1998 Bluman L, 1999 Miron A., 2000 RefMan ID: 2917, 364, and 4382 | Intervention group (IG1): DA brochure before genetic counseling Intervention group (IG2): Individualized DA brochure before genetic counseling | Knowledge ^b^ | Reported on average, subjects correctly answered 51% (SD: 20) of the items. | | Refer to paper (Bluman, 1999) for details.
Inlgehart J, 1998 Bluman L, 1999 Miron A., 2000 RefMan ID: 2917, 364, and 4382 | Intervention group (IG1): DA brochure before genetic counseling Intervention group (IG2): Individualized DA brochure before genetic counseling | Perceived risk of carrying a mutation | - More than 75% of the women overestimated their risk, and about 25% underestimated it.; - The average difference between the women's risk estimates and the mathematical model's estimate was 32%. | | Logistic regression model found that women who have > 3 first-, second-, or third-degree affected relatives were more likely to overestimate their risk (odds ratio 0.3, 95% CI: 0.2 to 0.6, p<0.05). Overestimation of risk was not significantly predicted by age, race, or previous genetic testing of a family member.
Inlgehart J, 1998 Bluman L, 1999 Miron A., 2000 RefMan ID: 2917, 364, and 4382 | Intervention group (IG1): DA brochure before genetic counseling Intervention group (IG2): Individualized DA brochure before genetic counseling | Interest in genetic testing ^c^ | Of the 200 baseline surveys analyzed:; - 168 (84%) of the women were probably or definitely interested in genetic testing. | | Logistic regression model found that women who had been advised to be tested by their doctor were 2 times more likely to respond that they were definitely interested (odds ratio 1.5, 95% CI: 1.1 to 2.0; p<0.05).
Inlgehart J, 1998 Bluman L, 1999 Miron A., 2000 RefMan ID: 2917, 364, and 4382 | Intervention group (IG1): DA brochure before genetic counseling Intervention group (IG2): Individualized DA brochure before genetic counseling | Interest in prophylactic surgery | - Considering mastectomy: 35/82; - Not considering mastectomy: 47/82; - Considering oophorectomy: 42/95; - Not considering ooophorectomy: 53/95 | Measured women's interest in prophylactic surgery after receiving genetic testing results. Data presented grouped by carrier status. Refer to paper (Miron, 2000) for details.

a Outcomes measured before and at several points after the intervention (2 weeks after the intervention; then after genetic counseling session; after making the testing decision, and then after receiving genetic testing results).

b Knowledge measured using a 13-item True/False test that was adapted from a measure previously used by Lerman et al. (1996, 1997).

c Interest in genetic testing: six response options presented: (1) definitely will not be tested, (2) probably will not be tested, (3) considering being tested but still unsure, (4) probably will be tested, (5) definitely will be tested, and (6) have not yet considered testing.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.3a: Cassileth (1989) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Cassileth B 1989 Country: USA RefMan ID: 182 Study purpose:; - To facilitate information transfer between patient and clinician; - To increase patients' involvement in decisionmaking | Study design: Case series Blinding of outcome assessment: Not used Followup: 80-100% of the subjects were followed at the end of study Duration of the study: NR | Setting: Outpatient Type of cancer: Prostate, stage 4 Type of decision: Treatment (advanced) Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Surgical castration vs. hormonal castration (Zoladex^®^) | Description: Usual care ^a^ and DA brochure ^b^ Purpose:; - Increase knowledge; - Improve satisfaction with choice; Intervention administered by: Physician Timing of the intervention:; - pamphlet given at the end of the first consultation and before the decision was made | Number of patients enrolled: 159; 147 (92%) completed the study Eligibility criteria: Inclusion:; - Previously untreated stage D prostate cancer patients for whom hormonal therapy was indicated; Characteristics: Age: Mean, SD: NR Range: 48 to 96 years Education: Nonhigh school graduates: 59 (40%) Ethnicity: Caucasian: 99 (67%) SES: NR Religion: NR | Outcome measures:; - Decision; - Satisfaction with decision; - Determinant of patients' choice; Outcomes measured:; - same day and 3 months after intervention

a Oncology consultation in which patients discussed treatment options with their physicians.

b Patients took home a 2-page letter explaining, in an unbiased fashion, two therapeutic options: surgical castration or Zoladex^®^.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.3b: Cassileth (1989) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Cassileth, B 1989 RefMan ID: 182 | n = 159 Usual care and DA brochure | Decision ^a^ | | Immediately after intervention: Chose hormonal castration: 115/147 (78%) Chose surgical castration: 32/147 (22%)
Cassileth, B 1989 RefMan ID: 182 | n = 159 Usual care and DA brochure | Determinants of choice | | Most frequent reason given for choice: Of patients who had hormonal castration:; - chose this treatment to avoid surgery 41/115(36%) Of patients who had surgical castration:; - convenience of treatment 11/32 (33%)
Cassileth, B 1989 RefMan ID: 182 | n = 159 Usual care and DA brochure | Satisfaction with decision: Would choose same treatment again | | At 3-month followup:; - Would choose surgical castration again: 22/22 (100%); - Would choose hormonal therapy again: 88/89 (99%)

Outcomes measured before the intervention and after the intervention (same day, 12 weeks).

a Questionnaire presented in Figure 1, p. 59, in original article.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.4a: Adler (1999) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Adler K, 1999 Country: Australia RefMan ID: 7145 Study purpose:; - To offer women requiring adjuvant chemotherapy a choice of two treatment regimens | Study design: Case series Blinding of outcome assessment: Not done Followup: 80 - 100% of the subjects were followed at the end of the study Duration of the study: Total duration of the study: NR Duration for an individual patient: 7 months | Setting: Outpatient Type of cancer: Breast, early stage Type of decision: Treatment, adjuvant Model of decisionmaking:; - NR by authors; - Informedas determined by reviewers; Phase of decision: Information transfer Context of decision: Doxorubicin and cyclophosphamide (AC) vs. cyclophosphamide/methotrexate/ fluorouracile (CMF) | Description:; - Usual care ^a^; - Pamphlet ^b^; Purpose: Help make a decision Intervention administered by: Not specified Timing of the intervention: before the decision was made | Number of subjects enrolled: 41 Eligibility criteria: Women with early breast cancer Characteristics: Age: Mean, SD: NR; Range: 21 years to 60 years Education: NR Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Satisfaction with choice; - Satisfaction with decisionmaking; - Would choose same therapy again; Outcomes measured: 7 months after the intervention

a All women were educated by the team (oncologists, oncology nurses, and oncology pharmacist) regarding the difference between the treatments, including side effects, duration of administration, and number of needles involved. (p. 102)

b Written information for the patients to take home which could be discussed with family members before making a decision; no further description provided.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.4b: Adler (1999) Results

Author | Intervention | Outcome(s) | Postintervention Results | Notes
Adler K, 1999 RefMan ID: 7145 | n = 41 Usual care and pamphlet (no description) | Decision (n=36) | - chose doxorubicin/cyclophosphamide (AC): 22/36 (61%); - chose cyclophosphamide/methotrexate/fluorouracil (CMF): 12/36 (33%); - did not remember being given a choice: 2/36 (5%)
Adler K, 1999 RefMan ID: 7145 | n = 41 Usual care and pamphlet (no description) | Satisfaction with decisionmaking (n=34) | - found it beneficial to be given a choice: 27/34 (79%); - unsure if it was beneficial to be given a choice: 7/34 (21%)
Adler K, 1999 RefMan ID: 7145 | n = 41 Usual care and pamphlet (no description) | Satisfaction with DA (n=34) | - felt that they were not given enough information to make an informed choice: 5/34 (15%)
Adler K, 1999 RefMan ID: 7145 | n = 41 Usual care and pamphlet (no description) | Would choose same therapy again (n=34) | - of those who chose AC chemotherapy: 22/22 (100%); - of those who chose CMF chemotherapy: 8/12 (67%)
Adler K, 1999 RefMan ID: 7145 | n = 41 Usual care and pamphlet (no description) | Other results^a^

Outcomes were measured 1 month after completing adjuvant chemotherapy.

a Authors measured additional outcomes; refer to paper for details.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.5a: Protière (2000) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Protière C, 2000 Country: France RefMan ID: 5004 Study purpose:; - To determine the feasibility of giving breast cancer patients the opportunity to participate in their treatment choice | Study design: Case series Blinding of outcome assessment: Not used Followup: 80-100% of the subjects were followed at the end of the study Duration of the study: Total duration of the study: 15 months Duration for an individual patient: 4 months | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment (adjuvant) Model of decisionmaking:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Sequential vs. concomitant chemo/radiotherapy | Description:; - Usual care^a^; - DA brochure^b^; Purpose:; - To help make a decision; - To increase patient involvement in decisionmaking; Intervention administered by: Physician Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 71 patients 9 physicians Eligibility criteria:; - >18 years old; - nonmetastatic breast cancer; - no more than 3 involved lymph nodes; - in case of negative axillary dissection one (non-menopausal patients) or two (menopausal patients) of the following criteria: Scarff, Bloom, and Richardson (SBR) grade 3, negative hormonal receptor (HR -), presence of per-vascular tumoral emboli (PVTE +); Characteristics: Age: Not clear Education: < 12 yrs: 27 Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Physician ability to predict patient's choice; - Reasons for patient's choice of treatment; - Satisfaction with decisionmaking; - Ideal level of patient participation in decisionmaking; - Quality of life patient; - Perception of involvement in care; - Would recommend to other patients; Outcomes measured:; - 1 week after intervention; - After completing adjuvant chemotherapy

a The oncology consultation was structured on the pamphlet.

b DA brochure: A short leaflet presenting the pros and cons of each treatment option was given to patients to take home at the end of the consultation.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.5b: Protière (2000) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Protière C, 2000 RefMan ID: 5004 | n = 71 patients n = 9 physicians Usual care and DA brochure | Decision | | - Chose concomitant treatment: 41/64 (64%); - Chose sequential treatment: 23/64 (36%) | Variables associated with the choice of sequential treatment: level of education < High school (Odds Ratio [OR]: 4.68, 95% CI: 1.3-16.8); had discussed the choice with family (OR: 8.56, 95% CI 1.9-38.23); fear of cumulative side effects (OR 9.50; 95% CI 2.19-41.15)
Protière C, 2000 RefMan ID: 5004 | n = 71 patients n = 9 physicians Usual care and DA brochure | Physician ability to predict patient's choice | | - Physicians accurately predicted patient's choice: 42/64 (66%)
Protière C, 2000 RefMan ID: 5004 | n = 71 patients n = 9 physicians Usual care and DA brochure | Determinants of patient's choice | | Most frequent reason given for choice: Concomitant treatment:; - Shorter length of treatment: 34/41 (83%); Sequential treatment:; - Fear of side effects: 17/23 (74%)
Protière C, 2000 RefMan ID: 5004 | n = 71 patients n = 9 physicians Usual care and DA brochure | Satisfaction with decisionmaking | | Followup after completing treatment:; - Satisfied to participate in treatment choice 51/57 (89%)
Protière C, 2000 RefMan ID: 5004 | n = 71 patients n = 9 physicians Usual care and DA brochure | Would recommend treatment to others | | - Of those who chose the concomitant treatment: 39/39 (100%); - Of those who chose the sequential treatment: 13/18 (72%)
Protière C, 2000 RefMan ID: 5004 | n = 71 patients n = 9 physicians Usual care and DA brochure | Quality of life | | Global quality of life (mean score); - presequential treatment: 57.08, SD NR; - postsequential treatment: 64.22, SD 16.34; - preconcomitant treatment: 66.23, SD NR; - postconcomitant treatment: 51.07, SD 19.23 | Global quality of life posttreatment was significantly better for patients who had sequential rather than concomitant treatment (p<0.05).
Protière C, 2000 RefMan ID: 5004 | n = 71 patients n = 9 physicians Usual care and DA brochure | Other results^a^

Outcomes were measured at 1 week postintervention and at completion of chosen chemotherapy schedule.

a Ideal level of patient participation: Doctor should make decision: 7/57(12%); doctor should make decision but strongly consider patient's opinion: 7/57(12%); doctors and patients make decision together: 29/57 (51%); patient should make decision considering doctors' opinion: 9/57 (16%); patient should make decision: 4/57 (7%); no answer: 1/57 (2%)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.6a: Klass (1992) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Klass W, 1992 Country: Sweden Language of publication: Swedish RefMan ID: 3096 Study purpose:To evaluate patients' effects on choosing between medical or surgical treatment | Study design: Case series Blinding of outcome assessment: NR Followup: NR Duration of the study: Total duration of the study: 7 months Duration for one patient: 3 months | Setting: Outpatient Type of cancer: Prostate Type of decision: Treatment Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - information transfer; Context of decision:; - luteinizing hormone-releasing hormone (LHRH) vs. orchiectomy | Description:; - Usual care^a^; - DA brochure^b^; Purpose:; - Increase knowledge; - Make a decision/state a preference; Intervention administered by: NR Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 101 Eligibility criteria: Inclusion:; - advanced prostate cancer; Age: Mean: 73 years; SD: NR; range: NR Education: NR Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Satisfaction with the choice; - Determinants of choice; Outcomes measured:; - 1 week after the intervention; - 1 month after the intervention; - 2 months after intervention

a Consultation

b Written information of prostate cancer, why they needed to be treated, treatment options, treatment effect

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.6b: Klass (1992) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Klass W, 1992 RefMan ID: 3096 | n = 101 Usual care and DA brochure | Decision | | 1 week after intervention:; - Chose luteinizing hormone-releasing hormone (LHRH): 46/101 (45.5%); - Chose orchiectomy: 46/101 (45.5%); - Could not make a decision: 5/101 (4.9%) | 46% of both groups immediately decided; 2% who chose surgical treatment hesitated all the time, and 4% who chose medical treatment
Klass W, 1992 RefMan ID: 3096 | n = 101 Usual care and DA brochure | Determinants of choice
  | Surgical treatment | Medical treatment
  Simpler way to be treated | 31% | 17%
  | 19% | -
  Bother to have injections | - | 15%
  Immediate effect | - | 27%
  Treatment easy to change | - | 15%
  Scared of surgery
Klass W, 1992 RefMan ID: 3096 | n = 101 Usual care and DA brochure | Satisfaction with choice
  Satisfied | 33% | 33%
  Reasonable satisfied | 10% | 8%
  Very satisfied | 46% | 42%
  Extremely satisfied | 11% | 15%
  Not at all satisfied | - | 2%
Klass W, 1992 RefMan ID: 3096 | n = 101 Usual care and DA brochure | Desired involvement in decisionmaking
  Wanted to make the decision by themselves | 36% | 27%
  Wanted to make the decision with the doctor | 50% | 69%
  Wanted that the decision be made by the doctor | 8% | 2%
Klass W, 1992 RefMan ID: 3096 | n = 101 Usual care and DA brochure | Attitudes toward choice^a^ | | | * p = 0.001 ** p > 0.05
  Before and after 1 month | 20.0 - 17.9* | 17.8-17.0**
  Before and after 3 months | 20.0 - 17.2* | 17.8-17.0**

Outcomes measured after the intervention (1 week, 1 month, 2 months).

a Attitude scale: questionnaire that contained 10 questions for the medical patient group and 12 questions for the surgical patient group. Each question had five options. There were no negative values to treatment if the score was 10 or 12; if the score was 50 or 60, there were very negative values toward treatment choice.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.7a: Wolf (1996) Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Wolf A 1996, 1997, 1998 Country: USA RefMan ID: 040, 7441, 971 Study purpose To address the impact of information on patient preference for PSA testing | Study design: Randomized Controlled Trial Method of Randomization: NR Baseline comparability: Characteristics among groups were similar Blinding of outcome assessment: NR Followup: NR Duration of the study: Total duration of the study: 10 months Duration for an individual patient: 1 day | Setting: Outpatient Type of cancer: Prostate Type of decision: Screening/detection Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision:; - Interest in taking PSA test | Description: Control Group (CG):; - reading a brief statement ^a^ Intervention Group (IG):; - listening to an educational DA script ^b^; Purpose:; - To increase knowledge; - To make a decision/ reveal a preference; Intervention administered by: Research assistant Timing of the intervention:; - before the decision was made | Number of patients enrolled: 205 IG: 103 CG: 102 Eligibility criteria: Inclusion:; - English-speaking; - 50 years old or older; - having an outpatient appointment at their primary care physician Exclusion:; - prior PSA screening; - personal history of prostate cancer; Characteristics Age IG: mean 64.5 years CG: mean 65.0 years Education: Non-high-school graduates: IG: 72 (70%) CG: 69 (68%) Ethnicity Caucasian: IG: 64 (66%) CG: 65 (64%) SES: <$15,000 a year: IG: 69 (67%) CG: 64 (63%) | Outcome measures:; - Decision; Outcomes measured:; - after the decision aid was administered (same day)

a Patients were given "a brief statement that a blood test known as the PSA is available that can sometimes detect early prostate cancer before it is otherwise apparent." (p. 1334)

b Patients received "a scripted overview of PSA screening read aloud by a trained research assistant." The intervention script was developed to simulate a brief educational intervention that primary care physicians might employ before screening. The script stated the lifetime probability of developing and dying from prostate cancer, known risk factors for prostate cancer, and the ability of the PSA test to detect early asymptomatic cancer. It included the probability of having a positive test result, the positive predictive value, and the usual evaluation of a positive test result; the uncertain outcome of early intervention; and a brief description of the principal management options for early prostate cancer and their major complications. It was also stated that "many physicians do not recommend screening beyond age 75 years."

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.7b: Wolf (1996) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Wolf A, 1996, 1997, 1998 RefMan ID: 040, 7441, 971 | n = 205 Control Group (CG): n = 102; - Read a brief statement; Intervention Group (IG): n = 103; - Listening to an educational DA script | Decision ^a^ | None reported | Mean: 3.0 vs. 3.8; SD: NR* | *p < 0.001 (Student's t test two-tailed)
Wolf A, 1996, 1997, 1998 RefMan ID: 040, 7441, 971 | n = 205 Control Group (CG): n = 102; - Read a brief statement; Intervention Group (IG): n = 103; - Listening to an educational DA script | Other outcomes ^b^

Outcomes were measured after the decision aid was administered (same day).

a A 5-point Likert scale (from definitely not interested to definitely interested) measured the interest in PSA screening. In 1998, the authors reported the results in a subsample of 104 men > 65 years; the authors reported that the interest in PSA screening was significantly lower among intervention group men: IG: 2.8 vs. CG: 3.6 (p = 0.006).

b The authors evaluated the patient factors associated with interest in PSA screening. Based on the Health Belief Model (perceived seriousness of the underlying disease, perceived susceptibility to the disease, perceived efficacy of screening in terms of improved health outcome, and perceived barriers to screening) in a subsample of 205 men, the authors reported that the intervention group men considered the PSA test to be less efficacious and the control group patients were more willing to accept prostate cancer treatment risks. The authors did not report raw data. To assess confounders of interest in PSA screening, an ordinal logistic regression model was developed. The script was associated with a decreased interest in PSA test (OR: 0.32; 95% CI, 0.19-0.54; p < 0.001) and advancing age (OR: 0.97, 95% CI, 0.94-1.00; p = 0.04). Family history of prostate cancer was significantly associated with decreased interest in PSA testing (OR: 3.95; 95% CI, 1.52-10.29; p = 0.005).

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.8a: Wolf (2000) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Wolf A, 2000 Country: USA Language of publication: English RefMan ID: 5009 Study purpose: To assess the impact of informed consent on elderly patients' colorectal cancer screening preferences | Study design: Randomized Controlled Trial Method of randomization: NR Allocation concealment: NR Baseline comparibility: Characteristics of the groups were similar Blinding of outcome assessment: NR Followup: NR Duration of the study: Total duration of the study: 17 months Duration for one patient: 1 day | Setting: Outpatient Type of cancer: Colorectal Type of decision: Screening Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision: Colorectal screening by fecal occult blood testing (FOBT) and/or sigmoidoscopy versus no screening | Description Control group (CG):; - Listening to a brief statement^a^; Intervention group (IG1):; - Listening to an educational relative risk reduction DA script^b^; Intervention group (IG2):; - Listening to an educational absolute risk reduction DA script^c^; Purpose:; - To increase knowledge; - Help to make a decision; Intervention administered by: Research assistant Timing of the intervention: Before the decision was made | Number of subjects enrolled: 399; CG: 133, IG1: 130; IG2: 136 Eligibility criteria: Inclusion:; - Patients > 65 years; - Attending a routine visit with primary care physician; Exclusion:; - Personal history of colon cancer; Characteristics Gender: Number of female subjects CG: 82 (62%) IG1: 82 (63%); IG2: 88 (65%) Age: CG: Mean: 75 years; SD: 6; range: NR IG1: Mean: 74 years; SD: 6; range: NR IG2: Mean: 74 years; SD: 6; range: NR Education:> 12 years CG: 63 (47%) IG1: 72 (55%) IG2: 75 (55%) Ethnicity: not Caucasian CG: 31 (23%) IG1: 32 (24%); IG2: 38 (28%) SES: Annual income < $15,000 CG: 82 (62%) IG1: 79 (61%); IG2: 77 (57%) | Outcome measures:; - interest in colorectal screening; - intent to have colorectal screening; - knowledge; - perceived efficacy of screening; Outcomes measured: After the intervention (same day)

a Control script: Subjects listened to a research assistant (RA) read a short description of FOBT and flexible sigmoidoscopy.

b Relative-risk reduction information script: RA reads a 3-minute informational script that describes FOBT and flexible sigmoidoscopy and their screening test characteristics. The evidence regarding mortality reduction is presented in a graph as a relative risk reduction.

c Absolute-risk reduction information script: RA reads a 3-minute informational script that describes FOBT and flexible sigmoidoscopy and their screening test characteristics. The evidence regarding mortality reduction is presented in a graph as an absolute risk reduction.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.8b: Wolf (2000) Results

Author | Intervention | Outcome(s) | Baseline Results IG1 vs. IG2 vs. CG | Postintervention Results IG2 vs. IG1 vs. CG | Notes
Wolf A, 2000 RefMan ID: 5009 | n = 399 Control group (CG): n=133; - listening to a brief statement; Intervention group (IG1): n=130; - listening to an educational relative risk reduction DA script; Intervention group (IG2): n=136; - listening to an educational absolute risk reduction DA script | Interest in colorectal screening^a^ | | Probably/definitely interested in FOBT*: IG1: 71 (54%) vs. IG2: 70 (52%) vs.CG: 69 (52%) Probably/definitely interested in flexible sigmoidscopy**: IG1: 47 (36%) vs. IG2: 44 32%) vs. CG: 43 (32%) | No significant differences between the groups. One-way ANOVA (*p=0.9 and **p=0.8)
Wolf A, 2000 RefMan ID: 5009 | | Intent to undergo colorectal screening^b^ | | Intent to begin or continue FOBT*: IG1: 79 (61%) vs. IG2: 75 (55%) vs. CG: 74 (56%) Intent to begin or continue flexible sigmoidscopy**: IG1: 47 (36%) vs. IG2: 45 (33%) vs. CG: 43(32%) Intent to begin or continue FOBT and/or flexible sigmoidscopy***: IG1: 87 (67%) vs. IG2: 86 (63%) vs. CG: 78 (59%) | No significant differences between the groups. Chi-square test (*p=0.6, **p=0.8, and ***p=0.4)
Wolf A, 2000 RefMan ID: 5009 | | Knowledge | | Correctly answered: What is the chance that an abnormal stool card test will actually turn out to be cancer? (options: almost all, about half, or very few) Only pooled intervention group data presented. IG1 and IG2: 189 (71%) vs. CG: 72 (54%) | No significant difference between intervention groups reported (raw data not reported). Significant difference between combined intervention groups and controls (Chi-square test, p=0.0007)
Wolf A, 2000 RefMan ID: 5009 | | Perceived efficacy of screening | | Patients were asked the degree to which screening would reduce the risk of dying from cancer. (options: a great deal, somewhat, or very little) | Significant difference between groups (Mantel-Haenszel test, p for trend = 0.0002)
  | IG1 | | IG2 | | CG
  A great deal | 46 | (35%) | 37 | (27%) | 68 | (52%)
  Somewhat | 57 | (44%) | 61 | (45%) | 43 | (32%)
  Very little | 27 | (21%) | 38 | (28%) | 22 | (16%)

a Interest in colorectal screening: Measured on a 5-point Likert scale

b Intent to be screened: Yes/No response

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.9a: Watson (1998) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Watson M, 1998 Country: UK RefMan ID: 3201 Study purpose; - To determine the impact of receiving an audiotape of the genetic consultation | Study design: Randomized Controlled Trial Method of Randomization: NR Allocation concealment: NR Baseline comparability: NR Blinding of outcome assessment: NR Followup: 80-100% of allocated subjects were followed to the end of the study Duration of the study: Total duration: NR For an individual patient: 6 months | Setting: Outpatient Type of cancer: Breast Type of decision:; - Prevention/ screening; Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision: Choose among: BSE, mammography, tamoxifen, prophylactic surgery vs. none | Description Control Group (CG):; - Genetic counseling^a^ plus physical examination; - Summary letter of consultation; Intervention Group (IG):; - Genetic counseling^a^ plus physical examination; - Summary letter of consultation; - Audiotape of consultation^b^; Purpose:; - Increase knowledge; - Help make a decision; - Uptake of risk management methods; Intervention administered by: NR Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 115. Completed the study: CG: 55 IG: 56 Eligibility criteria: Inclusion:; - 18 years old or older; - Attending the cancer family clinics for the first time; - Family history of breast cancer; - No previous diagnosis of cancer; - No known mental illness.; Characteristics: Age: NR Education: NR Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Recall; - Mental health; - Cancer worry; - Intervention behavior (e.g., utilization of screening procedures); - Acceptability of the DA; Outcomes measured:; - Before intervention (same day); - 4 weeks and 6 months after intervention

a Standard consultation with a clinical geneticist that included a pedigree-based risk calculation and information regarding management options appropriate to the patients' level of cancer risk. All subjects were offered instruction on breast self-examination and clinical examination as part of the standard consultation.

b Audiotape of the consultation

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.9b: Watson (1998) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Watson M, 1998 RefMan ID: 3201 | n = 111 Control Group (CG) n = 55:; - Counseling; - Summary letter of the consultation; Intervention Group (IG) n = 56:; - Counseling; - Summary letter of the consultation; - Audiotape of the consultation | Recall^a^ | | | Overall, no raw data reported.
Watson M, 1998 RefMan ID: 3201 | | Mental health^b^ | - the authors reported 'no difference between groups' (p. 733) * | No difference at 4 weeks** and at 6 months*** | * p = 0.7 The authors report no significant changes within groups among time points: ** p = 0.1;*** p = 0.3
Watson M, 1998 RefMan ID: 3201 | | Cancer worry^c^ | mean: 11.14; SD: 3.23; CI: 10.0-12.0; median: 11.0 vs. mean: 11.39; SD: 3.37; CI: 10.0 - 11.0; median: 11.0. | 4 week followup: mean: 10.45; SD: 3.30; C.I.: 9.0-10.7; median: 10.0** 9 month followup: mean: 10.18; SD: 2.86; CI 9.0-10.0; median: 9.0. ** | *not specified if this was the 95% CI **data reported for the IG only. At 1 month, p = 0.02 and at 6 months, p = 0.003.
Watson M, 1998 RefMan ID: 3201 | | Intervention behavior | | The authors report (p 736): "No differences between cases and controls for rates of BSE, examination of breast by the doctor, or mammography at the 6-month followup." No data presented.
Watson M, 1998 RefMan ID: 3201 | | Acceptability of the DA^d^ | | - median score: 8.35; range 0.2 - 10.; - 8 women said that the tape was helpful because the information provided was complicated; - 5 women expressed that it was useful in clarifying what the doctor had said; - 3 women said the tape reinforced their memory of the visit and the advice given | The data about usefulness of information were provided as pooled data; however, the authors reported that there were significant differences between groups.

Outcomes measured before intervention (same day) and at 4 weeks and 6 months after intervention.

a At 1 month, the authors assessed the recall of risk information. Raw data were not reported; however the authors mentioned, "recall accuracy was not significantly better in those cases who referred to the tape when answering the questionnaire (p = 0.15)." As well, the authors reported that five specific items of genetic information were examined; however, they only described, "more cases than controls were able to remember correctly whether they had been given information on risk before age 50" (64% vs. 42%, respectively, p <0.05).

b General Health Questionnaire - GHQ12: a 12-item questionnaire for detecting psychiatric disorders in nonpsychiatric settings. A score of 3 or more is defined as a "psychological case."

c Cancer worry scale: scores range from 6 to 24, with higher scores meaning more cancer worry.

d Based on a visual analog scale (0 = not useful; 10=very useful) the usefulness was rated. The audiotape was rated on a 10-point visual analog scale as well (0 = not very helpful; 10 = extremely helpful).

Studies of Effectiveness of Decision Aids: RCT Design

Evidence Table 5.10a: Hack (1999) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Hack T, 1999 Country: Canada RefMan ID: 7197 Study purpose: To evaluate the impact of giving patients an audiotape of their primary treatment consultation (pilot study) | Study design: Randomized Controlled Trial Method of Randomization: NR Allocation concealment: NR Baseline comparability: NR Blinding of outcome assessment: NR Followup: NR Duration of the study: Total duration of the study: NR Duration for an individual patient: 6 weeks | Setting: Outpatient Type of cancer: Breast and prostate Type of decision: Treatment (not clear) Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision:; - Not clear | Description Control Group (CG):; - Usual care^a^; Intervention Group 1 (IG1):; - Usual care^a^; - Audiotape of consultation^b^; Intervention Group 2 (IG2):; - Usual care^a^; - Option to have audiotape of consultation^c^; Purpose:; - Increase knowledge; - Clinical trial entry; - Improve satisfaction with consultation; Intervention administered by:; - Research assistant; Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 36 Eligibility criteria: Inclusion:; - Initial diagnosis of breast (N = 18) or prostate (N = 18) cancer (not recurrent disease); - >18 years old; - Fluency in English; - Normal hearing; - No dementia or other mental condition that would make it impossible to understand the study and give fully informed consent; Characteristics: Age: Female: Mean: 52 years SD: NR; range: 34 - 77 Males: mean: 67 years; SD: NR; Range: 51 - 79 Education: >12 years: 28 (78%) Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Involvement in treatment decisionmaking; - Anxiety; - Satisfaction with decisionmaking; - Oncologist's likability and perceived expertise; - Knowledge; - Use of the DA; Outcomes measured:; - Before intervention (same day); - 6 weeks after intervention

a Primary treatment consultation with the oncologist. The authors reported, "During the consultation, the oncologist turned the tape recorder on after taking the patient's history and completing the physical examination and shut the machine off at the end of the discussion about treatment." (p. 8)

b Audiotape of the primary treatment consultation with the oncologist

c The patients in Intervention Group 2 were given the choice of receiving or not receiving the audiotape.

Studies of Effectiveness of Decision Aids: RCT Design

Evidence Table 5.10b: Hack (1999) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Hack T, 1999 RefMan ID: 7197 | n = 36 Control Group (CG):; - Usual care; Intervention Group 1 (IG1):; - Usual care; - Audiotape of consultation; Intervention Group 2 (IG2):; - Usual care; - Option to have audiotape of consultation | Involvement in treatment decisionmaking^a^ | Proportion of participants preferring each role:; - Active: 6/36 (16%); - Collaborative: 14/36 (39%); - Passive: 16/36 (44%) | Proportion of patients assumed each role: Postconsultation:; - Active: 0/36; - Collaborative: 11/36; - Passive: 25/36; 6-week followup:; - Active: 18/36; - Collaborative: 10/36; - Passive: 8/36
Hack T, 1999 RefMan ID: 7197 | n = 36 Control Group (CG):; - Usual care; Intervention Group 1 (IG1):; - Usual care; - Audiotape of consultation; Intervention Group 2 (IG2):; - Usual care; - Option to have audiotape of consultation | Knowledge^b^ | | - Prostate cancer patients received the audiotape by choice and recalled a more thorough consultation than did patients who received the audiotape without choice or the patients who did not receive the audiotape * | * p<0.05 (Kruskal-Wallis test). No raw data reported.
Hack T, 1999 RefMan ID: 7197 | n = 36 Control Group (CG):; - Usual care; Intervention Group 1 (IG1):; - Usual care; - Audiotape of consultation; Intervention Group 2 (IG2):; - Usual care; - Option to have audiotape of consultation | Use of the audiotape | | - Patients in IG2 (choice) were more likely to listen to a portion of the tape than were the patients in IG1, 83% vs. 55%.**; - Patients in the IG2 listened to the entire tape on average 2.5 times more often than did patients in IG1 (average 1 time).** | ** The authors reported, "these two findings approached statistical significance," however the p value was not reported.
Hack T, 1999 RefMan ID: 7197 | n = 36 Control Group (CG):; - Usual care; Intervention Group 1 (IG1):; - Usual care; - Audiotape of consultation; Intervention Group 2 (IG2):; - Usual care; - Option to have audiotape of consultation | Other results^c^

a Control Preference Scale (CPS): five statements ranging from: "I prefer to make the final decision" to "I prefer my doctor to make the final decision" were collapsed by the authors into three categories: active, collaborative, passive. At baseline, preferred roles were measured; postintervention, assumed roles were measured.

b The authors developed the Information Recall Questionnaire: 5-point scales (1 = we definitively did not discuss, 5 = we definitively did discuss) were used to discern the extent to which patients believed that their oncologist had discussed: treatment alternatives, treatment side effects, likelihood of cure, extent of disease, and type of illness information available.

c Data for anxiety and satisfaction scores were not provided by intervention group, but by type of cancer. The Physicians' Perceived Likeability and Technical Expertise Scale scores were not reported.

Studies of Effectiveness of Decision Aids: RCT Design

Evidence Table 5.11a: North (1992) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
North N, 1992 Country: UK RefMan ID: 3014 Study purpose: To determine if tape-recording the consultation increased retention of information; affects anxiety or depression | Study design: Randomized Controlled Trial Method of Randomization: NR Allocation concealment: NR Baseline comparability: NR Blinding of outcome assessment: NR Followup: 80-100% of allocated subjects were followed to the end of the study Duration of the study: Total duration of the study: NR Duration for an individual patient: 1 week | Setting: Outpatient Type of cancer: Not specified Type of decision: Treatment (not clear) Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision: NR | Description: Control Group (CG):; - Usual care plus checklist^a^; Intervention Group (IG):; - Usual care plus checklist; - Audiotape of consultation^b^; Purpose:; - Increase knowledge; Intervention administered by:; - Oncologist; Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 34 IG: 18; CG: 16 Eligibility criteria:; - Consecutive patients; - New referral to medical oncologists; Characteristics: Age: IG: mean: 54.1 years CG: mean 56.4 years Gender: IG: 9 male, 9 females; CG: 7 male, 9 females Education: NR Ethnicity: NR SES: NR Religion: NR | Primary outcome measures:; - Decision aid helps patients make a choice; - Knowledge; - Anxiety; - Acceptability of DA; Outcomes measured:; - before intervention (same day); - 1 week after intervention

a "The consultant oncologists used a standard checklist of information to ensure that all patients received the same topics and facts. An independent validation was obtained from a medical student using a similar checklist to ensure that the same information was given to each patient." (p. 357, 358)

b The consultation was tape-recorded.

Studies of Effectiveness of Decision Aids: RCT Design

Evidence Table 5.11b: North (1992) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
North N, 1992 RefMan ID: 3014 | n = 34 Control Group (CG) n = 16:; - Usual care plus checklist; Intervention Group (IG) n = 18:; - Usual care plus checklist; - Audiotape of consultation | Decision aid helps patients make a choice | | IG: 11/18 (61%)
North N, 1992 RefMan ID: 3014 | n = 34 Control Group (CG) n = 16:; - Usual care plus checklist; Intervention Group (IG) n = 18:; - Usual care plus checklist; - Audiotape of consultation | Knowledge^a^ | mean 3.28, SD 1.56 vs. 3.31, SD 1.62 | mean 9.33, SD 1.64 vs. 4.44, SD 2.13* | * two-way repeated measures ANOVA p<0.0001
North N, 1992 RefMan ID: 3014 | n = 34 Control Group (CG) n = 16:; - Usual care plus checklist; Intervention Group (IG) n = 18:; - Usual care plus checklist; - Audiotape of consultation | Anxiety^b^ | mean 7.06, SD 3.66 vs. 6.87, SD 3.12 | mean 3.11, SD 2.65 vs. 6.12, SD 2.87** | ** two-way repeated measures ANOVA p<0.001
North N, 1992 RefMan ID: 3014 | n = 34 Control Group (CG) n = 16:; - Usual care plus checklist; Intervention Group (IG) n = 18:; - Usual care plus checklist; - Audiotape of consultation | Acceptability of DA | | - 1/18 was mildly upset about the tape; - 17/18 expressed very positive feelings about the tape; - 11/18 said that the tape helped them remember information; - "several patients used the tape to explain their illness to their families"; - "at least three patients played the tape to, and discussed them with their general practitioners"

Outcomes measured before intervention (same day) and 1 week after intervention.

a Number of items recalled - 11 items: higher scores mean a higher number of items were recalled. These questions covered: the diagnosis, parts of the body involved, severity of the illness, choice of treatment, what treatment involved in terms of its aims, length, side effects, and success rate.

b Hospital Anxiety and Depression (HAD) scale. Higher scores indicate higher anxiety.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.12a: Goel (2001) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Goel V, 2001 Country: Canada Language of publication: English RefMan ID: 7855 Study purpose: To evaluate a decision aid for the choice of surgical management of early breast cancer | Study design: Randomized Controlled Trial Method of randomization:; - Cluster randomization (surgeons were the unit of randomization); Allocation concealment:; - Yes; Baseline comparability:; - Characteristics of the groups were similar; Blinding of outcome assessment: NR Followup: 6 months Duration of the study:; - Total duration of the study: 17 months; - Duration for one patient: 6 months | Setting: Out-patient Type of cancer: Breast Type of decision: Treatment Model of decisionmaking:; - Shared by authors; - Not clear as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Mastectomy versus lumpectomy plus radiotherapy | Description Intervention group (IG1):; - Usual care^a^; - DA brochure^b^; Intervention group (IG2):; - Usual care^a^; - Audiotape workbook with values clarification exercise^c^; Purpose:; - To provide information and to clarify personal values to facilitate shared decisionmaking; - To increase knowledge; - To improve satisfaction with decisionmaking; Intervention administered by:; - Not clear; Timing of the intervention:; - Not clear | Number of subjects enrolled: 136 IG1: 50; IG2: 86 Eligibility criteria: Inclusion:; - newly diagnosed stage I or II breast cancer; - suitability for either mastectomy or lumpectomy; Characteristics: Age: IG1: Mean: 57.4 years; SD: 12.8; range: NR IG2: Mean: 57.6 years; SD: 12.0; range: NR Education: IG1: more than high school: 23 (47%) IG2: more than high school: 40 (47%) Ethnicity: NR SES: NR | Outcome measures: - decisional conflict - decision - anxiety - knowledge - preference for shared decisionmaking - decisional regret Outcomes measured: - before intervention - 2 to 3 days after intervention (before surgery) - 6 months after intervention

a Surgical oncology consultation

b DA brochure: a trifold pamphlet that contained identical information as the audiotape workbook; but without the numbers, photographs, graphics, or values-clarification exercise

c Audiotape workbook: A 26-minute audiotape plus a workbook containing color photographs and graphics using 100 figures to present quantitative information. The intervention contains a three-step values clarification exercise: (1) review advantages and disadvantages of each treatment option, (2) patient considers value of each advantage and disadvantage, and (3) patient examines her workbook to determine which option she favors.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.12b: Goel (2001) General Characteristics

Author | Intervention | Outcome(s) | Baseline Results IG1 vs. IG2 | Postintervention Results IG1 vs. IG2 | Notes
Goel V 2001 RefMan ID: 7855 | Intervention Group 1 (IG1): n=50; - Usual care; - DA brochure; Intervention Group 2 (IG2): n=86; - usual care; - audiotape workbook with values clarification exercise | Initial treatment preference
  | IG1 | | IG2
  lumpectomy | 25/44 | (57%) | 40/77 | (52%)
  unsure | 7/44 | (16%) | 13/77 | (17%)
  mastectomy | 12/44 | (27%) | 24/77 | (31%)
Goel V 2001 RefMan ID: 7855 | Intervention Group 1 (IG1): n=50; - Usual care; - DA brochure; Intervention Group 2 (IG2): n=86; - usual care; - audiotape workbook with values clarification exercise | Preference for decisionmaking involvement | Prefer shared decisionmaking: IG1: 43/50 (87.8%) IG2: 72/86 (84.7%) | | No significant difference between groups. Chi-square (p=0.608)
Goel V 2001 RefMan ID: 7855 | Intervention Group 1 (IG1): n=50; - Usual care; - DA brochure; Intervention Group 2 (IG2): n=86; - usual care; - audiotape workbook with values clarification exercise | Anxiety^a^ | IG1 mean: 50.8; SD: 13.6 vs. IG2 mean: 51.9; SD: 13.8 | Raw data not presented. Stated no difference in anxiety between the groups pre-operatively (both group means > 50 points; high anxiety) and no difference at 6-month followup; both groups mean scores decreased to about 35 points (within normal range) | Pre-intervention: no significant difference between groups; t-test (p=0.684)
Goel V 2001 RefMan ID: 7855 | Intervention Group 1 (IG1): n=50; - Usual care; - DA brochure; Intervention Group 2 (IG2): n=86; - usual care; - audiotape workbook with values clarification exercise | Knowledge^b^ | | IG1 mean: 14.4; SD: 2.2 vs. IG2 mean: 14.7; SD: 2.0 | No significant difference between groups; t-test (p=0.433)
Goel V 2001 RefMan ID: 7855 | Intervention Group 1 (IG1): n=50; - Usual care; - DA brochure; Intervention Group 2 (IG2): n=86; - usual care; - audiotape workbook with values clarification exercise | Decision conflict^c^ | | IG1 mean: 2.08; SD: 0.46 vs. IG2 mean: 1.98; SD: 0.52 | No significant difference between groups; t-test (p=0.218)
Goel V 2001 RefMan ID: 7855 | Intervention Group 1 (IG1): n=50; - Usual care; - DA brochure; Intervention Group 2 (IG2): n=86; - usual care; - audiotape workbook with values clarification exercise | Would make same choice again | | | No significant difference between groups (chi-square, p=0.505*; p=0.931**, and p=0.320***)
  At 6-month followup: | IG1 | | IG2
  - Would choose again; - Was the right decision; - Decision a wise one | 40/44 | (91%) | 54/63 | (86%)*
  - Would choose again; - Was the right decision; - Decision a wise one | 42/44 | (95%) | 58/63 | (92%)**
  - Would choose again; - Was the right decision; - Decision a wise one | 41/44 | (93%) | 54/63 | (86%)***
Goel V 2001 RefMan ID: 7855 | Intervention Group 1 (IG1): n=50; - Usual care; - DA brochure; Intervention Group 2 (IG2): n=86; - usual care; - audiotape workbook with values clarification exercise | Decisional regret | | | No significant difference between groups (chi-square p=0.760*, p=0.449**)
  At 6-month followup: | IG1 | | IG2
  - Regret choice; - Decision did me a lot of harm | 5/44 | (11%) | 8/63 | (13%)*
  - Regret choice; - Decision did me a lot of harm | 3/44 | (7%) | 7/63 | (11%)**

a State of anxiety was measured using the state component of the State-Trait Anxiety Inventory.

b Knowledge was measured using the Breast Cancer Information Test-Revised (BCIT-R), which consists of 18 true/false questions.

c Decision conflict was measured using the O'Connor's Decisional Conflict Scale (DCS), where 1= low decisional conflict and 5= high decisional conflict. The DCS consists of 16 questions (results above are reported for overall scale; for subscale results, refer to the paper. No significant differences were found between groups on the subscale analyses).

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.13a: Fiset (2000) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Fiset V, 2000 Country: Canada Language of publication: English RefMan ID: 7873 Study purpose: To evaluate a take-home, self-administered decision aid that incorporates patient values | Study design: Pre-post test Blinding of outcome assessment: NR Followup: All patients included completed the study Duration of the study:; - Total duration of the study: 12 months; - Duration for one patient: Not clear | Setting: Outpatient Type of cancer: Lung Type of decision: Treatment Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Supportive care/radiation therapy versus supportive care/radiation therapy plus chemotherapy | Description; - Usual care^a^; - Audiotape booklet with worksheet^b^; Purpose:; - Increase knowledge; - Make a decision/state a preference; Intervention administered by:; - Patient; Timing of the intervention:; - Before the decision was made | Number of subjects enrolled: 20 Eligibility criteria: Inclusion:; - Newly diagnosed with stage IV non-small cell lung cancer; Exclusion:; - Brain metastases causing significant cognitive impairment; - Unsuitable due to physical or mental impairment or emotional distress; Characteristics: Gender: male 12; female 8 Age: Mean: 63 years; SD: 11; range: 38 to 83 years Education: < 12 years: 5 (25%) Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Knowledge; - Decisional conflict; - Preferred role in decisionmaking; - Acceptability of intervention; Outcomes measured:; - before the DA intervention, but after oncology consultation; - after the DA intervention (specific timing not reported)

a Initial consultation with medical oncologist who discussed available treatment options

b After the oncology consultation, patients were given the DA intervention to review at home. This intervention consisted of an audiotape and accompanying booklet plus a worksheet. The audiotape is 35 minutes in length and explains lung cancer and its stages; the functional impact of this disease; and the available treatment options of supportive care, radiation therapy, and chemotherapy. It details the risks and benefits of chemotherapy as well as the side-effects.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.13b: Fiset (2000) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Fiset, V. 2000 RefMan ID: 7873 | n = 20 Usual care Audiotape, booklet and worksheet | Decision^a^ | Initial preference for chemotherapy: | Chemotherapy preference after intervention: | No statistical analysis reported.
  Yes | 13/20 | (65%)
  Unsure | 6/20 | (30%)
  No | 1/20 | (5%)
  Yes | 14/20 | (70%)
  Unsure | 2/20 | (10%)
  No | 4/20 | (20%)
Fiset, V. 2000 RefMan ID: 7873 | n = 20 Usual care Audiotape, booklet and worksheet | Decisional conflict^b^ | Mean: 2.34; SD: 0.65 | Mean: 1.76; SD: 0.47 | Pre-post comparison: significant decrease post-DA (paired t-test, p<0.001)
Fiset, V. 2000 RefMan ID: 7873 | n = 20 Usual care Audiotape, booklet and worksheet | Knowledge^c^ | Percentage correct Mean: 72%; SD: 9% | Percentage correct Mean: 90%; SD: 9% | 95% CI: 12 to 23 Percentage difference: 18; (paired t-test, p<0.001)
Fiset, V. 2000 RefMan ID: 7873 | n = 20 Usual care Audiotape, booklet and worksheet | Perceived survival benefit of chemotherapy^d^ | Number subjects who answered "realistically": 7/20 (35%) | Number subjects who answered "realistically": 17/20 (85%) | Significantly more subjects gave "realistic" answers post-DA (McNemar's test for change, p=0.013)
Fiset, V. 2000 RefMan ID: 7873 | n = 20 Usual care Audiotape, booklet and worksheet | Preferred role in decisionmaking | | - Share decision with physician: 11/20 (55%); - Patient decides; considers doctor's opinion: 6/20(30%); - Unsure about what role they want: 3/20 (15%)
Fiset, V. 2000 RefMan ID: 7873 | n = 20 Usual care Audiotape, booklet and worksheet | Acceptability of DA intervention^e^ | | - Found DA helpful: 20/20 (100%); - Would recommend to others: 20/20 (100%); - Satisfied with amount of information: 16/20 (80%); - Satisfied with clarity of information: 16/20 (80%); - Found information balanced: 15/20 (75%); - Did not find information upsetting: 16/20 (80%); - Found survival information upsetting: 4/20 (20%)

a Decision: scored on 11-point scale ("supportive care/radiation therapy" at one end and "supportive care/radiation therapy plus chemotherapy" at the other; "unsure" in the center).

b Decisional conflict: used two subscales from O'Connor's Decisional Conflict Scale (decision uncertainty and modifiable factors); higher score greater=decisional conflict (range 1 to 5).

c Knowledge was measured by 16 true/false/unsure items based on information from the decision aid intervention.

d Perceived survival benefit was scored as 'realistic' if the subject responded that 10 of 100 more people would be alive at 1 year.

e "Acceptability was assessed using several of the standardized questions used in evaluations of shared decision-making programmes"; see reference #7 cited in the study for details.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.14a: Volk (1999) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Volk RJ 1999, 1998 Country: USA RefMan ID: 202, 130 Study purpose: To evaluate a patient educational approach to shared decision-making for prostate cancer screening | Study design: Randomized Controlled Trial Method of Randomization: Randomization by permuted blocks Allocation concealment: Adequate Baseline comparability: Characteristics among groups were similar Blinding of outcome assessment: Not used Followup: 80-100% of the subjects were followed at the end of the study. Duration of the study: Total duration of the study: 17 months Duration for an individual patient: 1 year | Setting: Outpatient Type of cancer: Prostate Type of decision: Screening Model of decision making:; - Shared as stated by authors;; - Informed as determined by the reviewers; Phase of decision:; - Information transfer; Context of decision: Prostate Specific Antigen (PSA) screening vs. none | Description Control Group(CG):; - Usual care^a^; Intervention Group (IG1):; - Usual care; - DA videotape + DA brochure^b^; Intervention Group (IG2):; - Usual care; - DA videotape + DA brochure^b^; - Utility assessment^c^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Not clear (NC) Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 160 CG: 80; IG1: 40; IG2: 40 Eligibility criteria:; - No history of prostate cancer; - Presenting for care at the Family Medicine Center; Characteristics: Age^d^: IG: mean: 58.5 years; SD: NR; range: 45 years to 70 years CG: mean: 59.5 years SD: NR; range: 45 years to 70 years Education (IG1 & 2 vs. CG)^d^: <12 years: 14 (18%) vs. 21 (17%) >12 years: 64 (52%) vs. 59 (74%) Ethnicity (IG1 & 2 vs. CG)^d^: Caucasian: 48 vs. 49 African American: 18 vs. 12 Hispanic: 10 vs. 15 SES (IG1 & 2 vs. CG)^d^: < $9,999 a year: 14 (18%) vs. 17 (21%) | Outcome measures:; - Decision/preference; - Knowledge; - Acceptability of the intervention; Outcomes measured:; - Before intervention (same day); - 2 weeks after intervention; - 1-year followup

a Office visit

b A 20-minute educational videotape with brochure on the risks and benefits of PSA testing for prostate cancer in men aged 50 years and over who are in good overall health. In the videotape, two physicians assume the role of patients; one favoring the regular PSA testing and the other opposing it. Epidemiology of prostate cancer, accuracy of the PSA test, and complications associated with treatment of prostate cancer are discussed. In addition, a man with prostate cancer describes his experience with expectant management (watchful waiting). The video was meant to be viewed before an office visit or at the patient's home. The brochure included many of the tables presented in the videotape, with a summary of the advantages and disadvantages of screening. (p. 334)

c No details were reported.

d Results for the two IGS were collapsed.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.14b: Volk (1999) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG^a^ | Notes
Volk RJ, 1999, 1998 RefMan ID: 202, 130 | Control Group (CG) n = 80; - Usual care; Intervention Group (IG) n = 80; - Usual care; - DA videotape + DA brochure | - Preference^b^ (outcome measured at baseline and at 2 weeks); - Decision (outcome measured at 1 year) | 62/78 (79%) vs. 62/80 (78%) | At 2 weeks:; - 48/78 (62%) vs. 64/80 (80%) *; At 1 year followup:; - received PSA: 38% vs. 56%; - intended to receive PSA in future: 45% vs. 71% | * Absolute difference between groups was 18.5%, p = 0.009. The authors report that the percentage of subjects wanting PSA test in the IG decreased by 17% (p = 0.01); no significant change was observed in the CG (p = 0.82) (McNemar change test).
Volk RJ, 1999, 1998 RefMan ID: 202, 130 | Control Group (CG) n = 80; - Usual care; Intervention Group (IG) n = 80; - Usual care; - DA videotape + DA brochure | Knowledge^c^ | mean: 2.7 vs. 2.8* | At 2 weeks: mean: 4.8 vs. 3.1**; - 48/78 (62%) of the IG subjects answered at least 5/10 questions correctly; and 25/80 (31%) of the CG subjects *** | **Standard deviations (SD): NR within group change: IG: p = 0.001; CG: p = 0.19 (Wilcoxon signed rank test) *** p = 0.001
Volk RJ, 1999, 1998 RefMan ID: 202, 130 | Control Group (CG) n = 80; - Usual care; Intervention Group (IG) n = 80; - Usual care; - DA videotape + DA brochure | Acceptability of the intervention | | IG participants rated the videotape:; - information amount "about right": 79%; - length of the tape: " about right": 86%; - clarity: "everything clear": 50%; - presentation: "completely balanced": 79%; - influenced your decision: "a great deal": 35%; - would recommend to others: "yes": 92%

a IG1 and IG2 were not significantly different on any indicators; therefore the authors collapsed them in the analysis.

b Measure was given by the responses to the question: "Given what you know about prostate cancer and Prostate Specific Antigen (PSA) testing, would you choose to have PSA test?" Response options were "yes," "no," and "I am not sure."

c Prostate cancer knowledge measurement tool developed for this study. Ten items: higher scores indicate a higher number of correct answers. Domains included epidemiology, screening accuracy, treatment effectiveness, and treatment-related complications.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.15a: Pignone (2000) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Pignone M, 2000 Country: USA Language of publication: English RefMan ID: 7442 Study purpose: To evaluate whether a decision aid consisting of an educational video, targeted brochure, and chart marker increased colon cancer screening | Study design: Randomized Controlled Trial Method of randomization:; - Computerized random-number generator; - Assignments placed in sealed, numbered envelopes; Allocation concealment: Yes Baseline comparibility: Control group subjects were more likely to have graduated from high school, otherwise were similar Blinding of outcome assessment:; - Yes, partially; Followup:; - At 3 and 6 months; Duration of the study:; - Total duration of the study: 13 months; - Duration for one patient: 6 months | Setting: Outpatient Type of cancer: Colorectal Type of decision: Screening Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Colorectal screening by fecal occult blood testing (FOBT) and/or sigmoidoscopy versus no screening | Description Control group (CG):; - Usual care^a^; - Unrelated videotape and brochure about car safety^b^; Intervention group (IG):; - Usual care^a^; - DA videotape^c^; - Targeted DA brochure^c^; - Chart marker^c^; Purpose:; - To increase knowledge; - Help to make a decision; Intervention administered by: Research assistant Timing of the intervention:; - Before the decision was made | Number of subjects enrolled: 249; CG: 124, IG: 125 Eligibility criteria: Inclusion:; - Patients 50 to 75 years; - Attending a visit with a primary care physician; Exclusion:; - personal or family history of colon cancer; - FOBT in the last year; - flexible sigmoidscopy, colonoscopy, or barium enema in past 5 years; Characteristics Gender: number of female subjects IG: 74 (59%) CG: 76 (61%) Age: IG:Mean: 63.1 yrs; SD: NR; range NR CG:Mean: 62.7 yrs; SD: NR; range: NR Education:> 12 years IG: 91 (73%); CG: 104 (84%) Ethnicity:Caucasian IG: 105 (84%); CG: 112 (90%) SES: NR | Outcome measures:; - Decision; - Intent to ask for colorectal screening; - Screening test preference; - Conversation about colon cancer screening with primary physician; Outcomes measured:; - After the intervention (same day); - Followup chart review 3 and 6 months post-intervention

a Usual care: scheduled visit with primary care physician for a new or ongoing health problem

b Control group: viewed a videotape (approximately 11 minutes in length) about car safety, seat belt use, and airbags and a pamphlet about car safety

c Intervention group: viewed an 11-minute DA videotape that provided information regarding susceptibility to colon cancer and availability of effective screening tests. Detailed how FOBT and flexible sigmoidoscopy are performed. The videotape also highlighted the meaning of both negative or positive results. It also contained four vignettes of patients' experiences with colon cancer screening. At the end of the videotape, subjects were asked to select the color-coded brochure (based on Prochaska stages-of-change-mode) reflecting interest in screening. Green brochure: ready to be screened; yellow brochure: some interest in screening but need additional information or discussion; red brochure: no interest in screening. Each type of brochure reinforced the messages of the DA videotape in a stage-appropriate manner. Chart marker corresponding to selected brochure was attached to subject's medical chart before the subject saw the primary care physician.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.15b: Pignone (2000) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Pignone, M. 2000 RefMan ID: 7442 | Control group (CG): n=124 -usual care^a^ - viewed an unrelated videotape and brochure about car safety^b^ Intervention group (IG): n=125 - usual care^a^ - DA videotape^c^ - targeted DA brochure^c^ - chart marker^c^ | Decision | | Patient reported ordering of screening test: | 95% CI (no p values reported) * 2.8 to 25.3 ** 0.0 to 17.1 *** 8.6 to 32.9
  | IG | CG | Difference^a^
  home FOBT | 42 (33.9%) | 21 (19.8%) | 14.1*
  Flexible sig. | 21 (17.1%) | 10 (8.5%) | 8.5**
  Either | 58 (47.2%) | 28 (26.4%) | 20.7***
Pignone, M. 2000 RefMan ID: 7442 | | Intent to ask for colorectal screening^b^ | Mean IG: 2.2; SD: NR vs. Mean CG: 2.2; SD: NR | Mean IG: 3.1; SD: 1.0 vs. Mean CG: 2.5; SD: 1.1* | Postintervention: IG intent significantly higher than CG intent (p<0.001*; Wilcoxon rank-sum test)
Pignone, M. 2000 RefMan ID: 7442 | | Test preference | | | Authors stated that test preferences differed between the two groups (no statistical analysis reported)
  Preference for: home FOBT | IG (n=122) | CG (n=105)
  Preference for: home FOBT | 81 (66%) | 63 (60%)
  Flexible sigmoidoscopy | 21 (17%) | 7 (7%)
  Both tests | 15 (12%) | 26 (25%)
  No screening test | 6 (5%) | 9 (9%)
Pignone, M. 2000 RefMan ID: 7442 | | Conversation with physician regarding screening | | IG: (68.5%) vs. CG: (43.4%) Difference: 25.1 percentage points | Significantly more IG subjects had screening conversations (95% CI: 12.7 to 37.6, no p value reported)
Pignone, M. 2000 RefMan ID: 7442 | | Screening test ordered within 3 months of intervention | | Followup chart-review: screening test ordered within 3 months postintervention | 95% CI (no p values reported) * 1.7 to 23.6 ** 3.0 to 19.3 *** 6.0 to 28.8
  | IG | CG | Difference^a^
  home FOBT | 42 (33.6%) | 26 (20.9%) | 12.6*
  Flexible sig. | 23 (18.4%) | 9 (7.3%) | 11.1**
  Either | 51 (40.8%) | 29 (23.4%) | 17.4***
Pignone, M. 2000 RefMan ID: 7442 | | Screening test completed within 6 months of intervention | | Followup chart-review: screening test completed within 6 months postintervention | 95% CI (no p values reported) * - 2.4 to 18.9 ** 5.1 to 20.4 *** 3.0 to 25.4
  | IG | CG | Difference^a^
  FOBT | 36 (28.5%) | 25 (20.2%) | 8.3*
  Flexible sig. | 22 (17.6%) | 6 (4.8%) | 12.8**
  Either | 46 (36.8%) | 28(22.6%) | 14.2***

a Percentage points difference

b Intent to ask primary care physician for colorectal screening: Measured on a 4-point Likert scale (1= not at all likely; 4= very likely)

c Additional analyses reported regarding screening test completion by level of intent to be screened; testing the validity of the stages-of-change model; and the magnitude of the effect of the DA intervention, by practice and by physician. Refer to paper for details.

Studies of Effectiveness of Decision Aids: Nonrandomized controlled trial design

Evidence Table 5.16a: Flood (1996) General Characteristics

Author/ Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Flood A, 1996, Anonymous, 1996 Country: USA RefMan ID: 120, 7149 Study purpose: To inquire how information about Prostate Specific Antigen (PSA) testing and the uncertain benefits of treating prostate cancer affect patients' desire for PSA testing | Study design: Controlled trial (quasi-experiment) Blinding of outcome assessment: NR Baseline comparability: Characteristics among groups were similar Followup: 80-100% of the subjects were followed at the end of the study Duration of the study: Total duration of the study: 1 week Duration for an individual patient: 1 week | Setting: Outpatient Type of cancer: Prostate Type of decision: Screening Model of decisionmaking:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision: Information transfer Context of decision: PSA test vs. none | Description: Control Group (CG); - Information videotape^a^; Intervention Group (IG); - DA videotape^b^; - Pamphlet^c^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Not specified Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 409 IG: 206; CG 203 Eligibility criteria: NR Characteristics: Age (IG vs. CG): Mean: 64.3 years vs.63.6 years Education (IG vs. CG): Some college: 99 (48%) vs. 107 (53%) Ethnicity: NR SES: NR | Outcome measures: - decision - knowledge Outcomes measured: 1 week after the intervention

a The videotape for the control group was a video produced in conjunction with the Prostate Cancer Educational Council and the Schering Corporation. The use of PSA testing was advocated in this video, but there was no mention of the scientific controversies concerning the value of active treatment for localized prostate cancer. Details were not provided about complications of prostate cancer treatment (p. 349).

b The videotape called Prostate-PORT (Patient Outcomes Research Team) was developed to encourage patients to participate in the decision to screen for prostate cancer. The initial part of the video emphasized the importance of shared decisionmaking; then the pros, cons, and reasons for different screening decisions were presented.

c No description reported.

Studies of Effectiveness of Decision Aids: Nonrandomized controlled trial design

Evidence Table 5.16b: Flood (1996) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Flood A, 1996; Anonymous, 1996 RefMan ID: 120, 7149 | n = 410 Control Group (CG): n = 203 information videotape Intervention Group (IG): n = 206 DA videotape | Decision | | - had PSA test after intervention: 181/184 (98%) vs. 188/188 (100%)*; - high chance of repeating PSA test within 2 years: 136/184 (73.9%) vs. 169/188 (89.8%) **; - would choose prostatectomy if cancer found: 47/184 (25%) vs. 96/188 (51%)***; - would choose radiation if cancer found: 21/184 (11%) vs. 42/188 (22%); - would choose watchful waiting if cancer found: 116/184 (63%) vs. 50/188 (26%)*** | * p = 0.079 ** p = 0.002 *** p = 0.0000
Flood A, 1996; Anonymous, 1996 RefMan ID: 120, 7149 | n = 410 Control Group (CG): n = 203 information videotape Intervention Group (IG): n = 206 DA videotape | Knowledge^a^ | | Proportion of subjects who answered correctly:; - Q1: 132/184 (71.7%) vs. 95/188 (50.3%)*; - Q2: 112/184 (61%) vs. 21/188 (11.4%)**; - Q3: 118/184 (64.2%) vs. 57/188 (30.5%)*** | Between-group comparisons (X ^2^ test): * p = 0.0002 ** p = 0.000 *** p = 0.0000

Outcomes were measured at 1 week after the outcome.

a A three-item questionnaire asking the following questions: 1) "Natural history of prostate cancer: How many untreated men with early stage prostate cancer would die of this disease?"; 2) "Prostate cancer treatment efficacy: Does active treatment extend life?"; and 3) "Test predictive value: How many men with elevated PSA have prostate cancer?" (p. 345)

Studies of Effectiveness of Decision Aids: Nonrandomized controlled trial design

Evidence Table 5.17a: Flood (1996) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Flood A, 1996, Anonymous, 1996 Country: USA RefMan ID: 7534, 7146 Study purpose: To examine how information about Prostate Specific Antigen (PSA) testing and the uncertain benefits of treating prostate cancer affect patients' desire for PSA testing | Study design: Controlled trial Baseline comparability: Characteristics of groups were similar Blinding of outcome assessment: Used Followup:; - 80-100% of the subjects were followed at the end of the study; Duration of the study: Not clear (NC) | Setting: Outpatient Type of cancer: Prostate Type of decision: Screening Model of decisionmaking:; - Sharedas stated by authors; - Informed as determined by reviewers; Phase of decision: Information transfer Context of decision: PSA test vs. none | Description: Control Group (CG); - Usual care^a^; Intervention Group (IG); - Usual care; - DA videotape^b^; - Pamphlet^c^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: Not specified Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 222; IG: 120; CG: 102 Eligibility criteria: Inclusion:; - > 50 years old; - scheduled for a routine physical examination; Exclusion:; - previous diagnosis of prostate cancer; - recent PSA test; Characteristics: Age (IG vs. CG): Mean: 66.5 years vs. 64.4 years; SD: NR; range: NR Education (IG vs. CG): Some college: 81 (68%) vs. 60 (61%) Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Knowledge; Outcomes measured:; - after the intervention (not clear)

a Patients scheduled for a routine physical examination or nonurgent followup visit at a General Internal Medicine Department.

b The videotape for the intervention group was meant to encourage patients to participate in the decision of having the screening test for prostate cancer. The initial part of the video emphasized the importance of shared decisionmaking; then the reasons for different screening decisions were presented.

c Along with the videotape there was an associated brochure; no further details were reported.

Studies of Effectiveness of Decision Aids: Nonrandomized controlled trial design

Evidence Table 5.17b: Flood (1996) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Flood A, 1996 Anonymous, 1996 Refman ID: 7534, 7146 | n = 222 Control Group (CG): n = 120; - Usual care; Intervention Group (IG): n = 102; - Usual care; - DA Videotape; - Pamphlet | Decision | | - Had PSA test at next visit: 12/103 (11.7%) vs. 21/93 (22.6%) *; - High chance of PSA test within 2 years: 31/103 (30.4%) vs. 62/93 (67%) **; - Would choose prostatectomy if cancer found: 8/103 (8.1%)) vs. 38/93 (40.7%)***; - Would choose radiation if cancer found: 6/103 (6.1%) vs. 18/93 (19.8%)***; - Would choose watchful waiting if cancer found: 89/103 (85.9%) vs. 37/93 (39.5%)*** | * p = 0.041 ** p = 0.0000 *** p = 0.0000
Flood A, 1996 Anonymous, 1996 Refman ID: 7534, 7146 | n = 222 Control Group (CG): n = 120; - Usual care; Intervention Group (IG): n = 102; - Usual care; - DA Videotape; - Pamphlet | Knowledge^a^ | | Proportion of subjects who answered correctly: Q1: 96/103 (92.9%) vs. 38/93 (40.9%) *** Q2: 72/103 (699%) vs. 22/93 (23.7%) *** Q3: 74/103 (71.8%) vs. 13/93 (14.5%) *** | Between group comparisons (X ^2^ test): *** p = 0.0000

Outcomes were measured after the subjects had seen the video but before the visit.

a A three-item questionnaire asking the following questions: 1) "Natural history of prostate cancer: How many untreated men with early stage prostate cancer would die of this disease?"; 2) "Prostate cancer treatment efficacy: Does active treatment extend life?"; and 3) "Test predictive value: How many men with elevated PSA have prostate cancer?" (p. 345)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.18a: Onel (1998) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Onel A, 1998 Country: USA RefMan ID: 1080 Study purpose: To explore the feasibility of using standardized video presentation to transfer information | Study design: Case series Blinding of outcome assessment: Not used Followup:; - 80-100% of the subjects were followed at the end of the study; Duration of the study: Total duration of the study: 15 months Duration for an individual patient: NR | Setting: Outpatient Type of cancer: Prostate Type of decision: Treatment, primary Model of decisionmaking:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision: Information transfer Context of decision:; - Choice among surgery, radiation therapy, hormonal therapy, or watchful waiting | Description: Usual care^a^ and DA videotape^b^ Purpose:; - To increase knowledge; Intervention administered by: Research assistant Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 111; 95 completed the study Eligibility criteria: Inclusion:; - newly diagnosed prostate cancer patients; Exclusion:; - having an incomplete medical record; - failure to complete the initial survey instrument; Characteristics: Age: Mean: 67 years; SD: NR; Range: 48 years to 83 years Education:> 12 years: NR Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Knowledge; - Satisfaction with choice; - Decision; - Would choose same treatment again; Outcomes measured:; - before (same day); - after intervention (not specified)

a "Urologists presented basic treatment options including radical surgery, radiation therapy, and watchful waiting during a standard 15 to 30 minutes office visit."

b Six versions of a 45-minute video presentation that discussed the risks and benefits of prostate cancer interventions, including detailed information concerning potential treatment outcomes associated with radical surgery, external beam radiation, and watchful waiting. (p. 64) "Each presentation was identical except for variations in the tables of risk factors which were adjusted according to the patient's age and tumor histology as assessed by the Gleason grading system." (p. 64)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.18b: Onel (1998) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Onel, 1998 RefMan ID: 1080 | n = 95 Usual care and DA videotape | Knowledge^a^ | Number of patients who rated their knowledge of prostate cancer as:; - excellent understanding 6/95 (6%); - very good/good understanding 36/95 (38%); - poor/fair understanding: 53/9 (56%) | Post video:; - Excellent understanding: 13/95 (14%); - Very good/good understanding: 76/95 (80%); - Poor/fair understanding: 6/95 (6%); Postphysician + postvideo:; - Excellent understanding: 38/95 (40%); - Very good/good understanding: 52/95 (55%); - Poor/fair understanding: 5/95 (5%) | - measured at baseline, after the videotape, and after the videotape and consultation
Onel, 1998 RefMan ID: 1080 | n = 95 Usual care and DA videotape | Satisfaction with decision | | Number of patients satisfied with choice:; - Radical surgery: 27/32 (84%); - Radiation: 31/33 (94%); - Watchful waiting: 20/22 (91%); - Hormonal: 8/8 (100%)
Onel, 1998 RefMan ID: 1080 | n = 95 Usual care and DA videotape | Satisfaction with decisionmaking | | - 2/95 patients stated they would have preferred the doctor to make the treatment choice; - 93/95 patients were "enthusiastic about the opportunity to participate" in decisionmaking
Onel, 1998 RefMan ID: 1080 | n = 95 Usual care and DA videotape | Decision | | Number of patients per chosen therapy:; - Radical surgery: 32/95 (34%); - Radiation: 33/95 (35%); - Watchful waiting: 22/95 (23%); - Hormonal: 8/95 (8%) | - after videotape and consultation
Onel, 1998 RefMan ID: 1080 | n = 95 Usual care and DA videotape | Would choose same therapy again | | Number of patients who would choose same therapy again: Radical surgery: 21/32 (66%) Radiation: 18/33 (55%) Watchful waiting: 15/22 (68%) Hormonal: 6/8 (71%)
Onel, 1998 RefMan ID: 1080 | n = 95 Usual care and DA videotape | Other results^b^

Outcomes were measured before (same day) and after intervention (not specified).

a "No formal methods were used to assess patients' knowledge of their disease and treatment options either before or after viewing the presentation." (p. 64) Patients were asked to rate their knowledge of prostate cancer.

b Other results: patients' perception of involvement in decisionmaking (refer to paper)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.19a: Wilson (1988) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Wilson R, 1988 Country: UK RefMan ID: 3850 Study purpose: To determine whether, if given a choice, patients with breast cancer would prefer mastectomy or conservation therapy | Study design: Case series Blinding of outcome assessment: Not used Followup: NR Duration of the study: Total duration of the study: 9 years Duration for an individual patient: 2 years | Setting: Inpatient Type of cancer: Breast, early stage Type of decision: Treatment (primary) Model of decisionmaking:; - NR by authors; - Informedas determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Mastectomy vs. breast conservation with radiotherapy | Description:; - Usual care; - Tape-slide presentation^a^; - Counseling^b^; Purpose:; - To help make a decision; - To provide standardized information; Intervention administered by: Not specified Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 153 Eligibility criteria:; - < 65 years of age; - T_1_, T_2_, N_1_, N_0_ tumors of the breast proven by needle aspiration cytology; Characteristics: Age: Mean, SD: NR; Range: 27 to 65; > 60 yrs old: 153 Education: NR Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Satisfaction with decisionmaking; - Would choose same therapy again; - Determinants of patient choice; Outcomes measured:; - 2 days and 24 months after the intervention

a Tape-slide presentation: two 10-minute presentations; one for each treatment option

b Counseling: before viewing the tape-slide presentations, the treatment options discussed in the oncology consultation are reviewed.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.19b: Wilson (1988) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Wilson R, 1988 RefMan ID: 3850 | n = 153 Usual care Counseling Tape-slide presentation | Decision | | Chose breast conservation: 54/153 (35%) Chose mastectomy: 99/153 (65%)
Wilson R, 1988 RefMan ID: 3850 | n = 153 Usual care Counseling Tape-slide presentation | Would choose same therapy again | | Authors report that they know of only one patient who regrets her treatment decision: 1/153 (.5%)
Wilson R, 1988 RefMan ID: 3850 | n = 153 Usual care Counseling Tape-slide presentation | Satisfaction with decision making | | 2-year followup:; - unhappy to have chosen treatment: 2/28 (7%)
Wilson R, 1988 RefMan ID: 3850 | n = 153 Usual care Counseling Tape-slide presentation | Determinants of choice | | 2 year followup: Two main reasons given for mastectomy choice:; - length of radiotherapy treatment; - no guarantee that they would not need a mastectomy later; Many different reasons were given by patients for choosing breast conservation: specific reasons not reported.

Outcomes measured 2 days post-DA and 2 years after the intervention.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.20a: Maslin (1998) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Maslin AM 1998Maslin AM 1998 Country: UK RefMan ID: 6901, 670 Study purpose: To evaluate the usefulness of a shared decisionmaking program for women with early breast cancer | Study design: Randomized controlled trial Method of Randomization: NR Allocation concealment: NR Baseline comparability: NR Blinding of outcome assessment: NR Followup: 80-100% of subjects in the CG were followed to the end of the study. Not clear for the subjects allocated to the IG Duration of the study: Total duration of the study: NR Duration for an individual patient: 9 months | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment, primary Model of decision making:; - Shared as stated by authors; - Informed as determined by the reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Not clear (surgical - not specified; chemotherapy -not specified; radiotherapy - not specified) | Description Control Group(CG):; - Usual care^a^; Intervention Group (IG):; - Usual care^a^; - Interactive computer program^b^; Purpose:; - Increase knowledge; - Help make a decision; - Improve satisfaction with choice; - Decrease anxiety; - Decrease depression; Intervention administered by: Nurse Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 100 IG: 51; CG: 49 Eligibility criteria: Inclusion:; - Small, localized breast cancer; - No evidence of metastatic disease.; Exclusion:; - Women who did not understand English; - Various clinical conditions (reported in Figure 2, p. 448 of original paper); Characteristics: Age^c^: Mean: 52.1 years; SD: NR; range: 28-73 years Education: NR Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Decision; - Acceptability of DA; - Perceived assessment of health status; - Anxiety; - Depression; - Satisfaction; Outcomes measured:; - before intervention (same day); - 9 months after intervention

a Standard care based on information patients were given from the multidisciplinary team.

b This program provides research-based information to patients. The information is presented verbally, visually, and diagrammatically and includes figures for relative risk reduction, absolute risk reduction, difference in event-free survival, and the number of patients needed to treat to achieve benefit. (p. 445)

c Reported as pooled data.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.20b: Maslin (1998) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG^a^ | Notes
Maslin AM, 1998 Maslin AM, 1998 RefMan ID: 6901, 670 | n = 100 Control Group (CG) n = 49:; - Usual care; Intervention Group(IG) n = 51:; - Usual care; - Interactive computer program | Decision^a^ | | | Authors reported: "The women's treatment option choices showed no statistically significant difference, p = 0.08..."
Maslin AM, 1998 Maslin AM, 1998 RefMan ID: 6901, 670 | n = 100 Control Group (CG) n = 49:; - Usual care; Intervention Group(IG) n = 51:; - Usual care; - Interactive computer program | Acceptability of DA^b^ | | - 82% found the video 'just about right in length'; - 96% found it interesting/very interesting; - 92% found it easy/very easy to understand; - 72% felt they now had a much clearer idea about breast cancer; - 67% were 'glad they had used the video and would it use again'; - 28% found it 'helpful but not necessarily use it again'; - 54% considered that it had not influenced their ultimate decision; - 30% considered that it had definitely influenced their treatment decision
Maslin AM, 1998 Maslin AM, 1998 RefMan ID: 6901, 670 | n = 100 Control Group (CG) n = 49:; - Usual care; Intervention Group(IG) n = 51:; - Usual care; - Interactive computer program | Perceived assessment of health status (mental health score MOS-SF36) | Median: 60.0 vs. 68.0; SD: NR | Median: 68.0 vs. 68.0; SD: NR* | * The IG improved significantly over time (p = 0.02)
Maslin AM, 1998 Maslin AM, 1998 RefMan ID: 6901, 670 | n = 100 Control Group (CG) n = 49:; - Usual care; Intervention Group(IG) n = 51:; - Usual care; - Interactive computer program | Other results^c^

Outcomes were measured before the intervention (same day) and 9 months after the intervention.

a Results were presented in bar graphs, so it was not possible to extract the raw data.

b This outcome was assessed using a 'Likert questionnaire' asking the patients' opinion about the information given in the interactive video, how it was presented, and what impact they felt it made on their decision about what treatment to choose.

c Anxiety, depression, satisfaction with decisionmaking, satisfaction with choice were reported as pooled data.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.21a: Street (1995) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Street R 1995, 1997 Country: USA RefMan ID: 043, 1358 Study purpose: To assess the relative effectiveness of two pre-consultation educational interventions | Study design: Randomized Controlled Trial Method of randomization: NR Allocation concealment: NR Baseline comparability: Characteristics among groups were similar Blinding of outcome assessment: NR Followup: NR Duration of the study: Total duration of the study: 16 months Duration for an individual patient: 1 week | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment (primary) Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision:; - Mastectomy vs. lumpectomy with radiation | Description: Intervention Group (IG1) Usual care^a^ DA brochure^b^ Intervention Group (IG2) Usual care^a^ Interactive computer program^c^ Purpose:; - Increase knowledge; - Increase patient involvement in decisionmaking; Intervention administered by: Nurse (coordinates the project) and physician (usual care) Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 60 IG1: 30; IG2: 30 Eligibility criteria: Inclusion:; - Stage I or II breast cancer; - Fluency in English; Exclusion:; - Debilitating condition (e.g., Alzheimer's Disease, stroke); Characteristics: Age: IG1: Mean 60.8 years; SD: NR; range: 35 to 82 years IG2: Mean: 57.4 years; SD: NR; range: 35 to 76 years Education (IG2 vs. IG1): IG1: >12 years: 30 (100%) IG2: < 12 years: 1 (3%),>12 years: 29 (97%) Ethnicity: Caucasian: IG1: 27 (90%), IG2: 28 (93%) SES: NR | Primary outcome measures:; - Decision; - Knowledge; - Optimism; - Patient perception of involvement in care; - Physician communication; Outcomes measured:; - before the intervention (same day); - 1 week after the intervention

a Consultation with physicians: medical oncologist, radiation oncologist, and surgeon. Each consultation was recorded.

b Eight-page brochure divided into three sections: 1) comments of four women on their reaction to the diagnosis of having breast cancer; 2) information about the anatomy of the sites where breast cancer can form and the various stages of breast cancer; 3) information on mastectomy and lumpectomy plus radiation therapy. The medical information in the brochure was the same as that in the multimedia program. It also included several statements encouraging patients to ask questions, express concerns, and offer opinions. The 'Experiences of Other Women' section was not included in the brochure.

c Interactive computer program called "Options for treating breast cancer" run on an Apple computer with a touch screen monitor. "The program was divided into four sections: Introduction, Understanding the Problem, Treatment Options and Experiences of Other Women. The Introduction includes information on how to use the program. Understanding the Problem briefly overviews the anatomy of the breast, where breast cancer may form, and the various stages of breast cancer. Treatment Options presents information on two options for local treatment, mastectomy and lumpectomy with irradiation.[...] The 'Experiences of Other Women' section includes audiovisual clips of 8 women [...] sharing their reactions to the diagnosis, their biggest help in coping with the disease, and their experiences during recovery and adjuvant therapy." (p. 2277-2278)

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.21b: Street (1995) Results

Author | Intervention | Outcome(s) | Baseline Results IG1 vs. IG2 | Postintervention Results: IG1 vs. IG2 | Notes
Street R, 1995, 1997 RefMan ID: 043, 1358 | n = 60 Intervention Group (IG1): n = 30; - Usual care; - DA brochure; Intervention Group(IG2): n = 30; - Usual care; - Interactive computer program | Decision | | Postconsultation:; - patient chose lumpectomy with radiation: IG1: 17/30 (57%), IG2: 23/30 (77%); - patient chose mastectomy: IG1: 7/30 (23%) IG2: 13/30 (43%) | The authors report that there was no significant difference in the choice between groups. No p values nor analysis was provided
Street R, 1995, 1997 RefMan ID: 043, 1358 | n = 60 Intervention Group (IG1): n = 30; - Usual care; - DA brochure; Intervention Group(IG2): n = 30; - Usual care; - Interactive computer program | Knowledge^a^ | Pre-education: mean: 58.5 vs 60.7* | Posteducation: mean: 76.4 vs. 82.6* Postconsultation: mean: 79.4 vs. 82.0* | * Standard deviation: NR The authors report: 1) change within groups from baseline: p < 0.001 (two-way repeated measures ANOVA); 2) p = 0.07 for comparison between groups (two-way repeated measures ANOVA)
Street R, 1995, 1997 RefMan ID: 043, 1358 | n = 60 Intervention Group (IG1): n = 30; - Usual care; - DA brochure; Intervention Group(IG2): n = 30; - Usual care; - Interactive computer program | Optimism^b^ | Pre-education: mean: 33.0 vs.33.8* | Posteducation: mean: 33.8 vs 34.1* Postconsultation: mean: 33.4 vs. 34.4* | p = 0.78, p = 0.34 and p = 0.93 (two-way repeated measures ANOVA)
Street R, 1995, 1997 RefMan ID: 043, 1358 | n = 60 Intervention Group (IG1): n = 30; - Usual care; - DA brochure; Intervention Group(IG2): n = 30; - Usual care; - Interactive computer program | Patient perception of involvement in care^c^ Physician communication^c^ Other results^d^

Outcomes were measured before (same day) and 1 week after the intervention.

a Knowledge about breast cancer treatment was measured using an 11-item multiple choice test. The score is the percentage of correct responses.

b Dispositional optimism was measured with 12 items, each using a 5-point Likert scale. Scores vary from 8 to 40, with higher scores meaning higher optimism.

c The outcomes of patient perception of involvement in care and physician communication were collapsed into one group, separated according to patient age (<65 years, 65+) and education.

d In the 1997 paper, followup data at 6 and 12 months were presented regarding decision control and quality of life; however, data were not presented by group. Authors reported active vs. passive participation in decisionmaking.

Studies of Effectiveness of Decision Aids: Nonrandomized controlled trial

Evidence Table 5.22a: Molenaar (2001) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Molenaar S, 2001 Country: The Netherlands Language of publication: English RefMan ID: 7850 Study purpose: To examine whether an interactive CDROM decision aid affects breast cancer patients' treatment decisions, satisfaction, and quality of life | Study design: Nonrandomized controlled trial^a^ Baseline comparibility: Characteristics of the groups were similar except for baseline decisional conflicit Followup: At 9 months: IG: 97% and CG: 90% of included subjects were followed-up. Duration of the study: Total duration of the study: 32 months Duration for one patient: 9 months | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment Model of decisionmaking:; - Shared by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Mastectomy versus breast conservation plus radiotherapy | Description Control group (CG):; - Usual care^b^; - Information pamphlet^c^; Intervention group (IG):; - Usual care^b^; - Interactive DA computer program^d^; Purpose:; - To increase knowledge; - Help to make a decision; Intervention administered by:; - Self-administered by patient with a nurse specialist present for technical assistance; Timing of the intervention:; - Before the decision was made | Number of subjects enrolled: 180; CG: 88, IG: 92 Eligibility criteria: Inclusion:; - Consecutive patients with stage I or II breast cancer; - Patients considered acceptable for either mastectomy or breast conservation plus radiotherapy; Exclusion:; - Insufficient understanding of Dutch language; Characteristics Age: IG: Mean: 55.4 years; SD: 10.8; range NR CG: Mean: 54.6 years; SD: 10.6; range: NR Education: < 12 years IG: 9 (8%); CG: 9 (8%) Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Decisional conflict satisfaction with:; (a) information (b) decisionmaking process (c) decision (d) care; - Quality of life; (a) generic and (b) breast cancer specific Outcomes measured:; - before the intervention; - after (3 and 9 months postsurgery)

a Study design: Three hospitals participated (A, B, C sites). The CDROM DA was introduced in intervals (three separate 6-month inclusion periods). During the first inclusion period the CDROM DA was used in site B, while sites A and C were control groups. In the second inclusion period the CDROM DA was used in sites A and C, while site B was the control intervention. In the third period the CDROM was used again at site B, and sites A and C had the control group intervention. Note that no patients were entered into the study for a month following completion of a CDROM DA period.

b Usual Care: Standard surgical oncology consultation in which the surgeon discussed the treatment options. In the control group: surgeons asked patients to make a preliminary treatment choice during the consultation.

c Information pamphlets were provided after the surgical consultation to "promote information recall, and further deliberation regarding their preliminary treatment choice." (p. 1679)

d Interactive CDROM: Consists of eight submenus, including one on each of the treatment options that provides the advantages and disadvantages. Presents combinations of pictures, video, and text accompanied by verbal explanations. Written summaries of selected parts of the program could be printed, such as a summary on the potential pros, cons, and uncertainties of breast conserving therapy and mastectomy.

Studies of Effectiveness of Decision Aids: Nonrandomized controlled trial

Evidence Table 5.22b: Molenaar (2001) Results

Author | Intervention | Outcome(s) | Baseline ResultsIG vs. CG | Postintervention ResultsIG vs. CG | Notes
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Decision | Preference for: | Actual decision: | No significant difference between groups either at baseline (chi-square test, p=0.20) or postintervention (chi-square test, p=0.29)
  | IG | CG
  Lumpectomy | 59 (54%) | 68 (60%)
  Unsure | 16 (15%) | 8 (7%)
  Mastectomy | 25 (23%) | 24 (21%)
  | IG | CG
  Lumpectomy | 69 (75%) | 60 (68%)
  Mastectomy | 23 (25%) | 28 (32%)
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Decisional conflict ^a^ | Overall means not reported | | MANOVA, p<0.01; decisional conflict was added as a covariate for all subsequent MANOVAs.
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Overall satisfaction | | IG had greater overall satisfaction compared to CG. | MANOVA for repeated measures p<0.01
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Satisfaction with information(general) ^b^ | | 3-month followup: IG mean: 86.4; SD 1.4* CG mean: 78.1; SD 1.5 9-month followup: IG mean: 85.4; SD 1.5** CG mean: 75.4; SD 1.5 | Significantly greater satisfaction in IG vs. CG at both 3- and 9-month followup (Student's t-test, p<0.01* and p<0.01**)
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Satisfaction with information(treatment-specific) ^b^ | | 3-month followup: IG mean: 75.9; SD 3.0* CG mean: 73.1; SD 3.4 9-month followup: IG mean: 79.9; SD 2.7** CG mean: 71.3; SD 2.8 | Significantly greater satisfaction in IG vs. CG at 9-month followup (Student's t-test, p=0.55* and p=0.03**)
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Satisfaction with decisionmaking process ^c^ | | 3-month followup: IG mean: 3.7; SD 0.1* CG mean: 3.7; SD 0.1 9-month followup: IG mean: 3.8; SD 0.1** CG mean: 3.6; SD 0.1 | Significantly greater satisfaction in IG vs. CG at 9-month followup (Student's t-test, p=0.44* and p=0.02**)
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Satisfaction with decision ^d^ | | 3-month followup: IG mean: 4.6; SD 0.1* CG mean: 4.4; SD 0.1 9-month followup: IG mean: 4.7; SD 0.1** CG mean: 4.3; SD 0.1 | Significantly greater satisfaction in IG vs. CG at both 3- and 9-month followup (Student's t-test, p=0.03* and p<0.00**)
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Satisfaction with care | | Reported data from five subscales; refer to paper for details. | IG significantly greater satisfaction with communication than CG at 9-month followup (t-test; p=0.04)
Molenaar S, 2001 RefMan ID: 7850 | Control group (CG): Usual careInformation pamphlet Intervention group (IG): Usual careInteractive DA computer program | Quality of life (QoL) ^e^ | QoL (generic) and (breast cancer specific): data presented for sub-scales; refer to paper for details. | QoL (generic)*: data presented for subscales; refer to paper for details QoL (breast cancer specific)**: data presented for subscales; refer to paper for details | - Baseline: no significant differences; - 9-month followup: Higher QoL in IG than CG (MANOVA repeated measures p<0.01*, p=0.05**)

a Decisional conflict was measured using the O'Connor Decisional Conflict Scale (DCS).

b Authors developed two instruments to measure satisfaction with information (general and treatment-specific). Range 0 to 100; higher score=greater satisfaction. See paper for further details.

c Authors also developed a scale to measure satisfaction with decisionmaking process. Range 1 to 5; higher score means greater satisfaction.

d Satisfaction with decision was measured using three of the four items from the decisional conflict subscale 'effective decision-making.'

e Quality of life: Generic was assessed using the Medical Outcomes Study 20 (MOS20) and breast cancer specific functioning was assessed using the European Organization for Research and Treatment of Cancer Quality of Life (EORTC QLQ_BR23)

Studies of Effectiveness of Decision Aids for Treatment: Case series design

Evidence Table 5.23a: Gramlich (1998) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Gramlich E, 1998 Country: USA RefMan ID: 883 Study purpose To improve the quality of treatment for breast cancer patients in Hawaii | Study design: Case series Blinding of outcome assessment: Not used Followup: NR Duration of the study: Total duration of the study: 32 months Duration for an individual patient: 6 months | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment (primary, adjuvant) Model of decisionmaking:; - Shared as stated by authors; - Not clear as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Adjuvant chemotherapy vs. none; - Breast-sparing surgery with radiotherapy vs. mastectomy | Description:; - Interactive computer program ^a^; - Usual care; Purpose:; - Increase knowledge; - Help make a decision; - Increase patient involvement in decisionmaking; Intervention administered by: NR Timing of the intervention:; - before the decision was made | Number of subjects enrolled: not clear Eligibility criteria: NR Characteristics: Age: NR Education: NR Ethnicity: approxiamtely 54% "were nonwhite" (p. 203) SES: NR Religion: NR | Outcome measures:; - Decision; - Satisfaction with decisionmaking; - Would recommend DA to other patients; - Acceptability of the decision aid; Outcomes measured:; - before the intervention and 6 months after

a Video disk aiming to supplement information provided by the physician. It discussed the options of mastectomy and breast-sparing surgery and the advantages of having or not having adjuvant chemotherapy.

Studies of Effectiveness of Decision Aids for Treatment: Case series design

Evidence Table 5.23b: Gramlich (1998) Results

Author | Intervention | Outcome (s) | Baseline Results | Post Intervention Results
Gramlich E, 1998 RefMan ID: 883 | n = not clear Interactive computer program and usual care | Decision (n=49) | - prefer mastectomy: 17/49 (35%); - no treatment preference: 5/49 (10%); - prefer breast-sparing surgery: 27/49 (55%) | Patients whose preference did not change post-DA:; - continue to prefer mastectomy: 14/17 (82%); - still have no treatment preference: 1/5 (20%); - continue to prefer breast-sparing: 27/27 (100%); Patients whose preference changed post-DA:; - changed to no preference from mastectomy: 3/17 (18%); - changed to breast-sparing from no preference: 4/5 (80%)
Gramlich E, 1998 RefMan ID: 883 | n = not clear Interactive computer program and usual care | Acceptability of decision aid (n=83) | | Majority of patients (over 90%) who viewed the surgery program rated it very good/excellent in terms of amount of information, clarity, and overall rating.
Gramlich E, 1998 RefMan ID: 883 | n = not clear Interactive computer program and usual care | Would recommend decision aid to other patients (n = not clear) | | Greater than 95% of patients who used the surgery program were very positive/generally positive about the DA being used with other patients.
Gramlich E, 1998 RefMan ID: 883 | n = not clear Interactive computer program and usual care | Satisfaction with decisionmaking (n = 57) | | At 6-month followup:; - satisfaction with treatment decision rated as excellent/very good: 47/57 (82%) of patients who viewed the surgery and/or adjuvant programs

Outcomes measured before and after using the DA intervention (exact timing not specified), and then at 6 months later.

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.24a: Davison (1999) General Characteristics

Author/Study Purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Davison B, 1999 Country: Canada RefMan ID: 5583 Study Purpose: To determine if providing information about screening for prostate cancer would enable men to assume a more active role in decisionmaking | Study design: randomized controlled trial Method of randomization: block randomization procedure Allocation concealment: NR Baseline comparability: characteristics of the groups were similar Blinding of outcome assessment: NR Followup: NR Duration of the study: NR | Setting: Outpatient Type of cancer: Prostate Type of decision: Screening Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Prostate Specific Antigen (PSA) + digital rectal examination (DRE) vs. none | Description: Control Group (CG):; - Usual care ^a^; - Unrelated discussion ^b^; Intervention Group (IG):; - Usual care ^a^; - Counseling ^c^; - DA brochure ^d^; Purpose:; - Increase patient involvement in decisionmaking; - Decrease anxiety; - Resolve decisional conflict; - Help to make a decision; Intervention administered by:; - Physician (PHE) and nurse (counseling and pamphlet) Timing of the intervention:; - before the decision was made | Number of subjects enrolled:100 CG: 50; IG: 50 Eligibility criteria: Inclusion:; - No previous history of prostate cancer; - Made an appointment for a periodic health examination; - 50-79 years old; - Read, speak, and write English; - No evidence of mental confusion; Characteristics: Age: IG: Mean 63.8 years; SD: 8.0 CG Mean: 60.7 years; SD: 8.6 Education: > 12 years: IG: 23 subjects; CG: 21 <12 years: IG: 27 subjects; CG 29 Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Control preference; - Anxiety; - Decisional conflict; - Quality of life (condition specific); Outcomes measured:; - before; - after the intervention (details not specified)

a Periodic health examination (PHE)

b The investigator discussed general issues before the medical appointment for about the same length of time that it would take to provide the information intervention (p. 258).

c "Men were asked what they knew about screening for prostate cancer. They were then provided with [...] verbal [...] information about the controversies surrounding screening [...]. Men were encouraged to discuss screening issues with their family physician and participate in making a screening decision to the extent that they were comfortable" (p. 258).

d Written information about controversies surrounding screening for prostate cancer

Studies of Effectiveness of Decision Aids: RCT design

Evidence Table 5.24b: Davison (1999) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Davison B, 1999 RefMan ID: 5583 | n = 100 Control Group (CG) n = 50:; - Usual care; - Discussion; Intervention Group (IG) n = 50:; - Usual care; - Counseling (individual); - DA brochure | Decision ^a^ | | 28 (56%) vs. 21 (42%) | No statistical analysis reported
Davison B, 1999 RefMan ID: 5583 | n = 100 Control Group (CG) n = 50:; - Usual care; - Discussion; Intervention Group (IG) n = 50:; - Usual care; - Counseling (individual); - DA brochure | Control preference ^b^ | Proportion of men preferring each role:; - active: 22 (44%) vs.17(34%);; - collaborative: 15 (30%) vs. 20 (40%); - passive: 13 (26%) vs.13 (26%) | Proportion of men assuming each role:; - active: 31(62%) vs.11(22%);; - collaborative: 9 (18%) vs.19 (38%);; - passive: 10 (20%) vs.20 (40%) | A significantly higher number of men who received the intervention assumed a more active role in making a screening decision than men in the control group (Mann-Whitney U test =-4.07, p = 0.00002, one-tailed) (p. 259-260)
Davison B, 1999 RefMan ID: 5583 | n = 100 Control Group (CG) n = 50:; - Usual care; - Discussion; Intervention Group (IG) n = 50:; - Usual care; - Counseling (individual); - DA brochure | Anxiety ^c^ | Mean: 24.9 vs.26.0; SD NR | Mean: 23.6 vs. 23.9; SD: NR | No significant differences existed between the groups, both pre- and postintervention (repeated measures ANOVA) (p. 260)
Davison B, 1999 RefMan ID: 5583 | n = 100 Control Group (CG) n = 50:; - Usual care; - Discussion; Intervention Group (IG) n = 50:; - Usual care; - Counseling (individual); - DA brochure | Decisional conflict ^d^ | | Mean: 28.52 vs. 35.20; SD: NR | p = 0.0001 one-tailed (Mann-Whitney U test) (p. 260)
Davison B, 1999 RefMan ID: 5583 | n = 100 Control Group (CG) n = 50:; - Usual care; - Discussion; Intervention Group (IG) n = 50:; - Usual care; - Counseling (individual); - DA brochure | Other results ^e^ quality of life

Outcomes were measured before and after the intervention (details not specified).

a Number of subjects who were screened with both a digital rectal examination and prostate-specific antigen test

b Control Preference Scale (CPS): five statements ranging from: "I prefer to make the final decision" to "I prefer my doctor to make the final decision" were collapsed by the authors into three categories: active, collaborative, and passive role. Preferred roles were measured at baseline, and the assumed roles were measured post-intervention.

c Anxiety was measured by the State Anxiety Inventory, a 20-item questionnaire with scores ranging from 20 to 80; high scores indicate high anxiety.

d Decisional Conflict Scale: 16-item measure with higher scores meaning higher decisional conflict.

e Reasons for patients' choice of treatment and quality of life; this outcome was evaluated as pooled data: in a multivariate logistic regression model the variables that were significantly predictive of men being screened with both PSA and DRE were having: (1) a DRE (p = 0.01); (2) an abnormal DRE at the time of the PHE, (p = 0.03); (3) grade 12 education or greater (p = 0.01); (4) a lower quality of life due to urinary symptoms (p = 0.02); (5) a rural residence (p = 0.04). (p. 261) Having symptoms of prostatism and perceived lower quality of life due to urinary symptoms were highly correlated (r = 0.706), p < 0.001. (p. 260)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.25a: Cotton (1995) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Cotton T, 1995 Country: Not clear RefMan ID: 1062 Study purpose: To ascertain whether women who had made a choice of treatment were still satisfied with the decision they had made | Study design: Case series Blinding of outcome assessment: Not used Followup: NR Duration of the study: Total duration of the study: NR Duration for an individual patient: 1 year | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment, primary Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Mastectomy vs. lumpectomy + radiotherapy | Description:; - Counseling ^a^; - Usual care ^b^; - Information pamphlet ^c^; Purpose:; - Help make a decision; Intervention administered by: Nurse Timing of the intervention: before the decision was made | Number of subjects enrolled: 20 Eligibility criteria: asymptomatic screen-detected breast cancer patients Characteristics Age: Mean, SD: NR; range: 51 years to 67 years Education: NR Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Decision; - Satisfaction with decisionmaking; - Would choose same therapy again; - Determinants of patients' choice of treatment; Outcomes measured:; - 12 months after the intervention

a The patients were seen by a nurse who met their information needs and provided counseling after the oncology consultation. (p. 12)

b Consultation with the surgeon

c "Literature supplied" -- no further description provided (p. 12)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.25b: Cotton (1995) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Cotton T, 1995 RefMan ID: 1062 | n=20 Counseling Usual care Information pamphlet | Decision | | - Chose mastectomy: 10/20 (50%); - Chose lumpectomy + radiation: 9/20 (45%); - Patient did not perceive she had a choice: 1/20 (5%)
Cotton T, 1995 RefMan ID: 1062 | n=20 Counseling Usual care Information pamphlet | Satisfaction with decisionmaking | | - Patient was glad to make her own therapy choice:14/19 (74%); - Patient was not glad to make her therapy choice: 5/19 (26%); - Found counseling from nurse unhelpful: 1/19 (5%); - Did not read literature given until after surgery: 7/19 (37%); - Found material given upsetting: 2/19 (10%); - Wished surgeon had made the decision: 2/19 (10%)
Cotton T, 1995 RefMan ID: 1062 | n=20 Counseling Usual care Information pamphlet | Would choose same therapy again | | - Patient would not have the same therapy again: 3/19 (16%) | - All three patients chose mastectomy
Cotton T, 1995 RefMan ID: 1062 | n=20 Counseling Usual care Information pamphlet | Determinants of patients' choice | | Reason given for mastectomy choice:; - Fear of recurrence and further surgery (8/10); - Fear of radiotherapy (1/10); - Frequent travel to hospital for radiotherapy would be a problem (1/10); Reason given for lumpectomy + radiation choice:; - Mastectomy felt to be too drastic (3/9); - Concern about self-image (4/9); - Patient stated this treatment option had been recommended by a health-care professional (2/9)

Outcomes measured 12 months after the intervention.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.26a: Cotton (1991) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Cotton T, 1991 Country: UK RefMan ID: 3372 Study purpose: To identify the demand for breast conservation by women when given the choice of treatment | Study design: Case series Blinding of outcome assessment: Not used Followup: NA Duration of the study: Total duration of the study: 1 year. Duration for each patient: NR | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment, primary Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Mastectomy vs. breast conservation with radiotherapy | Description:; - Counseling with visual aids ^a^ information pamphlet ^b^; Purpose:; - Make a decision/state a preference; - Increase patient involvement in decisionmaking; - Increase knowledge; Intervention administered by: Nurse Timing of the intervention:; - Before the decision was made | Number of patients enrolled: 91 Eligibility criteria: Inclusion: patients presenting with primary operable breast cancer Characteristics: Age: Not clear Ethnicity: NR SES: NR Education: NR | Outcome measures:; - Decision; Outcomes measured:; - after intervention

a After the surgeon broke the news about the diagnosis of breast cancer, the patients were left with the nurse counselor, who talked to them about breast cancer and allowed them to relieve their feelings. She then explained the positive and negative aspects of the treatments offered and the patients were encouraged to ask questions. During the counseling session, the women were shown pictures of the results of the different treatment options.

b The women were given written information to take home.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.26b: Cotton (1991) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Cotton T, 1991 RefMan ID: 3372 | n = 91 Usual care Counseling with visual aids ^a^ Information pamphlet | Decision | | - Chose lumpectomy + radiation: 41/91(45%); - Chose simple mastectomy: 47/91 (51%); - Chose subcutaneous mastectomy: 3/91 (3%) | The authors grouped women by age: 55 years old or less versus 56 years or greater. Using a chi-square test, the authors found that the younger group of women chose lumpectomy plus radiation significantly more often than the group of older women (p<0.001).

Outcomes were measured after the intervention (timing not reported).

a Patients were shown pictures of the results of both mastectomy and lumpectomy.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.27a: Sandison (1996) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Sandison A, 1996 Country: UK RefMan ID: 4438 Study purpose: Increase patient involvement in decisionmaking and to ensure patients are well informed and avoid suboptimal treatment or ill-informed treatment decisions | Study design: Case series Blinding of outcome assessment: Not used Followup: NA Duration of the study: Total duration of the study: 4 years Duration for an individual patient: 1 year | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment (primary) Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Four treatment options:; - Tamoxifen alone;; - Complete local excision and tamoxifen;; - Modified radical mastectomy and tamoxifen and complete local excision;; - Radiotherapy and tamoxifen. | Description:; - Usual care ^a^; - Counseling ^b^; - DA brochure ^c^; Purpose:; - Increase knowledge; - Increase patient involvement in decisionmaking; - Help make a decision; Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 50 Eligibility criteria:; - New diagnosis of breast cancer; - 70 years and older; Characteristics Age: Mean, SD: NR; range: 70 years to 94 years Education: NR Ethnicity: NR SES: NR | Outcome measures:; - decision; - satisfaction with decisionmaking; Outcomes measured:; - after the intervention at 2 days, 24 weeks, and 12 months.

a Oncology consultation: Patients were encouraged to ask questions, which often included asking the surgeon his/her preference. However, if patients did not ask, they were not told. (p. 994)

b A few days after the surgical oncology consultation, patients were seen by an oncology nurse and the treatment options were discussed again.

c "The patient was then given an information sheet to take away which reiterated the choices available, the advantages and disadvantages of each choice, the approximate risk of recurrence with each treatment and the likelihood of requiring further intervention." (p. 994)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.27b: Sandison (1996) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Sandison A, 1996 RefMan ID: 4438 | n = 50 Usual care Counseling DA brochure | Decision | | Patient decided to chose own treatment: 38/50 (76%) Patient asked surgeon to choose: 12/50 (24%) Of the 38 who chose their own treatment:; - Chose Tamoxifen only: 1/38 (3%); - Chose Tamoxifen + local excision: 2/38 (5%); - Chose Tamoxifen + mastectomy: 4/38 (11%); - Chose Tamoxifen + local excision + radiotherapy: 31/38 (82%)
Sandison A, 1996 RefMan ID: 4438 | n = 50 Usual care Counseling DA brochure | Satisfaction with decisionmaking | | 1- year followup:; - Patient felt they made the right choice: 36/38 (95%); - Patient was unhappy with their choice: 2/38(5%)

Outcomes were measured post-DA intervention and then at 1-year followup.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.28a: Okamato (1999) General Characteristics

Author | Design/Quality indicators | Clinical Situation | Intervention | Sample | Outcomes
Okamato, M 1999 Country: Japan Language of publication: Japanese RefMan ID: 585 Study purpose: To evaluate the introduction of a patient-determined treatment policy | Study design: Case series Blinding of outcome assessment: NR Followup: NR Duration of the study: Total duration of the study: 4 years Duration for one patient: Not clear | Setting: Outpatient Type of cancer: Hypopharyngeal Type of decision: Treatment Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Chemoradiotherapy versus surgery | Description; - Usual care ^a^; - Verbal and visual information ^b^; - plus additional counseling sessions as needed ^c^; Purpose:; - Increase knowledge; - Make a decision/state a preference; Intervention administered by: Physician Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 57 Eligibility criteria: Inclusion:; - diagnosed with hypopharyngeal cancer; Characteristics Gender: NR Age: Mean: NR; SD: NR; range: NR Education: NR Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Duration from initial visit to start of treatment; - Name of disease provided to patient; - 3-year crude survival rate; Outcomes measured:; - After the DA intervention (specific timing not reported)

a Initial consultation with physician to discuss available treatment options. The same physician administered the intervention to all patients.

b During the oncology consultation, patients were provided with visual (pictures and diagrams) and verbal information regarding the two treatment options. The information provided included the description of tumor, current stage of the tumor, why the patient needed to be treated, and then a discussion of the two treatment options, including the risks and benefits as well as side-effects.

c After the initial consultation, patients who came alone were requested to bring a family member to the next counseling session. Most of the patients took 1 to 1.5 hours of meeting time to reach a decision.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.28b: Okamato (1999) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Okamato, M. 1999 RefMan ID: 585 | n = 57 Usual care, Verbal and visual information, Additional counselling sessions as needed. | Decision
  Chemoradiotherapy | 43 (75%)
  Surgery | 11 (19%)
  No treatment | 1 (2%)
  Transferred to another hospital | 2 (4%)
Okamato, M. 1999 RefMan ID: 585 | n = 57 Usual care, Verbal and visual information, Additional counselling sessions as needed. | Name of disease provided to patient ^a^
  Cancer | 11 (20%)
  Malignant tumor | 28 (51%)
  Moss | 13 (23%)
  Moss (not cancer) | 1 (2%)
  Possibility of malignancy | 1 (2%)
  Atypical cell | 1 (2%)
Okamato, M. 1999 RefMan ID: 585 | n = 57 Usual care, Verbal and visual information, Additional counselling sessions as needed. | Duration from initial visit to start of treatment | | Intervention subjects (1993 to 1997) Compared to 60 cases before intervention was implemented (1983 to 1992): | Authors report that intervention increased time to treatment. No statistical analysis reported.
  - Less than 15 days:; - 15 to 30 days:; - More than 30 days: | 16 (31%) 28 (54%) 8 (15%)
  - Less than 15 days:; - 15 to 30 days:; - More than 30 days: | 50 (31%) 8 (54%) 2 (15%)
Okamato, M. 1999 RefMan ID: 585 | n = 57 Usual care, Verbal and visual information, Additional counselling sessions as needed. | 3-year crude survival rate | | No data presented. Author's report that there was no significant difference in survival of intervention subjects compared to patients before the intervention was implemented (1983 to 1992).

a The diagnosis of cancer was revealed only to those patients who requested to be informed during the initial consultation.

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.29a: Ashcroft (1996) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Ashcroft, J 1985; Leinster, SJ, 1989; Owens, RG, 1987 Country: UK RefMan ID: 1932, 7265, 139 Study purpose: To investigate the psychological and social effects of conservative therapy vs. mastectomy and impact of the choice | Study design: Case series Blinding of outcome assessment: Not used Followup: NR Duration of the study: Total duration of the study: NR Duration for an individual patient:1 year | Setting: Outpatient Type of cancer: Breast, early stage Type of decision: Treatment, primary Model of decisionmaking:; - NR by authors; - Shared as determined by reviewers; Phase of decision:; - Deliberation; - Making the decision; Context of decision:; - Mastectomy vs. lumpectomy plus radiotherapy | Description: Usual care^a^ Informal decision analysis^b^ Purpose:; - Resolve decisional conflict; - Help make a decision; Intervention administered by: not specified Timing of the intervention: at the point of decisionmaking | Number of subjects enrolled: 18 Eligibility criteria:; - Women with early breast cancer; - Scheduled for surgery; Characteristics Age: Mean, SD: NR; range: 20 to 70 years Education: NR Ethnicity: NR SES: NR | Primary outcome measures:; - Decision; - Anxiety; - Depression; Outcomes measured:; - before the intervention and after (same day, 2 days, 12 weeks, 12 months)

a Consultation with oncologist

b "We ask each patient to provide rough estimates of the relevant factors in her decision [...] the objective of the approach is to provide a structure that will appear to the patient to resemble an informal conversation with a member of the treatment team. At the same time we elicit information from the patient about relevant outcomes associated with each choice of treatment, together with her subjective assessment of the probabilities and utilities associated with these outcomes. The patient, having been offered the choice of mastectomy or lumpectomy, is asked which treatment she would like to discuss first. When she has made that choice, she is asked to think about and try to list all the events that might occur as a consequence of that treatment. [...] Having formulated this list, the patient is asked to give her own assessment of the chance that each event will happen by assigning it a rank of 0 to 10 (0 = absolute certainty that the event will not occur; 10 = absolute certainty that the event will occur). This number represents her subjective assessment of the probability that the event will occur. Similarly, the patient is asked to assess the desirability of each event, this time on a scale of 0 to 10 (no desirability and maximum desirability, respectively). In this way, we obtain an estimate of all the possible utilities associated with the outcomes. The subjective probability and utility figures are then added to the list of possible consequences of a given treatment. [...] When estimates of probability and utility for one form of treatment have been obtained, the procedure can be repeated for the alternative treatment. [...] In principle, given the information in the lists, it is then possible to construct a decision tree and to calculate the subjective expected utility of the treatment the patient has chosen." (p. 27)

Studies of Effectiveness of Decision Aids: Case series design

Evidence Table 5.29b: Ashcroft (1996) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Ashcroft J, 1985; Leinster SJ, 1989; Owens RG, 1987 RefMan ID: 1932, 7265, 139 | n = 18 Usual care Informal decision analysis^a^ | Decision | | - chose lumpectomy + radiotherapy: 8/18 (45%); - chose mastectomy: 6/18 (33%); - chose to enter a clinical trial in which there was random assignment to either mastectomy or lumpectomy plus radiation: 4/18 (22%)
Ashcroft J, 1985; Leinster SJ, 1989; Owens RG, 1987 RefMan ID: 1932, 7265, 139 | n = 18 Usual care Informal decision analysis^a^ | Anxiety and depression | | | Anxiety and depression were reported as pooled data. The authors included analysis of patients who were not offered a choice because their condition necessitated a specific treatment option (i.e., mastectomy, lumpectomy, or benign investigative surgery)
Ashcroft J, 1985; Leinster SJ, 1989; Owens RG, 1987 RefMan ID: 1932, 7265, 139 | n = 18 Usual care Informal decision analysis^a^ | Other results^b^

a Informal decision analysis was offered to the 14 patients who elected to choose between mastectomy and lumpectomy plus radiotherapy.

b Authors also measured body satisfaction, marital adjustment, social adaptability, self-esteem; refer to paper for details.

Studies of Effectiveness of Decision Aids for Treatment: RCT design

Evidence Table 5.30a: Irwin (1999) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Irwin, E 1999, 1995 Country: Canada RefMan ID: 7208, 7121 Study purpose; - Primary purpose: "to develop an instrument to facilitate women to participate in a treatment decision regarding the type of adjuvant chemotherapy" (p. 284); - Secondary purpose: "to examine the factors affecting the decision-making process for newly diagnosed patients when choosing between two equally effective adjuvant chemotherapy regimens" (p. 284) | Study design: Randomized controlled trial Method of randomization: NR Allocation concealment: NR Baseline comparability: NR Blinding of outcome assessment: NR Followup: NR Duration of the study: Total duration of the study: 47 weeks Duration for an individual patient: 2 weeks | Setting: Outpatient Type of cancer: Breast cancer Type of decision: Treatment (adjuvant) Model of decisionmaking:; - Shared as reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; Context of decision: Adriamycin + Cyclophosphamide (AC) vs. Cyclophosphamide + Methotrexate + 5-Fluorouracil (CMF) | Description: Intervention Group 1 (IG1):; - decision board^a^ (DB) with presentation of AC first; - take home version of DB; Intervention Group 2 (IG2):; - decision board^a^ (DB) with presentation of CMF first; - take-home version of DB; Purpose:; - Increase knowledge; - Increase patient involvement in decisionmaking; - Help make a decision; Intervention administered by: Research nurse (first 30 patients) and primary care nurses Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 46 IG1 23; IG2: 23 Eligibility criteria: Inclusion:; - diagnosis of primary node-positive breast cancer; - referred for a medical oncology consultation following surgery; - fluency in spoken and written English; Characteristics: Age^b^: Mean: 45.5 years; SD: NR Range: 34 to 53 years Education^b^:> 12 years: 39 (85%) Ethnicity: NR SES^b^: > $30,000 a year: 29 (63%) | Outcome measures:; - Decision; - Knowledge; - Acceptability of the decision aid; - Determinants of patients' choice of treatment; Outcomes measured:; - 2 weeks after the intervention

a The Decision Board was 75 x 45 cm large and was composed of 3 sections: (1) general information about chemotherapy; (2) details about treatment schedule; and (3) incidence of nausea, vomiting, and alopecia associated with each treatment option. "The clinician read aloud the written material and explained the graphical information contained on seven cards and placed them on the board in sequence. Some additional information was given about less common side effects associated with each treatment but not included in the Board." (p. 285)

b Reported as pooled data.

Studies of Effectiveness of Decision Aids for Treatment: RCT design

Evidence Table 5.30b: Irwin (1999) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Irwin E, 1999 1995 RefMan ID: 7208, 7121 | n = 46 Intervention Group 1 (IG1) n = 23; - decision board with presentation of AC first; Intervention Group 2 (IG2) n = 23; - decision board with presentation of CMF first | Decision^a^ | | Total sample:; - chose AC: 23/46 (50%); - chose CMF: 21/46 (46%); - chose no chemotherapy: 2/46 (4%); IG1 vs. IG2; - chose AC: 10/23 (43%) vs. 13/23 (57%) *; - chose CMF: 12/23 (52%) vs. 9/23 (39%)*; - chose no chemotherapy: 1/23 (4%) vs. 1/23(4%)* | * no p value reported, but the authors reported that there were no significant differences between groups
Irwin E, 1999 1995 RefMan ID: 7208, 7121 | n = 46 Intervention Group 1 (IG1) n = 23; - decision board with presentation of AC first; Intervention Group 2 (IG2) n = 23; - decision board with presentation of CMF first | Knowledge^b^ | | | The authors reported "NS between treatment groups," however the data were reported pooled.
Irwin E, 1999 1995 RefMan ID: 7208, 7121 | n = 46 Intervention Group 1 (IG1) n = 23; - decision board with presentation of AC first; Intervention Group 2 (IG2) n = 23; - decision board with presentation of CMF first | Acceptability of the decision aid^c^ | | Instrument was rated "quite helpful" 45/46 (98%) Difficulty in making decision:; - "not very difficult" 14/46 (30%); - "somewhat difficult" 17/46 (37%); - "very difficult" 15/46 (33%)
Irwin E, 1999 1995 RefMan ID: 7208, 7121 | n = 46 Intervention Group 1 (IG1) n = 23; - decision board with presentation of AC first; Intervention Group 2 (IG2) n = 23; - decision board with presentation of CMF first | Determinants of choice^d^

a AC: Adriamycin + Cyclophosphamide; CMF: Cyclophosphamide + Methotrexate + 5-Fluorouracil. 16/24 who had mastectomy chose AC; 7/24 who had mastectomy chose CMF; 7/22 who had breast-conserving surgery chose AC; 14/22 who had breast-conserving surgery chose CMF. Authors report an unexpected association between type of surgery and choice of chemotherapy: p = 0.03 (X ^2^ test).

b Eight questions regarding the understanding of benefits and risks of AC and CMF. "The percentage of correct responses [...] ranged from 80 to 100%." (p. 287) Data are presented in Table 2, p. 288 of the 1999 article.

c Pooled data reported.

d An open-ended question asked the participants to give the top three reasons for their choice. The women were also asked to rate the importance of each of 15 factors listed in a questionnaire. The authors report that the most frequent reason for choice was side effects. Other reasons were quality of life and time. (p. 289)

Studies of Effectiveness of Decision Aids: Nonconcurrent cohort design

Evidence Table 5.31a: Whelan (1995) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Whelan T, 1995 Country: Canada RefMan ID: 068 Study purpose: To develop an instrument to help clinicians inform patients about the benefits and risks of breast irradiation following lumpectomy and to help an informed patient decide whether she prefers this therapy | Study design: Nonconcurrent cohort Blinding of outcome assessment: NR Baseline comparability: Characteristics of the groups were similar Followup: NR Duration of the study: Total duration of the study: 9 months Duration for an individual patient: 1 week | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment (adjuvant) Model of decisionmaking:; - Shared as stated by author; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: breast irradiation vs. none | Description: Control Group (CG) 1:; - usual care ^a^; Control Group (CG) 2:; - usual care ^a^; - physician uses checklist ^b^; Intervention Group (IG); - usual care ^a^; - decision board ^c^; - take home version of decision board; Purpose:; - increase knowledge; - help make a decision; Intervention administered by:; - physician or nurse; Timing of the intervention: at the point of decisionmaking | Number of subjects enrolled: 82 IG: 30; CG1: 23; CG2: 29 Eligibility criteria:; - Node-negative breast cancer; - Primary tumors < 5 cm; - Treated by a lumpectomy; Characteristics Age (IG vs. CG1 vs. CG2): > 50 years: 23 vs. 19 vs. 21 Education (IG vs. CG1 vs. CG2): > 12 yrs: 23 vs. 23 vs. 25; Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Knowledge; - Acceptability of DA; - Patient perception of involvement in care; - Reasons for making a choice; Outcomes measured:; - 1 week after the intervention

a Consultation with radiation oncologist

b The clinicians were given a checklist to use during the consultative process to ensure that there was consistency in the content of information presented. The checklist was based on the information provided in the decision board. The checklist contained a specific statement that breast irradiation has not been shown to influence survival.

c The Decision Board was composed of an introduction and scenarios: the introduction covered background information about the disease, prognosis, and the purpose of the Board. The scenarios described the treatment options of radiation therapy vs. none and the subsequent outcomes of recurrence of cancer in the breast or not for women with node-negative breast cancer treated by lumpectomy and axillary dissection. Probability wheels were used to describe the risk of recurrence of cancer with or without radiation therapy. Side effects of the therapy were described. (p. 848)

Studies of Effectiveness of Decision Aids: Nonconcurrent cohort design

Evidence Table 5.31b: Whelan (1995) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG's | Postintervention Results IG vs. CG1 vs. CG2 | Notes
Whelan, T 1995 RefMan ID: 068 | n = 82 Control Group 1 (CG1): n = 23; - usual care; Control Group 2 (CG2): n = 29; - Usual care; - Physician uses checklist; Intervention Group (IG): n = 30; - Usual care; - Decision board (DB); - Take-home version of decision board | Decision | | - Chose breast irradiation: 28/30 (93%) vs. 22/23 (96%) vs. 28/29 (97%)
Whelan, T 1995 RefMan ID: 068 | | Knowledge ^a^ | | - Percentage of correct answers: 82.7 vs. 75.3 vs. 76.0 * | *Patients who used decision board had increased understanding in 1/10 statements: breast irradiation could not be repeated to the same breast (p < 0.0001) (X ^2^ test)
Whelan, T 1995 RefMan ID: 068 | | Acceptability of DA | | - 27/27 (100%) reported that DB was easy to understand; - 22/27 (81%) thought that it helped them think of questions to ask; - 22/27 (67%) DB helped them explain to others her disease; - 25/27 (93%) would recommend DB to other patients
Whelan, T 1995 RefMan ID: 068 | | Patient perception of involvement in care | | Felt they were offered a choice:; - 29/30 (97%) vs. 16/23 (70%) vs. 20/29* (69%) **; - 48/52 (92%) of the CG's patients vs. 6 (20%) of IG reported that their clinician had recommended breast irradiation*** | ** (p = 0.02) (X ^2^ test) (p. 850) *** p < 0.0001
Whelan, T 1995 RefMan ID: 068 | | Other results ^b^ | | Mean score for each reason by group (IG vs. CG1 vs CG2):; - "Side effects are acceptable": 3.61 vs. 3.29 vs. 3.07*; - "Doctor recommended radiation": 3.04 vs. 3.29 vs. 3.07** | * higher value in Decision Board group, p = 0.0001 ** lower value in Decision Board group, p = 0.0006 (3-way comparison)

Outcomes measured 1 week after the intervention.

a Measured as patient comprehension with 10 true or false statements on basic information about breast irradiation. Percentages of correct responses were calculated from raw data presented in Table 3, p 850.

b With a 6-item questionnaire, patients' choices were assessed: each reason chosen was scored from 1 (not very important) to 5 (extremely important). A mean score was calculated for each reason by group.

Studies of Effectiveness of Decision Aids. Nonconcurrent cohort design

Evidence Table 5.32a. Whelan (1999) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Whelan T, 1999 Country: Canada RefMan ID: 153 Study purpose To evaluate the impact of a decision board to help clinicians inform patients about surgical therapy options in the clinical encounter | Study design: Nonconcurrent cohort Blinding of outcome assessment: Not used Followup: NR Baseline comparability:; - Characteristics of the groups were similar; Duration of the study: Total duration of the study: 18 months Duration for an individual patient: 2 weeks | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment (primary) Model of decisionmaking:; - Shared as stated by authors; - Not clear to the reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Mastectomy vs. lumpectomy + radiation | Description: Control Group (CG); - Usual care ^a^ Intervention Group (IG); - Usual care ^a^; - Decision board ^b^; - Take home version of decision board; Purpose:; - Increase knowledge; - Improve communication between clinician and patient; - Help make a decision; Intervention administered by: Physician Timing of the intervention: 57% of patients' decision was made during consultation, 32% a couple of days after consultation, and 11% before. | Number of subjects enrolled: 369; IG: 175; CG: 194 Eligibility criteria: Inclusion:; - Recently diagnosed stage I or II adenocarcinoma of the breast confirmed by cytology or pathologic examination; Exclusion:; - Medical contraindications of breast-conserving therapy; - Multicentric carcinoma; - Diffuse abnormal mammographic changes; - Serious comorbidity; - Not otherwise candidate for breast irradiation; - Inability to speak and read English fluently; Characteristics: Age (IG vs. CG): Mean: 56.2 vs. NR; SD: NR; Range: 33 to 80 vs. NR; > 60 years: 66 vs. 90 Education (IG vs. CG): >12 years: 123 vs. NR Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Knowledge; - Control preference; - Satisfaction; - Acceptability of DA; - Reasons for making a choice; Outcomes measured:; - 2 weeks after the intervention

a Consultation with surgeon

b The decision board was made of foam core 25 x 20 inches large. It had four subtitles: Treatment Choice, Side Effects, Results of Treatment Choice for the Breast, and Results of Treatment Choice for Survival. For each subtitle, there are two corresponding explanatory panels; one for mastectomy and one for lumpectomy plus radiation. A take-home version of the decision board was provided to each patient.

Studies of Effectiveness of Decision Aids. Nonconcurrent cohort design

Evidence Table 5.32b. Whelan (1999) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Whelan T, 1999 RefMan ID: 153 | n = 376 Control Group (CG) n = 194; - Usual care; Intervention Group (IG) n = 175; - Usual care; - Decision board (DB); - Take-home version of DB | Decision | | Chose lumpectomy + radiation: 127/175 (73%) vs. 170/194 (88%) * Intervention Group: 45/175 (26%) chose mastectomy, and 2/175 (1%) chose no surgical treatment and chose alternative therapies | * The authors reported that breast-conserving surgery was performed more commonly by the introduction of the DB; p = 0.001.
Whelan T, 1999 RefMan ID: 153 | n = 376 Control Group (CG) n = 194; - Usual care; Intervention Group (IG) n = 175; - Usual care; - Decision board (DB); - Take-home version of DB | Knowledge ^a^ | | Intervention Group: Mean: 11.8; SD NR; Range 6 to 14
Whelan T, 1999 RefMan ID: 153 | n = 376 Control Group (CG) n = 194; - Usual care; Intervention Group (IG) n = 175; - Usual care; - Decision board (DB); - Take-home version of DB | Control preference ^b^ | | Intervention Group:; - 90/175 (51%) preferred to make final choice; - 63/175 (36%) preferred to share decision with their doctor; - 20/175 (11%) preferred doctor to decide after considering patients opinion; - 2/175 (1%) preferred the doctor to decide
Whelan T, 1999 RefMan ID: 153 | n = 376 Control Group (CG) n = 194; - Usual care; Intervention Group (IG) n = 175; - Usual care; - Decision board (DB); - Take-home version of DB | Satisfaction | | Intervention Group:; - 169/175 (97%) were satisfied with the information; - 166/175 (95%) were satisfied with the decisonmaking process
Whelan T, 1999 RefMan ID: 153 | n = 376 Control Group (CG) n = 194; - Usual care; Intervention Group (IG) n = 175; - Usual care; - Decision board (DB); - Take-home version of DB | Acceptability of DA | | - 171/175 (98%) reported that DB was easy to understand; - 142/175 (81%) indicated the DB helped them to make a choice; - 109/175 (62%) helped them to think of questions to ask; - 171/175 (98%) recommended that DB should be used with other patients
Whelan T, 1999 RefMan ID: 153 | n = 376 Control Group (CG) n = 194; - Usual care; Intervention Group (IG) n = 175; - Usual care; - Decision board (DB); - Take-home version of DB | Other results ^c^

Outcomes measured 2 weeks after the intervention.

a Correct responses to 14 statements that covered various content areas with a true, false, or unsure statement.

b Patient preference for decisionmaking was assessed using a 6-point Likert scale, with 1 = "I prefer to make the final decision about which treatment I receive," 5 = "I prefer to leave all decisions regarding my treatment to my doctor," and 6 = "I am unsure."

c Reasons for patients' choice: The authors reported that, based on a multivariate analysis, the only factor that predicted for a patient's choice was the surgeon's recommendation for the type of surgery (p = 0.0001); however, the other factors included in the model were reported.

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.33a. Levine (1992) General Characteristics

Author | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Levine M, 1992 Country: Canada RefMan ID: 113 Study purpose: Helping the informed patient state her preference in a difficult situation | Study design: Case series Blinding of outcome assessment: not used Followup: NA Duration of the study: Total duration of the study: NR Duration for an individual patient: 2 weeks | Setting: Outpatient Type of cancer: Breast (stage 1) Type of decision: Treatment, adjuvant Model of decision making:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Adjuvant chemotherapy vs. none | Description:; - Decision board (DB) ^a^; - Take-home version of DB; - Counseling ^b^; Purpose:; - Facilitate information transfer between patient and clinician; - Make a decision/state a preference; - Increase knowledge; Intervention administered by:; - Experienced oncology nurse; Timing of the intervention:; - before the decision was made | Number of patients enrolled: 37 Eligibility criteria: Inclusion:; - Women with node-negative breast cancer; Characteristics: Age: Mean, 43.6 years; SD, NR; range 26 to 59 years Education: NR Ethnicity: NR SES: NR | Outcome measures:; - Decision; - Acceptability of the decision aid; - Decision aid facilitates question asking; - Decision aid helps patient explain treatment options to others; - Decision aid helps patient make a choice; Outcomes measured:; - 2 weeks after intervention

a A visual aid designed to present the information about treatment options, chance of outcome resulting from the treatment choice, and quality of life associated with choice in a standardized manner

b The patient's questions were answered both during presentation of the board by the nurse and afterward by the nurse and the physician.

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.33b. Levine (1992) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Levine M, 1992 RefMan ID: 113 | n = 37; - Decision board (DB); - Counseling; - Take-home version of DB | Decision | | - chose chemotherapy: 34/37 (92%); - chose not to have chemotherapy: 3/37 (8%)
Levine M, 1992 RefMan ID: 113 | n = 37; - Decision board (DB); - Counseling; - Take-home version of DB | Acceptability of decision aid | | - very easy or easy to understand: 29/30 (97%); - difficult to understand: 1/30 (3%)
Levine M, 1992 RefMan ID: 113 | n = 37; - Decision board (DB); - Counseling; - Take-home version of DB | Decision aid facilitates question asking | | - DB helped patient think of questions: 24/30 (80%); - DB did not help patient think of questions: 5/30 (17%); - No response: 1/30 (3%)
Levine M, 1992 RefMan ID: 113 | n = 37; - Decision board (DB); - Counseling; - Take-home version of DB | Decision aid helps patients explain treatment options to others | | Of the 24 patients who showed the take-home DB to someone:; - DB helped to explain options: 21/24 (88%); - DB did not help to explain options: 2/24 (8%); - No response: 1/24 (4%)
Levine M, 1992 RefMan ID: 113 | n = 37; - Decision board (DB); - Counseling; - Take-home version of DB | Would recommend decision aid to other patients | | - Would recommend DB: 29/30 (97%); - Would not recommend DB: 1/30 (3%)
Levine M, 1992 RefMan ID: 113 | n = 37; - Decision board (DB); - Counseling; - Take-home version of DB | Decision aid helps patients make a choice | | - DB definitely helped make decision: 15/30 (50%); - DB helped make decision: 11/30 (37%); - DB did not help: 4/30 (13%)

Outcomes were measured 2 weeks after intervention. Thirty of the 37 patients were asked to complete a questionnaire regarding the acceptability of the DB intervention.

Studies of Effectiveness of Decision Aids. RCT design

Evidence Table 5.34a. Lerman (1997) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Lerman C 1997, 1999 Country: USA RefMan ID: 121, 4293 Study purpose: To evaluate the impact of alternate strategies on decisionmaking for genetics | Study design: Randomized Controlled Trial Method of Randomization: NR Allocation concealment: NR Baseline comparability: NR Blinding of outcome assessment: Not used Dropouts/withdrawals: 80-100% of allocated subjects were followed to the end of the study. Duration of the study: Total duration: NR Duration for an individual patient: 1 month | Setting: Outpatient Type of cancer: Breast and ovary Type of decision: Screening/detection Model of decision making:; - Informed as stated by author and as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - To give blood sample for future BRCA1 testing | Description: Control Group (CG):; - No intervention Intervention Group (IG1):; - Educational session ^a^ : visual aids; - DA brochure ^b^ Intervention Group (IG2):; - Educational session oral/visual aids ^a^; - DA brochure ^b^; - Nondirective genetic counseling ^c^; Purpose:; - Increase knowledge; - Help to make a decision; Intervention administered by:; - Trained oncology nurses or a genetic counselor supervisor; Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 578 Completed: CG: 164; IG1: 114; IG2: 122 Eligibility criteria: Inclusion:; - Low to moderate risk for breast cancer; - 18-75 years of age; - Having at least one first-degree relative with breast or ovarian cancer; Exclusion:; - Personal history of cancer (except basal cell or squamous cell skin cancers); Characteristics: Age: > 50 years: IG1: 34 (27%), IG2: 30 (23%), CG: 50 (28%) Education: > 12 years; IG1: 107 (94%), IG2: 108 (88%), CG: 144 (88%) Ethnicity: Caucasian / African American IG1: 84 (74%) / 29 (25%), IG2: 92 (75%) / 28 (23%) CG: 107 (65%) / 49 (30 %) SES: < $35,000: IG1: 22 (19 %), IG2: 27 (22%), CG: 30 (18%) | Primary outcome measures:; - Decision; - Knowledge; - Evaluation of risk perception; - Perceived benefits of BRCA1 testing; - Perceived limitations and risks of BRCA1 testing; Outcomes measured:; - Before intervention (not clear); - 1 month after intervention

a A structured protocol that reviewed: (a) individual risk factors for breast and ovarian cancer; (b) patterns of inheritance of breast/ovarian cancer susceptibility; (c) benefits of BRCA1 testing; (d) limitations of BRCA1 testing; (e) risks of BRCA1 testing; (f) limitations of options for breast and ovarian cancer prevention and surveillance.

b Printed DA brochure covering the points (a) to (f) in 1.

c Nondirective counseling organized in a semistructured protocol. It addressed: (a) experience with cancer in the family; (b) anticipated impact of positive or negative BRCA1 test results; (c) anticipated outcomes of deciding not to be tested; (d) perceived coping resources and skills to adapt to different testing outcomes; and (e) intentions regarding communication of test results to family, friends, and others. (pp. 149, 150)

Studies of Effectiveness of Decision Aids. RCT design

Evidence Table 5.34b. Lerman (1997) Results

Author | Intervention | Outcome(s) | Baseline Results IG1 vs. IG2 vs. CG | Postintervention Results IG1 vs. IG2 vs. CG | Notes
Lerman C, 1997, 1999 RefMan ID: 121, 4293 | n = 578 Control Group (CG): n = 164 No intervention Intervention Group 1 (IG1): n = 114; - Educational session: oral/visual aids; - DA brochure; Intervention Group 2 (IG2): n = 122; - Educational session: oral/visual aids; - DA brochure; - Genetic counseling | Decision: genetic testing: Intention to be tested ^a^ | - Mean: 2.74; SD: 1.06 vs.; - Mean: 2.75; SD: 1.05 vs.; - Mean: 2.61; SD: 1.07 | - Mean: 2.73; SD: 1.12 vs.*; - mean: 2.77; SD: 1.07 vs.; - mean: 2.60; SD: 1.02 | * Among-group differences in changes from baseline to 1 month: repeated measures ANOVA: p = 0.97
Lerman C, 1997, 1999 RefMan ID: 121, 4293 | | Decision: genetic testing intention ^b^ | Authors report 55% of all participants wanted genetic testing | - 65/114; - 75/122; - 87/164 | Authors report no evidence for an intervention effect on the categorical measure (p. 152) (analysis used not clear)
Lerman C, 1997, 1999 RefMan ID: 121, 4293 | | Decision: provision of blood sample | | - IG1: 58/114 (51%); - IG2: 63/122 (52%) | Authors report that there were no statistically significant differences between groups
Lerman C, 1997, 1999 RefMan ID: 121, 4293 | | Knowledge ^c^ | - Mean: 5.90; SD: 2.17 vs.; - Mean: 5.84; SD: 2.12 vs.; - Mean: 5.93; SD: 2.01 | - Mean: 7.74; SD: 2.16 vs. **; - Mean: 7.58; SD: 2.09 vs.; - Mean: 5.39; SD: 2.39 | ** Analysis as above, p = 0.0001 (repeated measures ANOVA)
Lerman C, 1997, 1999 RefMan ID: 121, 4293 | | Evaluation of risk perception ^d^ | - Mean: 2.12; SD: 0.59 vs.; - Mean: 2.20; SD: 0.59 vs.; - Mean: 2.10; SD: 0.63 | - Mean: 1.88; SD: 0.57 vs.***; - Mean: 2.06; SD: 0.62 vs.; - Mean: 2.06; SD: 0.56 | ***Analysis as above, p = 0.04
Lerman C, 1997, 1999 RefMan ID: 121, 4293 | | Perceived benefits of BRCA1 testing ^e^ | - Mean: 17.92; SD: 2.80 vs.; - Mean: 17.63; SD: 2.95 vs.; - Mean: 17.65; SD: 3.03 | - Mean: 16.62; SD: 3.56 vs. ****; - Mean: 16.19; SD: 3.37 vs.; - Mean:16.93; SD: 3.29 | **** Analysis as above, p = 0.11
Lerman C, 1997, 1999 RefMan ID: 121, 4293 | | Perceived limitations and risks of BRCA1 testing ^e^ | - Mean: 9.41; SD: 2.62 vs.; - Mean: 9.20; SD: 2.43 vs.; - Mean: 9.46; SD: 2.46 | - Mean: 10.09; SD: 2.82 vs.*****; - Mean: 10.26; SD: 2.93 vs.; - Mean: 9.50; SD: 2.73 | ***** Analysis as above, p.004

Outcomes measured before and 1 month after intervention.

a One single Likert-style item: "At the present time, which of the following statements describes you best?" with 1 = I haven't thought about it to 4 = definitely will have genetic testing.

b Probably or definitely would have BRCA1 testing

c 11-item true-false scale: higher scores indicate higher number of correct answers.

d Perceived personal risk of mutation: one single Likert-style item: "In your opinion, how likely is it that you have an altered breast-ovarian cancer susceptibility gene?" with 1 = not at all likely to 4 = definitely.

e Seven-item questionnaire using 3-point Likert-style scale that rated the level of importance of each benefit with 1 = not at all important to 3 = very important (maximum score = 21).

Studies of Effectiveness of Decision Aids. RCT design

Evidence Table 5.35a. Davison (1997) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Davison B, 1997; Pasacreta JV, 1998 Country: Canada RefMan ID: 1423, 7072 Study Purpose: To decrease patient anxiety and depression | Study design: Randomized Controlled Trial Method of Randomization: Block Randomization procedure Allocation concealment: NR Baseline comparability: Characteristics among groups were similar Blinding of outcome assessment: Not used Followup: 80-100% of allocated subjects were followed to the end of the study Duration of the study: Total duration: NR Duration for an individual patient: 6 weeks | Setting: Outpatient Type of cancer: Prostate Type of decision: Treatment, primary Model of decisionmaking:; - Empowerment model as stated by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: Not clear | Description Control Group (CG):; - Information pamphlet ^a^; - Usual care ^b^; Intervention Group(IG): Similar to the CG plus; - Counseling ^c^; - Audiotape of consultation ^d^; - Question list ^e^; Purpose:; - Increase patient's involvement in decisionmaking; - Increase knowledge; - Enhance patient's autonomy; Intervention administered by: Nurse Timing of the intervention:; - before the initial consultation | Number of patients enrolled: 60; IG: 30; CG: 30 Eligibility criteria:; - Newly diagnosed prostate cancer patients; - Not having had their initial treatment consultation; - Able to read, speak, and write in English; - With no evidence of mental confusion; Characteristics: Age (IG vs. CG): Mean: 66.0 years; SD: 8.3; range: 41 to 80 years; vs. mean 69.8 years, SD: 5.0, range 53 to 81 years; >70 years: 9 (30%) vs. 11 (33%) Education (IG vs. CG): Non-high-school graduate 15 (50%) vs. 20 (66%) Ethnicity: NR SES: NR | Outcome measures:; - Control preference; - Anxiety; - Depression; - Acceptability of DA; Outcomes measured:; - before intervention; - 6 weeks after intervention

a Five pamphlets containing information about prostate cancer (disease process, treatment options with advantages and disadvantages of each, diagnostic tests, prostate specific antigen blood testing, etc)

b Initial treatment consultation with the physician

c The men were asked to think about the information needed to assist them in the decisionmaking process. The investigator showed them where they could find that information in the brochures and encouraged them to read the package. The men were also encouraged to participate in the decision about treatment and to bring their significant others to the consultation.

d The patients were offered a blank audiotape and given the opportunity to ask their physician to record the consultation.

e List of questions that the patients could ask their physician. This list was reviewed with the patients and additional questions arising from the counseling session were added.

Studies of Effectiveness of Decision Aids. RCT design

Evidence Table 5.35b. Davison (1997) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Davison B, 1997 Pasacreta JV, 1998 RefMan ID: 1423, 7072 | Control Group (CG) n = 30; - Information pamphlet; - Usual care; Intervention Group(IG) n = 30 Similar to the CG plus:; - Counseling; - Audiotape of consultation; - Question list | Control preference ^a^ | - Active role: 11/30 (37%) vs. 4/30 (13%) *; - Collaborative role: 11/30 (37%) vs.15/30 (50%)*; - Passive role: 8/30 (27%) vs. 11/30 (37%)* | - Active role: 17/30 (57%) vs. 5/30 (17%)**; - Collaborative role: 10/30 (33%) vs. 15/30 (50%); - Passive role: 3/30 (10%) vs. 10/30 (33%) | * At baseline, no significant differences were found between groups for role preferences (p = 0.11) (Chi-square test) ** A significant proportion of men in the IG assumed a more active role as compared with men in the CG p = 0.001 (Chi-square test)
Davison B, 1997 Pasacreta JV, 1998 RefMan ID: 1423, 7072 | Control Group (CG) n = 30; - Information pamphlet; - Usual care; Intervention Group(IG) n = 30 Similar to the CG plus:; - Counseling; - Audiotape of consultation; - Question list | Anxiety ^b^ | Not clear ** | Not clear ** | ** Raw data were not reported; the authors described the results using line graphs. They reported that IG men had lower anxiety scores (p < 0.005) (ANCOVA).
Davison B, 1997 Pasacreta JV, 1998 RefMan ID: 1423, 7072 | Control Group (CG) n = 30; - Information pamphlet; - Usual care; Intervention Group(IG) n = 30 Similar to the CG plus:; - Counseling; - Audiotape of consultation; - Question list | Depression ^c^ | Not clear ** | Not clear ** | ** Results described using line graphs; the authors reported that depression scores had NS differences between groups.
Davison B, 1997 Pasacreta JV, 1998 RefMan ID: 1423, 7072 | Control Group (CG) n = 30; - Information pamphlet; - Usual care; Intervention Group(IG) n = 30 Similar to the CG plus:; - Counseling; - Audiotape of consultation; - Question list | Acceptability of DA | | - 22/26 listened to their audiotape.; - 11/22 used the tape to review the information.; - 2/22 reported that the tape assisted them in treatment decisionmaking.; - "Majority of men reported the question list helpful in formulating questions to ask." *** 22 men ranked the information interventions: audiotape was the most useful, brochure second, and question list third. | *** Raw data were not reported.

Outcomes measured before intervention and 6 weeks after intervention.

a Control Preference Scale (CPS): five statements ranging from: "I prefer to make the final decision" to "I prefer my doctor to make the final decision" were collapsed by the authors into three categories: active, collaborative, and passive role. Preferred roles were measured at baseline and the assumed roles were measured postintervention.

b "Anxiety was measured by the Spielberger State-Trait Anxiety Inventory (STAI), which is a short self-report measure of both state and trait anxiety. This inventory had two scales of 20 statements each, one asking subjects to indicate 'how they felt at the moment' and the other 'how they usually feel.'" (p. 189)

c "Depression was measured by the Center for Epidemiologic Studies Depression Scale (CES-D), which is a "short self-report scale consisting of 20 items." (p. 189).

Studies of Effectiveness of Decision Aids. Nonrandomized controlled trial

Evidence Table 5.36a. Sepucha (2000) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Sepucha K, 2000 Country: USA RefMan ID: 3624 Study purpose: To improve the quality of medical consultation between physicians and breast cancer patients | Study design: Controlled trial (quasi-experiment) Baseline comparability: Characteristics among groups were similar Blinding of outcome assessment: Not used Followup: NR Duration of the study: Total duration of the study: 6 months Duration for an individual patient: NR | Setting: Outpatient Type of cancer: Breast Type of decision: Treatment (not clear) Model of decisionmaking:; - Shared as stated by authors and as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; - Making the decision; Context of decision: Not clear | Description: Control Group (CG):; - Usual care ^a^; - Pre-consultation planning ^b^; - Consultation observation ^c^; Intervention Group (IG); - Usual care ^a^; - Consultation planning ^b^; - Consultation recording ^d^; Purpose:; - Improve communication between clinicians and patients; - Increase patient involvement in decisionmaking; - Increase satisfaction with the consultation; Intervention administered by: Investigator trained in consultation recording methods Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 24 IG: 12; CG: 12 Eligibility criteria:; - Diagnosis of breast cancer (or ductal carcinoma in situ); - Fluency in written and spoken English; Characteristics: Age: Mean (years) IG: 47; SD: 6.9 CG: 48; SD: 6.7 Education:; - At least some college: IG: 11 (92%); CG: 12 (100%); Ethnicity:; - Caucasian: IG:10 (83%) CG:11 (92%); SES: NR | Outcome measures:; - Quality of the decision; - Satisfaction with consultation; Outcomes measured:; - Before (same day); - After the intervention (not clear)

a Consultation with the oncologist

b 30-minute preconsultation planning session. A researcher created a flow chart of the patients' specific questions and concerns; the authors reported that this method would help breast cancer patients prepare for their medical visit.

c The authors reported that they designed the control condition to provide a comparison; a researcher observed the consultation but did not participate unless asked to by the patient or physician.

d The intervention is divided into five phases: contracting, agenda, mapping, commitments, and debriefing. In the first phase, the patient and the clinician discuss how they would like to share the decisionmaking responsibility; in the second phase, they set an agenda; in the mapping phase, the researcher facilitated the progress through the agenda, took note of the main points, and encouraged the patient to ask questions; in the fourth phase, the researcher helped the clinician and the patient to make commitments and finally the researcher, the clinician, and the patient reviewed the summary of the consultation.

Studies of Effectiveness of Decision Aids. Nonrandomized controlled trial

Evidence Table 5.36b. Sepucha (2000) Results

Author | Intervention | Outcome(s) | Baseline Results IG vs. CG | Postintervention Results IG vs. CG | Notes
Sepucha K, 2000 RefMan ID: 3624 | n = 24 Control Group (CG) n = 12:; - Usual care; - Preconsultation planning; - Consultation observation; Intervention Group (IG) n = 12:; - Usual care; - Consultation planning; - Consultation recording | Patient decision quality ^a^ | | - Median: 13.0; SD: NR vs. 9.5; SD: NR*; - Mean change, Patient Decision Scale (3 - 2): 9.7 vs. 6.6** | *Patient Decision Scale 3 was statistically different for IG vs. CG: p = 0.008 ** (p = 0.057) (Wilcoxon rank sum test, one-tailed for both analysis) (p. 1234)
Sepucha K, 2000 RefMan ID: 3624 | | Satisfaction with consultation ^b^ | | - Median: 11.0; SD: NR vs. 7.0; SD: NR***; - 75% of the patients in the IG scored 10 or higher, and less than 17% in the CG scored 10 or higher | ***p = 0.073 (same analysis as above)

Outcomes measured before (same day) and after the intervention (not clear).

a Decision Quality Scale: 10-item Likert scale with scores ranging from -20 to 20. Higher scores indicate higher decision quality. Patients completed it three times: before any intervention (Patient Decision Scale 1), after the consultation planning session (Patient Decision Scale 2), and after the consultation (Patient Decision Scale 3).

b Satisfaction with consultation (SWC) Scale completed by both patients and doctors after the consultation. 7-item Likert scale; higher scores indicate higher satisfaction.

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.37a. Stalmeier (1999) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Stalmeier P, 1999; Unic, I, 2000 Country: Netherlands RefMan ID: 127, companion 7388 Study purpose: To support women at high risk for breast cancer in the choice between screening and prophylactic mastectomy | Study design: Case series Blinding of outcome assessment: Not used Followup: 80-100% of the subjects were followed at the end of the study Duration of the study: Total duration of the study: 2 years Duration for one patient: Not clear | Setting: Outpatient Type of cancer: Breast Type of decision: Prevention Model of decisionmaking:; - Shared as stated by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Prophylactic mastectomy (PM) vs. breast cancer screening (BCS) | Description:; - Counseling ^a^; - Information videotape ^b^; - Information pamphlet ^c^; - Multiple utility assessments ^d^; Purpose:; - To help make a decision; Intervention administered by: Researcher Timing of the intervention: Before the decision was made | Number of subjects enrolled: 54 Eligibility criteria: Inclusion:; - Healthy women with a strong family history of breast cancer who were referred for genetic counseling and testing; Exclusion:; - Previous cancer diagnosis; Characteristics: Age: Mean 38 years; SD: 11.0 Education: < 12 years: 7 > 12 yrs: 50 Ethnicity: NR SES: NR | Primary outcome measures:; - Decision; - Knowledge; - Decision burden; - Decision uncertainty; - Satisfaction with decision aid; Outcomes measured:; - before and after the intervention

a "Participants were encouraged to ask questions and to discuss relevant topics." (p. 232)

b Thirty-two-minute videotape called "Breast Cancer in the Family." The women were expected to view the video at home. In the video, high risk women and their partners, sisters, and daughters talked about physical and psychosocial aspects of prophylactic surgery and breast cancer screening. [RefMan ID 127]

c A brochure that gave general information about breast cancer, risk factors for the disease, genetic testing, breast cancer screening, prophylactic mastectomy, and breast reconstruction possibilities [RefMan ID 127]

d "The utility test assessed attitudes towards prophylactic mastectomy (PM) and breast cancer screening (BCS). The authors used the time-tradeoff method to arrive at the number of years with PM that was subjectively equal to a smaller number of years with BCS." (p. 232) [RefMan ID 127]

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.37b. Stalmeier (1999) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Stalmeier P, 1999; Unic I, 2000 RefMan ID: 127, 7388 | n=54 Counseling (individual) Information videotape and pamphlet Multiple utility assessments | Decision uncertainty ^a^ (n=51) | Mean: 2.13; SD 1.37 | Mean: 1.70; SD: 0.9 | Pre/post comparison (p < 0.05)
Stalmeier P, 1999; Unic I, 2000 RefMan ID: 127, 7388 | n=54 Counseling (individual) Information videotape and pamphlet Multiple utility assessments | Decision burden ^b^ (n=51) | Mean: 5.61; SD: 2.87 | Mean: 4.80; SD: 2.12 | Pre/post comparison (p < 0.01)
Stalmeier P, 1999; Unic I, 2000 RefMan ID: 127, 7388 | n=54 Counseling (individual) Information videotape and pamphlet Multiple utility assessments | Knowledge (n=51) | Subjective knowledge of:; - Prophylactic mastectomy(PM) ^c^ : mean: 5.21; SD:1.94; - Breast cancer screening (BCS) ^c^ : mean: 7.12; SD: 1.47 | - subjective knowledge of PM ^c^ : Mean: 7.37; SD: 1.17; - subjective knowledge of BCS ^c^ : Mean: 7.78; SD: 1.06 | PM: pre/post comparison (p < 0.001) BCS: prepost comparison (p < 0.01)
Stalmeier P, 1999; Unic I, 2000 RefMan ID: 127, 7388 | n=54 Counseling (individual) Information videotape and pamphlet Multiple utility assessments | Decision (n=48) | | - Chose PM after finding positive carrier status: 8/12 (66%); - Chose BCS after finding positive carrier status: 4/12 (33%); - Patient choice treatment agreed with decision analytic recommendation: 12/12 (100%) Of the 36 women awaiting testing results:; - Chose hypothetically PM: 21/36 (58%) ^d^; - Chose hypothetically breast screening: 11/36 (30%); - Could not decide between options in a hypothetical situation: 2/36 (6%); - Would not provide a hypothetical choice 2/36 (6%); - Three women found not to be carriers were not asked
Stalmeier P, 1999; Unic I, 2000 RefMan ID: 127, 7388 | n=54 Counseling (individual) Information videotape and pamphlet Multiple utility assessments | Satisfaction with DA (n=49) | | mean: 74; SD: 11 | Mean rescaled from 0 to 100
Stalmeier P, 1999; Unic I, 2000 RefMan ID: 127, 7388 | n=54 Counseling (individual) Information videotape and pamphlet Multiple utility assessments | Other results ^e^

a Higher score indicates higher uncertainty.

b Higher score reflects greater decision burden.

c Scale: 1 = very bad; 10 = excellent

d Married women (p = 0.006) and those with children (p = 0.02) were more likely to choose PM (analysis combined data for both real and hypothetical choices). Refer to paper for other results.

e Other results, including risk perception and aspects of satisfaction with DA intervention, were also assessed; refer to paper for details.

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.38a. Wolberg (1987) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Wolberg W, 1987; Ward S, 1989; Wolberg W, 1989; Wolberg W, 1991 Country: USA RefMan ID: 4157, 3661, 7532, 3299 Study purpose: To explain available treatment options | Study design: Case series Blinding of outcome assessment: Not used Followup: Not applicable (NA) Duration of the study: Total duration of the study: 10 years Duration for an individual patient: NR | Setting: Outpatient Type of cancer: Breast, nonmetastatic Type of decision: Treatment (primary) Model of decisionmaking:; - Not reported by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision:; - Mastectomy vs. breast conservation plus radiotherapy | Description:; - Usual care ^a^; - Slide-tape presentation ^b^; - Counseling ^c^; - Bottom line sheet ^d^; Purpose:; - Increase knowledge; - Help make a decision; Intervention administered by: NR Timing of the intervention:; - before the decision was made | Number of subjects enrolled: 250 Eligibility criteria: Inclusion:; - 250 consecutive women with nonmetastatic breast cancer who were eligible for breast conservation (refer to paper for details); Characteristics: Age: NR Education: NR Ethnicity: NR SES: NR Religion: NR | Outcome measures:; - Decision; - Anxiety; - Depression; - Determinants of patients' choice; - Sexual adjustment; Outcomes measured:; - before and after the intervention (not clear);; - Anxiety, depression, and sexual adjustment were measured before surgery only.

a "The surgeon describes each procedure in terms of risks, benefits, and expected outcome." (ID 3661; p. 346)

b "An educational slide-tape presentation, jointly developed by personnel in radiotherapy, surgical oncology, and medical oncology, explained available options to patients." (Ref Man ID4157; p. 69)

c Clinic staff answered patient's questions and discussed problems but did not recommend either treatment option.

d Handout described in Table 1. (ID 3661, p. 346)

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.38b. Wolberg (1987) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Wolberg W, 1987 Ward S, 1989; Wolberg W, 1989; Wolberg W, 1991 RefMan ID: 4157, 3661, 7532, 3299 | N = 250 Counseling Slide-tape presentation Bottom-line sheet Usual care | Decision (n=250) | | - chose breast conservation: 122/250 (48%); - chose mastectomy: 128/250 (51%); - breast conservation accomplished: 100/122* (82%) | *The expressed desire of women eligible for breast conservation correlated with age. < 35 years (yrs) - 64%; 35-44 yrs - 74%; 45-54 yrs - 60%; 55 -64 yrs - 35%; > 64 yrs - 30% (p = 0.006)
Wolberg W, 1987 Ward S, 1989; Wolberg W, 1989; Wolberg W, 1991 RefMan ID: 4157, 3661, 7532, 3299 | N = 250 Counseling Slide-tape presentation Bottom-line sheet Usual care | Anxiety ^a^ (n=39) | - Decided to have lumpectomy: mean=16.36, SD=8.43; - Chose mastectomy: mean=24.59, SD=9.81 | | - Significantly greater anxiety at baseline in the group of women who chose mastectomy compared to women who decided on lumpectomy (p<0.01)
Wolberg W, 1987 Ward S, 1989; Wolberg W, 1989; Wolberg W, 1991 RefMan ID: 4157, 3661, 7532, 3299 | N = 250 Counseling Slide-tape presentation Bottom-line sheet Usual care | Depression ^a^ (n=39) | - Decided to have lumpectomy: mean=16.86, SD=13.01; - Chose mastectomy: mean=26.76, SD=16.76 | | - At baseline, women who chose mastectomy felt more depressed compared to women who decided on lumpectomy (p<0.05)
Wolberg W, 1987 Ward S, 1989; Wolberg W, 1989; Wolberg W, 1991 RefMan ID: 4157, 3661, 7532, 3299 | N = 250 Counseling Slide-tape presentation Bottom-line sheet Usual care | Other results ^b^

a Anxiety-depression: measured with the Profile of Mood State (POMS). This is a rating scale designed to measure six transient moods: tension-anxiety, depression-dejection, anger-hostility, vigor-activity, fatigue-inertia, and confusion-bewilderment. Subjects are presented with 65 adjectives describing their mood in the past week, which they rate using a 5-point scale.

b Reasons for patients' choice of treatment: Total subsample = 22: mastectomy n = 11, conservation n = 11. In the mastectomy group, 7/11 had concern about radiotherapy side effects; 9/11 concern about radiotherapy efficacy (p = 0.003). In the conservation group, 9/11 had concern about body integrity (p = 0.04). For all participants, the three most important factors were a second surgery in the future, fear of cancer recurrence, and physician preference. Reasons among the conservation group were different than the mastectomy group: concern about losing breast (p = 0.04), breast reconstruction (p = 0.02), and survival rates were equal for the two types of surgery (p = 0.001).

Sources of information about cancer: This outcome was measured with the Breast Cancer Information Test (BCIT), an ad hoc 17-true-false-item questionnaire that provided a measure of patient knowledge about breast cancer. Across all participants, people sources of information were considered more important than were other sources (p = 0.003).

Sexual adjustment: measured with the Derogatis Sexual Function Inventory (DSFI), a series of true-false and multiple choice questionnaires that discriminate between patients with and without sexual dysfunction and between patients with psychogenic and organic impotence. Women who chose mastectomy demonstrated more sexual relationship problems (p < 0.05).

Satisfaction: 77% (N = 17) of the participants strongly agreed that they had adequate time to make a decision. 68% (N = 15) strongly agreed that they had enough information on which to base their decision. 27% (N = 6) somewhat agreed that they had enough information on which to base their decision. 64% (N = 14) strongly disagreed about being so distressed at the time of the decision that they had difficulty thinking.

Psychosexual adaptation as measured by POMS psychosocial adjustment to illness scale (PAIS), DSFI, Million Clinical Multiaxial Inventory (MCMI); comparisons are made in three groups: benign biopsy (72 subjects), breast cancer treated with mastectomy (78 subjects), breast cancer treated with conservation surgery (41 subjects). Data are not presented in a way that let us know which of these three groups actually gave the option between mastectomy or conservation surgery.

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.39a. Brundage (2000) General Characteristics

Author/Study purpose | Design/Quality indicators | Clinical situation | Intervention | Sample | Outcomes
Brundage M, 2000 Country: Canada RefMan ID: 3597 Study purpose: To determine if using a decision aid (DA) helps patients to understand information and to clarify their values relevant to the decision | Study design: case series Blinding of outcome assessment: not used Followup: NR Duration of the study: Total duration of the study: 2 years Duration for an individual patient: NR | Setting: Outpatient Type of cancer:; - Locally advanced small-cell lung cancer; Type of decision:; - Treatment (advanced); Model of decisionmaking:; - NR by authors; - Informed as determined by reviewers; Phase of decision:; - Information transfer; - Deliberation; Context of decision: radiotherapy (RT) vs. combined modality treatment (CMT) | Description:; - Counseling ^a^; - Decision board (DB) ^b^; - Treatment tradeoff exercises ^c^; - DA brochure ^d^; Purpose:; - To help the patient make a decision; Intervention administered by:; - Research associate; Timing of the intervention:; - After the initial consultation but before a second consultation when the treatment decision was made | Number of subjects enrolled: 18 Eligibility criteria: Inclusion:; - Locally advanced, unresectable non-small-cell lung cancer; - Candidate for RT and CMT; Exclusion:; - Insufficient fluency in English; - Diagnosis of major affective disorder; - High risk for severe emotional distress or any condition that limited the patient ability to understand the content of the interview; Characteristics: Age: Mean: 68.2 years; SD: 8.0 Education: < 12 yrs: 11; >12 yrs: 7 Ethnicity: NR SES: NR | Primary outcome measures:; - Patients decision control preference; - Decision; - Knowledge; - Change in strength of treatment preference; - DA helps patients make a choice; - Decisional uncertainty; - Would recommend to others; Outcomes measured:; - before and after the intervention (timing not specified)

a A research associate described the two treatment options following a structured format: each treatment was divided into seven components: details of the treatment regimen; early and late side effects; possible effects of the treatment on personal functioning, emotional state, and social interactions; and cancer symptoms. The patient was allowed to ask questions to clarify issues during the interview.

b Each component described by the research associate was printed on a card that was read and placed on a display board in front of the patient.

c Two treatment tradeoff exercises with the following objectives: (1) Determine the absolute increase in 3-year survival probability that the subject would want before choosing CMT and (2) Determine the increase in median survival time that the subject would want before choosing CMT.

d Take-home DA brochure containing treatment description with survival probabilities.

Studies of Effectiveness of Decision Aids. Case series design

Evidence Table 5.39b. Brundage (2000) Results

Author | Intervention | Outcome(s) | Baseline Results | Postintervention Results | Notes
Brundage M, 2000 RefMan ID: 3597 | n = 18 Counseling Decision board Treatment trade-off exercises DA brochure | Control preference ^a^ | - Active role preferred: 7/18 (39%); - Collaborative role preferred: 8/18 (44%); - Passive role preferred: 3/18 (17%)
Brundage M, 2000 RefMan ID: 3597 | n = 18 Counseling Decision board Treatment trade-off exercises DA brochure | Decision | - Preferred combined modality treatment (CMT): 13/18 (72%); - No treatment preferred: 3/18 (17%); - Preferred radiotherapy (RT): 2/18 (11%) | - Chose CMT: 16/18 (89%); - Chose RT: 2/18 (11%)
Brundage M, 2000 RefMan ID: 3597 | n = 18 Counseling Decision board Treatment trade-off exercises DA brochure | Knowledge ^b^ | - Correct response: direction of survival difference between treatments: 7/13; - Correct response: magnitude of survival difference between treatments: 0/13 | - Correct response: direction of survival difference between treatments: 11/13; - Correct response: magnitude of survival difference between treatments: 10/13
Brundage M, 2000 RefMan ID: 3597 | n = 18 Counseling Decision board Treatment trade-off exercises DA brochure | Change in strength of treatment preference | | - Patient with no preference pre-intervention chose CMT after: 3/3; - Patient strength of treatment preference did not change post-DA: 10/15; - Patient strength of treatment preference increased post-DA: 5/15
Brundage M, 2000 RefMan ID: 3597 | n = 18 Counseling Decision board Treatment trade-off exercises DA brochure | DA helps patients make a choice ^c^ | | - Strongly agreed/agreed DA was useful in making decision: 13/13
Brundage M, 2000 RefMan ID: 3597 | n = 18 Counseling Decision board Treatment trade-off exercises DA brochure | Decision Uncertainty ^d^ | | | Measured pre- and post-DA; data not presented. Reported 12/13 had lower scores post-DA and 1/13 had a higher score.
Brundage M, 2000 RefMan ID: 3597 | n = 18 Counseling Decision board Treatment trade-off exercises DA brochure | Would recommend to other patients | | - 13/13 (100%) would recommend DA

Outcomes were measured before and after the intervention (timing not clear).

a Five statements from (1) "I prefer to make the final selection of which treatment I will receive" to "I prefer to leave all decisions regarding my treatment to my doctor."

b Four questions of the format, "Out of 100 people treated with radiotherapy alone, how many will be alive after 3 years?"

c The subjects indicated the strength of their treatment on a 7-point Likert scale.

d Measured with Decisional Conflict Scale. Particular attention was given to the decisional uncertainty subscale: 1 = low uncertainty, 5 = high uncertainty. Lower scores reflect lower decisional conflict.