# Bibliography

J Clin Oncol 1996 May 14(5):1730 6 8622094
Consultant 1997 37(8):2189 98
Eur J Surg Oncol 1997 23(Suppl. A):54 62 9066748
Aabakken L, Baasland I, Lygren I, et al Development and evaluation of written patient information for endoscopic procedures Endoscopy 1997 29(1):23 6 9083732
Aaronson NK, Visser-Pol E, Leenhouts GH, et al Telephone-based nursing intervention improves the effectiveness of the informed consent process in cancer clinical trials J Clin Oncol 1996 Mar 14(3):984 96 8622050
Abbott RR, Taylor DK, Barber K A comparison of prostate knowledge of African-American and Caucasian men: Changes from prescreening baseline to postintervention Cancer J Sci Am 1998 4(3):175 7 9612599
Abner J, Poole M Development of two booklets for cancer patients Oncol Nurs Forum 1982 9(3):58 61 6921795
Abramsky L, Rodeck CH Women's choices for fetal chromosome analysis Prenatal Diagnosis 1991 Jan 11(1):23 8 2027851
Adams M Information and education across the phases of cancer care Sem Oncol Nurs 1991 May 7(2):105 11
Adler K Research in brief. Chemotherapy: the patient's choice Eur J Oncol Nurs 1999 Jun 3(2):102 4
Adolfsson J Treatment of localized prostatic cancer -- different alternatives. Patients with localized prostatic cancer must actively participate in the choice of therapy Lakartidningen 2000 Sep 6 97(36):3870 4 11036336
Agre P Interactive computer technology Cancer Pract 1994 Jan 2(1):74 6 8055010
Agre P, Kurtz RC, Krauss BJ A randomized trial using videotape to present consent information for colonoscopy Gastrointest Endosc 1994 May 40(3):271 6 8056226
Ah-Fat F, Sharma MC, Damato BE Taping outpatient consultations: a survey of attitudes and responses of adult patients with ocular malignancy Eye 1998 12(5):789 91 10070510
Ahronheim JC, Davol SB Pursuit of assisted dying: a pilot study of inquiries made to a national consumer-based organization J Pain Symptom Manage 1999 18(6):401 5 10641465
Aiken LS, West SG, Woodward CK, et al Increasing screening mammography in asymptomatic women: evaluation of a second-generation, theory-based program Health Psychol 1994 Nov 13(6):526 38 7889908
Aktan-Collan K, Mecklin JP, Jarvinen H, et al Predictive genetic testing for hereditary non-polyposis colorectal cancer: uptake and long-term satisfaction Int J Cancer 2000 Jan 20 89(1):44 50
Albertsen P A 72-year-old man with localized prostate cancer JAMA 1995 Jul 5 274(1):69 74 7791261
Alby N Psychology neglected in genetic testing for cancer Eur J Cancer 1998 34(8):
Alcoe SY, Gilbey VJ, McDermot RS, et al The effects of teaching breast self-examination: reported confidence and frequency of practise over a six-year period Patient Educ Couns 1994 Apr 23(1):13 21 7971536
Alcoe SY, Gilbey VJ, McDermot RS, et al The practise of breast self-examination over a six-year period following teaching Patient Educ Couns 1995 May 25(2):183 96 7659631
Alderman C Breast cancer: a woman's right to choose Nurs Times 1986 Oct 15 82(42):18 9 3641202
Alexander T One man's tough choices on prostate cancer Fortune 1993 128(6):86 92 10129683
Ali NS Providing culturally sensitive care to Egyptians with cancer Cancer Practice: a Multidisciplinary Journal of Cancer Care 1996 Jul 4(4):212 5
Andersen MR, Urban N Involvement in decision-making and breast cancer survivor quality of life Ann Behav Med 1999 21(3):201 9 10626025
Andersen MR, Urban N, Etzioni R Community attitudes and mammography use: does it really matter what other people think? Women Health 1999 29(3):83 95 10466512
Anderson AL Variables discriminating uninsured and underinsured mammography acceptors from mammography decliners Dissertation Abstracts International: Section B: The Sciences and Engineering 1997 57(7-B):
Anderson JL Evaluation of a practical approach to teaching about communication with terminal cancer patients Med Educ 1982 Jul 16(4):202 7 7121336
Anderson SG Psychological aspects of breast reconstruction at the time of mastectomy: Predictors of choice and post-surgical outcomes Dissertation Abstracts International 1992 53(6-B):
Andrew C Treatment information and the radiotherapy patient Radiography Today 1991 Sep 57(652):25 9 1755956
Andrews GR Self-instructional material for management of cancer chemotherapy patients Nurs J India 1997 Aug 88(8):179 80
Andrist LC A model of women-centered practice: Shared decision-making between breast cancer surgeons and patients Dissertation Abstracts International 1993 54(4-A):
Annas GJ Breast cancer: the treatment of choice Hastings Cent Rep 1980 Apr 10(2):27 9 7372466
Annunziata MA. Ethics of relationship. From communication to conversation. Ann N Y Acad Sci. 1997 Feb 20;809:400-10. [pmid: 9103591].
Anonymous To treat or not to treat -- the dilemma Heart Lung 1978 May 7(3):499 504 246863
Anonymous. Truth telling in pediatrics. Case for discussion. Prog Clin Biol Res. 1983;139:171-2. [pmid: 6583709].
Anonymous Informed consent: ethical, legal, and medical implications for doctors and patients who participate in randomised clinical trials Br Med J (Clin Res Ed) 1983 Apr 2 . 286(6371):1117 21
Anonymous Useful guidelines: when children have cancer Sykepleien 1984 Jun 20 71(11):21 3
Anonymous Case conference. A father says, "Don't tell my son the truth." J Med Ethics 1985 Sep 11(3):153 8 4057221
Anonymous What doctors tell patients with breast cancer about diagnosis and treatment: findings from a study in general hospitals. GIVIO (Interdisciplinary Group for Cancer Care Evaluation) Italy Br J Cancer 1986 Aug 54(2):319 26 3741767
Anonymous The care of the dying: a symposium on the case of Betty Wright Law Med Health Care 1989 17(3):207 33 2811461
Anonymous Gender disparities in clinical decision making. Council on Ethical and Judicial Affairs, American Medical Association JAMA 1991 Jul 24 266(4):559 62
Anonymous Patient choice in managing cancer Drug Ther Bull 1993 Sep 27 31(20):77 9
Anonymous Patient education for screening mammography: the unmet need Rhode Island Med 1993 Jul 76(7):366 7
Anonymous Patient choice in management. Drug and Therapeutics Bulletin, Consumers' Association, London, UK Eur J Cancer Care (Engl) 1994 Jun 3(2):87 90 7711974
Anonymous Bridging research to action: a framework and decision-making process for cancer control. Advisory Committee on Cancer Control, National Cancer Institute of Canada Can Med Assoc J 1994 Oct 15 151(8):1141 6
Anonymous Genetic testing for cancer risk: research projects being funded Oncology (Huntingt) 1994 Dec 8(12):16 8 419372
Anonymous Clinical information: prostate cancer patient involvement key to better prostate care New Mexico Nurse 1995 40(4):
Anonymous Researchers confirm the importance of involving patients in BPH treatment decisions and discuss coverage of PSA testing Res Activities 1995 Nov(189):1 2
Anonymous Quality-of-life issues complicate decisions about prostate cancer screening Res Activities 1995(189):
Anonymous Software aids breast cancer patient decisions Patient Educ Manage 1995 Feb 2(2):27 9
Anonymous Educating patients about prostate screening and treatment influences their medical decisions Res Activities 1996 Nov(198):7 8
Anonymous National Institutes of Health Consensus Development Conference Statement: Breast Cancer Screening for Women Ages 40-49, January 21-23, 1997. National Institutes of Health Consensus Development Panel J Natl Cancer Inst 1997 Jul 16 89(14):1015 26
Anonymous. Facts on prostate cancer in African Americans. Am Cancer Soc. 1997:1-16.
Anonymous. NIH consensus statement. Volume 15, number 1 January 21-23, 1997: breast cancer screening for women ages 40-49.United States Department of Health & Human Services Publications 1997; Jan (35p).
Anonymous Patient education influences medical decisions... adapted from the Agency for Health Care Policy and Research's Research Activities, Vol. 198, November 1996 Concern 1997 Apr 26(2):
Anonymous Primary decisions: counseling patients with early-stage prostate cancer Emerg Med 1997 Feb 29(2):85 6
Anonymous Program finds a better way to manage breast cancer Healthc Demand Dis Mange 1998 4(12):186 8
Anonymous Move forward with prostate Ca education despite lack of consensus over screening Healthc Demand Dis Mange 1998 4(6):93 4
Anonymous Concerned? Possibilities of treatment in cancer Ask your doctor...Krankenpfl J 1998 Nov 36(11):424 7
Anonymous New web site to help with mammography decision-making Healthfacts 1998 Feb 23(2):
Anonymous Doctor-patient relationships in primary care. Doctor, help: My child has cancer BMJ 1999 Aug 28 319(7209):554 6
Anonymous From the Centers for Disease Control and Prevention. Patients' reports of counseling on mammography screening by health-care providers -- North Carolina, 1997 JAMA 1999 Jul 14 282(2):124 5
Anonymous Patients should be involved in prostate cancer screening decisions Res Activities 1999 Dec(232):
Anonymous To better understand radiotherapy: an information booklet. The French Society for Radiotherapy and Oncology and The National Syndicate of Radiotherapy Oncologists Cancer Radiother 2000 Jul 4(4):285 93 10994393
Ansell D, Lacey L, Whitman S, et al A nurse-delivered intervention to reduce barriers to breast and cervical cancer screening in Chicago inner city clinics Public Health Rep 1994 Jan 109(1):104 11 8303003 1402249
Antick JR Factors related to pretreatment preferences in women at risk for breast cancer Dissertation Abstracts International: Section B: The Sciences and Engineering 1996 57(1-B):
Arbit E, Wronski M Clinical decision making in brain metastases Neurosurg Clin North Am 1996 7(3):447 57
Arksey H, Sloper P Disputed diagnoses: the cases of RSI and childhood cancer Soc Sci Med 1999 Aug 49(4):483 97 10414808
Asai A Should physicians tell patients the truth? West J Med 1995 163(1):36 9 7667981 1302914
Asai A, Kishino M, Fukui T, et al Choices of Japanese Patients in the Face of Disagreement Bioethics 1998 12(2):162 72 11655331
Ash CR Nursing issues in managing skin cancer in the year 2000 Cancer Control 1998 5(3 Suppl.):42 3 10762483
Ashbury FD, Findlay H, Reynolds B, et al A Canadian survey of cancer patients' experiences: are their needs being met? J Pain Symptom Manage 1998 Nov 16(5):298 306 9846024
Ashcroft JJ, Leinster SJ, Slade PD. Psychosocial issues in malignant disease; mastectomy versus breast conservation. Psychological effects on patients' choice of treatment. BPOS Proceedings. 1984:7-8.
Ashcroft JJ, Leinster SJ, Slade PD Breast cancer patient choice of treatment: preliminary communication J R Soc Med 1985 Jan 78(1):43 6
Ashing-Giwa K, Ganz PA Understanding the breast cancer experience of African-American women J Psychosoc Oncol 1997 15(2):19 35
Askins M Educating children with cancer: Prevention, learning, and guidance programs Int J Pediatr Hematol Oncol 1998 5(1):
Asselain B, Gremy F Qualitative criteria in therapeutic evaluation and decision-making in oncology Bull Cancer 1980 67(5):501 6 7214043
Atman CJ, Bostrom A, Fischhoff B, et al Designing risk communications: completing and correcting mental models of hazardous processes, Part I Risk Anal 1994 Oct 14(5):779 88 7800862
Aucoin-Gallant G The learning needs of the cancer patient: a conceptual analysis Can Oncol Nurs J 1996 Feb 6(1):14 7 9157893
Audisio RA, Filiberti A, Geraghty JG, et al Personalized surgery for rectal tumours: the patient's opinion counts Support Care Cancer 1997 Jan 5(1):17 21 9010985
Audrain J, Rimer B, Cella D, et al Genetic counseling and testing for breast-ovarian cancer susceptibility: what do women want? J Clin Oncol 1998 Jan 16(1):133 8 9440734
Awong L, Miles A Ethical dilemmas. When an adolescent wants to forgo therapy Am J Nurs 1998 Jul 98(7):67 8
Bahadur G, Ralph D Gonadal tissue cryopreservation in boys with paediatric cancers Hum Reprod 1999 14(1):11 7 10374086
Baider L, Uziely B, De-Nour AK. The impact of perceived behavior on patient-physician satisfaction. Ann N Y Acad Sci. 1997 Feb 20;809:266-78.
Baile WF, Glober GA, Lenzi R, et al Discussing disease progression and end-of-life decisions Oncology (Huntingt) 1999 13(7):1021 31 419372 10442349
Baile WF, Buckman R, Lenzi R, et al SPIKES-A six-step protocol for delivering bad news: application to the patient with cancer Oncologist 2000 5(4):302 11 10964998
Bailey K, Wilkinson S Communication issues. Patients' views on nurses' communication skills: a pilot study Int J Pall Nurs 1998 Nov 4(6):300 5
Baker L Patient education for kids Health Care Educ 1978 7(6):28 35 10239732
Bakker DA, Blais D, Reed E, et al Descriptive study to compare patient recall of information: nurse-taught versus video supplement Can Oncol Nurs J 1999 9(3):115 20 10703303
Bakker M, Weug D, Crommelin M, et al Information for the radiotherapy patient Radiography (London) 1999 May 5(2):99 106 193731
Baldwin D A model for describing low-income African American women's participation in breast and cervical cancer early detection and screening Adv Nurs Sci 1996 Dec 19(2):27 42
Balneaves LG, Long B An embedded decisional model of stress and coping: implications for exploring treatment decision making by women with breast cancer J Adv Nurs 1999 Dec 30(6):1321 31 10583642
Balneaves LG, Long B An embedded decisional model of stress and coping: implications for exploring treatment decision making by women with breast cancer J Adv Nurs 1999 Oct 30(4):882 92 10520101
Banks SM, Salovey P, Greener S, et al The effects of message framing on mammography utilization Health Psychol 1995 Mar 14(2):178 84 7789354
Barbarin OA, Chesler MA The medical context of parental coping with childhood cancer Am J Community Psychol 1986 14(2):221 35 3717089
Barbarin OA, Sargent JR, Sahler OJ, et al Sibling Adaptation to Childhood Cancer Collaborative Study: Parental Views of Pre- and Postdiagnosis Adjustment of Siblings of Children with Cancer J Psychosoc Oncol 1995 13(3):1 20
Barbour GL, Blumenkrantz MJ Videotape aids informed consent decision JAMA 1978 Dec 15 240(25):2741 2
Barnicle MM Chemotherapy and pregnancy Sem Oncol Nurs 1992 May 8(2):124 32
Barofsky I Therapeutic compliance and the cancer patient Health Educ Q 1984 10Suppl:43 56 6706614
Barratt A, Cockburn J, Furnival C, et al Perceived sensitivity of mammographic screening: Women's views on test accuracy and financial compensation for missed cancers J Epidemiol Community Health 1999 53(11):716 20 10656101
Barry B, Henderson A Nature of decision-making in the terminally ill patient Cancer Nurs 1996 Oct 19(5):384 91 8885487
Barry MJ, Fowler FJJ, Mulley AGJ, et al Patient reactions to a program designed to facilitate patient participation in treatment decisions for benign prostatic hyperplasia Med Care 1995 Aug 33(8):771 82 7543639
Barry MJ, Cherkin DC, Chang Y, et al. A randomized trial of a multimedia shared decision-making program for men facing a treatment decision for benign prostatic hyperplasia. Dis Manage Clin Outcomes. 1997;(1):5-14.
Bartholome WG. The ethical rights of the child patient. Front Radiat Ther Oncol. 1981;16:156-66. [pmid: 7333476].
Basch CE, Gold RS, McDermott RJ, et al Confounding variables in the measurement of cancer patient compliance Cancer Nurs 1983 Aug 6(4):285 93 6554110
Bastani R, Marcus AC, Maxwell AE, et al Evaluation of an intervention to increase mammography screening in Los Angeles Prev Med 1994 Jan 23(1):83 90 8016038
Bastian H, Keirse MJNC, Searle J Influencing people's experiences of screening (Protocol for a Cochrane Review) The Cochrane Library 2000Issue 1.Oxford Update Software
Bates D, McIntosh D, Chambers CR An evaluation of verbal and written methods in counselling cancer patients Can J Hosp Pharm 1995 48(2):98 9 10142844
Baum A, Friedman AL, Zakowski SG Stress and genetic testing for disease risk Health Psychol 1997 Jan 16(1):8 19 9028812
Baum M The ethics of clinical trials Isr J Med Sci 1995 31(2-3):197 200 7744596
Beadle GF, Henderson MA, Rodger A Managing early breast cancer Med J Aust 1995 163(10):546 50 8538528
Bean CA, Griffin AS, Bodansky B, et al Case in point. Case study Oncol Nurs Forum 1996 Oct 23(9):1385 6 8899754
Bearison DJ. "They never want to tell you": Children talk about cancer. Cambridge, MA, USA: Harvard University Press.; 1991.
Beattie J, Baron J Investigating the effect of stimulus range on attribute weight J Exp Psychol Hum Perception Perform 1991 May 17(2):571 85
Beaver K, Luker KA, Owens RG, et al Treatment decision making in women newly diagnosed with breast cancer Cancer Nurs 1996 Feb 19(1):8 19 8904382
Beaver K, Bogg J, Luker KA Decision-making role preferences and information needs: A comparison of colorectal and breast cancer Health Expect 1999 2(4):266 76 11281903
Beck CT Critique of Deciding on breast cancer treatment: a description of decision behavior Nursing Scan in Research 1993 Sep 6(5):14 5
Beebe DB, Rosenfeld AB, Collins N An approach to decisions about coverage of investigational treatments Hmo Pract 1997 11(2):65 7 10168110
Beisecker AE, Helmig L, Graham D, et al Attitudes of oncologists, oncology nurses, and patients from a women's clinic regarding medical decision making for older and younger breast cancer patients Gerontologist 1994 Aug 34(4):505 12 7959109
Bejes C, Marvel MK Attempting the improbable: offering colorectal cancer screening to all appropriate patients Fam Pract Res J 1992 Mar 12(1):83 90 1549951
Bekker H, Thornton JG, Airey CM, et al Informed decision making: an annotated bibliography and systematic review Health Technol Assess 1999 3(1):1 156
Bender W Impressions from Linkoping, Sweden (the sixth annual scientific meeting of EACE, May, 1993). European Association for Cancer Education J Cancer Educ 1993 8(4):261 4 8186076
Benedict S, Cole DJ, Baron L, et al Factors influencing choice between mastectomy and lumpectomy for women in the Carolinas J Surg Oncol 2001 76(1):6 12 11223818
Benevento A Decision-making in breast cancer Dissertation Abstracts International 1990 50(8-B):
Bennahum DA, Forman WB, Vellas B, et al Life expectancy, comorbidity, and quality of life. A framework of reference for medical decisions Clin Geriatr Med 1997 Feb 13(1):33 53 8995099
Bennett CL, Buchner DA, Ullman M Approaches to prostate cancer by managed care organizations Urology 1997 50(1):79 86 9218023
Bennett ES Soft truth: Ethics and cancer in Northeast Thailand Anthropol Med 1999 6(3):395 404
Bennett M, Alison D Discussing the diagnosis and prognosis with cancer patients Postgrad Med J 1996 72(843):25 9 8746281
Bental DS, Cawsey A, Jones R Patient information systems that tailor to the individual Patient Educ Couns 1999 Feb 36(2):171 80 10223021
Beresford SA, Farmer EM, Feingold L, et al Evaluation of a self-help dietary intervention in a primary care setting Am J Public Health 1992 Jan 82(1):PG: 79-84
Berner S, Partridge EE, Baum SK The effects of the PDQ Patient Information File (PIF) on patients' knowledge, enrollment in clinical trials, and satisfaction J Cancer Educ 1997 12(2):121 5 9229276
Bernhardt BA, Geller G, Strauss M, et al. Toward a model informed consent process for BRCA 1 testing: A qualitative assessment of women's attitudes. J Genet Couns. 1997;6:207-22. [pmid: 11656642].
Bernhardt BA, Geller G, Doksum T, et al Evaluation of nurses and genetic counselors as providers of education about breast cancer susceptibility testing Oncol Nurs Forum 2000 Jan 27(1):33 9 10660921
Berrino F, Bouchardy C, Sasco AJ Screening for breast cancer in pre-menopausal women. Who should decide? Int J Cancer 1995 60(2):153 5 7829231
Berry DA, Parmigiani G Assessing the benefits of testing for breast cancer susceptibility genes: A decision analysis Breast Dis 1998 10(1-2):115 25 15687554
Berry DL, Dodd MJ, Hinds PS, et al Informed consent: process and clinical issues Oncol Nurs Forum 1996 Apr 23(3):507 12 8801511
Berry SR, Singer PA The cancer specific advance directive Cancer 1998 82(8):1570 7 9554536
Bezwoda WR, Colvin H, Lehoka J. Transcultural and language problems in communicating with cancer patients in southern Africa. Ann N Y Acad Sci. 1997 Feb 20;809:119-32.
Bier H The incurable tumor patient HNO 1994 Jun 42(6):340 3 7520894
Biesecker BB, Boehnke M, Calzone K, et al Genetic counseling for families with inherited susceptibility to breast and ovarian cancer JAMA 1993 Apr 21 269(15):1970 4
Biger C, Epstein LM, Hagoel L, et al An evaluation of an education programme, for prevention and early diagnosis of malignancy in Israel Eur J Cancer Prev 1994 Jul 3(4):305 12 7950884
Bilodeau BA, Degner LF Information needs, sources of information, and decisional roles in women with breast cancer Oncol Nurs Forum 1996 May 23(4):691 6 8735327
Binger CM Psychosocial intervention with the child cancer patient and family Psychosomatics 1984 25(12):899 902 6514981
Bird JA, McPhee SJ, Jenkins C, et al Three strategies to promote cancer screening. How feasible is wide-scale implementation? Med Care 1990 Nov 28(11):1005 12 2250488
Birkmeyer JD, Birkmeyer NO Decision analysis in surgery Surgery 1996 120(1):7 15 8693425
Bishara E, Lowe F, Forest MI, et al Is there a relationship between psychological well-being and patient-carers consensus? A clinical pilot study J Palliat Care 1997 13(4):14 22
Bjorge T, Gunbjorud AB, Haugen OA, et al Mass screening for cervical cancer in Norway: evaluation of the pilot project Cancer Causes and Control 1995 Nov 6(6):477 84 8580294
Black WC, Nease RFJ, Tosteson AN Perceptions of breast cancer risk and screening effectiveness in women younger than 50 years of age J Natl Cancer Inst 1995 May 17 87(10):720 31
Blacklay A, Eiser C, Ellis A Development and evaluation of an information booklet for adult survivors of cancer in childhood. The United Kingdom Children's Cancer Study Group Late Effects Group Arch Dis Child 1998 Apr 78(4):340 4 9623397
Blanchard CG, Ruckdeschel JC Psychosocial aspects of cancer in adults: implications for teaching medical students J Cancer Educ 1986 1(4):237 48 3079146
Blanchard CG, Labrecque MS, Ruckdeschel JC, et al Information and decision-making preferences of hospitalized adult cancer patients Soc Sci Med 1988 27(11):1139 45 3206248
Blanchard CG, Ruckdeschel JC, Albrecht TL. Patient-family communication with physicians. In: Baider L, Cooper CL, editors. Chichester England UK: John Wiley & Sons. 1996:p. 369-87.
Blichert-Toft M, Beckmann J Open information A limiting factor in clinical research.Ugeskr Laeger 1981 May 4 143(19):1199 202
Blichert TM, Mouridsen H, Andersen KW Clinical trials Semin Surg Oncol 1996 12(1):32 8 8821407
Blotcky AD Helping adolescents with cancer cope with their disease Sem Oncol Nurs 1986 May 2(2):117 22
Bluman LG, Rimer BK, Berry DA, et al Attitudes, knowledge, and risk perceptions of women with breast and/or ovarian cancer considering testing for BRCA1 and BRCA2 J Clin Oncol 1999 17(3):1040 6 10071299
Blumberg BD. Meeting the educational needs of adolescents with cancer. Prog Clin Biol Res. 1983;130:85-9. [pmid: 6622486].
Blumberg BD, Lewis MJ Developing materials to meet the educational needs of adolescents with cancer Oncol Nurs Forum 1983 10(1):35 9
Bodansky B, O'Rourke M, Griffin AS Case study. Patient resources for prostate cancer Oncol Nurs Forum 1996 Oct 23(9):1385 6 8899754
Boecke M Nursing care plan for the child with acute leukemia J Pract Nurs 1978 Sep 28(9):19 21 278829
Boehm S, Coleman BP, Schlenk EA, et al Prostate cancer in African American men: Increasing knowledge and self-efficacy J Community Health Nurs 1995 12(3):161 9 7561994
Bohanec M, Zupan B, Rajkovic V Applications of qualitative multi-attribute decision models in health care Int J Med Inf 2000 58-59(2):191 205
Boivin J, Moffatt M Prophylactic mastectomy: an agonizing choice Nurs Spect (Gt Phila Tri State Ed) 1998 7(4):4 5
Boliukh BA The reasons for patients with stomach cancer refusing surgical treatment Vop Onkol 1992 38(1):98 101
Bolmsjoe I, Hermeren G. Challenging assumptions in end-of-life situations. Palliat Med. 1998;12:451-6. [pmid: 10621865].
Bomalaski JJ The treatment of recurrent ovarian carcinoma: balancing patient desires, therapeutic benefit, cost containment and quality of life Curr Opin Obstet Gynecol 1999 Feb 11(1):11 5 10047957
Bonevski B, Sanson-Fisher R, Girgis A, et al Evaluation of an instrument to assess the needs of patients with cancer. Supportive Care Review Group Cancer 2000 Jan 1 88(1):217 25
Bonfill X Cancer and quality of life Med Clin 1990 Jun 16 95(3):106 9
Bonicatto S, Dew MA, Soria JJ, et al Validity and reliability of symptom checklist '90 (SCL90) in an Argentine population sample Soc Psychiatry Psychiatr Epidemiol 1997 32(6):332 8 9299927
Bonnet V, Couvreur C, Demachy P, et al Evaluating radiotherapy patients' need for information: a study using a patient information booklet Cancer Radiother 2000 Jul 4(4):294 307 10994394
Boon H, Brown JB, Gavin A, et al Breast cancer survivors' perceptions of complementary/alternative medicine (CAM): making the decision to use or not to use Qual Health Res 1999 9(5):639 53 10558372
Borgers R, Mullen PD, Meertens R, et al The information-seeking behavior of cancer outpatients: a description of the situation Patient Educ Couns 1993 Nov 22(1):35 46 8134320
Borland R, Marks R, Gibbs A, et al Effects of type of information in health education brochures upon performance on an experimental melanoma detection task Health Educ Res 1995 10(2):191 8
Borland R, Mee V, Meehan JW Effects of photographs and written descriptors on melanoma detection Health Educ Res 1997 Sep 12(3):375 84 10174220
Borwhat M Perspective of the patient advocate Obstet Gynecol Surv 1998 53(10 Suppl.):S23 S24
Bosze P Should estrogen replacement therapy be applied in women with genital and breast cancer? Orv Hetil 1995 Feb 136(8 Suppl 1):465 72 7877821
Botkin JR, Croyle RT, Smith KR, et al A model protocol for evaluating the behavioral and psychosocial effects of BRCA1 testing J Natl Cancer Inst 1996 Jul 3 88(13):872 82
Bottorff JL, Steele R, Davies B, et al Striving for balance: palliative care patients' experiences of making everyday choices J Palliat Care 1998 14(1):7 17 9575708
Bottorff JL, Ratner PA, Johnson JL, et al Communicating cancer risk information: the challenges of uncertainty Patient Educ Couns 1998 Jan 33(1):67 81 9481350
Bottorff JL, Steele R, Davies B, et al Facilitating day-to-day decision making in palliative care Cancer Nurs 2000 23(2):141 50 10763286
Bouaud J, Seroussi B, Antoine EC, et al Patient-centred consultation of clinical practice guidelines: OncoDoc, a decision support system for the management of breast cancer patients Therapie 1999 54(2):209 15 10394256
Bourjolly JN Locus of control among black and white women with breast cancer: A preliminary study J Psychosoc Oncol 1999 17(1):21 31
Bowman J, Sanson-Fisher R, Boyle C, et al A randomised controlled trial of strategies to prompt attendance for a Pap smear J Med Screen 1995 2(4):211 8 8719151
Bowsher WG Update on urology - Prostate cancer. 4 - Treatment of local disease Eur J Surg Oncol 1995 21(6):679 82 8631420
Boyle DM Realities to guide novel and necessary nursing care in geriatric oncology Cancer Nurs 1994 Apr 17(2):125 36 8019996
Bradbury J, Bryant H, Casebolt T, et al A Canadian experiment with breast cancer information exchange pilot projects Patient Educ Couns 1996 Jul 28(2):169 74 8852090
Braden CJ, Mishel MH, Longman AJ Self-Help Intervention Project. Women receiving breast cancer treatment Cancer Pract 1998 Mar 6(2):87 98 9573908
Brandberg Y, Bergenmar M, Bolund C, et al Information to patients with malignant melanoma: A randomized group study Patient Educ Couns 1994 23(2):97 105 21207908
Brandt C, Verres R Coping of patients receiving outpatient radiotherapy -- An analysis of requirements on psychosocial care Z Onkol 1999 31(4):109 13
Branin JJ, Griemel ER. Improving women's knowledge and satisfaction with preventive cancer screening. AHSR & FHSR Annu Meet Abst. 2000;13:186-7.
Branoff R, Santi K, Campbell JK, et al A family practice residency cervical screening project: perceived screening barriers Fam Med 1997 Feb 29(2):119 23 9048173
Bratt O [Localized prostatic cancer -- should the patient or the physician choose the treatment?] Lakartidningen 2000 97(41):
Brawley OW Prostate cancer and black men Semin Urol Oncol 1998 16(4):184 6 9858323
Bremnes RM, Andersen K, Wist EA Cancer patients, doctors and nurses vary in their willingness to undertake cancer chemotherapy Eur J Cancer 1995 Nov 31A(12):1955 9
Brenner PR Managing patients and families at the ending of life: hospice assumptions, structures, and practice in response to staff stress Cancer Invest 1997 15(3):257 64 9171860
Bretscher M Caring for dying patients: what is right? J Clin Oncol 2000 18(1):233 4 10623715
Brett AS The mammography and prostate-specific antigen controversies: implications for patient-physician encounters and public policy J Gen Intern Med 1995 May 10(5):266 70 7542328
Brewster WR, DiSaia PJ, Grosen EA, et al An experience with estrogen replacement therapy in breast cancer survivors Int J Fertil Womens Med 1999 44(4):186 92 10499739
Brock DW, Wartman SA When competent patients make irrational choices [see comments] N Engl J Med 1990 May 31 322(22):1595 9
Brody DS The patient's role in clinical decision-making Ann Intern Med 1980 Nov 93(5):718 22 7212484
Browman GP, Levine MN, Mohide EA, et al The practice guidelines development cycle: A conceptual tool for practice guidelines development and implementation J Clin Oncol 1995 13(2):502 12 7844612
Browman GP Essence of evidence-based medicine: A case report J Clin Oncol 1999 17(7):1969 73 10561246
Brown D, Roberts JA, Elkins TE, et al Hard choices: the gynecologic cancer patient's end-of-life preferences Gynecol Oncol 1994 Dec 55(3 Pt 1):355 62 7835774
Brown HG Patient issues in breast reconstruction Cancer 1991 Sep 1 68(5 Suppl):1167 9 1913500
Brown M, Wilson A Breast restoration decision making followed 2 predominant patterns and did not involve active information seeking behaviour [commentary on Reaby LL. Breast restoration decision making: enhancing the process. Cancer Nurs 1998 Jun; 21(3):196-204] EBN 1999 Jan 2(1):
Brown PG Families who have a child diagnosed with cancer: What the medical caregiver can do to help them and themselves Issues Comp Pediatr Nurs 1989 12(2-3):247 60
Brown V Informed consent for PSA testing J Fam Pract 1996 Sep 43(3):234 5 8797747
Browne D, Baatz LM, Millard F, et al Oncology services: The Department of Defense perspective Cancer 1998 82(10 Suppl.):2010 5 9587099
Brundage MD, Davidson JR, Mackillop WJ. Patients' preferred roles in treatment decisions: do they relate to information and treatment preferences?. J Clin Invest Med. 1996;19.
Brundage MD, Davidson JR, Mackillop WJ Trading treatment toxicity for survival in locally advanced non-small cell lung cancer J Clin Oncol 1997 Jan 15(1):330 40 8996160
Brundage MD, Groome PA, Feldman-Stewart D, et al Decision analysis in locally advanced non-small-cell lung cancer: is it useful? J Clin Oncol 1997 Mar 15(3):873 83 9060523
Brundage MD, Cosby RH, Feldman-Stewart D, et al A pilot study of decision aid for patients with locally-advanced non-small cell lung cancer Med Decis Making 1998 Oct 18(4):
Brundage MD, Davidson JR, Mackillop WJ, et al Using a treatment-tradeoff method to elicit preferences for the treatment of locally advanced non-small-cell lung cancer Med Decis Making 1998 Jul 18(3):256 67 9679990
Brundage MD, Feldman SD, Dixon P, et al A treatment trade-off based decision aid for patients with locally advanced non-small cell lung cancer Health Expect 2000 3(1):55 68 11281912
Brundage MD, Feldman-Stewart D, Cosby R, et al Phase I study of a decision aid for patients with locally advanced non-small-cell lung cancer J Clin Oncol 2001 19(5):1326 35 11230475
Bruno-Goldberger Y The Child and His Cancer; L'Enfant et son cancer Neuropsychiatrie de l'enfance et de l'adolescence 1996 44(6-7):225 35
Brusamolino E, Surbone A. Telling the truth to the patient with cancer. A cross-cultural dialogue. Ann N Y Acad Sci. 1997 Feb 20;809:411-21.
Buchanan-Davidson B Tanning salons, a skin cancer threat Wis Med J 1980 Jun 79(6):116 7 7405264
Buchanan BG, Moore JD, Forsythe DE, et al An intelligent interactive system for delivering individualized information to patients Artif Intell Med 1995 Apr 7(2):117 54 7647838
Buchanan BG, Carenini G, Mittal VO, et al Designing computer-based frameworks that facilitate doctor -- patient collaboration Artif Intell Med 1998 Feb 12(2):169 91 9520223
Buchanan J, Borland R, Cosolo W, et al Patients' beliefs about cancer management Support Care Cancer 1996 Mar 4(2):110 7 8673348
Buckman R Communicating with cancer patients Practitioner 1989 233(1477):1393 4 2616510
Budoff PW Breast cancer as viewed by the family physician Surg Clin North Am 1984 Dec 64(6):1209 12 6515529
Bujorian GA Clinical trials: patient issues in the decision-making process Oncol Nurs Forum 1988 Nov 15(6):779 83 3205836
Bunin GR, Kazak AE, Mitelman O Informing subjects of epidemiologic study results Pediatrics 1996 97(4):486 91 8632933
Burack RC, Wood DP, Jr Screening for prostate cancer. The challenge of promoting informed decision making in the absence of definitive evidence of effectiveness Med Clin North Am 1999 83(6):1423 42 10584601
Burack RC, George J, Gurney JG Mammography use among women as a function of age and patient involvement in decision-making J Am Geriatr Soc 2000 Jul 48(7):817 21 10894323
Burchell RC Decision regarding hysterectomy Am J Obstet Gynecol 1977 Jan 15 127(2):113 7 831490
Burhansstipanov L, Dignan MB, Wound DB, et al Native American recruitment into breast cancer screening: The NAWWA project J Cancer Educ 2000 15(1):28 32 10730800
Burke JD A conversation with a physician and a cancer patient [interview by Judith D Burke] Wis Med J 1997 Apr 96(4):12 5
Burke W, Daly M, Garber J, et al Recommendations for follow-up care of individuals with an inherited predisposition to cancer. II. BRCA1 and BRCA2. Cancer Genetics Studies Consortium JAMA 1997 Mar 26 277(12):997 1003
Burke W, Petersen G, Lynch P, et al Recommendations for follow-up care of individuals with an inherited predisposition to cancer. I. Hereditary nonpolyposis colon cancer. Cancer Genetics Studies Consortium JAMA 1997 Mar 19 277(11):915 9
Burklow JT, Blumberg BD, Laufer JK, et al The use of formative evaluation methods in the development of patient/family educational materials... siblings or children of cancer patients J Assoc Pediatr Oncol Nurses 1988 5(1/2):12 5 3385619
Burton M Training a consultant surgeon in Rogerian counselling techniques Clin Psychol Forum 1999(123):13 5
Burton MV, Parker RW Psychological aspects of cancer surgery: Surgeons' attitudes and opinions Psychooncology 1997 6(1):47 64 9126715
Bush EG, Magyar PH Conflicting claims: an ethical dilemma in family-centered care J Assoc Pediatr Oncol Nurses 1986 3(3):9 27
Butler MN, Hailey BJ. Reactions of younger and older women to physician's styles of presentation of breast cancer treatment options. Psychol Health Med. 1996. Heatlh.
Butow P, Ellis P, Cox K Coping with cancer chemotherapy Mod Med Aust 1998 41(1):32 7
Butow PN, Dunn SM, Tattersall MH, et al Patient participation in the cancer consultation: evaluation of a question prompt sheet Ann Oncol 1994 Mar 5(3):199 204 8186168
Butow PN, Dunn SM, Tattersall MH, et al Computer-based interaction analysis of the cancer consultation Br J Cancer 1995 May 71(5):1115 21 7734311
Butow PN, Kazemi JN, Beeney LJ, et al When the diagnosis is cancer: patient communication experiences and preferences Cancer 1996 Jun 15 77(12):2630 7
Butow PN, Tattersall MH, Goldstein D. Communication with cancer patients in culturally diverse societies. Ann N Y Acad Sci. 1997 Feb 20;809:317-29.
Butow PN, Maclean M, Dunn SM, et al The dynamics of change: cancer patients' preferences for information, involvement and support Ann Oncol 1997 Sep 8(9):857 63 9358935
Butow P, Brindle E, McConnell D, et al Information booklets about cancer: Factors influencing patient satisfaction and utilisation Patient Educ Couns 1998 33(2):129 41 9732653
Butow PN, Dunn SM, Tattersall MH Communication with cancer patients: Does it matter? J Palliat Care 1995 11(4):34 8
Byers RM Factors affecting choice of initial therapy in oral cancer Semin Surg Oncol 1995 11(3):183 9 7638505
Byram SJ Breast cancer and mammogram screening: Mental models and quantitative assessments of beliefs Dissertation Abstracts International: Section B: The Sciences and Engineering 1999 59(8-B):
Byrnes JP, McClenny B Decision-making in young adolescents and adults J Exp Child Psychol 1994 Dec 58(3):359 88 7844499
Cain JM, Hammes BJ Ethics and pain management: respecting patient wishes J Pain Symptom Manage 1994 Apr 9(3):160 5 7516956
Caldwell LM Commentary on decision making by patients with breast cancer: the role of information in treatment selection [original article by Hughes K appears in Oncol Nurs Forum 1993; 20 (4):623-8] Nursing Scan in Research 1993 Nov 6(6):18 9
Caldwell LM Commentary on deciding on breast cancer treatment: a description of decision behavior [original article by Pierce PF appears in Nurs Res 1993; 42 (1): 22-8] Nursing Scan in Research 1993 Jul 6(4):2 3
Calle EE, Miracle-McMahill HL, Moss RE, et al Personal contact from friends to increase mammography usage Am J Prev Med 1994 Nov 10(6):361 6 7880557
Calzone KA, Stopfer J, Blackwood A, et al Establishing a cancer risk evaluation program Cancer Pract 1997 Jul 5(4):228 33 9250079
Cappelli M, Surh L, Humphreys L, et al Psychological and social determinants of women's decisions to undergo genetic counseling and testing for breast cancer Clin Genet 1999 Jun 55(6):419 30 10450858
Carlsson ME, Strang PM Facts, misconceptions, and myths about cancer. What do patients with gynecological cancer and the female public at large know? Gynecol Oncol 1997 Apr 65(1):46 53 9103390
Carlsson ME, Strang PM How patients with gynecological cancer experience the information process J Psychosom Obstet Gynaecol 1998 Dec 19(4):192 201 9929845
Carlsson ME, Strang PM Educational support programme for gynaecological cancer patients and their families Acta Oncol 1998 37(3):269 75 9677099
Carlsson ME, Strang PM, Nygren U Qualitative analysis of the questions raised by patients with gynecologic cancers and their relatives in an educational support group J Cancer Educ 1999 14(1):41 6 10328323
Carmel S Life-sustaining treatments: What doctors do, what they want for themselves and what elderly persons want Soc Sci Med 1999 49(10):1401 8 10509829
Carpenter LC, Radelt S, Scandinaro J Facilitating community breast cancer detection and screening Oncol Nurs Forum 1992 19(1):
Carpenter V, Colwell B Cancer knowledge, self-efficacy, and cancer screening behaviors among Mexican-American women J Cancer Educ 1995 10(4):217 22 8924398
Carr WP, Maldonado G, Leonard PR, et al Mammogram utilization among farm women J Rural Health 1996 12(4):278 90 10162859
Carrère M, Moumjid-Ferdjaoui N, Charavel M, et al. Eliciting patients' preferences for adjuvant chemotherapy in breast cancer: development and validation of a bedside decision-making instrument in a French Regional Cancer Centre. Health Expect. 2000:97-113.
Carroll S Breast cancer. Part 3: Psychosocial care Prof Nurse 1998 Sep 13(12):875 83 10095683
Carroll S Role of the breast care clinical nurse specialist in facilitating decision-making for treatment choice: a practice profile Eur J Oncol Nurs 1998 Mar 2(1):34 42
Carson S Human papillomatous virus infection update: impact on women's health Nurse Pract 1997 22(4):24 5 9128877
Carter F, Graham E, Pal N, et al Prostate cancer screening in primary care South Med J 1999 Mar 92(3):300 4 10094271
Carter KJ, Ritchey NP, Castro F, et al Analysis of three decision-making methods: a breast cancer patient as a model Med Decis Making 1999 Jan 19(1):49 57 9917020
Carton AB Intervention raises risks and rewards Cap Nurs 1986 1(11):4 5 3643060
Casali P, Licitra L, Costantini M, et al Quality of life assessment and clinical decision-making Ann Oncol 1997 8(12):1207 11 9496385
Casarett D, Ross LF Overriding a patient's refusal of treatment after an iatrogenic complication N Engl J Med 1997 336(26):1908 10 9197222
Casarett D Case presentation: Are dying patients too vulnerable to participate in research? J Pain Symptom Manage 1999 18(2):
Cassileth BR, Volckmar D, Goodman RL The effect of experience on radiation therapy patients' desire for information Int J Radiat Oncol Biol Phys 1980 Apr 6(4):493 6 7390930
Cassileth BR, Zupkis RV, Sutton-Smith K, et al Information and participation preferences among cancer patients Ann Intern Med 1980 Jun 92(6):832 6 7387025
Cassileth BR, Heiberger RM, March V, et al Effect of audiovisual cancer programs on patients and families J Med Educ 1982 Jan 57(1):54 9 7054510
Cassileth BR, Soloway MS, Vogelzang NJ, et al Patients' choice of treatment in stage D prostate cancer Urology 1989 May 33(5 Suppl):57 62
Cawley M, Kostic J, Cappello C Informational and psychosocial needs of women choosing conservative surgery/primary radiation for early stage breast cancer Cancer Nurs 1990 Apr 13(2):90 4 2331696
Cella DF Measuring quality of life in palliative care Semin Oncol 1995 22(Suppl. 3):73 81 7537908
Chadwick DJ, Gillatt DA, Gingell JC Medical or surgical orchidectomy: the patients' choice BMJ 1991 Mar 9 302(6776):
Chambers T. Cross-cultural issues in caring for patients with cancer. Cancer Treat Res. 2000;102:23-37. [pmid: 10650478].
Champion V, Huster G Effect of interventions on stage of mammography adoption J Behav Med 1995 Apr 18(2):169 87 7563045
Champion VL Strategies to increase mammography utilization Med Care 1994 Feb 32(2):118 29 8302104
Champion VL Results of a nurse-delivered intervention on proficiency and nodule detection with breast self-examination Oncol Nurs Forum 1995 Jun 22(5):819 24 7675689
Champion VL, Springston J Mammography adherence and beliefs in a sample of low-income African American women Int J Behav Med 1999 6(3):228 40 16250677
Chan EY, Sulmasy DP What should men know about prostate-specific antigen screening before giving informed consent? Am J Med 1998 105(4):266 74 9809686
Chapman G Teaching case. An oncology patient's choice to forgo nonvolitional nutrition support: ethical considerations Nutr Clin Pract 1996 Dec 11(6):265 8 9016144
Chapman GB, Elstein AS, Hughes KK Effects of patient education on decisions about breast cancer treatments: a preliminary report Med Decis Making 1995 Jul 15(3):231 9 7564937
Chapman GB, Elstein AS, Kuzel TM, et al A multi-attribute model of prostate cancer patient's preferences for health states Qual Life Res 1999 May 8(3):171 80 10472149
Charles C, Gafni A, Whelan T Shared decision-making in the medical encounter: what does it mean? (or it takes at least two to tango) Soc Sci Med 1997 Mar 44(5):681 92 9032835
Charles C, Gafni A, Whelan T Decision-making in the physician-patient encounter: revisiting the shared treatment decision-making model Soc Sci Med 1999 Sep 49(5):651 61 10452420
Charles C, Whelan T, Gafni A What do we mean by partnership in making decisions about treatment? BMJ 1999 319(7212):780 2 10488014 1116606
Charles C, Gafni A, Whelan T. International conference on Treatment Decision-Making in the Clinical Encounter. Health Expect. 2000;3:1-5. [pmid: 11281906].
Charles CA, Redko C, Whelan T, et al Doing Nothing Is No Choice: Lay Constructions of Treatment Decision-Making among Women with Early Stage Breast Cancer Sociol Health Illn 1998 20(1):71 95
Cheng JD, Hitt J, Koczwara B, et al Impact of quality of life on patient expectations regarding phase I clinical trials J Clin Oncol 2000 Jan 18(2):421 8 10637258
Chesler MA, Barbarin OA Relating to the medical staff: how parents of children with cancer see the issues Health Soc Work 1984 9(1):49 65 6706256
Chesler MA, Paris J, Barbarin OA "Telling" the child with cancer: parental choices to share information with ill children J Pediatr Psychol 1986 Dec 11(4):497 516 3559843
Chiu YY, Dickinson JI, Jones RG, et al. The colon book: a look at polyps and colon cancer, their treatment, and your prospects for recovery. Krames Communications. 1996.
Chlebowski RT, Blackburn GL, Buzzard IM, et al Adherence to a dietary fat intake reduction program in postmenopausal women receiving therapy for early breast cancer. The Women's Intervention Nutrition Study J Clin Oncol 1993 Nov 11(11):2072 80 8229121
Chlebowski RT, McTiernan A Elements of informed consent for hormone replacement therapy in patients with diagnosed breast cancer J Clin Oncol 1999 Jan 17(1):130 42 10458226
Chodak GW The role of conservative management in localized prostate cancer Cancer 1994 Oct 1 74(7 Suppl):2178 81 8087787
Chopra KF, Tyring SK The impact of the human immunodeficiency virus on the human papillomavirus epidemic Arch Dermatol 1997 133(5):629 33 9158417
Chrisler JC Commentary on women's decision making about mammography: a replication of the relationship between stages of adoption and decisional balance [original article by Rakowski W et al appears in Health Psychol 1993; 12 (3): 209-14] AWHONN's Women's Health Nursing Scan 1993 Sep 7(5):10 1
Church JM Prophylactic colectomy in patients with hereditary nonpolyposis colorectal cancer Ann Med 1996 Dec 28(6):479 82 9017106
Chye RW, Lickiss JN Palliative care in bilateral malignant ureteric obstruction Ann Acad Med Singapore 1994 Mar 23(2):197 203 7521610
Ciampi A, Silberfeld M, Till JE Measurement of individual preferences. The importance of "situation-specific" variables Med Decis Making 1982 2(4):483 95 7182704
Clancy BJ Biopsy-mastectomy -- a one or two step procedure Kans Nurse 1978 Jan 53(1):5 7 244657
Clancy CM, Cebul RD, Williams SV Guiding individual decisions: a randomized, controlled trial of decision analysis Am J Med 1988 Feb 84(2):283 8 2970220
Clark JA, Wray N, Brody B, et al Dimensions of quality of life expressed by men treated for metastatic prostate cancer Soc Sci Med 1997 Oct 45(8):1299 309 9381242
Class P Genetics nursing: helping patients make tough choices Nurs Spect 1998 Jun 15 8(12):9 10
Clayson ME Breast awareness may reduce mortality. A health education opportunity for women admitted to hospital Prof Nurse 1992 Apr 7(7):442 6 1574505
Clemow L, Costanza ME, Haddad WP, et al Underutilizers of mammography screening today: characteristics of women planning, undecided about, and not planning a mammogram Ann Behav Med 2000 22(1):80 8 10892532
Clore ER Natural and artificial tanning J Pediatr Health Care 1995 May 9(3):103 8 7769553
Clover K, Redman S, Forbes J, et al Two sequential randomized trials of community participation to recruit women for mammographic screening Prev Med 1996 Mar 25(2):126 34 8860277
Clover KA, Redman S, Forbes JF, et al Promotion of attendance for mammographic screening through general practice: a randomised trial of two strategies Med J Aust 1992 Jan 20 156(2):91 4
Cockburn J, Staples M, Hurley SF, et al Psychological consequences of screening mammography J Med Screen 1994 Jan 1(1):7 12 8790480
Cockburn J, Redman S, Kricker A Should women take part in clinical trials in breast cancer? issues and some solutions... presented in part at the National Health and Medical Research Council National Breast Cancer Centre workshop "Clinical Trials in Breast Cancer: Should Women Take Part?," Sydney, Australia, August 1995 J Clin Oncol 1998 Jan 16(1):354 62 9440764
Cockburn J, Pit S, Redman S Perceptions of screening mammography among women aged 40-49 Aust N Z J Public Health 1999 23(3):318 21 10388180
Codori A Psychological opportunities and hazards in predictive genetic testing for cancer risk Gastroenterol Clin North Am 1997 Mar 26(1):19 39 9119438
Codori AM, Petersen GM, Miglioretti DL, et al Attitudes toward colon cancer gene testing: factors predicting test uptake Cancer Epidemiol Biomarkers Prev 1999 Apr 8(4 Pt 2):345 51 10207639
Coebergh JW, Van-der-Does-Van dB, Hop WJ, et al Small influence of parental educational level on the survival of children with leukaemia in The Netherlands between 1973 and 1979 Eur J Cancer Part A 1996 32(2):286 9
Cohen SP, Jaskulsky SR Prostate cancer Tx. Therapeutic options based on tumor grade, life expectancy, and patient preferences Geriatrics 2001 56(2):39, 42, 47 39, 42, 48 11219024
Cohodes DR Through the looking glass: decision making and chemotherapy Health Aff 1995 14(4):203 8
Col NF, Moulton AW, Cyr MG A framework for clinical decisions regarding hormone replacement therapy Infertil Reprod Med Clin North Am 1999 10(2):229 42
Colditz GA Hormones and breast cancer: evidence and implications for consideration of risks and benefits of hormone replacement therapy J Womens Health 1999 Apr 8(3):347 57 10326989
Coleman CN If the doctor says cancer: what to do next... and next Bottom Line/Health 1999 Oct 13(10):9 10
Collins ED, Kerrigan CL, Anglade P Surgical treatment of early breast cancer: what would surgeons choose for themselves? Eff Clin Pract 1999 2(4):149 51 10539538
Collins V, Halliday J, Warren R, et al Assessment of education and counselling offered by a familial colorectal cancer clinic Clin Genet 2000 57(1):48 55 10733235
Cooley ME, Moriarty H, Berger MS, et al Patient literacy and the readability of written cancer educational materials Oncol Nurs Forum 1995 Oct 22(9):1345 51 8539175
Cooper SE, Blitz JT. A therapeutic play group for hospitalized children with cancer. J Psychosoc Oncol. 1985:23-37.
Copeland DR, Silberberg Y, Pfefferbaum B Attitudes and practices of families of children in treatment for cancer. A cross-cultural study Am J Pediatr Hematol Oncol 1983 5(1):65 71 6859456
Corder MP, Ellwein LB A decision-analysis methodology for consideration of morbidity factors in clinical decision-making Am J Clin Oncol 1984 Feb 7(1):19 31 6546469
Corder MP, Ellwein LB Comparison of treatments for symptomatic Hodgkin's lymphoma employing decision analysis Am J Clin Oncol 1984 Feb 7(1):33 8 6546470
Coreil J, Behal R Man to man prostate cancer support groups Cancer Pract 1999 7(3):122 9 10352074
Corless CL Evaluating early-stage prostate cancer: What pretreatment criteria best guide therapeutic decision making? Hematol Oncol Clin North Am 1996 10(3):565 79 8773497
Cormier AC Patients can benefit from information on Internet resources Oncol Nurs Forum 1997 Apr 24(3):
Corney R, Everett H, Howells A, et al The care of patients undergoing surgery for gynaecological cancer: the need for information, emotional support and counselling J Adv Nurs 1992 Jun 17(6):667 71 1607497
Cornuz J, Zellweger JP, Burnand B Smoking cessation: importance for the patient and role of the practitioner Schweiz Med Wochenschr 1994 Jul 30 124(30):1315 25
Corral F, Cueva P, Yepez J, et al Limited education as a risk factor in cervical cancer Bull Pan Am Health Organ 1996 30(4):322 9 9041743
Costello K, Conway K Nursing management of MS patients receiving interferon beta-1b therapy Rehabilitation Nurs 1997 22(2):62 6
Cotton P Prognosis, diagnosis, or who knows? Time to learn what gene tests mean JAMA 1995 273(2):93 5 7799499
Cotton T, Locker AP, Jackson L, et al A prospective study of patient choice in treatment for primary breast cancer Eur J Surg Oncol 1991 Apr 17(2):115 7 2015917
Cotton T Breast care. Advocating the right choice for women Nurs Standard 1991 Nov 27 6(10):55 6
Cotton T Patient choice in breast cancer treatment Nurs Times 1995 91(17):
Coulter A, Entwistle V, Gilbert D Sharing decisions with patients: is the information good enough? BMJ 1999 Jan 30 318(7179):318 22
Cousins N Denial. Are sharper definitions needed? JAMA 1982 Jul 9 248(2):210 2 7087112
Coward DD, Wilkie DJ Metastatic bone pain Cancer Nurs 2000 23(2):101 8 10763280
Cowen ME, Miles BJ, Cahill DF, et al The danger of applying group-level utilities in decision analyses of the treatment of localized prostate cancer in individual patients Med Decis Making 1998 Oct 18(4):376 80 10372579
Cox K, Avis M Ethical and practical problems of early anti-cancer drug trials: a review of the literature Eur J Cancer Care 1996 5(2):90 5
Cox K, Avis M Psychosocial aspects of participation in early anticancer drug trials. Report of a pilot study Cancer Nurs 1996 Jun 19(3):177 86 8674026
Cox K Enhancing cancer clinical trial management: recommendations from a qualitative study of trial participants' experiences Psychooncology 2000 9(4):314 22 10960929
Craddock RB Commentary on deciding on breast cancer treatment: a description of decision behavior [original article by Pierce PF appears in Nurs Res 1993; 42(1):22-8] ONS Nursing Scan in Oncology 1993 2(3):4-Jun
Crawford SW Decision making in critically ill patients with hematologic malignancy West J Med 1991 Nov 155(5):488 93 1815387 1003059
Creasman WT HRT and women who have had breast or endometrial cancer J Epidemiol Biostat 1999 4(3):217 20 10695960
Cremer L Rehabilitation of an adolescent with medulloblastoma Cancer Pract 1998 6(3):138 42 9652244
Cross-Skinner S Commentary on telephone counseling improves adherence to colposcopy among lower-income minority women [original article by Lerman C et al appears in J Clin Oncol 1992; 10(2):330-3] ONS Nursing Scan in Oncology 1992 1(2):6 Aug
Crosson K Cancer patient education: what, where, and by whom? Health Educ Q 1984 10Suppl:19 29 6706612
Croyle RT, Achilles JS, Lerman C Psychologic aspects of cancer genetic testing: a research update for clinicians Cancer 1997 80(3 Suppl.):569 75 11657060
Croyle RT, Smith KR, Botkin JR, et al Psychological responses to BRCA1 mutation testing: preliminary findings Health Psychol 1997 Jan 16(1):63 72 9028816
Cull A, Miller H, Porterfield T, et al The use of videotaped information in cancer genetic counselling: a randomized evaluation study Br J Cancer 1998 Mar 77(5):830 7 9514066
Cullen MH, Billingham LJ, Cook J, et al Management preferences in stage I non-seminomatous germ cell tumours of the testis: an investigation among patients, controls and oncologists Br J Cancer 1996 Nov 74(9):1487 91 8912550
Curry SJ, Taplin SH, Anderman C, et al A randomized trial of the impact of risk assessment and feedback on participation in mammography screening Prev Med 1993 May 22(3):350 60 8327418
Dabney MK, Huelsman K Counseling by computer: breast cancer risk and genetic testing. Developed by the University of Wisconsin-Madison Department of Medicine and the Program in Medical Ethics Genet Test 2000 4(1):43 4 10794359
Dahlquist LM, Power TG, Carlson L Physician and parent behavior during invasive pediatric cancer procedures: Relationships to child behavioral distress J Pediatr Psychol 1995 20(4):477 90 7666289
Daly M, Seay J, Balshem A, et al Feasibility of a telephone survey to recruit health maintenance organization members into a tamoxifen chemoprevention trial Cancer Epidemiol Biomarkers Prev 1992 Jul 1(5):413 6 1305474
Damhuis RA, Blom JH The influence of age on treatment choice and survival in 735 patients with renal carcinoma Br J Urol 1995 Feb 75(2):143 7 7850317
Damian D, Tattersall MH Letters to patients: improving communication in cancer care Lancet 1991 Oct 12 338(8772):923 5
Danigelis NL, Worden JK, Mickey RM The importance of age as a context for understanding African-American women's mammography screening behavior Am J Prev Med 1996 12(5):358 66 8909647
Danis M, Mutran E, Garrett JM, et al A prospective study of the impact of patient preferences on life-sustaining treatment and hospital cost Crit Care Med 1996 24(11):1811 7 8917030
Dantz B Case presentation: pain, suffering and the unconscious patient J Pain Symptom Manage 1999 Apr 17(4):
Daugherty C, Ratain MJ, Grochowski E, et al Perceptions of cancer patients and their physicians involved in phase I trials J Clin Oncol 1995 13(5):1062 72 7738612
Daugherty CK, Siegler M, Ratain MJ, et al Learning from our patients: one participant's impact on clinical trial research and informed consent Ann Intern Med 1997 Jun 1 126(11):892 7
Daugherty CK, Ratain MJ, Minami H, et al Study of cohort-specific consent and patient control in phase I cancer trials J Clin Oncol 1998 Jul 16(7):2305 12 9667244
Daugherty CK Ethical issues in the development of new agents Invest New Drugs 1999 17(2):145 53 10638485
Daugherty CK Informed consent, the cancer patient, and phase I clinical trials Cancer Treat 2000 102(1):77 89
Davey C, Austoker J, Jansen C Improving written information for women about cervical screening: evidence-based criteria for the content of letters and leaflets Health Educ J 1998 Sep 57(3):263 81
Davey DA HRT, cancer and cardiovascular disease -- second thoughts? S Afr Med J 2000 90(10):994 6 11081103
Davidson JR, Brundage MD. What information do people need before choosing a cancer treatment?. Med Decis Making. 1994;14.
Davidson JR, Brundage MD, Feldman-Stewart D Lung cancer treatment decisions: patients' desires for participation and information Psychooncology 1999 Nov 8(6):511 20 10607984
Davis SW, Stone JC, Seay JA, et al. Clinical trials booklet evaluation. Prog Clin Biol Res. 1990;339:409-17. [pmid: 2392433].
Davis SW, Nealon EO, Stone JC. Evaluation of the National Cancer Institute's clinical trials booklet. J Natl Cancer Inst. 1993;14:139-45.
Davis TC, Arnold C, Berkel HJ, et al Knowledge and attitude on screening mammography among low-literate, low-income women Cancer 1996 78(9):1912 20 8909311
Davison BJ, Degner LF, Morgan TR Information and decision-making preferences of men with prostate cancer Oncol Nurs Forum 1995 Oct 22(9):1401 8 8539181
Davison BJ, Degner LF Empowerment of men newly diagnosed with prostate cancer Cancer Nurs 1997 Jun 20(3):187 96 9190093
Davison BJ, Degner LF Promoting patient decision making in life-and-death situations Sem Oncol Nurs 1998 May 14(2):129 36
Davison BJ, Kirk P, Degner LF, et al Information and patient participation in screening for prostate cancer Patient Educ Couns 1999 37(3):255 63 14528551
Davison C, Macintyre S, Smith GD The Potential Social Impact of Predictive Genetic Testing for Susceptibility to Common Chronic Diseases: A Review and Proposed Research Agenda Sociol Health Illn 1994 16(3):340 71 11660089
Dawson NA Response criteria in prostatic carcinoma Semin Oncol 1999 Apr 26(2):174 84 10597728
de-Vries-Kragt K The dilemmas of a carrier of BRCA1 gene mutations Patient Educ Couns 1998 35(1):75 80 9832899
de Flon S, Ramm K, Piene H Quality assurance -- a tool for improving information to patients J Cancer Care 1995 Jan 4(1):17 20
de Gonzalez V, Bertolino L, Pavlovsky S. Argentina. Telling the truth to cancer patients in a multicultural society. Ann N Y Acad Sci. 1997 Feb 20;809:152-62.
de Haes JC, Stiggelbout AM Assessment of values, utilities and preferences in cancer patients Cancer Treat Rev 1996 Jan 22Suppl A:13 26 8625338
De Trill M, Kovalcik R. The child with cancer. Influence of culture on truth-telling and patient care. Ann N Y Acad Sci. 1997 Feb 20;809:197-210.
Deber R, Kraetschmer N, Trachtenberg J Shared decision making: How does one measure success? Med Decis Making 1994 14(4):429
Deber RB, Kraetschmer N, Irvine J What role do patients wish to play in treatment decision making? Arch Intern Med 1996 Jul 8 156(13):1414 20
deChristopher J Children with cancer: their perceptions of the health care experience Top Clin Nurs 1981 Jan 2(4):9 19 7003829
Decruyenaere M, Evers KG, Denayer L, et al Predictive testing for hereditary breast and ovarian cancer: A psychological framework for pre-test counselling Eur J Hum Genet 2000 8(2):130 6 10757645
Decruyenaere M, Evers-Kiebooms G, Welkenhuysen M, et al Cognitive representations of breast cancer, emotional distress and preventive health behaviour: a theoretical perspective Psychooncology 2000 9(6):528 36 11180588
Degen R, Holthausen H, Wolf P The genetics of localization-related symptomatic epilepsy: risk of a family history with seizures in patients who have undergone surgery J Neurol 1997 244(7):439 45 9266463
Degner L Patient participation in treatment decision making Axon 1992 Sep 14(1):13 4 1476947
Degner L, Goodwin C, Carriere KC, et al Clinical trial of a computer-assisted intervention for women with breast cancer: a study in progress Can Oncol Nurs J 1997 May 7(2):
Degner LF, Russell CA Preferences for treatment control among adults with cancer Res Nurs Health 1988 Dec 11(6):367 74 3231738
Degner LF, Sloan JA Decision making during serious illness: what role do patients really want to play? J Clin Epidemiol 1992 Sep 45(9):941 50 1432023
Degner LF, Kristjanson LJ, Bowman D, et al Information needs and decisional preferences in women with breast cancer JAMA 1997 May 14 277(18):1485 92
Degner LF, Davison BJ, Sloan JA, et al Development of a scale to measure information needs in cancer care J Nurs Meas 1998 6(2):137 53 10028780
Degner LF Preferences to participate in treatment decision making: the adult model J Pediatr Oncol Nurs 1998 Jul 15(3 Suppl 1):3 9 9700236
DeGregorio MW; Wiebe VJ. Tamoxifen and breast cancer. Yale Univ Press (New Haven, CT); 1996.
Deleyiannis FB, Weymuller J Outcomes research in head and neck oncology Curr Opin Otolaryn Head Neck Surg 1996 4(2):73 7
Delvaux N, Razavi D. Psychological training for health-care professionals in oncology. A way to improve communication skills. Ann N Y Acad Sci. 1997 Feb 20;809:336-49.
Demin E. Communication with the breast-cancer patient. An opinion from Russia. Ann N Y Acad Sci. 1997 Feb 20;809:485-95. [pmid: 9103598].
Demoly P, Pujol JL, Lioux C, et al Informed consent and the physician-patient relations in thoracic oncology Presse Med 1991 Oct 5 20(31):1487 90
DePalma A Prostate Cancer Shared Decision: a CD-ROM educational and decision-assisting tool for men with prostate cancer Semin Urol Oncol 2000 Aug 18(3):178 81 10975488
Derdiarian AK Effects of information on recently diagnosed cancer patients' and spouses' satisfaction with care Cancer Nurs 1989 Oct 12(5):285 92 2804964
Dermatis H, Lesko LM Psychosocial correlates of physician-patient communication at time of informed consent for bone marrow transplantation Cancer Nurs 1991 9(6):621 8
Desch CE, Penberthy LT, Hillner BE, et al A sociodemographic and economic comparison of breast reconstruction, mastectomy, and conservative surgery Surgery 1999 125(4):441 7 10216535
Desforges JF Diagnostic planning using computer assisted decision-making for the patient with Hodgkin's disease Bull Cancer 1980 67(4):418 23 7013862
Detweiler JB, Bedell BT, Salovey P, et al Message framing and sunscreen use: gain-framed messages motivate beach-goers Health Psychol 1999 Mar 18(2):189 96 10194055
Deutsch G Improving communication with oncology patients: taping the consultation Clin Oncol (R Coll Radiol) 1992 Jan 4(1):46 7 1736980
Devereux JA, Jones DP, Dickenson DL Can children withhold consent to treatment? BMJ 1993 May 29 306(6890):1459 61
Devine EC, Westlake SK The effects of psychoeducational care provided to adults with cancer: meta-analysis of 116 studies Oncol Nurs Forum 1995 Oct 22(9):1369 81 8539178
Diamond GA, Rozanski A, Steuer M Playing doctor: application of game theory to medical decision-making J Chronic Dis 1986 39(9):669 82 3734022
Diefenbach PN, Ganz PA, Pawlow AJ, et al Screening by the prostate-specific antigen test: what do the patients know? J Cancer Educ 1996 11(1):39 44 8777154
Dietz BJ, Lovett JM, Cox D Patient teaching booklet on chemotherapy made flexible through the use of individual drug cards Oncol Nurs Forum 1978 Oct 5(4):
Diez B, Lascar E, Alizade A. Talking to a child with cancer. A valuable experience. Ann N Y Acad Sci. 1997 Feb 20;809:142-51.
Dijkstra A, de Vries H, Roijackers J, et al Tailoring information to enhance quitting in smokers with low motivation to quit: three basic efficacy questions Health Psychol 1998 Nov 17(6):513 9 9848801
Dijkstra A, de Vries H, Roijackers J Targeting smokers with low readiness to change with tailored and nontailored self-help materials Prev Med 1999 Feb 28(2):203 11 10048112
Doak CC, Doak LG, Friedell GH, et al Improving comprehension for cancer patients with low literacy skills: strategies for clinicians CA: Cancer J Clin 1998 May 48(3):151 62 9594918
Doak LG, Doak CC, Meade CD Strategies to improve cancer education materials Oncol Nurs Forum 1996 Sep 23(8):1305 12 8883075
Dodd MJ Measuring informational intervention for chemotherapy knowledge and self-care behavior Res Nurs Health 1984 Mar 7(1):43 50 6565300
Dohan MC Reflections on a bone marrow transplant Ann Intern Med 2000 132(7):589 90 10744598
Dolan JG Are patients capable of using the analytic hierarchy process and willing to use it to help make clinical decisions? Med Decis Making 1995 Jan 15(1):76 80 7898301
Dolan JG. Involving patients in decisions regarding preventive health interventions using the analytic hierarchy process. Health Expect. 2000;3:37-45. [pmid: 11281910].
Dolan JG, Kerr J Colorectal cancer screening: a multicriteria decision analysis Med Decis Making 1998 Oct 18(4):488
Dole GF, Carney PA Characteristics of underserved women who did and those who did not use a free/low-cost voucher as part of a mammography screening program J Cancer Educ 1998 13(2):102 7 9659629
Donabedian A Commentary: physician behavior in response to additional diagnostic information Inquiry 1982 19(1):89 90 6461604
Donaghy KB Biopsychosocial factors in breast cancer treatment decisions: development of the Breast Cancer Treatment Inventory Dissertation Abstracts International: Section B: The Sciences and Engineering 1998 59(3-B):
Doudna C Patient focused breast care Adm Radiol J 1996 15(4):20 1 10157771
Dougherty L, Stuttaford J Patient education. Turning over a new leaflet... booklets designed specifically for cancer patients Nurs Times 1993 Nov 10 89(45):46 8
Douglas MS Perspective of the patient advocate Obstet Gynecol Surv 1998 53(10 Suppl.):
Doukas DJ, Doukas MA Considering advance directives for oncology patients Prim Care 1998 25(2):423 31 9628961
Dow KH Having children after breast cancer Cancer Pract 1994 Nov 2(6):407 13 7697079
Downs SH, Black N The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions J Epidemiol Community Health 1998 Jun 52(6):377 84 9764259
Dowsett SM, Saul JL, Butow PN, et al Communication styles in the cancer consultation: preferences for a patient-centered approach Psychooncology 2000 9(2):147 56 10767752
Drossaert CH, Boer H, Seydel ER Health education to improve repeat participation in the Dutch breast cancer screening programme: evaluation of a leaflet tailored to previous participants Patient Educ Couns 1996 Jul 28(2):121 31 8852086
Du PS, Du PA, Polissar N, et al Implementing guidelines for cancer pain management: results of a randomized controlled clinical trial J Clin Oncol 1999 17(1):361 70 10458255
Dudjak, L.A. A study of factors influencing the decision to participate in a cancer control clinical trial University of Pittsburgh. 1997.
Duffy TP When to let go Nurs Times 1992 Apr 2 326(14):933 5
Dunaway FW, Hueston WJ, Clevinger L An exploratory study of the experiences of rural women with breast cancer J Ky Med Assoc 1995 Jun 93(6):241 5 7622959
Dunn SM, Butow PN, Tattersall MH, et al General information tapes inhibit recall of the cancer consultation J Clin Oncol 1993 Nov 11(11):2279 85 8229143
Dunsmore J, Quine S Information, support, and decision-making needs and preferences of adolescents with cancer: implications for health professionals J Psychosoc Oncol 1995 13(4):39 56
Durbin M From both sides now: a parent-physician's view of parent-doctor relationships during pediatric cancer treatment Pediatrics 1997 100(2):263 7 9240810
Durfy SJ, Bowen DJ, McTiernan A, et al Attitudes and interest in genetic testing for breast and ovarian cancer susceptibility in diverse groups of women in western Washington Cancer Epidemiol Biomarkers Prev 1999 8(4 II):369 75 10207642
Durie BM, Ludwig H, Fritz E, et al Which risk/benefit tradeoffs would lead patients with myeloma to opt for inteferon treatment? Cancer Res Ther Control 1998 6(1-4):143 4
Dutton S, Evans M, Johnson C, et al We can make it: teenagers' guide to beating cancer Oncol Nurs Forum 1990 Nov 17(6):930 6 1702209
Dwyer J Nutrition education of the cancer patient and family. Myths and realities Cancer 1986 Oct 15 58(8 Suppl):1887 96 3756810
Dwyer ML The oncology patient's experience in making a treatment decision Dissertation Abstracts International 1993 54(3B):
Eardley A, Elkind A, Spencer B, et al Health education in a computer-managed cervical screening programme Health Educ J 1988 47(2-3):43 7 10292169
Early DS, Saifuddin T, Johnson JC, et al Patient attitudes toward undergoing colonoscopy without sedation Am J Gastroenterol 1999 94(7):1862 5 10406249
Eddleman J, Warren C Cancer resource center Cancer Pract 1994 Sep 2(5):371 8 7697076
Eddy DM Clinical decision making: from theory to practice. Anatomy of a decision JAMA 1990 Jan 263(3):441 3 2294311
Eden OB, Black I, Emery AE The use of taped parental interviews to improve communication with childhood cancer families Pediatr Hematol Oncol 1993 Apr 10(2):157 62 8318371
Edwards A, Elwyn G How should effectiveness of risk communication to aid patients' decisions be judged? A review of the literature Med Decis Making 1999 Oct 19(4):428 34 10520681
Edwards A, Hood K, Matthews E et al Personalized risk communication in health screening programs (Protocol) the Cochrane Library 2000Issue 3.Oxford Update software
Edwardson SR The choice between hospital and home care for terminally ill children Nurs Res 1983 Jan 32(1):29 34 6549840
Efimov GA, Krasnov YO, Chigirinskii LM Survival of lung cancer patients who refused surgical treatment Vop Onkol 1980 26(4):79 84
Ehmann JL Rehabilitation... breast cancer rehabilitation J Gynecol Oncol Nurs 1997 7(1):27 37
Eisen A, Rebbeck TR, Wood WC, et al Prophylactic surgery in women with a hereditary predisposition to breast and ovarian cancer J Clin Oncol 2000 May 18(9):1980 95 10784640
Eisen SA, Waterman B, Skinner CS, et al Sociodemographic and health status characteristics associated with prostate cancer screening in a national cohort of middle-aged male veterans Urology 1999 53(3):516 22 10096377
Eiser C, Havermans T, Craft A, et al Development of a measure to assess the perceived illness experience after treatment for cancer Arch Dis Child 1995 Apr 72(4):302 7 7763060
Eiser C, Havermans T Children's understanding of cancer Psychooncology 1992 1(3):169 81
Eisinger F, Sobol H, Seitz JF Risk management for familial adenomatous polyposis and lynch syndrome Ann Gastroenterol Hepatol (Paris) 1997 33(2):67 72
Eisinger F Ethics and oncogenetics. How to deal with contradictions? Bull Cancer 1998 85(3):246 50 9752314
Eisinger F, Alby N, Bremond A, et al Recommendations for medical management of hereditary breast and ovarian cancer: The INSERM-FNCLCC ad hoc committee Ann Genet 1999 42(1):51 64 10214508
Ekert H Long term needs of children and parents with chronic life threatening diseases Aust Fam Physician 1983 Apr 12(4):237 1 6615346
el-Ghazali S. Is it wise to tell the truth, the whole truth, and nothing but the truth to a cancer patient?. Ann N Y Acad Sci. 1997 Feb 20;809:97-108. [pmid: 9103561].
Elger BS, Harding TW Testing adolescents for a hereditary breast cancer gene (BRCA1): respecting their autonomy is in their best interest Arch Pediatr Adolesc Med 2000 Feb 154(2):113 9 10665596
Elit LM, Levine MN, Gafni A, et al Patients' preferences for therapy in advanced epithelial ovarian cancer: development, testing, and application of a bedside decision instrument Gynecol Oncol 1996 Sep 62(3):329 35 8812525
Ellamushi HE, Khan R, Kitchen ND Consent to surgery in a high risk speciality: a prospective audit Ann R Coll Surg Engl 2000 82(3):213 6 10858689
Ellerby JH, McKenzie J, McKay S, et al Bioethics for clinicians: 18. Aboriginal cultures Can Med Assoc J 2000 Oct 3 163(7):845 50
Ellis DA, Hopkin JM, Leitch AG, et al "Doctors' orders": controlled trial of supplementary, written information for patients BMJ 1979 Feb 17 1(6161):
Ellis J, O'Connor A, Dunning J, et al The incidence and correlates of non-adherence in adolescents receiving chemotherapy Can Oncol Nurs J 1992 Feb 2(1):3 7
Ellis P Improving recruitment to cancer clinical trials Cancer Forum 1999 23(3):153 5
Ellis PM, Dowsett SM, Butow PN, et al Attitudes to randomized clinical trials amongst out-patients attending a medical oncology clinic Health Expect 1999 2(1):33 43 11281873
Ely EA Collaborative practice with children and parents. Enhancing preparation for and management of cancer treatment Cancer Pract 1997 Nov 5(6):387 90 9397708
Emanuel EJ, Emanuel LL Four models of the physician-patient relationship JAMA 1992 Apr 22 267(16):2221 6
Emery E, Kehrli P, Nataf F, et al Brain metastases: Therapeutic strategy Neurochirurgie 1999 45(5):398 400 10717589
Ende J, Kazis L, Ash A, et al Measuring patients' desire for autonomy: decision making and information-seeking preferences among medical patients J Gen Intern Med 1989 Jan 4(1):23 30 2644407
Eng C, Clayton D, Schuffenecker I, et al The relationship between specific ret proto-oncogene mutations and disease phenotype in multiple endocrine neoplasia type 2: International RET mutation consortium analysis JAMA 1996 276(19):1575 9 8918855
Enterline JP, Lenhard REJ, Blum BI, et al OCIS: 15 years' experience with patient-centered computing MD Comput 1994 Mar 11(2):83 91 8201891
Entwistle VA, Watt IS Disseminating information about healthcare effectiveness: a survey of consumer health information services Qual Health Care 1998 7(3):124 9 10185137
Entwistle VA, Sowden AJ, Watt IS Evaluating interventions to promote patient involvement in decision-making: by what criteria should effectiveness be judged? J Health Serv Res Policy 1998 Apr 3(2):100 7 10180658
Entwistle VA. Supporting and resourcing treatment decision-making: some policy considerations. Health Expect. 2000;3:77-85. [pmid: 11281914].
Erikson J Breast cancer activists seek voice in research decisions Science 1995 269(5230):1508 9 7667631
Ernster VL Mammography screening for women aged 40 through 49 -- a guidelines saga and a clarion call for informed decision making Am J Public Health 1997 Jul 87(7):1103 6 9240097 1380881
Espie M, Cuvier C Treating breast cancer during pregnancy. What can be taken safely? Drug Saf 1998 18(2):135 42 9512920
Estabrooks, C A, Goel, V, Thiel, E et al. Consumer Decision Aids: where do we stand? A systematic review of structured consumer decision aids. Institute for Clinical Evaluative Sciences. 00-01-TR. 2000.
Estey A, Musseau A, Keehn L Comprehension levels of patients reading health information Patient Educ Couns 1991 Oct 18(2):165 9
Etzioni R, Thompson IM, Prout-GR J Prostate cancer and computer models: Background, limitations, and potential Urol Oncol 1996 2(2):57 64 21224137
Evans AL, Brody BA The do-not-resuscitate order in teaching hospitals JAMA 1985 Apr 253(15):2236 9 3974115
Evans D An ethical dilemma: the dishonest doctor Nurs Forum 1995 Jul 30(3):5 11 7659550
Evans MI, Pryde PG, Evans WJ, et al The choices women make about prenatal diagnosis Fetal Diag Ther 1993 Apr 8Suppl 1:70 80
Evason R I am 60 and I have cancer Can Med Assoc J 1995 152(1):84 6 7804923 1337497
Everheart C Taking care of yourself for life: health promotion and education for child-cancer survivors J Pediatr Oncol Nurs 1991 Apr 8(2):58 9 1675066
Exposito HJ Decision making in oncology: 1. How do we decide? Oncologia 1995 18(7):73 9
Exposito J Decision making in oncology: 2. Could we improve it? Oncologia 1995 18(9):63 8
Faden R, Faden A False belief and the refusal of medical treatment J Med Ethics 1977 Sep 3(3):133 6 926132
Faivre J, Arveux P, Milan C, et al Participation in mass screening for colorectal cancer: results of screening and rescreening from the Burgundy study Eur J Cancer Prev 1991 Oct 1(1):49 55
Fallowfield L. Truth sometimes hurts but deceit hurts more. Ann N Y Acad Sci. 1997 Feb 20;809:525-36. [pmid: 9103603].
Fallowfield L Offering choice of surgical treatment to women with breast cancer Patient Educ Couns 1997 Mar 30(3):209 14 9104377
Fallowfield L, Jenkins V Effective communication skills are the key to good cancer care Eur J Cancer 1999 Oct 35(11):1592 7 10673967
Fallowfield LJ, Hall A, Maguire GP, et al Psychological outcomes of different treatment policies in women with early breast cancer outside a clinical trial BMJ 1990 Sep 22 301(6752):575 80
Fallowfield LJ Quality of life measurement in breast cancer J R Soc Med 1993 Jan 86(1):10 2 8423565 1293814
Fallowfield LJ, Hall A, Maguire P, et al Psychological effects of being offered choice of surgery for breast cancer BMJ 1994 Aug 13 309(6952):
Fallowfield LJ, Jenkins V, Brennan C, et al Attitudes of patients to randomised clinical trials of cancer therapy Eur J Cancer 1998 Sep 34(10):1554 9 9893627
Falvo DR, Tippy PK. Comparison of interventions to increase asymptomatic women's use of mammography screening. Health Values: The Journal of Health Behavior, Education and Promotion. 1993:12-7.
Faria SL, Souhami L. Communication with the cancer patient. Information and truth in Brazil. Ann N Y Acad Sci. 1997 Feb 20;809:163-71.
Farmer AJ The minimization to clients of screen-detected breast cancer: a qualitative analysis J Adv Nurs 2000 Feb 31(2):306 13 10672087
Farrow DC, Hunt WC, Samet JM Temporal and regional variability in the surgical treatment of cancer among older people J Am Geriatr Soc 1996 44(5):559 64 8617905
Faulkenberry JE, Palos L, Canel ME Cancer screening: an educational program for employees AAOHN J 1987 Nov 35(11):478 84 3675749
Faulkner A, Regnard C Handling difficult questions in palliative care -- a flow diagram Palliat Med 1994 Jul 8(3):245 50 7524971
Fawzy FI, Fawzy NW, Arndt LA, et al Critical review of psychosocial interventions in cancer care. [Review] [60 refs] Arch Gen Psychiatry 1995 Feb 52(2):100 13 7848046
Feldman-Stewart D, Chammas S, Hayter C, et al An empirical approach to informed consent in ovarian cancer J Clin Epidemiol 1996 Nov 49(11):1259 69 8892494
Feldman-Stewart D, Brundage MD, Hayter C, et al What prostate cancer patients should know: variation in professionals' opinions Radiother Oncol 1998 Nov 49(2):111 23 10052876
Feldman-Stewart D, Brundage MD, McConnell BA. Practical issues in assisting shared decision-making. Health Expect. 2000;3:46-54. [pmid: 11281911].
Feldman-Stewart D, Brundage MD, Hayter C, et al What questions do patients with curable prostate cancer want answered? Med Decis Making 2000 Jan 20(1):7 19 10638532
Feldman-Stewart D, Kocovski N, McConnell BA, et al Perception of quantitative information for treatment decisions Med Decis Making 2000 Apr 20(2):228 38 10772360
Feldman-Stewart D, Brundage MD, Nickel JC, et al The information required by patients with early-stage prostate cancer in choosing their treatment BJU International 2001 87(3):218 23 11167645
Feldman MD, Zhang J, Cummings SR Chinese and U. S. Internists adhere to different ethical standards J Gen Intern Med 1999 14(8):469 73 10491230 1496727
Feldman SD, Brundage MD, McConnell BA, et al Practical issues in assisting shared decision-making Health Expect 2000 3(1):46 54 11281911
Fennelly JJ. Being honest with the patient and ourselves: do we give our patients accurate insight into anticipated results of treatment? An Irish perspective. Ann N Y Acad Sci. 1997 Feb 20;809:393-9. [pmid: 9103590].
Ferdjaoui N, Carrere MO, Charavel M, et al Integrating patients' preferences in therapeutic decisions in cancer: Development of a decision board J Econ Med 1999 17(5):327 42
Fernsler JI, Cannon CA The whys of patient education Sem Oncol Nurs 1991 May 7(2):79 86
Fernsler JI, Manchester LJ Evaluation of a computer-based cancer support network Cancer Pract 1997 Jan 5(1):46 51 9128496
Ferrante JM Colorectal cancer screening Med Clin North Am 1996 80(1):27 43 8569299
Ferrell BR, Rivera LM Ethical decision making in oncology. A case study approach Cancer Pract 1995 3(2):94 9 7704076
Ferrell BR, Virani R, Grant M HOPE: Home Care Outreach for Palliative Care Education Cancer Pract 1998 6(2):79 85 9573907
Ferriols LR, Ferriols LF, Alos AM, et al Quality of life in clinical oncology Farm Hosp 1995 19(6):315 22
Ferris DG, Golden NH, Petry LJ, et al Effectiveness of breast self-examination prompts on oral contraceptive packaging J Fam Pract 1996 Jan 42(1):43 8 8537804
Fetting JH, Siminoff LA, Piantadosi S, et al Effect of patients' expectations of benefit with standard breast cancer adjuvant chemotherapy on participation in a randomized clinical trial: a clinical vignette study J Clin Oncol 1990 Sep 8(9):1476 82 2202790
Fey MF, Sauter C, Alberto P Chenotherapy for gastrointestinal cancer and non-small lung cancer: a controversial issue Schweiz Med Wochenschr 1996 126(20):872 8 8685683
Fielding R, Hung J Preferences for information and involvement in decisions during cancer care among a Hong Kong Chinese population Psychooncology 1996 5(4):321 9
Fieler VK, Borch A Results of a patient education project using a touch-screen computer Cancer Pract 1996 Nov 4(6):341 5 9128487
Finkelstein M, Love N When should tamoxifen be offered for breast cancer prevention? A practical look at risk-benefit issues Postgrad Med 1999 105(6):61 78
Finlay I End-of-life care in patients dying of gynecologic cancer Hematol Oncol Clin North Am 1999 13(1):77 108 10080071
Finney K Commentary on Effects on mastectomy versus lumpectomy on emotional adjustment to breast cancer: a prospective study of the first year postsurgery ONS Nursing Scan in Oncology 1992 Nov 1(4):14 5
Fiset V, O'Connor AM, Evans W, et al Development and evaluation of a decision aid for patients with stage IV non-small cell lung cancer Health Expect 2000 3(2):125 36 11281919
Fisher B Justification for lumpectomy in the treatment of breast cancer: a commentary on the underutilization of that procedure J Am Med Womens Assoc 1992 Sep 47(5):169 73 1460221
Fisher DL Parents Confronting and Comprehending the Medical and Nightmare Worlds of Childhood Leukemia Dissertation Abstracts International Section A: Humanities and Social Sciences 1987 47(8):3192 A
Fisher G, Mayer DK, Yon JL, et al The impact of patient anger and resentment on treatment decisions Cancer Pract 1997 Sep 5(5):274 8 9341349
Fisher S Doctor-patient communication: a social and micro-political performance Sociol Health Illn 1984 Mar 6(1):1 29 10266301
Fisher S. And another time, dear, we'll need to do a pap smear: the unfolding phases of medical discourse. In: Fisher S, editors. In the patient's best interest: women and the politics of medical decisions. New Brunswick, N.J.: Rutgers University Press. 1986;4:p. 91-129.
Fitch MI, Greenberg M, Cava M, et al Exploring the barriers to cervical screening in an urban Canadian setting Cancer Nurs 1998 21(6):441 9 9849002
Fitch MI, Johnson B, Gray R, et al Survivors' perspectives on the impact of prostate cancer: implications for oncology nurses Can Oncol Nurs J 1999 9(1):23 34 10232144
Fletcher DM, Rosenzweig MQ Clinical issues. Decision making in breast cancer: clinical and personal factors Innovations in Breast Cancer Care 1999 4(3):82 90
Fletcher SW, Harris RP, Gonzalez JJ, et al Increasing mammography utilization: a controlled study J Natl Cancer Inst 1993 Jan 20 85(2):112 20
Flood AB, Wennberg JE, Nease RFJ, et al The importance of patient preference in the decision to screen for prostate cancer. Prostate Patient Outcomes Research Team J Gen Intern Med 1996 Jun 11(6):342 9 8803740
Fogarty LA Message, source and person factors in breast cancer treatment decision-making Dissertation Abstracts International: Section B: The Sciences and Engineering 1996 57(5-B):
Foley EC, D'Amico F, Merenstein JH Five-year follow-up of a nurse-initiated intervention to improve mammography recommendation J Am Board Fam Pract 1995 Nov 8(6):452 6 8585403
Foley GV Enhancing child-family-health team communication Cancer 1993 May 15 71(10 Suppl):3281 9 8490869
Foltz A, Sullivan J Reading level, learning presentation preference, and desire for information among cancer patients J Cancer Educ 1996 11(1):32 8 8777153
Foltz AT, Sullivan JM Limited literacy revisited: implications for patient education Cancer Pract 1999 May 7(3):145 50 10352077
Fong YF, Lim FK, Arulkumaran S Prophylactic oophorectomy: a continuing controversy Obstet Gynecol Surv 1998 53(8):493 9 9702789
Ford S, Fallowfield L, Hall A, et al The influence of audiotapes on patient participation in the cancer consultation Eur J Cancer 1995 Dec 31A(13-14):2264 9
Ford S, Hall A, Ratcliffe D, et al The Medical Interaction Process System (MIPS): an instrument for analysing interviews of oncologists and patients with cancer Soc Sci Med 2000 Feb 50(4):553 66 10641807
Forsyth MC, Fulton DL, Lane DS, et al Changes in knowledge, attitudes and behavior of women participating in a community outreach education program on breast cancer screening Patient Educ Couns 1992 Jun 19(3):241 50 1300622
Foster P, Anderson CM Reaching targets in the national cervical screening programme: are current practices unethical? J Med Ethics 1998 Jun 24(3):151 7 9650108
Fox SA, Stein JA The effect of physician-patient communication on mammography utilization by different ethnic groups Med Care 1991 Nov 29(11):1065 82 1943268
Fox SA, Roetzheim RG Screening mammography and older Hispanic women. Current status and issues Cancer 1994 Oct 1 74(7 Suppl):2028 33
Fox SA, Roetzheim RG, Kington RS Barriers to cancer prevention in the older person Clin Geriatr Med 1997 Feb 13(1):79 95 8995102
Foxwell M, Alder E More information equates with less anxiety. Reducing anxiety in cervical screening Prof Nurse 1993 Oct 9(1):32 6 8415785
Frank E, Baldwin G, Langlieb AM Continuing medical education habits of US women physicians J Am Med Womens Assoc 2000 55(1):27 8 10680404
Frank TS Testing for hereditary risk of ovarian cancer Cancer Control 1999 6(4):327 4 10758563
Frank TS, Braverman AM The pros and cons of genetic testing for breast and ovarian cancer risk Int J Fertil Womens Med 1999 44(3):139 45 10435912
Fredette SL A model for improving cancer patient education Cancer Nurs 1990 Aug 13(4):207 15 2208096
Freeborne N, Lynn J, Desbiens NA Insights about dying from the SUPPORT project. The Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments J Am Geriatr Soc 2000 May 48(5 Suppl):S199 S205 10809476
Freedman JD, Mitchell CK A simple strategy to improve patient adherence to outpatient fecal occult blood testing J Gen Intern Med 1994 Aug 9(8):462 4 7965243
Freeman WT, Walker PG Counselling patients referred for colposcopy CME J Gynecol Oncol 2000 5(1):60 3
Freireich EJ. Ethical considerations in cancer chemotherapy. Ann Rev Pharmacol Toxicol. 1979;19:547-57. [pmid: 88204].
Frogge MH, Vance RB, Meyer M, et al Multidisciplinary rounds: patient-family-staff dynamics: when the patient/family are colleagues Cancer Pract 1998 Sep 6(5):258 61 9767343
Gabel M, Hilton NE, Nathanson SD Multidisciplinary breast cancer clinics. Do they work? Cancer 1997 Jun 15 79(12):2380 4
Gafni A, Charles C, Whelan T The physician-patient encounter: the physician as a perfect agent for the patient versus the informed treatment decision-making model [see comments] Soc Sci Med 1998 Aug 47(3):347 54 9681904
Galavotti C, Richter DL Talking about hysterectomy: the experiences of women from four cultural groups J Womens Health Gender-based Med 2000 9(Suppl 2):S63 S67
Gallot D Multiple cancers of the colon. Cancers and polyps. Should total colectomy be performed? Ann Chir 1989 43(9):709 13 2604357
Galloway S, Graydon J, Harrison D, et al Informational needs of women with a recent diagnosis of breast cancer: development and initial testing of a tool J Adv Nurs 1997 Jun 25(6):1175 83 9181414
Gamble K Communication and information: the experience of radiotherapy patients Eur J Cancer Care (Engl) 1998 Sep 7(3):153 61 9793006
Gambone JC, Reiter RC Hysterectomy: improving the patient's decision-making process Clin Obstet Gynecol 1997 Dec 40(4):868 77 9429800
Ganz PA, Schag AC, Lee JJ, et al Breast conservation versus mastectomy. Is there a difference in psychological adjustment or quality of life in the year after surgery? Cancer 1992 Apr 1 69(7):1729 38
Ganz PA Age and gender as factors in cancer therapy Clin Geriatr Med 1993 Feb 9(1):145 55 8443732
Ganz PA Advocating for the woman with breast cancer CA: Cancer J Clin 1995 Mar 45(2):114 26 7889390
Ganz PA, Greendale GA, Kahn B, et al Are older breast carcinoma survivors willing to take hormone replacement therapy? Cancer 1999 Sep 1 86(5):814 20
Ganz PA, Greendale GA, Petersen L, et al Managing menopausal symptoms in breast cancer survivors: results of a randomized controlled trial J Natl Cancer Inst 2000 Jul 5 92(13):1054 64
Garber J A 40-year-old woman with a strong family history of breast cancer JAMA 1999 Nov 24 282(20):1953 60 10580462
Gardiner JC, Mullan PB, Rosenman KD, et al Mammography usage and knowledge about breast cancer in a Michigan farm population before and after an educational intervention J Cancer Educ 1995 10(3):155 62 8534602
Garr DR, Ornstein SM, Jenkins RG, et al The effect of routine use of computer-generated preventive reminders in a clinical practice Am J Prev Med 1993 Jan 9(1):55 61 8439440
Garrett TJ, Vahdat LT, Kinne DW Systemic adjuvant therapy of breast cancer J Surg Oncol 1997 64(2):167 72 9047258
Garrison J, Abner J, Oakley M Accessibility and utilization of educational materials for cancer patients Oncol Nurs Forum 1983 10(2):60 2 6553322
Gascoigne P, Mason MD, Roberts E Factors affecting presentation and delay in patients with testicular cancer: results of a qualitative study Psychooncology 1999 8(2):144 54 10335558
Gaskin DJ, Kong J, Meropol NJ, et al Treatment choices by seriously ill patients: the Health Stock Risk Adjustment model Med Decis Making 1998 Jan 18(1):84 94 9456213
Gaspar M, Frank A, Peters K. Medical information from the viewpoint of the involved patients and physicians. Beitrage zur Gerichtlichen Medizin. 1985;43:37-9. [pmid: 4051985].
Gastrin G Preliminary results of primary screening for breast cancer with the Mama Program Soz Praventivmed 1993 38(5):280 7 8256530
Gattellari M, Butow PN, Tattersall MH, et al Misunderstanding in cancer patients: why shoot the messenger? Ann Oncol 1999 Jan 10(1):39 46 10076720
Gazzola M Roadmaps: what it's like J Pediatr Oncol Nurs 2000 17(4):253 4 11063519
Geiger AM, Mullen ES, Sloman PA, et al Evaluation of a breast cancer patient information and support program Eff Clin Pract 2000 Jul 3(4):157 65 11183430
Geller G, Botkin JR, Green MJ, et al Genetic testing for susceptibility to adult-onset cancer. The process and content of informed consent JAMA 1997 May 14 277(18):1467 74
Geller G, Strauss M, Bernhardt BA, et al "Decoding" informed consent. Insights from women regarding breast cancer susceptibility testing Hastings Cent Rep 1997 Mar 27(2):28 33
Geller G, Bernhardt BA, Doksum T, et al Decision-making about breast cancer susceptibility testing: how similar are the attitudes of physicians, nurse practitioners, and at-risk women? J Clin Oncol 1998 Aug 16(8):2868 76 9704741
Geller G, Doksum T, Bernhardt BA, et al Participation in breast cancer susceptibility testing protocols: influence of recruitment source, altruism, and family involvement on women's decisions Cancer Epidemiol Biomarkers Prev 1999 Apr 8(4 Pt 2):377 83 10207643
Gemer L Breast conservation therapy for breast cancer treatment in Brown County Wis Med J 1999 98(4):50 5
Gerard JP, Romestaing P, Marquis I, et al Evaluation of consequences of written informed consent on physician-patient relations. Apropos of Huriet's law Bull Cancer 1993 Oct 80(10):903 4 8204933
Gerber B, Krause A Patients' satisfaction in relation to information about possible operative treatment of primary breast cancer Zentralblatt fur Gynakologie 1997 119(4):149 53 9206919
Gess JK A Community Wide Study of the Hospice Referral Process Dissertation Abstracts International Section A: Humanities and Social Sciences 1999 60(6):2231 A
Ghavamzadeh A, Bahar B. Communication with the cancer patient in Iran. Information and truth. Ann N Y Acad Sci. 1997 Feb 20;809:261-5.
Giacomini MK, Cook DJ Users' guides to the medical literature: XXIII. Qualitative research in health care B. What are the results and how do they help me care for my patients? Evidence-Based Medicine Working Group JAMA 2000 284(4):478 82 10904512
Giacomini MK, Cook DJ Users' guides to the medical literature: XXIII. Qualitative research in health care A. Are the results of the study valid? Evidence-Based Medicine Working Group JAMA 2000 284(3):357 62 10891968
Giesler RB, Ashton CM, Brody B, et al Assessing the performance of utility techniques in the absence of a gold standard Med Care 1999 Jun 37(6):580 8 10386570
Gil F Hereditary breast cancer risk: factors associated with the decision to undergo BRCA 1 testing Eur J Cancer Prev 1996 Dec 5(6):488 90 9061281
Gilbar O, Steiner M When death comes: where should patients die? Hospice Journal -- Physical, Psychosocial, & Pastoral Care of the Dying 1996 11(1):31 48
Gilles MT, Crewe S, Granites IN, et al A community-based cervical screening program in a remote Aboriginal community in the Northern Territory Aust J Public Health 1995 Oct 19(5):477 81 8713197
Girgis A, Sanson-Fisher RW, Tripodi DA, et al Evaluation of interventions to improve solar protection in primary schools Health Educ Q 1993 20(2):275 87 8491638
Girgis A, Boyes A, Sanson-Fisher RW, et al Perceived needs of women diagnosed with breast cancer: rural versus urban location Aust N Z J Public Health 2000 Apr 24(2):166 73 10790936
Glajchen M Psychosocial consequences of inadequate health insurance for patients with cancer Cancer Pract 1994 Mar 2(2):115 20 8055013
Glajchen M, Moul JW Teleconferencing as a method of educating men about managing advanced prostate cancer and pain J Psychosoc Oncol 1996 14(2):73 87
Glasse L. Breast cancer screening in older women: the consumer perspective. J Gerontol. 1992 Nov. 47 Spec No:137-41.
Glavassevich M, McKibbon A, Thomas S Information needs of patients who undergo surgery for head and neck cancer Can Oncol Nurs J 1995 Feb 5(1):9 11
Glazer-Waldman HR, Francis S, Smith C Families' knowledge acquisition and written health materials Child Health Care 1987 15(3):152 5
Glazer HR, Kirk LM, Bosler FE Patient education pamphlets about prevention, detection, and treatment of breast cancer for low literacy women Patient Educ Couns 1996 Mar 27(2):185 9 8788348
Gobis LJ Recent developments in health law relevant to health care providers Nurse Pract 1992 Mar 17(3):77 80 1565304
Goel V, Sawka C, Thiel E, et al A randomized trial of a decision aid for breast cancer surgery Med Decis Making 1998 Oct 18(4):
Goel V, Sawka CA, Thiel EC, et al Randomized trial of a patient decision aid for choice of surgical treatment for breast cancer Med Decis Making 2001 21(1):1 6 11206942
Goetsch CM, Smith SM, Olopade OI, et al Assessing hereditary breast cancer risk Cancer Pract 1999 7(6):279 84 10732524
Gold JA The word from WIPRO: informing breast surgery patients about treatment options Wis Med J 1995 94(7):403 4 7571686
Goldberg RJ Systematic understanding of cancer patients who refuse treatment Psychother Psychosom 1983 39(3):180 9 6622631
Goldberg RJ Disclosure of information to adult cancer patients: issues and update J Clin Oncol 1984 Aug 2(8):948 55 6747672
Goldenberg SL, Ramsey EW, Jewett MA Prostate cancer: 6. Surgical treatment of localized disease Can Med Assoc J 1998 Nov 17 159(10):1265 71
Goldworth A Informed consent in the genetic age Camb Q Healthc Ethics 1999 8(3):393 400 10388939
Golin CE, Wenger NS, Liu H, et al A prospective study of patient-physician communication about resuscitation J Am Geriatr Soc 2000 48(5):S52 S60 10809457
Gomella LG, Albertsen PC, Benson MC, et al The use of video-based patient education for shared decision-making in the treatment of prostate cancer Semin Urol Oncol 2000 Aug 18(3):182 7 10975489
Gomella LG The wild, wild Web: resources for counseling patients with prostate cancer in the information age Semin Urol Oncol 2000 Aug 18(3):167 71 10975486
Gonzalez G. Health care in the United States. A perspective from the front line. Ann N Y Acad Sci. 1997 Feb 20;809:211-22. [pmid: 9103572].
Goodwin JS, Samet JM, Hunt WC Determinants of survival in older cancer patients J Natl Cancer Inst 1996 88(15):1031 8 8683633
Gotay CC Accrual to cancer clinical trials: directions from the research literature Soc Sci Med 1991 33(5):569 77 1962228
Gotay CC, Bultz BD Patient decision making inside and outside the cancer care system J Psychosoc Oncol 1986 4(1-2):105 14
Goyder E, Barratt A, Irwig LM Telling people about screening programmes and screening test results: how can we do it better? J Med Screen 2000 7(3):123 6 11126159
Grabski WJ, Salasche SJ Positive surgical excision margins of a basal cell carcinoma Dermatol Surg 1998 Aug 24(8):921 4 9723063
Grady KE, Kegeles SS, Lund AK, et al Who volunteers for a breast self-examination program? Evaluating the bases for self-selection Health Educ Q 1983 10(2):79 94 6671901
Grahn G "Learning to cope" -- an intervention in cancer care Support Care Cancer 1993 Sep 1(5):266 71 8156239
Grahn G Patient information as a necessary therapeutic intervention Eur J Cancer Care (Engl) 1996 Mar 5(1 Suppl):7 8 8715517
Graling PR, Grant JM Demographics and patient treatment choice in stage I breast cancer AORN Journal 1995 Sep 62(3):376 84 8534056
Gramlich EP, Waitzfelder BE Interactive video assists in clinical decision making Methods Inf Med 1998 Jun 37(2):201 5 9656665
Gramling A. Prostate cancer. [1 videocassette (30 min)]. Cinahl. New York: Time Life Medical. 1996. [pmcid: 190016].
Grandinetti D "Ethical hope" -- a lifeline for sick patients Med Econ 1999 76(15):118 28 10557815
Grann VR, Jacobson JS, Sundararajan V, et al The quality of life associated with prophylactic treatments for women with BRCA1/2 mutations Cancer J Sci Am 1999 Sep 5(5):283 92 10526669
Grant CHI, Cissna KN, Rosenfeld LB Patients' perceptions of physicians communication and outcomes of the accrual to trial process Health Communication 2000 12(1):23 39 10938905
Gray RE Persons with cancer speak out: reflections on an important trend in Canadian health care J Palliat Care 1992 8(4):30 7 1487790
Gray RE, Greenberg M, Fitch M, et al Perspectives of cancer survivors interested in unconventional therapies J Psychosoc Oncol 1997 15(3/4):149 71
Gray RE, Fitch M, Greenberg M A comparison of physician and patient perspectives on unconventional cancer therapies Psychooncology 1998 Nov 7(6):445 52 9885085
Gray RE, Greenberg M, Fitch M, et al A strategy for informing patients and health professionals about unconventional cancer therapies J Cancer Educ 1998 13(1):31 8 9565859
Gray RE, Greenberg M, Fitch M, et al Information needs of women with metastatic breast cancer Cancer Prev Control 1998 Apr 2(2):57 62 9765765
Gray RE, Philbrook A Prostate cancer: 13. Whose prostate is it anyway? The view from the other side of the examining table Can Med Assoc J 1999 Mar 23 160(6):833 6
Gray RE, Fitch M, Phillips C, et al To tell or not to tell: patterns of disclosure among men with prostate cancer Psychooncology 2000 9(4):273 82 10960925
Graydon J, Galloway S, Palmer-Wickham S, et al Information needs of women during early treatment for breast cancer J Adv Nurs 1997 Jul 26(1):59 64 9231278
Green LW. The future of cancer patient education. Health Educ Q. 1984;10 Suppl:102-10. [pmid: 6706611].
Green MJ, Fost N An interactive computer program for educating and counseling patients about genetic susceptibility to breast cancer J Cancer Educ 1997 12(4):204 8 9440011
Greenberg DL, Root RK Decision making by analogy N Engl J Med 1995 332(9):592 6 7838195
Greene DD. Personal stories within virtual environments: creating three experiences in cancer information software. Stud Health Technol Inform. 1998;50:193-5. [pmid: 10180538].
Greene DD, Heeter C. Personal stories within virtual environments: embodiments of a model for cancer patient information software. Stud Health Technol Inform. 1998;58:151-60. [pmid: 10350915].
Greenwald P Cancer risk factors for selecting cohorts for large-scale chemoprevention trials J Cell Biochem 1996 63(SUPPL. 25):29 36
Gregoire I, Kalogeropoulos D, Corcos J The effectiveness of a professionally led support group for men with prostate cancer Urol Nurs 1997 Jun 17(2):58 66 9239139
Gregory S, McKie L The smear test: women's views Nurs Standard 1991 May 8 5(33):32 6
Greimel ER, Gappmayer LE, Girardi FL, et al Increasing women's knowledge and satisfaction with cervical cancer screening J Psychosom Obstet Gynaecol 1997 18(4):273 9 9443137
Greiner L, Weiler C Early-stage breast cancer. What do women know about treatment choices? Am J Nurs 1983 Nov 83(11):
Gribble JN Informed consent documents for BRCA1 and BRCA2 screening: How large is the readability gap? Patient Educ Couns 1999 38(3):175 83 10865683
Griffiths F Women's control and choice regarding HRT Soc Sci Med 1999 49(4):469 81 10414807
Griffiths M, Leek C Patient education needs: opinions of oncology nurses and their patients Oncol Nurs Forum 1995 Jan 22(1):139 44 7708514
Gritz ER, Carr CR, Rapkin DA, et al A smoking cessation intervention for head and neck cancer patients: trial design, patient accrual, and characteristics Cancer Epidemiol Biomarkers Prev 1991 Nov 1(1):67 73 1845173
Gritz ER, Carr CR, Rapkin D, et al Predictors of long-term smoking cessation in head and neck cancer patients Cancer Epidemiol Biomarkers Prev 1993 May 2(3):261 70 8318879
Groff JY, Mullen PD, Byrd T, et al Decision making, beliefs, and attitudes toward hysterectomy: a focus group study with medically underserved women in Texas J Womens Health Gender-based Med 2000 9(Suppl. 2):S39 S50
Gross R, Jensen N Using evidence to make decisions Wis Med J 1999 Mar 98(2):53 6
Gross RE, Van Zee KJ, Heerdt AS The Special Surveillance Breast Program: a model of intervention for women at high risk for breast cancer J N Y State Nurses Assoc 1997 Dec 28(4):9 12 9564357
Grossi M Management and long-term complications of pediatric cancer Pediatr Clin North Am 1998 45(6):1637 58 9889769
Grunberger T, Gorlitzer M, Soliman T, et al Is it possible to renounce postoperative irradiation in a highly selected patient group of elderly breast cancer patients? Acta Chir Austriaca 1995 27(5-6):269 73
Guadagnoli E, Ward P Patient participation in decision-making Soc Sci Med 1998 Aug 47(3):329 39 9681902
Guidry JJ, Aday LA, Zhang D, et al Information sources and barriers to cancer treatment by racial/ethnic minority status of patients J Cancer Educ 1998 13(1):43 8 9565861
Guidry JJ, Walker VD Assessing cultural sensitivity in printed cancer materials Cancer Pract 1999 7(6):291 6 10732526
Gulavita S, Sinnott C, Setliff AE, et al. Short report: what do men with prostate cancer want to know?. Can Fam Physician. 2000 Sep;46:1769-71. [pmid: 11013795].
Gustafson D, Wise M, McTavish F, et al Development and pilot evaluation of a computer-based support system for women with breast cancer J Psychosoc Oncol 1993 11(4):69 93
Gustafson DH, Taylor JO, Thompson S, et al Assessing the needs of breast cancer patients and their families Qual Manag Health Care 1993 2(1):6 17 10131022
Gustafson DH, Robinson TN, Ansley D, et al Consumers and evaluation of interactive health communication applications. The Science Panel on Interactive Communication and Health Am J Prev Med 1999 16(1):23 9
Gustafson DH, Hawkins R, Boberg E, et al Impact of a patient-centered, computer-based health information/support system Am J Prev Med 1999 16(1):1 9
Guyatt GH, Sackett DL, Cook DJ Users' guides to the medical literature. II. How to use an article about therapy or prevention. A. Are the results of the study valid? Evidence-Based Medicine Working Group JAMA 1993 Dec 1 270(21):2598 601
Haasche A, Hassenstein U Needs and expectations of cancer patients from their physicians: what do patients expect? Geburtshilfe Frauenheilkd 1996 Mar 56(3):M39 M41
Haberfelde M, Coleman C, Rabinowitz FB, et al. Breast health. Krames Communications. 1993.
Hack TF, Degner LF, Dyck DG Relationship between preferences for decisional control and illness information among women with breast cancer: a quantitative and qualitative analysis Soc Sci Med 1994 Jul 39(2):279 89 8066506
Hack TF, Degner LF Coping with breast cancer: a cluster analytic approach Breast Cancer Res Treat 1999 54(3):185 94 10445417
Hack TF Relationship between coping style, treatment decision-making role preference, and psychological adjustment in women with breast cancer: a cluster-analytic approach Dissertation Abstracts International: Section B: The Sciences and Engineering 1995 55(11-B):
Hack TF, Pickles T, Bultz BD, et al Feasibility of an audiotape intervention for patients with cancer: a multicenter, randomized, controlled pilot study J Psychosoc Oncol 1999 17(2):1 15
Haddad AM The anatomy and physiology of ethical decision making in oncology J Psychosoc Oncol 1993 11(1):69 82
Haddon GL. Health-related cognitions: expanding on illness cognition models. In: Habermann GM, editors.Wellington, NZ: New Zealand Psychological Society, Inc. 1997:p. 49-55.
Hagan C Every woman's breast cancer guide Am Health Women 1997 16(8):58 60
Hagoel L, Dishon S, Almog R, et al Proband family uptake of familial-genetic counselling Psychooncology 2000 9(6):522 7 11180587
Hagopian GA The effects of informational audiotapes on knowledge and self-care behaviors of patients undergoing radiation therapy Oncol Nurs Forum 1996 May 23(4):697 700 8735328
Haidet P, Hamel MB, Davis RB, et al Outcomes, preferences for resuscitation, and physician-patient communication among patients with metastatic colorectal cancer Am J Med 1998 105(3):222 9 9753025
Hailey BJ, Willoughby SG, Butler MN, et al Effects of communication style on women's satisfaction with physicians Psychol Health Med 1998 3(4):435 8
Haines IE, Zalcberg J, Buchanan JD Not-for-resuscitation orders in cancer patients -- principles of decision-making Med J Aust 1990 Aug 20 153(4):225 9
Hallak J, Sharma RK, Thomas-AJ J, et al Why cancer patients request disposal of cryopreserved semen specimens posttherapy: A retrospective study Fertil Steril 1998 69(5):889 93 9591498
Halloran MC Rational ethical judgments utilizing a decision-making tool Heart Lung 1982 Nov 11(6):566 70 6922857
Hallowell N, Murton F, Statham H, et al Women's need for information before attending genetic counselling for familial breast or ovarian cancer: a questionnaire, interview, and observational study BMJ 1997 Jan 25 314(7076):281 3
Hallowell N 'You don't want to lose your ovaries because you think 'I might become a man. " Women's perceptions of prophylactic surgery as a cancer risk management option Psychooncology 1998 May 7(3):263 75 9638787
Hames A, Stirling E Choice aids recovery: Study 1 Nurs Times 1987 Feb 25 83(8):49 51
Hames A, Stirling E Choice aids recovery: Study 2 Nurs Times 1987 Feb 25 83(8):49 51
Hampshire M Computer care Nurs Standard 1998 12(25):17 27
Hansson MG Ethical management of hereditary cancer information Acta Oncol 1999 38(3):305 8 10380820
Harris KA The informational needs of patients with cancer and their families Cancer Practice: a Multidisciplinary Journal of Cancer Care 1998 Jan 6(1):39 46
Harrison C, Kenny NP, Sidarous M, et al Bioethics for clinicians: 9. Involving children in medical decisions Can Med Assoc J 1997 Mar 15 156(6):825 8
Harrison R, Dey P, Slevin NJ, et al Randomized controlled trial to assess the effectiveness of a videotape about radiotherapy Br J Cancer 2001 Jan 5 84(1):8 10
Hartmann LC, Sellers TA, Schaid DJ, et al Clinical options for women at high risk for breast cancer Surg Clin North Am 1999 Oct 79(5):1189 206 10572558
Harvey VL Proactive communication and cancer patients Dissertation Abstracts International Section A: Humanities and Social Sciences 1994 54(11-A):
Hayes DF, Henderson IC, Shapiro CL, et al Treatment of metastatic breast cancer: present and future prospects Semin Oncol 1995 22(Suppl. 5):5 21
Haynes RB, Sackett DL, Gray JM, et al Transferring evidence from research into practice: 1. The role of clinical care research evidence in clinical decisions [editorial] ACP Journal Club 1996 Nov 125(3):A14 A16
Hayward K Patient-held oncology records Nurs Standard 1998 May 20 12(35):44 6
Hazelton J The role of the nurse in Phase I clinical trials J Pediatr Oncol Nurs 1991 Jan 8(1):43 5 2012693
Hebert CN, Brisson J, Latreille J, et al Time trends in systemic adjuvant treatment for node-negative breast cancer J Clin Oncol 1999 17(5):1458 64 10334531
Heckrath C, Fuchs A, Kruse J, et al The importance of close doctor-patient interactions for children with cancer Monatsschr Kinderheilkd 1998 146(8):788 96
Heffron WA, Bommelaere K, Masters R Group discussions with the parents of leukemic children Pediatrics 1973 Dec 52(6):831 40 4769002
Hein B, Wolf H Patient satisfaction with the information received after molecular oncology examination of bladder cancer Ugeskr Laeger 1997 Oct 6 159(41):6068 72
Heiney SP, Wells LM, Coleman B, et al "Lasting Impressions: adolescents with cancer share how to cope" -- a videotape program J Pediatr Oncol Nurs 1991 Jan 8(1):18 23 2012688
Heiney SP, Wells LM Developing, implementing, and evaluating a handbook for parents of pediatric hematology/oncology patients J Pediatr Oncol Nurs 1995 Jul 12(3):129 34 7646832
Helgeson VS, Cohen S, Schulz R, et al Group support interventions for women with breast cancer: who benefits from what? Health Psychol 2000 19(2):107 14 10762094
Henderson BJ, Maguire BT Lay representations of genetic disease, and predictive testing J Health Psychol 1998 3(2):233 41
Henderson MM, Kushi LH, Thompson DJ, et al Feasibility of a randomized trial of a low-fat diet for the prevention of breast cancer: dietary compliance in the Women's Health Trial Vanguard Study Prev Med 1990 Mar 19(2):115 33 2193306
Hendry WF Decision making in abdominal surgery following chemotherapy for testicular cancer Eur J Cancer Part A: Gen Topics 1995 31(5):649 50
Henkel E Evaluation of the Heidelberg cancer information service by the consumer Onkologie 1990 Oct 13(5):375 9 2082232
Henry RY, O'Mahony D Treatment of prostate cancer J Clin Pharm Ther 1999 24(2):93 102 10380061
Henteleff PD Reflections on palliative care: a "trouble case." J Palliat Care 1989 Dec 5(4):19 24 2614582
Herbert C, Launoy G, Gignoux M Factors affecting compliance with colorectal cancer screening in France: differences between intention to participate and actual participation Eur J Cancer Prev 1997 Feb 6(1):44 52 9161812
Herbert CP, Verhoef M, White M, et al Complementary therapy and cancer: decision making by patients and their physicians Setting a research agenda Patient Educ Couns 1999 38(2):87 92 14528700
Hermann JF, Ettinger DS, Gams R The final dilemma. End-of-life treatment decisions Cancer Pract 1998 Jan 6(1):57 9 9460328
Hern HEJ, Koenig BA, Moore LJ, et al The difference that culture can make in end-of-life decisionmaking Camb Q Healthc Ethics 1998 7(1):27 40 9523039
Hernandez L, Cella D Health-related quality of life: important result of cancer treatments P R Health Sci J 1998 Mar 17(1):89 91 9642726
Hietanen P, Aro AR, Holli K, et al Information and communication in the context of a clinical trial Eur J Cancer 2000 Oct 36(16):2096 104 11044647
Hietanen PS Measurement and practical aspects of quality of life in breast cancer Acta Oncol 1996 35(1):39 42 8619938
Hill D, Carson N, Gardner G, et al Simple health education about breast cancer in general practice Int J Health Educ 1979 22(1):25 9 463309
Hill D, White V, Marks R, et al Changes in sun-related attitudes and behaviours, and reduced sunburn prevalence in a population at high risk of melanoma Eur J Cancer Prev 1993 Nov 2(6):447 56 8287008
Hill HL. Radiation or mastectomy: a choice for living. J Psychosoc Oncol. 1986. of.
Hillhouse J, Turrisi R, Holwiski F, et al An examination of psychological variables relevant to artificial tanning tendencies J Health Psychol 1999 4(4):507 16
Hillner BE. Financial costs, benefits, and patient risk preferences in node-negative breast cancer: insights from a decision analysis model. Recent Results Cancer Res. 1993;127:277-84. [pmid: 8502826].
Hilsman WJ Deciding on radiation therapy: a patient's perspective Semin Urol Oncol 2000 Aug 18(3):200 4 10975492
Hinds C, Streater A, Mood D Functions and preferred methods of receiving information related to radiotherapy. Perceptions of patients with cancer Cancer Nurs 1995 Oct 18(5):374 84 7585492
Hinds PS, Oakes L, Furman W, et al Decision making by parents and healthcare professionals when considering continued care for pediatric patients with cancer Oncol Nurs Forum 1997 Oct 24(9):1523 8 9348593
Hinds PS, Oakes L, Quargnenti A, et al Challenges and issues in conducting descriptive decision-making studies in pediatric oncology: a tale of two studies J Pediatr Oncol Nurs 1998 Jul 15(3 Suppl 1):10 7 9700237
Hinds PS, Oakes L, Quargnenti A, et al An international feasibility study of parental decision making in pediatric oncology Oncol Nurs Forum 2000 Sep 27(8):1233 43 11013904
Hiromoto BM, Dungan J Contract learning for self-care activities. A protocol study among chemotherapy outpatients Cancer Nurs 1991 Jun 14(3):148 54 2059958
Hittmair DM, Sailer U, Benke T Impaired arithmetic facts but intact conceptual knowledge -- A single-case study of dyscalculia Cortex 1995 31(1):139 47 7781311
Ho EE, Atwood JR, Benedict J, et al A community-based feasibility study using wheat bran fiber supplementation to lower colon cancer risk Prev Med 1991 Mar 20(2):213 25 1647531
Hoagland AC, Morrow GR, Bennett JM, et al Oncologists' views of cancer patient noncompliance Am J Clin Oncol 1983 Apr 6(2):239 44 6829498
Hoarau H, Kantor G, Dilhuydy JM, et al Radiotherapy care experience: an anthropological study Cancer Radiother 2000 4(1):54 9 10742809
Hoare T, Thomas C, Biggs A, et al Can the uptake of breast screening by Asian women be increased? A randomized controlled trial of a linkworker intervention J Public Health Med 1994 Jun 16(2):179 85 7946492
Hockenberry-Eaton M, Minick P Living with cancer: children with extraordinary courage Oncol Nurs Forum 1994 Jul 21(6):1025 31 7971409
Hodne CJ, Reiter RC Decision-making in women's health care Clin Obstet Gynecol 1994 Mar 37(1):162 79 8194207
Hoehn JL, Goldberg NJ. Collaborative practice key to enhancing informed decision making in the treatment of breast cancer. Proc Annu Meet Am Soc Clin Oncol. 1994;13.
Hoerni B, Zittoun R, Rojouan J, et al Data collection from patients treated for Hodgkin's disease. Relation to quality of life Bull Cancer 1986 73(3):305 10 3756367
Hoerni B Physician-patient relations and decision in oncology Bull Cancer 1987 74(3):307 12 3620736
Hoerni B The decision making process in oncology Bull Cancer 1991 78Suppl 1:7s 10s 1912691
Hofferbert S, Worringen U, Backe J, et al Simultaneous interdisciplinary counseling in German breast/ovarian cancer families: first experiences with patient perceptions, surveillance behavior and acceptance of genetic testing Genet Couns 2000 11(2):127 46 10893664
Hoffman MS. Pap test: the procedure & results: a guide for women. San Ramon, CA: Hin, Inc.; 1996.
Hogbin B, Fallowfield L. Getting it taped: The 'bad news" consultation with cancer patients. Br J Hosp Med. 1989;41:330-3. [pmid: 2720274].
Hogbin B, Jenkins VA, Parkin AJ. Remembering 'bad news' consultations: an evaluation of tape-recorded consultations. Psychooncology. 1992;1:147-54.
Hoke LA A short-term psychoeducational intervention for families with parental cancer Harv Rev Psychiatry 1997 Jul 5(2):99 103 9385028
Holder AR Childhood malignancies and decision making Yale J Biol Med 1992 Mar 65(2):99 104 1519381
Holland JC, Rowland J. Emotional effects of cancer and cancer therapy. Prog Clin Biol Res. 1983;132E:21-33. [pmid: 6647469].
Hollen PJ, Hobbie WL Risk taking and decision making of adolescent long-term survivors of cancer Oncol Nurs Forum 1993 Jun 20(5):769 76 8337171
Hollen PJ Psychometric properties of two instruments to measure quality decision making Res Nurs Health 1994 Apr 17(2):137 48 8127994
Hollen PJ, Hobbie WL Decision making and risk behaviors of cancer-surviving adolescents and their peers J Pediatr Oncol Nurs 1996 Jul 13(3):121 33 8755441
Hollen PJ, Hobbie WL, Finley SM Cognitive late effect factors related to decision making and risk behaviors of cancer-surviving adolescents Cancer Nurs 1997 Oct 20(5):305 14 9394052
Hollen PJ A clinical profile to predict decision making, risk behaviors, clinical status, and health-related quality of life for cancer-surviving adolescents: part 2 Cancer Nurs 2000 Oct 23(5):337 43 11037953
Hollen PJ A clinical profile to predict decision making, risk behaviors, clinical status, and health-related quality of life for cancer-surviving adolescents. Part 1 Cancer Nurs 2000 23(4):247 57 10939172
Holmes-Rovner M, Rovner D, Kroll J, et al. Does decision support make people more rational?. Med Decis Making. 1995;15:418.
Holmes-Rovner M, Kroll J, Schmitt N, et al Patient satisfaction with health care decisions: the satisfaction with decision scale Med Decis Making 1996 Jan 16(1):58 64 8717600
Holmes-Rovner M, Kroll J, Rovner DR, et al Patient decision support intervention: increased consistency with decision analytic models Med Care 1999 Mar 37(3):270 84 10098571
Holmes-Rovner M, Valade D, Orlowski C, et al Implementing shared decision-making in routine practice: barriers and opportunities Health Expect 2000 3(3):182 91 11281928
Hope T. Evidence-based patient choice. London: King's Fund; 1996.
Hoshino K Bioethics in severely neurologically disturbed children No To Hattatsu 1998 30(2):101 8 9545772
Houn F, Helzlsouer KJ, Friedman NB, et al The practice of prophylactic mastectomy: a survey of Maryland surgeons Am J Public Health 1995 85(6):801 5 7762713 1615504
Houts PS, Rusenas I, Simmonds MA, et al Information needs of families of cancer patients: a literature review and recommendations J Cancer Educ 1991 6(4):255 61 1756111
Houts PS, Bachrach R, Witmer JT, et al Using pictographs to enhance recall of spoken medical instructions Patient Educ Couns 1998 35(2):83 8 10026551
Houts PS, Hermann JF Educational needs related to complementary and alternative therapies Cancer Pract 1999 7(5):262 5 10687596
Howe RJ Prostate cancer: a patient's perspective J Urol 1994 Nov 152(5 Pt 2):1700 3 7933230
Hubert A, Kantor G, Dilhuydy JM, et al Patient information about radiation therapy: a survey in Europe Radiother Oncol 1997 43(1):103 7 9165145
Hughes BR, Altman DG, Newton JA Melanoma and skin cancer: evaluation of a health education programme for secondary schools Br J Dermatol 1993 Apr 128(4):412 7 8494755
Hughes DB, Smith AR, Hoppe R, et al Treatment planning for Hodgkin's disease: a pattern of care study Int J Radiat Oncol Biol Phys 1995 33(2):519 24 7673042
Hughes KK Decision making by patients with breast cancer: the role of information in treatment selection Oncol Nurs Forum 1993 May 20(4):623 8 8321703
Hughes KK Psychosocial and functional status of breast cancer patients. The influence of diagnosis and treatment choice Cancer Nurs 1993 Jun 16(3):222 9 8348530
Huijer M, van Leeuwen E Personal values and cancer treatment refusal J Med Ethics 2000 Oct 26 26(5):358 62
Huizinga GA, Sleijfer DT, van de Wiel HB, et al Decision-making process in patients before entering phase III cancer clinical trials: a pilot study Cancer Nurs 1999 Apr 22(2):119 25 10217027
Hulka CA, Slanetz PJ, Halpern EF, et al Patients' opinion of mammography screening services: Immediate results versus delayed results due to interpretation by two observers Am J Roentgenol 1997 168(4):1085 9 9124120
Humphrey GB, Littlewood JL, Kamps WA Physician/patient communication: a model considering the interaction of physicians' therapeutic strategy and patients' coping style J Cancer Educ 1992 7(2):147 52 1419579
Humphris GM, Duncalf M, Holt D, et al The experimental evaluation of an oral cancer information leaflet Oral Oncol 1999 35(6):575 82 10705093
Hunt LM Practicing oncology in provincial Mexico: a narrative analysis Soc Sci Med 1994 Mar 38(6):843 53 8184335
Hunt LM, Mattingly C Diverse Rationalities and Multiple Realities in Illness and Healing Med Anthropol Q 1998 12(3):267 72 9746894
Hurd LB Presenting a patient's guide to ileoanal reservoir surgery. An overview of the IAR procedure for prospective chronic ulcerative colitis or adenomatous familial polyposis surgical patients and their families Ostomy Wound Manage 1992 Jun 38(5):52 60 1320384
Hurley SF, Huggins RM, Jolley DJ, et al Recruitment activities and sociodemographic factors that predict attendance at a mammographic screening program Am J Public Health 1994 Oct 84(10):1655 8 7943490 1615067
Hutchison C Phase I trials in cancer patients: participants' perceptions Eur J Cancer Care (Engl) 1998 Mar 7(1):15 22 9582747
Hutton J, Brown RE, Borowitz M, et al A new decision model for cost-utility comparisons of chemotherapy in recurrent metastatic breast cancer Pharmacoeconomics 1996 9(Suppl. 2):8 22
Hwang ES, Esserman LJ Management of ductal carcinoma in situ Surg Clin North Am 1999 79(5):1007 30 10572548
Hwang MY JAMA patient page. Know your options for breast cancer JAMA 1999 Feb 24 281(8):
Hytten K, Kaasa S [Information and support to cancer patients. Experience from a course for young cancer patients at the Montebello Center Tidsskr Nor Laegerforen 1992 May 30 112(14):1839 40
Iammarino NK, Scardino PT Testicular cancer: the role of the primary care physician in prevention and early detection Tex Med 1991 May 87(5):66 71
Iglehart JD, Miron A, Rimer BK, et al Overestimation of hereditary breast cancer risk Ann Surg 1998 228(3):375 84 9742920 1191495
Inoue T, Murayama S Current status of phase III study of combined treatment with radiotherapy and chemotherapy for head and neck cancer Jpn J Cancer Chemother 1995 22(3):350 6
Irwin E, Arnold A, Rath D, et al. Offering a choice between two adjuvant chemotherapy regimens: what factors affect treatment decision making for women with breast cancer?. Proc Annu Meet Am Soc Clin Oncol. 1995;14.
Irwin E, Arnold A, Whelan TJ, et al Offering a choice between two adjuvant chemotherapy regimens: a pilot study to develop a decision aid for women with breast cancer Patient Educ Couns 1999 37(3):283 91 14528554
Israel L A brief medical survey of decision-making theory Bull Cancer 1980 67(4):374 5 7225595
Israel MJ, Mood DW Three media presentations for patients receiving radiation therapy Cancer Nurs 1982 Feb 5(1):57 63 6175394
Itano J, Tanabe P, Lum JL, et al Compliance of cancer patients to therapy West J Nurs Res 1983 5(1):5 20 6551108
Itoh K, Sasaki Y, Fujii H, et al Patients in phase I trials of anti-cancer agents in Japan: motivation, comprehension and expectations Br J Cancer 1997 76(1):107 13 9218741
Iveson-Iveson J Cancer education services Nurs Mirror 1978 Mar 16 146(11):
Jacobs C A patient teaching tool Cancer Nurs 1979 Apr 2(2):153 66 255107
Jacobs C, Ross RD, Walker IM, et al. A randomized study of the effects of education and peer support groups. Am J Clin Oncol. 1983;6:247-53.
Jacobsen PB, Valdimarsdottier HB, Brown KL, et al Decision-making about genetic testing among women at familial risk for breast cancer Psychosom Med 1997 Sep 59(5):459 66 9316177
Jadad AR, Moore RA, Carroll D, et al Assessing the quality of reports of randomized clinical trials: is blinding necessary? Control Clin Trials 1996 Feb 17(1):1 12 8721797
Jahkola T Self-perceptions of women after early breast cancer surgery Eur J Surg Oncol 1998 Feb 24(1):9 14 9542507
Jankovic M, Loiacono NB, Spinetta JJ, et al Telling young children with leukemia their diagnosis: the flower garden as analogy Pediatr Hematol Oncol 1994 Jan 11(1):75 81 7512361
Jansen SJ, Stiggelbout AM, Wakker PP, et al Unstable preferences: a shift in valuation or an effect of the elicitation procedure? Med Decis Making 2000 Jan 20(1):62 71 10638538
Janz NK, Schottenfeld D, Doerr KM, et al A two-step intervention of increase mammography among women aged 65 and older Am J Public Health 1997 Oct 87(10):1683 6 9357355 1381136
Jarvis W Helping your patients deal with questionable cancer treatments CA: Cancer J Clin 1986 Sep 36(5):293 301 3093015
Jatoi I, Baum M American and European recommendations for screening mammography in younger women: a cultural divide? BMJ 1993 Dec 4 307(6917):1481 3
Jayant K, Rao RS, Nene BM, et al Improved stage at diagnosis of cervical cancer with increased cancer awareness in a rural Indian population Int J Cancer 1995 63(2):161 3 7591197
Jazieh AR, Brown D Development of a patient information packet for veterans with cancer receiving chemotherapy J Cancer Educ 1999 14(2):96 8 10397485
Jenkins CA, Scarfe A, Bruera E Case report. Integration of palliative care with alternative medicine in patients who have refused curative cancer therapy: a report of two cases J Palliat Care 1998 14(4):55 9
Jenkinson J, Wilson-Pauwels L, Jewett MA, et al Development of a hypermedia program designed to assist patients with localized prostate cancer in making treatment decisions J Biocomm 1998 25(2):2 11
Jensen AB, Madsen B, Andersen P, et al Information for cancer patients entering a clinical trial -- an evaluation of an information strategy Eur J Cancer 1993 29A(16):2235 8 8110492
Jensen AB, Madsen B, Andersen P, et al Information to cancer patients prior to participation in clinical trials. Evaluation of a structured information program Ugeskr Laeger 1995 Feb 20 157(8):1016 20
Jensen G Patients choose nurse for themselves (interview by Anne Vesterdal) Sygeplejersken 1990 Jan 17 90(3):20 2 2315864
Jensen N How evidence-based medicine incorporates patient preferences Wis Med J 1999 Mar 98(2):49 52
Jezewski MA, Finnell DS The meaning of DNR status: Oncology nurses' experiences with patients and families Cancer Nurs 1998 21(3):212 21 9615512
Jimison HB, Sher PP, Appleyard R, et al The use of multimedia in the informed consent process J Am Med Inform Assoc 1998 May 5(3):245 56 61298 9609494
Johnson EY, Lookingbill DP Sunscreen use and sun exposure. Trends in a white population Arch Dermatol 1984 Jun 120(6):727 31 6721537
Johnson FR, Luken RA Radon risk information and voluntary protection: evidence from a natural experiment Risk Anal 1987 Mar 7(1):97 107 3615997
Johnson IA, Adelstein DJ The use of recorded interviews to enhance physician-patient communication J Cancer Educ 1991 6(2):99 102 1911176
Johnson JD, Meischke H Women's preferences for cancer-related information from specific types of mass media Health Care Women Int 1994 Jan 15(1):23 30 8169166
Johnson JD, Roberts CS, Cox CE, et al Breast cancer patients' personality style, age, and treatment decision making J Surg Oncol 1996 Nov 63(3):183 6 8944063
Johnson JT, Casper J, Lesswing NJ Toward the total rehabilitation of the alaryngeal patient Laryngoscope 1979 Nov 89(11):1813 9 502702
Johnson SR The clinical decision regarding hormone replacement therapy Endocrinol Metab Clin North Am 1997 26(2):413 35 9193893
Johnston SD, Broadley K, Henson G, et al A difficult case: management of metastatic melanoma during pregnancy BMJ 1998 Mar 14 316(7134):848 51
Jones A Gestalt therapy: theory and practice Nurs Standard 1992 Jun 10 6(38):31 4
Jones CM The characteristics of patients involved in clinical cancer trials Dissertation Abstracts International Section A: Humanities and Social Sciences 1996 57(4-A):
Jones R, Pearson J, McGregor S, et al Randomised trial of personalised computer based information for cancer patients BMJ 1999 Nov 6 319(7219):1241 7 28275
Jones WL, Rimer B, Engstrom PF, et al. Important gaps in patients' knowledge prior to chemotherapy. Prog Clin Biol Res. 1983;130:391-400. [pmid: 6622474].
Jones WL, Dayal HH, Grover PL, et al. Research in cancer patient education and compliance. Prog Clin Biol Res. 1983;120:467-81. [pmid: 6878303].
Josephson U, Wickman M, Sandelin K Initial experiences of women from hereditary breast cancer families after bilateral prophylactic mastectomy: a retrospective study Eur J Surg Oncol 2000 26(4):351 6 10873354
Jurgens H Recent advances in childhood cancer Eur J Cancer Part A 1997 33(Suppl. 4):S15 S22
Juvonen S, Lauri S New cancer patients: access to information, need for information and participation in decision-making J Cancer Care 1996 Oct 5(4):155 61
Kaasa S, Klepp O, Hagen S, et al Treatment intention in hospitalized cancer patients in oncological wards in Norway: a national survey Cancer Treat Rev 1996 22(Suppl. A):33 9
Kalaycioglu ME Clinical decision-making: acute myelogenous leukemia in first complete remission Clev Clin J Med 1996 63(2):91 3
Kalinowski BH Local therapy for breast cancer: treatment choices and decision making. [Review] [21 refs] Sem Oncol Nurs 1991 Aug 7(3):187 93
Kamps WA, Akkerboom JC, Nitschke R, et al Altruism and informed consent in chemotherapy trials of childhood cancer Loss, Grief and Care 1987 1(3-4):93 110
Kaplan RM An outcomes-based model for directing decisions in women's health care. [Review] [36 refs] Clin Obstet Gynecol 1994 Mar 37(1):192 206 8194209
Kaplan RM Decisions about prostate cancer screening in managed care Curr Opin Oncol 1997 Sep 9(5):480 6 9327227
Kaplan RM Shared medical decision-making: a new paradigm for behavioral medicine -- 1997 Presidential address Ann Behav Med 1999 21(1):3 11 18425648
Karlsen S, Addington-Hall J How do cancer patients who die at home differ from those who die elsewhere? Palliat Med 1998 Jul 12(4):279 86 9743826
Karp J, Brown KL, Sullivan MD, et al The prophylactic mastectomy dilemma: a support group for women at high genetic risk for breast cancer J Genet Couns 1999 Jun 8(3):163 73
Kash KM, Holland JC, Halper MS, et al Psychological distress and surveillance behaviors of women with a family history of breast cancer J Natl Cancer Inst 1992 Jan 1 84(1):24 30
Kash KM, Holland JC, Osborne MP, et al Psychological counseling strategies for women at risk of breast cancer J Natl Cancer Inst 1995(17):73 9
Kash KM, Ortega VK, Dabney MK, et al Psychosocial aspects of cancer genetics: women at high risk for breast and ovarian cancer Semin Surg Oncol 2000 18(4):333 8 10805955
Kasper JF, Mulley AGJ, Wennberg JE Developing shared decision-making programs to improve the quality of health care QRB Qual Rev Bull 1992 Jun 18(6):183 90 1379705
Kasper JF, Fowler FJJ Responding to the challenge. A status report on shared decision-making programs Hmo Pract 1993 Dec 7(4):176 81 10145929
Kassirer JP, Moskowitz AJ, Lau J, et al Decision analysis: a progress report Ann Intern Med 1987 Feb 106(2):275 91 3541727
Kassirer JP Incorporating patients' preferences into medical decisions [editorial; comment] N Engl J Med 1994 Jun 30 330(26):1895 6 8196734
Katayama T, Mikasa H, Hisashige A. Development of a decision making system on the internet for treatment of an early-stage breast cancer. Ann Meet Int Soc Technol Ass Health Care. 1900;14.
Kaufert JM Cultural mediation in cancer diagnosis and end of life decision-making: the experience of Aboriginal patients in Canada Anthropol Med 1999 6(3):405 21
Kazak AE, Stuber ML, Barakat LP, et al Assessing Posttraumatic Stress Related to Medical Illness and Treatment: the Impact of Traumatic Stressors Interview Schedule (ITSIS) Families, Systems & Health 1996 14(3):365 80
Kearsley JH Therapeutic decision-making in clinical oncology: a matter of perspective Australas Radiol 1989 Feb 33(1):4 7 2712788
Kehl RJ When the doctor becomes the patient: a personal case history of a low grade B cell lymphoma cancer patient J Okla Dent Assoc 1998 89(1):22 8 10596630
Keller M Psychosocial care of breast cancer patients Anticancer Res 1998 18(3 C):2257 9 9703797
Kelly-Powell ML Personalizing choices: patients' experiences with making treatment decisions Res Nurs Health 1997 Jun 20(3):219 27 9179176
Kelly PT Informational needs of individuals and families with hereditary cancers Sem Oncol Nurs 1992 Nov 8(4):288 92
Kelly PT Breast cancer risk: the role of the nurse practitioner Nurse Pract Forum 1993 Jun 4(2):91 5 8513269
Kemp N, Skinner E, Toms J Randomized clinical trials of cancer treatment -- a public opinion survey Clin Oncol 1984 Jun 10(2):155 61 6734007
Kendall C, Hailey BJ The relative effectiveness of three reminder letters on making and keeping mammogram appointments J Behav Med 1993 19(1):29 34
Kenny P, Quine S, Shiell A, et al Participation in treatment decision-making by women with early stage breast cancer Health Expect 1999 2(3):159 68 11281892
Kerfoot SJ An adolescent 'problem' patient: child or adult? Rehabilitation Nurs 1993 Nov 18(6):400 1
Kerner DN Impact of a decision aid videotape on young women's attitudes and knowledge about hormone replacement therapy Dissertation Abstracts International: Section B: The Sciences and Engineering 1999 59(8-B):
Kernohan EE. Evaluation of a pilot study for breast and cervical cancer screening with Bradford's minority ethnic women: a community development approach, 1991-93. Br J Cancer Suppl. 1996 Sep;29:S42-S46. [pmid: 8782798].
Kerridge I, Lowe M, Mitchell K Competent patients, incompetent decisions Ann Intern Med 1995 Dec 1 123(11):878 81
Kiebert GM, Stiggelbout AM, Leer JW, et al Test-retest reliabilities of two treatment-preference instruments in measuring utilities Med Decis Making 1993 Apr 13(2):133 40 8483398
Kiebert GM, Stiggelbout AM, Kievit J, et al Choices in oncology: factors that influence patients' treatment preference Qual Life Res 1994 Jun 3(3):175 82 7920491
Kiefe CI, McKay SV, Halevy A, et al Is cost a barrier to screening mammography for low-income women receiving Medicare benefits? A randomized trial Arch Intern Med 1994 Jun 13 154(11):1217 24
King J, Fairbrother G, Thompson C, et al Colorectal cancer screening: optimal compliance with postal faecal occult blood test Aust N Z J Surg 1992 Sep 62(9):714 9 1520154
Kirk D. Immediate versus deferred treatment for advanced disease. Cancer Surv. 1995;23:183-90. [pmid: 7542563].
Kirkland BJ Psychological adjustment to breast cancer: congruence of locus of control and information and decision making participation Dissertation Abstracts International: Section B: The Sciences and Engineering 1996 56(11-B):
Kissil D, Lippman AJ Prostate cancer: essays on decision making N J Med 1996 May 93(5):57 60
Klafehn PD A piece of my mind. A trial for my life JAMA 1995 Jun 21 273(23):
Klass W, Varenhorst E, Hjertberg H, et al A study on prostatic cancer. The patient can decide himself: medical or surgical treatment Lakartidningen 1992 May 6 89(19):1659 61
Klein JF, Berry CC, Felice ME The development of a testicular self-examination instructional booklet for adolescents J Adolesc Health Care 1990 May 11(3):235 9 2358393
Kline NE Implementing a computerized teaching documentation tool for pediatric oncology patients and families J Pediatr Oncol Nurs 1996 Oct 13(4):232 4 8908911
Klingebiel T Phases in disease and therapy. An attempt at understanding Pflege Zeitschrift 1994 Feb 47(2):102 4 8136978
Klocker JG, Klocker-Kaiser U, Schwaninger M. Truth in the relationship between cancer patient and physician. Ann N Y Acad Sci. 1997 Feb 20;809:56-65.
Knobf MT Decision-making for primary breast cancer treatment Medsurg Nurs 1994 3(3):169 74 8055034
Knobf MT Treatment options for early stage breast cancer Medsurg Nurs 1994 3(4):249 57 7920851
Kodish ED, Pentz RD, Noll RB, et al Informed consent in the childrens cancer group: results of preliminary research Cancer 1998 82(12):2467 81 9635541
Kohatsu ND, Cramer E, Bohnstedt M Use of a clinician reminder system for screening mammography in a public health clinic Am J Prev Med 1994 Nov 10(6):348 52 7880554
Kohle K. Emotional status in the decision process. Verh Dtsch Ges Inn Med. 1986;92:452-4. [pmid: 3811545].
Kohn J Human values in caring for cancer patients Can Med Assoc J 1984 Aug 1 131(3):237 9 6744169
Koike M, Hisashige A, Mikasa H, et al. Informed consent and decision making in choice of therapy for early breast cancer. Ann Meet Int Soc Technol Ass Health Care. 1900;13.
Koike M, Hisashige A, Makuuchi M. Patient's preference and its effect on decision making in choice of operation for early stages of breast cancer in Japan. In Koike, M., Hisashige, A., and Makuuchi, M., editors. Annual Meeting of International Society of Technology Assessment in Health Care 1994.
Kopans DB Mammography screening and the controversy concerning women aged 40 to 49 Radiol Clin North Am 1995 33(6):1273 90 7480670
Korec S, Andrasiova M. Telling the truth -- yes? Maybe? No? Yes. Ann N Y Acad Sci. 1997 Feb 20;809:496-9.
Korsch BM, Gozzi EK, Francis V Gaps in doctor-patient communication. 1. Doctor-patient interaction and patient satisfaction Pediatrics 1968 Nov 42(5):855 71 5685370
Kotwall CA, Maxwell JG, Covington DL, et al Clinicopathologic factors and patient perceptions associated with surgical breast-conserving treatment Ann Surg Oncol 1996 Mar 3(2):169 75 8646518
Kowalczyk CL, Malone J, Peterson EP, et al Well-differentiated endometrial adenocarcinoma in an infertility patient with later conception: a case report J Reprod Med Obstet Gynecol 1999 44(1):57 60
Kraft RB The breast cancer controversy & its implications for the informed consent doctrine J Leg Med 1980 Oct 2(1):47 84 6970242
Krahn MD, Mahoney JE, Eckman MH, et al Screening for prostate cancer. A decision analytic view JAMA 1994 Sep 14 272(10):773 80
Krakauer EL, Penson RT, Truog RD, et al Sedation for intractable distress of a dying patient: acute palliative care and the principle of double effect Oncologist 2000 5(1):53 62 10706650
Kraus PL Body image, decision making, and breast cancer treatment Cancer Nurs 1999 Dec 22(6):421 7 10603689
Kreitler S, Chaitchik S, Rapoport Y, et al Psychosocial effects of level of information and severity of disease on head-and-neck cancer patients J Cancer Educ 1995 10(3):144 54 8534601
Kremers SP, Mesters I, Pladdet IE, et al Participation in a sigmoidoscopic colorectal cancer screening program: a pilot study Cancer Epidemiol Biomarkers Prev 2000 Oct 9(10):1127 30 11045799
Kristeller JL, Hebert J, Edmiston K, et al Attitudes toward risk factor behavior of relatives of cancer patients Prev Med 1996 25(2):162 9 8860281
Kristjanson LJ, Ashcroft T The family's cancer journey: a literature review Cancer Nurs 1994 Feb 17(1):1 17 8180973
Krizek C, Roberts C, Ragan R, et al Gender and cancer support group participation Cancer Pract 1999 Mar 7(2):86 92 10352066
Krohn M, Trams G Subjective stress of adjuvant chemotherapy in breast cancer patients Geburtshilfe Frauenheilkd 1992 Nov 52(11):693 7 1452006
Krol Y, van Dam FS, Horenblas S, et al Information needs of men with prostate cancer and their partners Ned Tijdschr Geneeskd 2000 Feb 26 144(9):431 7
Krupnick JL, Rowland JH, Goldberg RL, et al Professionally-led support groups for cancer patients: an intervention in search of a model Int J Psychiatry Med 1993 23(3):275 94 8270357
Kuhse H 'No' to the intention/foresight distinction in medical end-of-life decisions Med Law 1997 16(3):643 9 9409143
Kulman L Sacrificing breasts before cancer strikes US News & World Report 1999 Jan 25 126(3):
Kuni CC Mammography in the 1990s: a plea for objective doctors and informed patients Am J Prev Med 1993 May 9(3):185 90 8347371
Kunkel EJ, Myers RE, Lartey PL, et al Communicating effectively with the patient and family about treatment options for prostate cancer Semin Urol Oncol 2000 Aug 18(3):233 40 10975496
Kurtz ME, Kurtz JC, Given B, et al Promotion of breast cancer screening in a work site population Health Care Women Int 1994 Jan 15(1):31 42 8169167
Kurtzman SH, MacGillivray DC, Deckers PJ Evolving strategies for the management of non-palpable breast abnormalities Surg Oncol 1995 4(1):1 14 7780607
Kusch M, Vetter C, Bode U Inpatient psychological management in pediatric oncology: the concept of liaison management Prax Kinderpsychol Kinderpsychiatr 1993 Nov 42(9):316 26 8295854
Kusiak A, Kern JA, Kernstine KH, et al Autonomous decision-making: a data mining approach IEEE Trans Inf Technol Biomed 2000 4(4):274 84 11206812
Labrecque MS, Blanchard CG, Ruckdeschel JC, et al The impact of family presence on the physician-cancer patient interaction Soc Sci Med 1991 33(11):1253 61 1776038
Lackner SL, Goldenberg S, Arrizza G, et al The contingency of social support Qual Health Res 1994 4(2):224 43
Lamadrid AS Knowledge and fears of Chilean women with respect to Papanicolaou smears Bol Oficina Sanit Panam 1996 121(6):542 9
Lamb M Vulvar cancer: patient information booklet Oncol Nurs Forum 1986 Nov 13(6):79 82 3642567
Lamb MA, Bargman C, Brozovich K Ovarian cancer: patient information booklet Oncol Nurs Forum 1985 Sep 12(5):83 8
Lancaster G, Elton P Does the offer of cervical screening with breast screening encourage older women to have a cervical smear test? J Epidemiol Community Health 1992 Oct 46(5):523 7 1479324
Landro L Patient-physician communication: an emerging partnership Oncologist 1999 4(1):55 8 10337371
Lane DS, Burg MA Strategies to increase mammography utilization among community health center visitors. Improving awareness, accessibility, and affordability Med Care 1993 Feb 31(2):175 81 8433579
Lantz PM, Stencil D, Lippert MT, et al Breast and cervical cancer screening in a low-income managed care sample: the efficacy of physician letters and phone calls Am J Public Health 1995 85(6):834 6 7646664 1615506
Larsson US, Johanson M, Svardsudd K Sensitive patient-doctor communications relating to the breasts and prostate J Cancer Educ 1994 9(1):19 25 8204453
Laufs A Freedom of therapy: choice of methods and quality of treatment Chirurg 1984 Aug 55(8):541 2 6489003
Lauver D, Rubin M Message framing, dispositional optimism, and follow-up for abnormal Papanicolaou tests Res Nurs Health 1990 Jun 13(3):199 207 2343159
Lawrence VA, Streiner D, Hazuda HP, et al A cross-cultural consumer-based decision aid for screening mammography Prev Med 2000 30(3):200 8 10684743
Lazcano-Ponce EC, Castro R, Allen B, et al Barriers to early detection of cervical-uterine cancer in Mexico J Womens Health 1999 Apr 8(3):399 408 10326994
Lea DH Client advocacy and collaboration with insurance and laboratory testing agencies: a case study illustrating genetic counselor roles J Genet Couns 1999 8(3):175 81 11658064
Leard LE, Savides TJ, Ganiats TG Patient preferences for colorectal cancer screening J Fam Pract 1997 Sep 45(3):211 8 9300000
Lee CY A randomized controlled trial to motivate worksite fecal occult blood testing Yonsei Med J 1991 Jun 32(2):131 8 1949916
Lee JJ, Vogel VG Who uses screening mammography regularly? Cancer Epidemiol Biomarkers Prev 1995 4(8):901 6 8634664
Lee SJ, Earle CC, Weeks JC Outcomes research in oncology: history, conceptual framework, and trends in the literature. [Review] [41 refs] J Natl Cancer Inst 2000 Feb 2 92(3):195 204
Leeman CP Patient autonomy and undertreatment of critical disease Hosp Pract 1998 33(2):177 83
Leflar RB The cautious acceptance of informed consent in Japan Med Law 1997 16(4):705 20 9573708
Lehrman S Should you get the breast cancer gene test? Health (San Francisco) 1998 12(8):129 30 80741
Leigh S Survivorship and pancreatic cancer: the role of advocacy Oncology (Huntingt) 1996 Sep 10(9 Suppl):38 9 419372 8884808
Leikin S The role of adolescents in decisions concerning their cancer therapy Cancer 1993 May 15 71(10 Suppl):3342 6 8490879
Leikin SL An ethical issue in pediatric cancer care: nondisclosure of a fatal prognosis Pediatric Annals 1981 10(10):37 41 7312444
Leikin SL Therapeutic choices by children with cancer J Pediatr 1983 Jul 103(1):167 9 6864386
Leikin SL Beyond proforma consent for childhood cancer research J Clin Oncol 1985 Mar 3(3):420 8 3882894
Leino-Kilpi H, Iire L, Suominen T, et al Client and information: a literature review J Clin Nurs 1993 Nov 2(6):331 40
Leinster SJ, Ashcroft JJ, Slade PD, et al Mastectomy versus conservative surgery: psychosocial effects of the patient's choice of treatment J Psychosoc Oncol 1989 7(1-2):179 92
Lerman C, Rimer BK, Engstrom PF Cancer risk notification: psychosocial and ethical implications J Clin Oncol 1991 Jul 9(7):1275 82 2045867
Lerman C, Ross E, Boyce A, et al The impact of mailing psychoeducational materials to women with abnormal mammograms Am J Public Health 1992 May 82(5):729 30 1566953 1694134
Lerman C, Hanjani P, Caputo C, et al Telephone counseling improves adherence to colposcopy among lower-income minority women J Clin Oncol 1992 Feb 10(2):330 3 1732434
Lerman C, Rimer BK, Daly M, et al Recruiting high risk women into a breast cancer health promotion trial Cancer Epidemiol Biomarkers Prev 1994 Apr 3(3):271 6 8019378
Lerman C, Croyle RT Genetic testing for cancer predisposition: behavioral science issues J Natl Cancer Inst Monographs 1995(17):63 6
Lerman C, Lustbader E, Rimer B, et al Effects of individualized breast cancer risk counseling: A randomized trial J Natl Cancer Inst 1995 87(4):286 92 7707420
Lerman C, Schwartz MD, Miller SM, et al A randomized trial of breast cancer risk counseling: interacting effects of counseling, educational level, and coping style Health Psychol 1996 Mar 15(2):75 83 8681923
Lerman C, Croyle RT Emotional and behavioral responses to genetic testing for susceptibility to cancer Oncology (Huntingt) 1996 Feb 10(2):191 5, 9 419372 8838261
Lerman C, Narod S, Schulman K, et al BRCA1 testing in families with hereditary breast-ovarian cancer. A prospective study of patient decision making and outcomes JAMA 1996 Jun 26 275(24):1885 92
Lerman C, Biesecker B, Benkendorf JL, et al Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing J Natl Cancer Inst 1997 Jan 15 89(2):148 57
Lerman C, Schwartz MD, Lin TH, et al The influence of psychological distress on use of genetic testing for cancer risk J Consult Clin Psychol 1997 Jun 65(3):414 20 9170764
Lerman C, Hughes C, Lemon SJ, et al What you don't know can hurt you: adverse psychologic effects in members of BRCA1-linked and BRCA2-linked families who decline genetic testing J Clin Oncol 1998 May 16(5):1650 4 9586874
Lerman C, Hughes C, Trock BJ, et al Genetic testing in families with hereditary nonpolyposis colon cancer JAMA 1999 May 5 281(17):1618 22
Lerman C, Hughes C, Benkendorf JL, et al Racial differences in testing motivation and psychological distress following pretest education for BRCA1 gene testing Cancer Epidemiol Biomarkers Prev 1999 8(4 II):361 7 10207641
Lerner S. Remove two and call me in the morning... prophylactic mastectomy. Mamm. 1998 Apr:52-5.
Levenson PM, Pfefferbaum B, Silberberg Y, et al Sources of information about cancer as perceived by adolescent patients, parents, and physicians Patient Couns Health Educ 1981 3(2):71 6 10252499
Levenson PM, Pfefferbaum BJ, Copeland DR, et al Information preferences of cancer patients ages 11-20 years J Adolesc Health Care 1982 Aug 3(1):9 13 7118689
Levenson PM, Pfefferbaum B, Overall JE A factor analysis of the informational concerns of adolescent cancer patients Child Health Care 1983 11(4):148 53 10262152
Leventhal H, Nerenz DR, Leventhal EA, et al The behavioral dynamics of clinical trials Prev Med 1991 Jan 20(1):132 46 2008422
Levi RB, Marsick R, Drotar D, et al Diagnosis, disclosure, and informed consent: learning from parents of children with cancer J Pediatr Hematol Oncol 2000 Jan 22(1):3 12 10695815
Levin JR, Hirsch SH, Bastani R, et al Acceptability of mobile mammography among community-dwelling older women J Am Geriatr Soc 1997 45(11):1365 70 9361664
Levine M, Ginsburg D, Pritchard K, et al The role of adjuvant systemic therapy in node-negative breast cancer Curr Oncol 1999 6(2):78 89
Levine MN, Gafni A, Markham B, et al A bedside decision instrument to elicit a patient's preference concerning adjuvant chemotherapy for breast cancer Ann Intern Med 1992 Jul 1 117(1):53 8
Levine RJ Referral of patients with cancer for participation in randomized clinical trials: ethical considerations CA: Cancer J Clin 1986 Mar 36(2):95 9 3082491
Levine RJ Ethics of clinical trials. Do they help the patient? Cancer 1993 Nov 1 72(9 Suppl):2805 10 8402508
Levy LM. Communication with the cancer patient in Zimbabwe. Ann N Y Acad Sci. 1997 Feb 20;809:133-41. [pmid: 9103564].
Levy M Breast cancer treatment alternatives: the patient decision-making process Health Values 1986 10(1):16 21 10275383
Levy SM, Herberman RB, Lee JK, et al Breast conservation versus mastectomy: distress sequelae as a function of choice J Clin Oncol 1989 Mar 7(3):367 75 2918332
Lewis C, Linet MS, Abeloff MD Compliance with cancer therapy by patients and physicians Am J Med 1983 Apr 74(4):673 8 6837593
Lewis M, Pearson V, Corcoran-Perry S, et al Decision making by elderly patients with cancer and their caregivers Cancer Nurs 1997 Dec 20(6):389 97 9409060
Lewis ML, Corcoran-Perry SA, Narayan SM, et al Women's approaches to decision making about mammography Cancer Nurs 1999 Oct 22(5):380 8 10526431
Li S, Chou JL. Communication with the cancer patient in China. Ann N Y Acad Sci. 1997 Feb 20;809:243-8.
Lierman LM, Young HM, Powell-Cope G, et al Effects of education and support on breast self-examination in older women Nurs Res 1994 May 43(3):158 63 8183657
Lilja Y, Ryden S, Fridlund B Effects of extended preoperative information on perioperative stress: an anaesthetic nurse intervention for patients with breast cancer and total hip replacement Intensive Crit Care Nurs 1998 Dec 14(6):276 82 10196910
Lind SE, DelVecchio Good MJ, Seidel S, et al Telling the diagnosis of cancer J Clin Oncol 1989 May 7(5):583 9 2709087
Lindholm E, Berglund B, Kewenter J, et al Worry associated with screening for colorectal carcinomas Scan J Gastroenterol 1997 Mar 32(3):238 45
Lindholm LH, Isacsson A, Slaug B, et al Acceptance by Swedish users of a multimedia program for primary and secondary prevention of malignant melanoma J Cancer Educ 1998 13(4):207 12 9883779
Lindley C, Vasa S, Sawyer WT, et al Quality of life and preferences for treatment following systemic adjuvant therapy for early-stage breast cancer J Clin Oncol 1998 Apr 16(4):1380 7 9552041
Lindley C, McCune JS, Thomason TE, et al Perception of chemotherapy side effects cancer versus noncancer patients Cancer Pract 1999 Mar 7(2):59 65 10352062
Links M, Kramer J Breaking bad news: realistic versus unrealistic hopes Support Care Cancer 1994 Mar 2(2):91 3 8156271
Lintz KC, Penson RT, Chabner BA, et al A staff dialogue on caring for an intensely spiritual patient: psychosocial issues faced by patients, their families, and caregivers Oncologist 1998 3(6):439 45 10388136
Lippman SM, Bassford TL, Meyskens FL, Jr A quantitatively scored cancer-risk assessment tool: its development and use J Cancer Educ 1992 7(1):15 36 1571244
Lipson M Disclosure of diagnosis to children with human immunodeficiency virus or acquired immunodeficiency syndrome J Dev Behav Pediatr 1994 Jun 15(3):S61 S65 8063922
Liu G, Franssen E, Fitch MI, et al Patient preferences for oral versus intravenous palliative chemotherapy J Clin Oncol 1997 15(1):110 5 8996131
Llewellyn-Thomas HA, Sutherland HJ, Ciampi A, et al The assessment of values in laryngeal cancer: reliability of measurement methods J Chronic Dis 1984 37(4):283 91 6715494
Llewellyn-Thomas HA, McGreal MJ, Thiel EC, et al Patients' willingness to enter clinical trials: measuring the association with perceived benefit and preference for decision participation Soc Sci Med 1991 32(1):35 42 2008619
Llewellyn-Thomas HA, Sutherland HJ, Thiel EC Do patients' evaluations of a future health state change when they actually enter that state? Med Care 1993 Nov 31(11):1002 12 8231333
Llewellyn-Thomas HA, McGreal MJ, Thiel EC Cancer patients' decision making and trial-entry preferences: the effects of "framing" information about short-term toxicity and long-term survival Med Decis Making 1995 Jan 15(1):4 12 7898297
Llewellyn-Thomas HA, Thiel EC, Sem FW, et al Presenting clinical trial information: a comparison of methods Patient Educ Couns 1995 May 25(2):97 107 7659635
Llewellyn-Thomas HA, Williams JI, Levy L, et al Using a trade-off technique to assess patients' treatment preferences for benign prostatic hyperplasia Med Decis Making 1996 Jul 16(3):262 82 8818125
Llewellyn-Thomas HA Investigating patients' preferences for different treatment options Can J Nurs Res 1997 29(3):45 64 9505582
Lloyd GG, Parker AC, Ludlam CA, et al Emotional impact of diagnosis and early treatment of lymphomas J Psychosom Res 1984 28(2):157 62 6737329
Lloyd S, Watson M, Waites B, et al Familial breast cancer: a controlled study of risk perception, psychological morbidity and health beliefs in women attending for genetic counselling Br J Cancer 1996 Aug 74(3):482 7 8695370
Lloyd SM, Watson M, Oaker G, et al Understanding the experience of prophylactic bilateral mastectomy: a qualitative study of ten women Psychooncology 2000 9(6):473 85 11180582
Lo B, Jonsen AR Ethical decisions in the care of a patient terminally ill with metastatic cancer Ann Intern Med 1980 Jan 92(1):107 11 6153140
Lo B. Informed consent. Front Radiat Ther Oncol. 1986;20:54-7. [pmid: 3949178].
Loader S, Levenkron JC, Rowley PT Genetic testing for breast-ovarian cancer susceptibility: a regional trial Genet Test 1998 2(4):305 13 10464609
Lobb EA, Butow PN, Kenny DT, et al Communicating prognosis in early breast cancer: do women understand the language used? Med J Aust 1999 Sep 20 171(6):290 4
Loehrer PJS Knowledge in cancer beliefs: obstacles to care? Cancer Treat Rev 1993 19Suppl A:23 7 8431929
Loken K, Steine S, Laerum E Mammography: influence of departmental practice and women's characteristics on patient satisfaction: comparison of six departments in Norway Qual Health Care 1998 7(3):136 41 10185139
Lokich J, Swartz M, Lippman AJ, et al Individual choice and medical logic at odds: Who should determine the level of aggressiveness in cases of advanced, incurable cancer? Semin Oncol 1996 Seminars-in-Oncology 1996 23(5):
Lombard D, Neubauer TE, Canfield D, et al Behavioral community intervention to reduce the risk of skin cancer J Appl Behav Anal 1991 24(4):677 86 1797771 1279624
Long DS How breast cancer patients choose a treatment method. [Review] [16 refs] Radiol Technol 1993 Sep 65(1):30 3 8234658
Love N Forgotten men? Postgrad Med 1996 100(3):85 6 8668624
Lovegrove E, Rumsey N, Harcourt D, et al Factors implicated in the decision whether or not to join the tamoxifen trial in women at high familial risk of breast cancer Psychooncology 2000 May 9(3):193 202 10871715
Lovejoy NC Multinational approaches to cervical cancer screening: a review Cancer Nurs 1996 19(2):126 34 8635166
Lovik A, Almendingen K, Dotterud M, et al Dietary information after radiotherapy of head and neck cancer Tidsskr Nor Laegerforen 1996 Aug 20 116(19):2303 6
Ludwig H, Fritz E, Neuda J, et al Patient preferences for interferon alfa in multiple myeloma J Clin Oncol 1997 15(4):1672 9 9193368
Luker KA, Beaver K, Leinster SJ, et al The information needs of women newly diagnosed with breast cancer J Adv Nurs 1995 Jul 22(1):134 41 7560521
Luker KA, Beaver K, Leinster SJ, et al Information needs and sources of information for women with breast cancer: a follow-up study J Adv Nurs 1996 Mar 23(3):487 95 8655823
Lum JL, Chase M, Cole SM, et al Nursing care of oncology patients receiving chemotherapy Nurs Res 1978 Nov 27(6):340 6 251245
Lumsden G Counselling prostate patients Aust Nurs Journal 1997 May 4(10):24 5
Lunglmayr G, Girsch E. Patient choice in the treatment of advanced prostate cancer. R Soc Med Serv Int Congr Symp Ser. 1987;125.
Lurie N, Margolis KL, McGovern PG, et al Why do patients of female physicians have higher rates of breast and cervical cancer screening? J Gen Intern Med 1997 Jan 12(1):34 43 9034944 1497051
Lynch HT, Drouhard T, Vasen HA, et al Genetic counseling in a Navajo hereditary nonpolyposis colorectal cancer kindred Cancer 1996 77(1):30 5 8630936
Lynch HT, Watson P, Tinley S, et al An update on DNA-based BRCA1/BRCA2 genetic counseling in hereditary breast cancer Cancer Genet Cytogenet 1999 Mar 109(2):91 8 10087939
Lynch HT, Watson P, Shaw TG, et al Clinical impact of molecular genetic diagnosis, genetic counseling, and management of hereditary cancer: part II: hereditary nonpolyposis colorectal carcinoma as a model Cancer 1999 Oct 15 86(8 Suppl):1637 43
Lynch HT, Watson P, Shaw TG, et al Clinical impact of molecular genetic diagnosis, genetic counseling, and management of hereditary cancer. Part I: Studies of cancer in families Cancer 1999 Dec 1 86(11 Suppl):2449 56
Lynden P Controversy. Your breasts or your life? Am Health Women 1900 Sep 16(5):29 30
Lynn J Choices of curative and palliative care for cancer patients CA: Cancer J Clin 1986 Mar 36(2):100 4 2420422
Maas A, Stalpers L Assessing utilities by means of conjoint measurement: an application in medical decision analysis Med Decis Making 1992 Oct 12(4):288 97 1484478
MacCormick RE, Mackinnon KJ Decision making in cancer treatment: age and socio-economic status as independent variables Med Teach 1990 12(3-4):353 5 2095454
Mackillop WJ, Stewart WE, Ginsburg AD, et al Cancer patients' perceptions of their disease and its treatment Br J Cancer 1988 Sep 58(3):355 8 2460120
MacLean CD Principles of cancer screening Med Clin North Am 1996 80(1):1 14 8569290
MacLehose RR, Reeves BC, Harvey IM, et al A systematic review of comparisons of effect sizes derived from randomised and non-randomised studies Health Technol Assess 2000 4(34):1 154
Macnicol AM, Wright AF, Watson ML Education and attitudes in families with adult polycystic kidney disease Nephrol Dial Transplant 1991 6(1):27 30 2057113
Macomber L T, Sadler G R. Cancer information highway: enhancing patient/staff education using the Internet. In San Diego, California: HIMMS; 1997. p.345-59.
Maggino T, Alessi C, Drago D Information supply to cancer patients. Women's expectations and physicians' attitudes It J Gynaecol Obstet 1997 9(1):20 7
Maguire P Improving communication with cancer patients. [Review] [80 refs] Eur J Cancer 1999 Dec 35(14):2058 65 10711246
Maguire P. Improving the quality of life of cancer patients. In: Ed, editors.Levy, Jay A. NY,USA: Plenum Press.: New York. 1997:p. 73-5.
Mahon SM, Casperson D Teaching women about mammography through use of a brochure Oncol Nurs Forum 1991 Nov 18(8):1375 8 1762978
Mahon SM Screening and early detection in high-risk families Oncol Nurs Forum 1992 19(1):91 4 1538993
Mahon SM, Casperson DS Hereditary cancer syndrome: Part 2. -- Psychosocial issues, concerns, and screening -- results of a qualitative study Oncol Nurs Forum 1995 Jun 22(5):775 82 7675684
Mahon SM Using brochures to educate the public about the early detection of prostate and colorectal cancer Oncol Nurs Forum 1995 Oct 22(9):1413 9 8539182
Mahon SM Patient education. Educating women about early detection of gynecologic cancers using a brochure Oncol Nurs Forum 1996 Apr 23(3):529 35 8801514
Mahon SM Case in point... genetic testing to determine breast cancer susceptibility Oncol Nurs Forum 1997 May 24(4):635 6 9159774
Malaguarnera M Therapeutic choices in cancer of the elderly Arch Gerontol Geriatr 1996 23(Suppl. 5):499 504 18653084
Malik IA, Qureshi AF. Communication with cancer patients. Experiences in Pakistan. Ann N Y Acad Sci. 1997 Feb 20;809:300-8.
Maltoni M, Pirovano M, Scarpi E, et al Prediction of survival of patients terminally ill with cancer: results of an Italian prospective multicentric study Cancer 1995 75(10):2613 22 7537625
Man SH, Laupacis A, O'Connor AM, et al A patient decision aid regarding antithrombotic therapy for stroke prevention in atrial fibrillation: a randomized controlled trial JAMA 1999 Aug 25 282(8):737 43
Mandelblatt J, Kanetsky PA Effectiveness of interventions to enhance physician screening for breast cancer J Fam Pract 1995 40(2):162 71 7654272
Mandelblatt JS, Yabroff KR Effectiveness of interventions designed to increase mammography use: a meta-analysis of provider-targeted strategies Cancer Epidemiol Biomarkers Prev 1999 8(9):759 67 10498394
Mandelblatt JS, Hadley J, Kerner JF, et al Patterns of breast carcinoma treatment in older women: patient preference and clinical and physical influences Cancer 2000 Aug 1 89(3):561 73
Mander T Haematology and palliative care: an account of shared care for a patient undergoing bone marrow transplantation for chronic myeloid leukaemia Int J Nurs Pract 1997 Mar 3(1):62 6 9274219
Manfredi C, Czaja R, Buis M, et al Patient use of treatment-related information received from the Cancer Information Service Cancer 1993 Feb 15 71(4):1326 37
Mansell D, Poses RM, Kazis L, et al Clinical factors that influence patients' desire for participation in decisions about illness Arch Intern Med 2000 Oct 23 160(19):2991 6
Mant D, Fitzpatrick R, Hogg A, et al Experiences of patients with false positive results from colorectal cancer screening Br J Gen Pract 1990 Oct 40(339):423 5 2271264 1371385
Mant D, Fuller A, Northover J, et al Patient compliance with colorectal cancer screening in general practice Br J Gen Pract 1992 Jan 42(354):18 20 1586526 1371962
Marcus AC, Crane LA, Kaplan CP, et al Improving adherence to screening follow-up among women with abnormal Pap smears: results from a large clinic-based trial of three intervention strategies Med Care 1992 Mar 30(3):216 30 1538610
Margolese RG Breast cancer surgery: who chooses and how? [editorial] Can Med Assoc J 1994 Feb 1 150(3):331 3 8293373
Margolis GJ, Goodman RL Psychological factors in women choosing radiation therapy for breast cancer Psychosomatics 1984 25(6):464 6 6739698
Margolis GJ, Goodman RL Emotional stress in breast cancer treatment Stress Med 1987 3(2):85 6
Margolis GJ, Goodman RL, Rubin A, et al Psychological factors in the choice of treatment for breast cancer Psychosomatics 1989 30(2):192 7 2710917
Mark JS, Spiro H Informed consent for colonoscopy. A prospective study Arch Intern Med 1990 Apr 150(4):777 80 2327839
Markman M Realistic goals of cancer therapy: effective and humane care Clev Clin J Med 1994 Nov 61(6):468 72
Marshall KG. Screening for prostate cancer. How can patients give informed consent?. Can Fam Physician. 1993 Nov;39:2385-90. [pmid: 7505673].
Marteau TM, Kidd J, Michie S, et al Anxiety, knowledge and satisfaction in women receiving false positive results on routine prenatal screening: a randomized controlled trial J Psychosom Obstet Gynaecol 1993 Sep 14(3):185 96 7505159
Marwick C Other voices weigh in on mammography decision JAMA 1997 277(13):1027 8 9091679
Masera G, Jankovic M, Adamoli L, et al. The psychosocial program for childhood leukemia in Monza, Italy. Ann N Y Acad Sci. 1997;824(-):210-20. [pmid: 9382446].
Maslin AM, Baum M, Walker JS, et al Using an interactive video disk in breast cancer patient support Nurs Times 1998 Nov 4 94(44):52 5
Maslin AM, Baum M, Walker JS, et al Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K Nt Research 1998 Nov 3(6):444 55
Massimo L Ethical problems in bone marrow transplantation in children Bone Marrow Transplant 1996 18(Suppl. 2):8 12 8932790
Mathewson CM The nurse's role in prostate cancer education: prevention, treatment, and rehabilitation Cancer Control 1998 5(3 Suppl.):44 5 10762484
Matthews AK Lesbians and cancer support: clinical issues for cancer patients Health Care Women Int 1998 May 19(3):193 203 9601301
Matthews EJ, Edwards AG, Barker J, et al Efficient literature searching in diffuse topics: lessons from a systematic review of research on communicating risk to patients in primary care Health Lib Rev 1999 Jun 16(2):112 20
Mattsson LA, Milsom I, Stadberg E What do women want? Br J Obstet Gynaecol 1996 May 103Suppl 13:104 6 8624335
Matuk L Choices Can Nurse 1991 Jun 87(6):30 1 2049770
Maung ZT, Taylor PR, Robinson P, et al Patient education for self-referral and on-demand treatment for herpes zoster in lymphoma patients Leuk Lymphoma 1993 Nov 11(5-6):447 52 8124217
Maurel J, Launoy G, Petit T, et al Cancer registers. Evaluation of practical aids for decision making with an example for colorectal cancer Hepato Gastro 1997 4(2 Suppl.):13 20
Maurer WJ Breast cancer screening complacency and compliance Wis Med J 1995 94(6):305 6 7625089
Mayer DK Commentary on age and clinical decision making in oncology patients ONS Nursing Scan in Oncology 1995 Jul 4(4):11 2
Mayer JA, Kossman MK, Miller LC, et al Evaluation of a media-based mammography program Am J Prev Med 1992 Jan 8(1):23 9 1575997
Mayer JA, Clapp EJ, Bartholomew S, et al Facility-based inreach strategies to promote annual mammograms Am J Prev Med 1994 Nov 10(6):353 6 7880555
Mayerhofer K, Bodner K, Aktas C, et al Knowledge of tumor markers and the psychological consequences of tumor marker sampling in patients with gynecologic cancers Anticancer Res 2000 20(2 B):1281 4 10810435
Mazur DJ, Hickam DH Treatment preferences of patients and physicians: influences of summary data when framing effects are controlled Med Decis Making 1990 Jan 10(1):2 5 2325523
Mazur DJ, Hickam DH Patients' and physicians' interpretations of graphic data displays Med Decis Making 1993 Jan 13(1):59 63 8433638
Mazur DJ, Hickman DH Patient preferences: survival vs. quality-of-life considerations J Gen Intern Med 1993 Jul 8(7):374 7 8410398
Mazur DJ, Merz JF How the manner of presentation of data influences older patients in determining their treatment preferences J Am Geriatr Soc 1993 Mar 41(3):223 8 8440842
Mazur DJ, Hickam DH The effect of physician's explanations on patients' treatment preferences: five-year survival data Med Decis Making 1994 Jul 14(3):255 8 7934712
Mazur DJ, Merz JF Older patients' willingness to trade off urologic adverse outcomes for a better chance at five-year survival in the clinical setting of prostate cancer J Am Geriatr Soc 1995 43(9):979 84 7657938
Mazur DJ, Merz JF How older patients' treatment preferences are influenced by disclosures about therapeutic uncertainty: surgery versus expectant management for localized prostate cancer J Am Geriatr Soc 1996 Aug 44(8):934 7 8708303
Mazur DJ, Hickam DH Five-year survival curves: how much data are enough for patient-physician decision making in general surgery? Eur J Surg 1996 Feb 162(2):101 4 8639721
Mazur DJ, Hickam DH Patient preferences for management of localized prostate cancer West J Med 1996 Jul 165(1-2):26 30 8855681 1307537
Mazur DJ, Hickam DH, Mazur MD How patients' preferences for risk information influence treatment choice in a case of high risk and high therapeutic uncertainty: asymptomatic localized prostate cancer Med Decis Making 1999 Oct 19(4):394 8 10520677
Mazur DJ Information disclosure and beyond: how do patients understand and use the information they report they want? Med Decis Making 2000 20(1):132 4 10638546
Mazza D STI screening Aust Fam Physician 1999 Aug 28(8):827 8 10495535
McAlpine L, Jones J Evaluating the impact of an oncology newsletter as an educational tool Can Oncol Nurs J 1994 May 4(2):76 9
McAvoy BR, Raza R Can health education increase uptake of cervical smear testing among Asian women? BMJ 1991 Apr 6 302(6780):833 6
McCarthy EP, Phillips RS, Zhong Z, et al Dying with cancer: patients' function, symptoms, and care preferences as death approaches J Am Geriatr Soc 2000 48(5 Suppl.):S110 S121 10809464
McClellan R Evaluation of the potential health risks of man-made fibres using fibrous glass as an example J Occup Health Saf Aus N Z 1996 12(3):247 57
McClement SE, Hack TF Audio-taping the oncology treatment consultation: a literature review Patient Educ Couns 1999 Mar 36(3):229 38 14528558
McCusker J, Morrow GR Factors related to the use of cancer early detection techniques Prev Med 1980 May 9(3):388 97 7208447
McGowan V M, Foreman J L. Focus group research as a tool to understand consumer views of screening technologies [abstract]. In Annual Meeting of International Society of Technology Assessment in Health Care 1900. p. 47.
McGrath P It's ok to say no! A discussion of ethical issues arising from informed consent to chemotherapy Cancer Nurs 1995 18(2):97 103 7720056
McGuire DB Cancer education -- Challenges of the present: oncology nursing J Cancer Educ 1997 12(1):20 3 9095435
McGuire WL, Tandon AK, Allred DC, et al Prognosis and treatment decisions in patients with breast cancer without axillary node involvement Cancer 1992 Sep 15 70(6 Suppl):1775 81
McHugh P, Lewis S, Ford S, et al The efficacy of audiotapes in promoting psychological well-being in cancer patients: a randomised, controlled trial Br J Cancer 1995 Feb 71(2):388 92 7841058
McKenna RJS Clinical aspects of cancer in the elderly. Treatment decisions, treatment choices, and follow-up Cancer 1994 Oct 1 74(7 Suppl):2107 17
McKneally MF, Martin DK An entrustment model of consent for surgical treatment of life-threatening illness: perspective of patients requiring esophagectomy J Thorac Cardiovasc Surg 2000 Aug 120(2):264 9 10917940
McLoughlin HA, Oosthuizen BL The information needs of cancer patients in the Pretoria and Witwatersrand area Curationis 1996 Jun 19(2):31 5
McMillan SC Nurses' compliance with American Cancer Society guidelines for cancer prevention and detection Oncol Nurs Forum 1990 Sep 17(5):721 7 2251190
McNeil BJ, Weichselbaum R, Pauker SG Fallacy of the five-year survival in lung cancer Nurs Times 1978 Dec 21 299(25):1397 401
McNeil BJ, Pauker SG The patient's role in assessing the value of diagnostic tests Radiology 1979 Sep 132(3):605 10 472235
McNeil BJ, Weichselbaum R, Pauker SG Speech and survival: tradeoffs between quality and quantity of life in laryngeal cancer N Engl J Med 1981 Oct 22 305(17):982 7
McNeil BJ, Pauker SG, Sox HCJ, et al On the elicitation of preferences for alternative therapies N Engl J Med 1982 May 27 306(21):1259 62
McPherson K, Britton A The impact of patient treatment preferences on the interpretation of randomised controlled trials Eur J Cancer 1999 35(11):1598 602 10673968
McQuellon RP, Muss HB, Hoffman SL, et al Patient preferences for treatment of metastatic breast cancer: a study of women with early-stage breast cancer J Clin Oncol 1995 Apr 13(4):858 68 7707112
McQuellon RP, Kimmick G, Hurt GJ Quality-of-life measurement in women with breast cancer Breast J 1997 3(4):178 86
McTavish FM, Gustafson DH, Owens BH, et al CHESS (Comprehensive Health Enhancement Support System): an interactive computer system for women with breast cancer piloted with an underserved population J Ambulatory Care Manage 1995 18(3):35 41 10143478
McWilliam CL, Brown JB, Stewart M Breast cancer patients' experiences of patient-doctor communication: a working relationship Patient Educ Couns 2000 39(2-3):191 204 11040719
Mead VP, Rhyne RL, Wiese WH, et al Impact of environmental patient education on preventive medicine practices J Fam Pract 1995 Apr 40(4):363 9 7699350
Meade CD, Diekmann J, Thornhill DG Readability of American Cancer Society patient education literature Oncol Nurs Forum 1992 Jan 19(1):51 5 1538988
Meade CD, McKinney WP, Barnas GP Educating patients with limited literacy skills: the effectiveness of printed and videotaped materials about colon cancer Am J Public Health 1994 Jan 84(1):119 21 8279598 1614927
Meade CD Producing videotapes for cancer education: methods and examples Oncol Nurs Forum 1996 Jun 23(5):837 46 8792353
Meana M, Stewart DE, Lickrish GM, et al Patient preference for the management of mildly abnormal Papanicolaou smears Journal of Womens Health & Gender-Based Medicine 1999 Sep 8(7):941 7
Mehta P, Rodrigue J, Nejame C, et al Acquiescence to adjunctive experimental therapies may relate to psychological distress: Pilot data from a bone marrow transplant center Bone Marrow Transplant 2000 25(6):673 6 10734303
Meili L The community hospital perspective of clinical trials and the role of the nurse educator Sem Oncol Nurs 1991 Nov 7(4):280 7
Meiman S Development of an evaluation tool for educational material J Pediatr Oncol Nurs 1996 Jan 13(1):50 2 8904468
Meiser B, Butow P, Barratt A, et al Attitudes toward prophylactic oophorectomy and screening utilization in women at increased risk of developing hereditary breast/ovarian cancer Gynecol Oncol 1999 75(1):122 9 10502438
Meiser B, Tiller K, Gleeson MA, et al Psychological impact of prophylactic oophorectomy in women at increased risk for ovarian cancer Psychooncology 2000 9(6):496 503 11180584
Meister S A look at Pap test accuracy and the duty to inform from a risk management perspective QRC Advisor 1997 14(2):1 8 10176015
Melville A, Liberati A, Grilli R, et al Management of primary breast cancer. [Review] [203 refs] Qual Health Care 1996 5(4):250 8 10164151
Menon M, Parulkar BG, Baker S Should we treat localized prostate cancer? An opinion Urology 1995 46(5):607 16 7495109
Meredith C, Symonds P, Webster L, et al Information needs of cancer patients in west Scotland: cross sectional survey of patients' views BMJ 1996 Sep 21 313(7059):724 6
Mermelstein RJ, Riesenberg LA Changing knowledge and attitudes about skin cancer risk factors in adolescents Health Psychol 1992 11(6):371 6 1286656
Messerli ML, Garamendi C, Romano J Breast cancer: information as a technique of crisis intervention Am J Orthopsychiatry 1980 Oct 50(4):728 31 7425110
Metsch LR, McCoy CB, McCoy HV, et al The role of the physician as an information source on mammography Cancer Pract 1998 Jul 6(4):229 36 9767336
Meyer BJ, Russo C, Talbot A Discourse comprehension and problem solving: decisions about the treatment of breast cancer by women across the life span Psychol Aging 1995 Mar 10(1):84 103 7779321
Meyer PJ, Nielsen DM Navigating the maze of breast cancer treatment Nebr Nurse 1997 30(2):14 23 9400219
Meyer TJ, Mark MM. Effects of psychosocial interventions with adult cancer patients: a meta-analysis of randomized experiments. Health Psychology. 1995.
Meyerowitz BE Quality of life in breast cancer patients: the contribution of data to the care of patients Eur J Cancer 1993 29A(Suppl 1):S59 S62 8427726
Meystre-Agustoni G, Dubois-Arber F, De Landstheer J, et al Exploring the reason for non-participation of women in a breast cancer screening campaign Eur J Public Health 1998 Jun 8(2):143 5
Meyza J. Truth-telling, information, and communication with cancer patients in Poland. Ann N Y Acad Sci. 1997 Feb 20;809:468-79. [pmid: 9103596].
Michaud G, Berthiaume L, Debalays E and others. Qualitative/Quantitative Descriptors of Risk and Benefit of Hormone Replacement Therapy. In 6th Annual Cochrane Colloquiem Abstracts 1998. p. 42.
Michie S, McDonald V, Bobrow M, et al Parents' responses to predictive genetic testing in their children: report of a single case study J Med Genet 1996 Apr 33(4):313 8 8730287
Michlmayr G Psychological guidance of patients with neoplastic diseases Osterr Krankenpflegez 1980 33(10):277 80 6904940
Mickey RM, Durski J, Worden JK, et al Breast cancer screening and associated factors for low-income African-American women Prev Med 1995 24(5):467 76 8524721
Miki J, Sezai S, Kamisaka K, et al The patient and his family in radiotherapy under informed consent; report of a case Jpn J Clin Radiol 1998 43(5):605 9
Milburn M Being in control: a study of a patient who enters a clinical trial for women with high risk breast cancer J Cancer Care 1996 Jul 5(3):101 6
Miller HH, Bauman LJ, Friedman DR, et al Psychosocial adjustment of familial polyposis patients and participation in a chemoprevention trial Int J Psychiatry Med 1986 Aug 16(3):211 30 3026981
Miller MF, Wong JG Reducing financial barriers enhances the return rate of stool Hemoccult packets Am J Med Sci 1993 Aug 306(2):98 100 8362899
Miller RJ Supporting a cancer patient's decision to limit therapy Semin Oncol 1994 Dec 21(6):787 91 7527596
Miller SM, Mangan CE Interacting effects of information and coping style in adapting to gynecologic stress: should the doctor tell all? J Pers Soc Psychol 1983 Jul 45(1):223 36 6886967
Miller SM Monitoring versus blunting styles of coping with cancer influence the information patients want and need about their disease: implications for cancer screening and management Cancer 1995 76(2):167 77 8625088
Miller SM, Fang CY, Manne SL, et al Decision making about prophylactic oophorectomy among at-risk women: psychological influences and implications Gynecol Oncol 1999 Dec 75(3):406 12 10600298
Miller SM, Buzaglo JS, Simms SL, et al Monitoring styles in women at risk for cervical cancer: Implications for the framing of health-relevant messages Ann Behav Med 1999 21(1):27 34 18425651
Mirand EA Challenges and opportunities for Cancer Educators in the new health care environment J Cancer Educ 1997 12(1):
Miron A, Schildkraut JM, Rimer BK, et al Testing for hereditary breast and ovarian cancer in the southeastern United States Ann Surg 2000 231(5):624 34 10767783 1421049
Miura G, Matsumoto T, Nomura S, et al Information given to patients with stage III or IV lung cancer Jpn J Lung Cancer 1999 39(4):361 7
Miura H, Taira O, Hiraguri S, et al Current trends and problems in disclosure to lung cancer patients Nihon Kokyuki Gakkai Zasshi 1998 Nov 36(11):963 8 9916481
Moate Z, Payne J Caring for a patient with oral cancer needing surgery Nurs Times 1994 Oct 12 90(41):36 8
Moe TJ Openness with cancer patients Tidsskr Nor Laegerforen 1993 Mar 30 113(9):
Mohler PJ Enhancing compliance with screening mammography recommendations: a clinical trial in a primary care office Fam Med 1995 Feb 27(2):117 21 7737444
Molenaar S, Sparangers M, Oosterveld P, et al The evaluation of an interactive computer programme on treatment options in early stage breast cancer: preliminary results Med Decis Making 1998 18(4):
Molenaar S, Sprangers M, de Haes J An interactive computer programme on breast cancer: reactions of patients and surgeons Psychooncology 1998 7(3):
Molenaar S, Sprangers MA, Postma-Schuit FC, et al Feasibility and effects of decision aids Med Decis Making 2000 20(1):112 27 10638544
Molenaar S, Sprangers MA, Rutgers EJ, et al Decision support for patients with early-stage breast cancer: effects of an interactive breast cancer CDROM on treatment decision, satisfaction, and quality of life J Clin Oncol 2001 19(6):1676 87 11250997
Molin C The special case of clinical trials Eur J Cancer Care (Engl) 1996 Mar 5(1 Suppl):5 6 8715516
Monfardini S What do we know on variables influencing clinical decision-making in elderly cancer patients? Eur J Cancer 1996 Jan 32A(1):12 4 8695218
Monson MA, Harwood KV Helping women select primary breast cancer treatment. [Review] [16 refs] Am J Nurs 1998 AprSuppl:3 7
Montbriand MJ Decision tree model describing alternate health care choices made by oncology patients Cancer Nurs 1995 Apr 18(2):104 17 7720049
Montbriand, MJ. Decision heuristics of patients with cancer: alternate and biomedical choices 1996.
Montgomery C, Lydon A, Lloyd K Psychological distress among cancer patients and informed consent J Psychosom Res 1999 Mar 46(3):241 5 10193914
Montgomery K. Information is not enough: the place of statistics in the doctor-patient relationship. Cancer Treat Res. 2000;102:13-21. [pmid: 10650477].
Montie JE Counseling the patient with localized prostate cancer Urology 1994 Feb 43(2 Suppl):36 40 8116131
Montorsi W The surgeon and the tumor patient facing the dilemma: radical surgery and the quality of life Minerva Med 1983 Apr 14 74(16):928 30 6843879
Moon H, Kim K, Lee KS, et al A survey of the cognition on clinical trial and informed consent of cancer patients and their families J Korean Soc Clin Pharm Ther 1995 3(2):141 50
Moore KN, Estey A The early post-operative concerns of men after radical prostatectomy J Adv Nurs 1999 May 29(5):1121 9 10320495
Moorman PG, Newman B, Millikan RC, et al Participation rates in a case-control study: the impact of age, race, and race of interviewer Ann Epidemiol 1999 Apr 9(3):188 95 10192651
Morioka Y Informed consent and truth telling to cancer patients Gastroenterol Jpn 1991 Dec 26(6):789 92 1765253
Morra ME, Varricchio C Teaching patients with limited reading skills Cancer Pract 1993 Jul 1(2):154 6 7686801
Morris J, Royle GT Choice of surgery for early breast cancer: pre- and postoperative levels of clinical anxiety and depression in patients and their husbands Br J Surg 1987 Nov 74(11):1017 9 3690226
Morris J, Ingham R Choice of surgery for early breast cancer: psychosocial considerations Soc Sci Med 1988 27(11):1257 62 3206256
Morris J, Royle GT Offering patients a choice of surgery for early breast cancer: a reduction in anxiety and depression in patients and their husbands Soc Sci Med 1988 26(6):583 5 3363399
Morris J, Farmer A, Royle G Recent changes in the surgical management of T1/2 breast cancer in England Eur J Cancer 1992 28A(10):1709 12 1389490
Morris J Surgical treatment for early breast cancer: should the patient decide? Eur J Cancer 1993 29A(13):1801 3 8260226
Morrow G, Gootnick J, Schmale A A simple technique for increasing cancer patients knowledge of informed consent to treatment Cancer 1978 Aug 42(2):793 9 679164
Morrow M A 47-year-old woman with ductal carcinoma in situ JAMA 1996 Jan 3 275(1):61 6 8531289
Morse LK Commentary on Knowledge of colorectal cancer among older persons ONS Nursing Scan in Oncology 1993 2(2):
Mort EA Clinical decision-making in the face of scientific uncertainty: hormone replacement therapy as an example J Fam Pract 1996 Feb 42(2):147 51 8606304
Mortenson LE, Thompson JR. A new weapon in the technology transfer arsenal: a clinical research/patient decision support system for microcomputers. Prog Clin Biol Res. 1984;156:379-96. 379. 96. [pmid: 6382321].
Mossman J, Boudioni M, Slevin ML Cancer information: a cost-effective intervention Eur J Cancer 1999 Oct 35(11):1587 91 10673966
Moul JW, Esther TA, Bauer JJ Implementation of a web-based prostate cancer decision site Semin Urol Oncol 2000 Aug 18(3):241 4 10975497
Moulton G Surgeons have critical role in genetic testing decisions, medical, legal experts say J Natl Cancer Inst 1998 90(11):804 5 9625165
Moyer A, Salovey P Patient participation in treatment decision making and the psychological consequences of breast cancer surgery Women Health 1998 4(2):103 16
Mueller CB Breast cancer trials on trial. A case of conflicting ethical interests Cancer 1995 May 15 75(10):2403 6 7736381
Muhlhauser I, Holdke B Mammography screening: presentation of scientific evidence as a basis for communication with women Z Arztl Fortbild Qualitatssich 2000 Oct 94(9):721 31 11127779
Muller JH, Desmond B Ethical dilemmas in a cross-cultural context. A Chinese example West J Med 1992 Sep 157(3):323 7 1413778 1011287
Muller R, Sergl M, Nauerth U, et al Thempo: A knowledge-based system for therapy planning in pediatric oncology Comp Biol Med 1997 27(3):177 200
Munn EM Nonparticipation in mammography screening: apathy, anxiety or cost? N Z Med J 1993 Jul 14 106(959):284 6 8321446
Munoz ST, Gross GJ, Waltman N, et al Barriers and facilitators to cancer screening for Hispanic women Cancer Res Ther Control 1999 8(3):261 5
Munro AJ A graphical method for the analysis of decisions in clinical oncology Clin Radiol 1986 May 37(3):263 6 3754796
Munro AJ Decision analysis in oncology: panacea or chimera? Clin Oncol (R Coll Radiol) 1992 Sep 4(5):306 12 1390348
Murphy-Ende, K. The relationship of self-directed learning, self-efficacy, and health value in young women with cancer using a computer health education program The University of Wisconsin. 1996.
Murphy M Talking with children and teenagers about cancer Cancer Forum 1995 19(2):141 3
Murtagh J Patient education. Endometriosis Aust Fam Physician 1992 Jul 21(7):
Muse P Informed consent and breast cancer: where does the nurse fit in? Mississippi RN 1985 May 47(3):12 5 3847763
Muss HB, White DR, Michielutte R, et al Written informed consent in patients with breast cancer Cancer 1979 Apr 43(4):1549 56 445353
Myers RE, Ross EA, Wolf TA, et al Behavioral interventions to increase adherence in colorectal cancer screening Med Care 1991 Oct 29(10):1039 50 1921523
Myers RE, Balshem AM, Wolf TA, et al Adherence to continuous screening for colorectal neoplasia Med Care 1993 Jun 31(6):508 19 8501998
Myers RE, Vernon SW, Tilley BC, et al Intention to screen for colorectal cancer among white male employees Prev Med 1998 27(2):279 87 9579008
Myers RE, Chodak GW, Wolf TA, et al Adherence by African American men to prostate cancer education and early detection Cancer 1999 86(1):88 104 10391568
Myers RE, Kunkel EJ Preparatory education for informed decision-making in prostate cancer early detection and treatment Semin Urol Oncol 2000 18(3):172 7 10975487
Naber SJ, Halstead LK, Broome ME, et al Communication and control: parent, child, and health care professional interactions during painful procedures Issues Comp Pediatr Nurs 1995 18(2):79 90
Nagata C Assessment of preference for breast cancer chemoprevention in Japanese young women Jpn J Cancer Res 1997 88(9):792 6 9369925
Nair MG, Hickok JT, Roscoe JA, et al Sources of information used by patients to learn about chemotherapy side effects J Cancer Educ 2000 15(1):19 22 10730798
Naish J, Brown J, Denton B Intercultural consultations: investigation of factors that deter non-English speaking women from attending their general practitioners for cervical screening BMJ 1994 Oct 29 309(6962):1126 8
Naitoh J, Zeiner RL, DeKernion JB Information from your family doctor. Treatment choices for prostate cancer Am Fam Physician 1998 Apr 1 57(7):1545 7
Naitoh J, Zeiner RL, DeKernion JB Information from your family doctor. Screening for prostate cancer Am Fam Physician 1998 Apr 1 57(7):1541 2
Naranjo LE, Dirksen SR The recruitment and participation of Hispanic women in nursing research: a learning process Public Health Nurs 1998 Feb 15(1):25 9 9503950
Nathanson MN, Monaco GP Meeting the educational and psychosocial needs produced by a diagnosis of pediatric/adolescent cancer Health Educ Q 1984 10(Suppl):67 75 6706617
Navarro AM, Senn KL, Kaplan RM, et al Por La Vida intervention model for cancer prevention in Latinas J Natl Cancer Inst 1995(18):137 45
Navarro AM, Senn KL, McNicholas LJ, et al Por la vida model intervention enhances use of cancer screening tests among latinas Am J Prev Med 1998 15(1):32 41 9651636
Nayfield SG, Bongiovanni GC, Alciati MH, et al Statutory requirements for disclosure of breast cancer treatment alternatives J Natl Cancer Inst 1994 Aug 17 86(16):1202 8
Negrier S, Lanier-Demma F, Lacroix-Kante V, et al Evaluation of the informed consent procedure in cancer patients candidate to immunotherapy Eur J Cancer 1995 Sep 31A(10):1650 2
Neill KM, Armstrong N, Burnett CB Choosing reconstruction after mastectomy: a qualitative analysis Oncol Nurs Forum 1998 May 25(4):743 50 9599357
Neptune SM, Hopper KD, Houts PS, et al Take-home informed consent for intravenous contrast media Invest Radiol 1996 31(2):109 13 8750446
Neufeld KR, Degner LF, Dick JA A nursing intervention strategy to foster patient involvement in treatment decisions Oncol Nurs Forum 1993 May 20(4):631 5 8321704
Neumark DE Providing information about advance directives to patients in ambulatory care and their families Oncol Nurs Forum 1994 May 21(4):771 5 8047476
Newall J, Cooper JS, Powers WE, et al Carcinoma of the uterine cervix: the Patterns of Care Study process survey Int J Radiat Oncol Biol Phys 1979 Mar 5(3):383 92 110746
Newton C, Mateo MA Uncertainty: strategies for patients with brain tumor and their family Cancer Nurs 1994 Apr 17(2):137 40 8019997
Ng LF, Shumacher A, Goh CB Autonomy for whom? A perspective from the Orient Palliat Med 2000 14(2):163 4 10829153
NHS Centre for Reviews and Dissemination. The management of primary breast cancer. Effective Health Care Bulletin. 1996:1-16.
NHS Centre for Reviews and Dissemination. Informing, communicating and sharing decisions with people who have cancer. Effective Health Care Bulletin. 2000:1-8.
Nishimura K, Tabata M, Katata K, et al [A lesson in interactions with a leukemic child who refused medication]. [Japanese] Kurinikaru Sutadi -- Clinical Study 1985 Oct 6(10):1216 25 3853694
Nitschke R, Humphrey GB, Sexauer CL, et al Therapeutic choices made by patients with end-stage cancer J Pediatr 1982 Sep 101(3):471 6 7108675
Nitschke R, Humphrey GB, Sexauer CL, et al Therapeutic choices made by patients with end-stage tumors Riv Inferm 1983 Mar 2(1):29 36 6427885
Nitschke R, Wunder S, Sexauer CL, et al. The final-stage conference: The patient's decision on research drugs in pediatric oncology. In: Roberts MC, Koocher GP, editors.Readings in pediatric psychology. New York, NY,USA.: Plenum Press. 1993:p. 65-79.
Nitschke R, Meyer WH, Sexauer CL, et al Care of terminally ill children with cancer Med Pediatr Oncol 2000 34(4):268 70 10742066
Nold RJ, Beamer RL, Helmer SD, et al Factors influencing a woman's choice to undergo breast-conserving surgery versus modified radical mastectomy Am J Surg 2000 180(6):413 8 11182389
Nordlicht S Psychiatric support during cancer treatment N Y State J Med 1980 Sep 80(10):1557 9 6932594
North N, Cornbleet MA, Knowles G, et al Information giving in oncology: a preliminary study of tape-recorder use Br J Clin Psychol 1992 Sep 31(3):357 9 1393167
Northouse LL, Wortman CB Models of helping and coping in cancer care. [Review] [97 refs] Patient Educ Couns 1990 Feb 15(1):49 64 2290741
Northover J Strategic decisions in colorectal cancer screening Eur J Gastroenterol Hepatol 1996 8(4):335 6 8781901
Norton L. Truth, science, and the oncologist. Ann N Y Acad Sci. 1997 Feb 20;809:66-71. [pmid: 9103557].
Nugent, EM. The experience of choosing for women with breast cancer (thesis). Denver (CO): University of Colorado Health Sciences Center. 1995:1-212. [pmcid: 239352].
Nylenna M The general practitioner and information to cancer patients Scan J Prim Health Care 1985 Feb 3(1):35 8
O'Connell CA, Skinner R The patient labeling program at Bristol-Myers Squibb Drug Inf J 1999 33(3):649 54
O'Connor A Efficacy of a decision aid for healthy women considering HRT after menopause: a potentially useful strategy for supporting the decision making of women with breast cancer Obstet Gynecol Surv 1998 53(10 Suppl.):S25 S26
O'Connor AM, Wells GA, Tugwell P, et al. Randomized trial of "explicit" values assessment techniques used in a consumer decision aid. Ann Meet Int Soc Technol Ass Health Care. 1900;14.
O'Connor AM, Boyd NF, Tritchler DL, et al Eliciting preferences for alternative cancer drug treatments. The influence of framing, medium, and rater variables Med Decis Making 1985 5(4):453 63 3842425
O'Connor AM, Boyd NF, Warde P, et al Eliciting preferences for alternative drug therapies in oncology: influence of treatment outcome description, elicitation technique and treatment experience on preferences J Chronic Dis 1987 40(8):811 8 3597681
O'Connor AM Effects of framing and level of probability on patients' preferences for cancer chemotherapy J Clin Epidemiol 1989 42(2):119 26 2918321
O'Connor AM, Pennie RA, Dales RE. Framing effects on expectations and actual treatment decisions. Med Decis Making. 1991:332.
O'Connor AM Validation of a decisional conflict scale Med Decis Making 1995 Jan 15(1):25 30 7898294
O'Connor AM, Pennie RA, Dales RE Framing effects on expectations, decisions, and side effects experienced: the case of influenza immunization J Clin Epidemiol 1996 Nov 49(11):1271 6 8892495
O'Connor AM Consumer/patient decision support in the new millennium: where should our research take us? Can J Nurs Res 1997 29(3):7 19 9505580
O'Connor AM, Drake ER, Fiset VJ, et al Annotated bibliography: studies evaluating decision-support interventions for patients Can J Nurs Res 1997 29(3):113 20
O'Connor AM, Llewellyn-Thomas HA, Sawka C, et al Physicians' opinions about decision aids for patients considering systemic adjuvant therapy for axillary-node negative breast cancer Patient Educ Couns 1997 Feb 30(2):143 53 9128616
O'Connor AM, Tugwell P, Wells GA, et al A decision aid for women considering hormone therapy after menopause: decision support framework and evaluation Patient Educ Couns 1998 Mar 33(3):267 79 9731164
O'Connor AM, Tugwell P, Wells GA, et al Randomized trial of a portable, self-administered decision aid for postmenopausal women considering long-term preventive hormone therapy Med Decis Making 1998 Jul 18(3):295 303 9679994
O'Connor AM, Wells GA, Tugwell P, et al. The effects of an 'explicit' values clarification exercise in a woman's decision aid regarding postmenopausal hormone therapy. Health Expect. 1999;2:21-32. [pmid: 11281872].
O'Connor AM Patient education in the year 2000: tailored decision support, empowerment, and mutual aid Qual Health Care 1999 Mar 8(1):
O'Connor AM, Drake ER, Fiset V, et al The Ottawa patient decision aids Eff Clin Pract 1999 2(4):163 70 10539541
O'Connor AM, Rostom A, Fiset V, et al Decision aids for patients facing health treatment or screening decisions: systematic review BMJ 1999 Sep 18 319(7212):731 4 28223
O'Connor AM, Fiset V, DeGrasse C, et al Decision aids for patients considering options affecting cancer outcomes: evidence of efficacy and policy implications. [Review] [94 refs] J Natl Cancer Inst Monographs 1999(25):67 80
O'Connor JA, Burge FI, King B, et al Does care exclude cure in palliative care? J Palliat Care 1986 Aug 2(1):9 15 2453644
O'Connor PA. "Truth telling in pediatrics -- in degrees.". Prog Clin Biol Res. 1983;139:189-94. [pmid: 6669540].
O'Dell KJ, Volk RJ, Cass AR, et al Screening for prostate cancer with the prostate-specific antigen test: are patients making informed decisions? J Fam Pract 1999 Sep 48(9):682 8 10498074
O'Donnell JF Making a difference J Cancer Educ 1998 13(1):6 13 9565855
O'Rourke ME, Germino BB Prostate cancer treatment decisions: a focus group exploration Oncol Nurs Forum 1998 Jan 25(1):97 104 9460777
O'Rourke ME Prostate cancer: how men choose a treatment Reflections 1999 25(4):25 7
O'Rourke ME Narrowing the options: the process of deciding on prostate cancer treatment Cancer Invest 1999 17(5):349 59 10370363
Oishi T, Noda Y, Gonda H, et al Difference in opinion on the truth-telling and treatment of lung cancer in patients, family, and medical staff Jpn J Lung Cancer 1997 37(6):877 86
Okamato M, Takahashi HO, Yao K, et al A prospective study of introducing self-determined treatment policy for the patients with hypopharyngeal cancer Nippon Jibinkoka Gakkai Kaiho 1999 Jul 102(7):918 24
Oleske D Questions about cancer: indicators for patient education Top Clin Nurs 1981 Jan 2(4):1 8 6905538
Olsen CG A case of futility or patient autonomy J Ethics Law Aging 1996 2(1):33 40 11654406
Olver IN, Buchanan L, Laidlaw C, et al The adequacy of consent forms for informing patients entering oncological clinical trials Ann Oncol 1995 Nov 6(9):867 70 8624288
Olver IN, Turrell SJ, Olszewski NA, et al Impact of an information and consent form on patients having chemotherapy Med J Aust 1995 162(2):82 3 7838031
Onel E, Hamond C, Wasson JH, et al Assessment of the feasibility and impact of shared decision making in prostate cancer Urology 1998 Jan 51(1):63 6 9457290
Ong LM, Visser MR, Kruyver IP, et al The Roter Interaction Analysis System (RIAS) in oncological consultations: psychometric properties Psychooncology 1998 Sep 7(5):387 401 9809330
Ong LM, Visser MR, van Zuuren FJ, et al Cancer patients' coping styles and doctor-patient communication Psychooncology 1999 Mar 8(2):155 66 10335559
Ong LM, Visser MR, Lammes FB, et al Effect of providing cancer patients with the audiotaped initial consultation on satisfaction, recall, and quality of life: a randomized, double-blind study J Clin Oncol 2000 Aug 18(16):3052 60 10944140
Oppenheim PI, Sotiropoulos G, Baraff LJ Incorporating patient preferences into practice guidelines: management of children with fever without source Ann Emerg Med 1994 Nov 24(5):836 41 7978555
Optenberg SA, Clark JY, Brawer MK, et al Development of a decision-making tool to predict risk of prostate cancer: the Cancer of the Prostate Risk Index (CAPRI) test Urology 1997 50(5):665 72 9372872
Orleans CT, Boyd NR, Bingler R, et al A self-help intervention for African American smokers: tailoring cancer information service counseling for a special population Prev Med 1998 Sep 27(5 Pt 2):S61 S70 9808825
Ornstein SM, Garr DR, Jenkins RG, et al Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services J Fam Pract 1991 Jan 32(1):82 90 1985140
Ortega AD, Lopez CL, Lopez CM Strategies for breast self-examination training to women of reproductive age Salud Publica Mex 2000 42(1):17 25 10743395
Osoba D Recommendations of the National Conference on Community Cancer Programs: a vision for the future Can Med Assoc J 1991 Jun 1 144(11):1433 6 1674443
Osoba D Measuring the effect of cancer on health-related quality of life. [Review] [79 refs] Pharmacoeconomics 1995 7(4):308 19 10155320
Osse BH, Vernooij-Dassen MJ, de Vree BP, et al Assessment of the need for palliative care as perceived by individual cancer patients and their families: a review of instruments for improving patient participation in palliative care Cancer 2000 Feb 15 88(4):900 11
Overbay JD Parental participation in treatment decisions for pediatric oncology ICU patients Dimens Crit Care Nurs 1996 Jan 15(1):16 24 8631216
Owen C, Tennant C, Levi J, et al Resuscitation in cancer. Comparison of patient and health staff preferences Gen Hosp Psychiatry 1994 Jul 16(4):277 85 7926704
Owens BH, Robbins KC CHESS: comprehensive health enhancement support system for women with breast cancer Plast Surg Nurs 1996 16(3):172 5 9060757
Owens RG, Ashcroft JJ, Leinster SJ, et al Informal decision analysis with breast cancer patients: an aid to psychological preparation for surgery J Psychosoc Oncol 1987 5(2):23 33
Oyama H, Wakao F, Mishina T, et al. Virtual cancer image data warehouse. Stud Health Technol Inform. 1997;39:151-4. [pmid: 10168912].
Padilla GV, Bulcavage LM Theories used in patient/health education. [Review] [74 refs] Sem Oncol Nurs 1991 May 7(2):87 96
Palda VA, Llewellyn-Thomas HA, Mackenzie RG, et al Breast cancer patients' attitudes about rationing postlumpectomy radiation therapy: applicability of trade-off methods to policy-making J Clin Oncol 1997 Oct 15(10):3192 200 9336355
Palm BT, Kant AC, van den Bosch WJ, et al Preliminary results of a general practice based call system for cervical cancer screening in The Netherlands Br J Gen Pract 1993 Dec 43(377):503 6 8312021 1372614
Pardini RS Effect of educational brochures on Cherokee women with abnormal pap smears Public Health Rep 1996 Nov 111(6):546 7 8955704 1381906
Park SI, Saxe JC, Weesner RE Does use of the Coloscreen Self-Test improve patient compliance with fecal occult blood screening? Am J Gastroenterol 1993 Sep 88(9):1391 4 8362837
Parle M, Maguire P, Heaven C The development of a training model to improve health professionals' skills, self-efficacy and outcome expectancies when communicating with cancer patients Soc Sci Med 1997 Jan 44(2):231 40 9015875
Parsons SK, Gelber S, Cole BF, et al Quality-adjusted survival after treatment for acute myeloid leukemia in childhood: a Q-TWiST analysis of the Pediatric Oncology Group study 8821 J Clin Oncol 1999 17(7):2144 52 10561270
Pasacreta JV, McCorkle R Providing accurate information to women about tamoxifen therapy for breast cancer: current indications, effects, and controversies Oncol Nurs Forum 1998 Oct 25(9):1577 83 9802053
Pasacreta JV An empowerment information intervention improved participation in treatment decision making in men with recently diagnosed prostate cancer EBN 1998 Apr 1(2):
Paskett ED, White E, Carter WB, et al Improving follow-up after an abnormal Pap smear: a randomized controlled trial Prev Med 1990 Nov 19(6):630 41 2263574
Paskett ED, Carter WB, Chu J, et al Compliance behavior in women with abnormal Pap smears. Developing and testing a decision model Med Care 1990 Jul 28(7):643 56 2366603
Paskett ED, Phillips KC, Miller ME Improving compliance among women with abnormal Papanicolaou smears Obstet Gynecol 1995 Sep 86(3):353 9 7651642
Paskett ED, Tatum C, Wilson A, et al Use of a photoessay to teach low-income African American women about mammography J Cancer Educ 1996 11(4):216 20 8989635
Passalacqua R, Campione F, Caminiti C, et al Patients' opinions, feelings, and attitudes after a campaign to promote the Di Bella therapy Lancet 1999 Apr 17 353(9161):1310 4
Pauker SG, Kassirer JP Decision analysis N Engl J Med 1987 Jan 29 316(5):250 8
Pautler SE, Tan JK, Dugas GR, et al Use of the Internet for self-education by patients with prostate cancer Urology 2001 57(2):230 3
Pearlman DN, Rakowski W, Ehrich B The information environment of women and mammography screening: assessing reciprocity in social relationships J Womens Health 1995 4(5):541 53
Pearlman DN, Rakowski W, Clark MA, et al Why do women's attitudes toward mammography change over time? Implications for physician-patient communication Cancer Epidemiol Biomarkers Prev 1997 Jun 6(6):451 7 9184780
Pearlman RA, Cain KC, Starks H, et al Preferences for life-sustaining treatments in advance care planning and surrogate decision making J Palliat Med 2000 3(1):37 48 15859720
Pearlstone DB, Pearlstone MM, Vassilopoulou-Sellin R, et al Hormone replacement therapy and breast cancer Ann Surg Oncol 1999 Mar 6(2):208 17 10082048
Peart O Helping patients overcome their fear of mammography Radiol Technol 1994 Sep 66(1):34 8 7997524
Peay MY, Peay ER The evaluation of medical symptoms by patients and doctors J Behav Med 1998 21(1):57 81 9547422
Peeters PH, Beckers CG, Hogervorst JM, et al Effect on breast cancer screening response in The Netherlands of inviting women for an additional scientific investigation J Epidemiol Community Health 1994 Apr 48(2):175 7 8189174
Pellissier JM, Venta ER Introducing patient values into the decision making process for breast cancer screening Women Health 1996 24(4):47 67 9104764
Pendergrass TW, Davis S Knowledge and use of "alternative" cancer therapies in children Am J Pediatr Hematol Oncol 1981 3(4):339 45 7332064
Pendleton L, Smith A Provision of breast prostheses Nurs Times 1986 Jun 4 82(23):37 9
Penman DT, Holland JC, Bahna GF, et al Informed consent for investigational chemotherapy: patients' and physicians' perceptions J Clin Oncol 1984 Jul 2(7):849 55 6737023
Penson RT, Seiden MV, Shannon KM, et al Communicating genetic risk: Pros, cons, and counsel Oncologist 2000 5(2):152 61 10794806
Percy ME, Llewellyn-Thomas H Assessing preferences about the DNR order: does it depend on how you ask? Med Decis Making 1995 Jul 15(3):209 16 7564934
Pergament D, Pergament E, Wonderlick A, et al At the crossroads: the intersection of the Internet and clinical oncology Oncology (Huntingt) 1999 Apr 13(4):577 83 419372 10234706
Pernotto DA, Bairnsfather L, Sodeman W "Informed consent" interactive videodisc for patients having a colonoscopy, a polypectomy, and an endoscopy Medinfo 19958 Pt 2:
Persson K, Johansson I, Ek AC Breast self-examination among Swedish women: a survey of frequency, knowledge, and attitudes J Cancer Educ 1995 10(3):163 7 8534603
Petersen GM, Brensinger JD, Johnson KA, et al Genetic testing and counseling for hereditary forms of colorectal cancer Cancer 1999 86(8 Suppl.):1720 30 10547544
Petersen S The decisional processing model: Medical decision-making among cancer patients Dissertation Abstracts International: Section B: The Sciences and Engineering 1998 59(2-B):
Peterson SK, Michas MG, Villejo LA Evaluation of a learning resource center for cancer patients Health Educ Res 1989 Dec 4(4):495 500
Petrisek A, Campbell S, Laliberte L Family history of breast cancer: impact on the disease experience Cancer Pract 2000 8(3):135 42 11898138
Petrisek AC, Laliberte LL, Allen SM, et al The treatment decision-making process: age differences in a sample of women recently diagnosed with nonrecurrent, early-stage breast cancer Gerontologist 1997 37(5):598 608 9343910
Pew R A. The patient's challenge: learning about your disease to make an informed decision. In Healthcare technology choices under managed care: communicating directly with patients and their clinicians: proceedings of a conference, November 7-8, Plymouth, PA: Plymouth Meeting; 1996. p.67-8.
Pezza PE Cancer curricula for secondary schools: making the right choice Int J Health Serv 1998 28(3):593 602 9711482
Pfefferbaum B, Levenson PM, van Eys J Comparison of physician and patient perceptions of communications issues South Med J 1982 Sep 75(9):1080 3 7123328
Pfefferbaum B, Levenson PM Adolescent cancer patient and physician responses to a questionnaire on patient concerns Am J Psychiatry 1982 Mar 139(3):348 51 7058951
Phillips JM Commentary on Educating patients with limited literacy skills: the effectiveness of printed and videotaped materials about colon cancer ONS Nursing Scan in Oncology 1994 Jul 3(4):6 7
Phillips K A. Do individual, provider and environmental factors influence health behaviors? The example of womens' adherence to mammography screening guidelines [abstract]. In Abstract Book/Association for Health Services Research 1900. p. 31-2.
Phillips KA, Warner E, Meschino WS, et al Perceptions of Ashkenazi Jewish breast cancer patients on genetic testing for mutations in BRCA1 and BRCA2 Clin Genet 2000 57(5):376 83 10852372
Pickett M, Bruner DW, Joseph A, et al Prostate cancer elder alert. Living with treatment choices and outcomes J Gerontol Nurs 2000 26(2):22 34 10776173
Piechowiak H Ethical problems in the initiation and refusal of treatment Fortshr Med 1980 98(23):875 6
Pierce PF Decision making of women with early stage breast cancer: a qualitative study of treatment choices Dissertation Abstracts International 1986 46(11-B):3784 5
Pierce PF Deciding on breast cancer treatment: a description of decision behavior Nurs Res 1993 42(1):22 8 8424063
Pierce PF When the patient chooses: describing unaided decisions in health care Hum Factors 1996 38(2):278 87 8768489
Piercy GB, Deber R, Trachtenberg J, et al Impact of a shared decision-making program on patients with benign prostatic hyperplasia Urology 1999 May 53(5):913 20 10223483
Pignone M, Bucholtz D, Harris R Patient preferences for colon cancer screening J Gen Intern Med 1999 Jul 14(7):432 7 10417601 1496606
Pignone M, Harris R, Kinsinger L. Vidoetape-Based Decision Aid for Colon Cancer Screening. Ann Intern Med. 2000;133:761-9. [pmid: 11085838].
Pijnenborg L, Van-der MP, Kardaun JF, et al Withdrawal or withholding of treatment at the end of life: results of a nationwide study Arch Intern Med 1995 155(3):286 92 7832600
Pimentel FL, Ferreira JS, Vila RM, et al Quantity and quality of information desired by Portuguese cancer patients Support Care Cancer 1999 Nov 7(6):407 12 10541983
Pinnock CB, O'Brien B, Marshall VR Older men's concerns about their urological health: a qualitative study Aust N Z J Public Health 1998 22(3):368 73 9629824
Plank DP Framing treatment options: a method to enhance informed consent... addressing quality of life issues that are important to the client Clin Nurse Spec 1994 Jul 8(4):174 8 8055411
Plaskon PP, Fadden MJ Cancer screening utilization: is there a role for social work in cancer prevention? Soc Work Health Care 1995 21(4):59 70 8560369
Poe CM A technological approach to reducing fear: the tape recorder Oncol Nurs Forum 1989 16(3):
Pokorski RJ, Sanderson P, Bennett N, et al Insurance issues and genetic testing: Challenges and recommendations -- Workshop No. 1 Cancer 1997 80(3 Suppl.):
Polascik TJ, Pearson JD, Partin AW Multivariate models as predictors of pathological stage using gleason score, clinical stage, and serum prostate-specific antigen Semin Urol Oncol 1998 16(3):160 71 9741421
Ponsioen BP Deliberation between physician and patient concerning active euthanasia at the patient's home Ned Tijdschr Geneeskd 1997 May 10 141(19):921 4 9340535
Porter S The breast cancer controversy -- information by legislation Ohio State Med J 1985 81(9):642 5 4047562
Porterfield HA Perspectives on prostate cancer treatment: awareness, attitudes, and relationships Urology 1997 Mar 49(3A Suppl):102 3 9123728
Porterfield LA, Love N Local and regional therapy for primary breast tumors: answers to major questions Postgrad Med 1995 98(4):65 6+68
Potter CE, Beldock JG, Rosenthal G, et al A clinician-friendly computer program for calculating breast cancer risk using the Gail and Claus models Ann N Y Acad Sci 1995 768(-):301 7 8526374
Poulsen B, Graversen HP, Beckmann J, et al A comparative study of post-operative psychosocial function in women with primary operable breast cancer randomized to breast conservation therapy or mastectomy Eur J Surg Oncol 1997 Aug 23(4):327 34 9315062
Powe BD Fatalism among elderly African Americans. Effects on colorectal cancer screening Cancer Nurs 1995 Oct 18(5):385 92 7585493
Powe BD, Weinrich S An intervention to decrease cancer fatalism among rural elders Oncol Nurs Forum 1999 Apr 26(3):583 8 10214599
Powell T Consultation-liaison psychiatry and clinical ethics: representative cases Psychosomatics 1997 38(4):321 6 9217402
Pozo C, Carver CS, Noriega V, et al Effects of mastectomy versus lumpectomy on emotional adjustment to breast cancer: a prospective study of the first year postsurgery J Clin Oncol 1992 Aug 10(8):1292 8 1634919
Prestifilippo J, Antman K, Berkman BJ, et al The ethical treatment of cancer. What is right for the patient? Cancer 1993 Nov 1 72(9 Suppl):2816 9
Preston JA, Scinto JD, Grady JN, et al The effect of a multifaceted physician office-based intervention on older women's mammography use J Am Geriatr Soc 2000 Jan 48(1):1 7 10642013
Pritzker, J.K. The development and formative evaluation of a psychoeducationally based program for post-mastectomy women University of Georgia. 1988.
Pronzato P, Bertelli G, Losardo P, et al What do advanced cancer patients know of their disease? A report from Italy Support Care Cancer 1994 Jul 2(4):242 4 7522106
Protiere C, Moatti JP, Maraninchi D, et al [Choice and disclosure of preferences, towards sharing the therapeutic decision in cancerology: from economic theory to medical practice]. [French] Bull Cancer 1998 Feb 85(2):173 9 9752336
Protiere C, Viens P, Genre D, et al Patient participation in medical decision-making: a French study in adjuvant radio-chemotherapy for early breast cancer Ann Oncol 2000 Jan 11(1):39 45
Prue CE Exploratory research of the factors that influence a woman's decison regarding hormone replacement therapy Dissertation Abstracts International Section A: Humanities and Social Sciences 1998 59(6-A):
Pruyn JF, Rijckman RM, van Brunschot CJ, et al Cancer patients' personality characteristics, physician-patient communication and adoption of the Moerman diet Soc Sci Med 1985 20(8):841 7 4001993
Pryde PG, Drugan A, Johnson MP, et al Prenatal diagnosis: choices women make about pursuing testing and acting on abnormal results. [Review] [66 refs] Clin Obstet Gynecol 1993 Sep 36(3):496 509 8403601
Psillidis L, Flach J, Padberg RM Participants strengthen clinical trial research: the vital role of participant advisors in the Breast Cancer Prevention Trial J Womens Health 1997 Apr 6(2):227 32 9140857
Pusic A, Thompson TA, Kerrigan CL, et al Surgical options for the early-stage breast cancer: factors associated with patient choice and postoperative quality of life Plast Reconstr Surg 1999 Oct 104(5):1325 33 10513913
Pyke-Grimm KA, Degner L, Small A, et al Preferences for participation in treatment decision making and information needs of parents of children with cancer: a pilot study J Pediatr Oncol Nurs 1999 Jan 16(1):13 24 9989013
Quaid KA, Faden RR, Freeman, et al. Informed consent for a prescription drug: impact of disclosed information on patient understanding and medical outcomes. Patient Educ Couns. 1990;15:249-59. [pmid: 11659330].
Quill TE Death and dignity. a case of individualized decision making Nurs Times 1991 Mar 7 324(10):691 4
Quill TE, Brody RV 'You promised me I wouldn't die like this!' A bad death as a medical emergency Arch Intern Med 1995 155(12):1250 4 7778954
Quinn M Whose turn to break the silence? Nurs Times 1986 Oct 15 82(42):47 8 3641211
Rabinowitz B, Adler D Tough choices. Helping patients make decisions about breast cancer Adm Radiol J 1989 8(9):43 5
Rabinowitz B, Beckman HB, Morse D, et al Discussing preventive services with patients: can we make a difference? Health Values: Achieving High Level Wellness 1994 Jul 18(4):20 6
Rabinowitz B Breast cancer genetics and psychosocial issues Breast J 1998 4(5):386 90
Rainsbury RM A patient declines mastectomy Br J Surg 1999 Dec 86(12):1491 2 10594494
Rajaram SS, Rashidi A Asian-Islamic women and breast cancer screening: a socio-cultural analysis Women Health 1999 28(3):45 58 10374807
Rakowski W, Fulton JP, Feldman JP Women's decision making about mammography: a replication of the relationship between stages of adoption and decisional balance Health Psychol 1993 May 12(3):209 14 8500450
Rakowski W, Ehrich B, Goldstein MG, et al Increasing mammography among women aged 40-74 by use of a stage-matched, tailored intervention Prev Med 1998 Sep 27(5 part 1):748 56 9808807
Rakowski W, Dube CE, Marcus BH, et al Assessing elements of women's decisions about mammography Health Psychol 1992 11(2):111 8 1582379
Rakowski W, Andersen MR, Stoddard AM, et al Confirmatory analysis of opinions regarding the pros and cons of mammography Health Psychol 1997 16(5):433 42 9302540
Randall T Producers of videodisc programs strive to expand patient's role in medical decision-making process [news] JAMA 1993 Jul 14 270(2):160 2 8315717
Rasmussen A, Lund B Patient information -- fear, hope and education (interview by Kirsten Bjornsson) Sygeplejersken 1992 92(46):14 7, 30
Ravdin PM. A computer based program to assist in adjuvant therapy decisions for individual breast cancer patients. Bull Cancer. 1995 Dec;82 Suppl 5:561s-4s. [pmid: 8680066].
Ravdin PM, Siminoff LA, Davis GJ, et al Computer program to assist in making decisions about adjuvant therapy for women with early breast cancer J Clin Oncol 2001 19(4):980 91 11181660
Razavi D, Delvaux N, Hopwood P. Improving communication with cancer patients. A challenge for physicians. Ann N Y Acad Sci. 1997 Feb 20;809:350-60.
Reaby LL The quality and coping patterns of women's decision-making regarding breast cancer surgery Psychooncology 1998 May 7(3):252 62 9638786
Reaby LL Reasons why women who have mastectomy decide to have or not to have breast reconstruction Plast Reconstr Surg 1998 Jun 101(7):1810 8 9623821
Reaby LL Breast restoration decision making: enhancing the process Cancer Nurs 1998 21(3):196 204 9615510
Reaby LL Breast restoration decision making Plast Surg Nurs 1999 19(1):22 9 10478127
Read M Patients' rights to information: the legislative framework Eur J Cancer Care (Engl) 1996 Mar 5(1 Suppl):2 3 8715514
Ream E, Richardson A The role of information in patients' adaptation to chemotherapy and radiotherapy: a review of the literature Eur J Cancer Care (Engl) 1996 Sep 5(3):132 8 9117045
Ream E, Richardson A Patient information. The role of information in patients' adaptation to chemotherapy and radiotherapy: a review of the literature Eur J Cancer Care 1996 Sep 5(3):132 8
Reaman GH, Bonfiglio J, Krailo M, et al Cancer in adolescents and young adults Cancer 1993 May 15 71(10 Suppl):3206 9
Redelmeier DA, Rozin P, Kahneman D Understanding patients' decisions. Cognitive and emotional perspectives JAMA 1993 Jul 7 270(1):72 6
Redelmeier DA, Detsky AS A clinician's guide to utility measurement Prim Care Clin Off Pract 1995 22(2):271 80
Reding DJ, Huber JA, Lappe KA Results of a rural breast health education demonstration project Cancer Pract 1995 3(5):295 302 7663548
Redmond K Why the issue of patient information is important Eur J Cancer Care (Engl) 1996 Mar 5(1 Suppl):
Redmond K Assessing patients' needs and preferences in the management of advanced colorectal cancer Br J Cancer 1998 77Suppl 2:5 7 9579849
Redmond K Treatment choices in advanced cancer: issues and perspectives Eur J Cancer Care 1998 Mar 7(45 ref):31 9
Rees CE, Bath PA The information needs and source preferences of women with breast cancer and their family members: a review of the literature published between 1988 and 1998 J Adv Nurs 2000 Apr 31(4):833 41 10759979
Reid GS, Robertson AJ, Bissett C, et al Cervical screening in Perth and Kinross since introduction of the new contract BMJ 1991 Aug 24 303(6800):447 50
Reid JC, Ringenberg QS, Kardash CM, et al Why are some pamphlets hard for patients to read? Mo Med 1994 Sep 91(9):589 92 7935298
Reiser SJ Words as scalpels: transmitting evidence in the clinical dialogue Ann Intern Med 1980 Jun 92(6):837 42 6992682
Reitherman RW Health care reform and mammography Radiol Technol 1993 May 64(5):311 2 8516431
Remennick LI Preventive behavior among recent immigrants: Russian-speaking women and cancer screening in Israel Soc Sci Med 1999 Jun 48(11):1669 84 10400265
Rex DK Colorectal cancer screening: a guide to the guidelines Can J Gastroenterol 1999 13(5):397 402 10377470
Reynolds PM, Sanson-Fisher RW, Poole AD, et al Cancer and communication: information-giving in an oncology clinic Br Med J (Clin Res Ed) 1981 May 2 282(6274):1449 51
Reynolds SA, Sachs SH, Davis JM, et al Meeting the information needs of patients on clinical trials: a new approach Cancer Nurs 1981 Jun 4(3):227 30 6909041
Rhiner M, Ferrell BR, Ferrell BA, et al A structured nondrug intervention program for cancer pain Cancer Pract 1993 Jul 1(2):137 43 8324539
Rhoads KF, Luce JA, Knudson MM Breast cancer beliefs and behaviors at the San Francisco General Hospital Breast J 2000 6(1):20 6 11348330
Richards CS, Ward PA, Roa BB, et al Screening for 185delAG in the Ashkenazim A J Hum Genet 1997 May 60(5):1085 98
Richards MA, Ramirez AJ, Degner LF, et al Offering choice of treatment to patients with cancers. A review based on a symposium held at the 10th annual conference of The British Psychosocial Oncology Group, December 1993 Eur J Cancer 1995 31A(1):112 6 7695961
Richardson JL, Mondrus GT, Danley K, et al Impact of a mailed intervention on annual mammography and physician breast examinations among women at high risk of breast cancer Cancer Epidemiol Biomarkers Prev 1996 Jan 5(1):71 6 8770470
Riessbeck KH, Dietze R "Informing the cancer patient": psychological guidance for our cancer patients? Radiobiol Radiother (Berl) 1981 22(2):165 83 7255674
Rigatos GA. Cancer and truth-telling in Greece. Historical, statistical, and clinical data. Ann N Y Acad Sci. 1997 Feb 20;809:382-92. [pmid: 9103589].
Righetti A, Giorgio G Factors influencing the communication of the diagnosis to patients who have cancer J Cancer Educ 1994 9(1):42 5 8204457
Rimer B, Jones WL, Keintz MK, et al. Informed consent: a crucial step in cancer patient education. Health Educ Q. 1984;10 Suppl:30-42.
Rimer B, Keintz MK, Strecher V, et al. The role of the physician in changing patients' smoking behavior: results of a survey of physicians. Prog Clin Biol Res. 1986;216:59-70. [pmid: 3725805].
Rimer BK, Resch N, King E, et al Multistrategy health education program to increase mammography use among women ages 65 and older Public Health Rep 1992 Jul 107(4):369 80 1641432 1403666
Rimer BK, Ross E, Cristinzio CS, et al. Older women's participation in breast screening. [Review] [65 refs]. J Gerontol. 1992 Nov;47. Spec No:85-91.
Rimer BK, Ross E, Balshem A, et al The effect of a comprehensive breast screening program on self-reported mammography use by primary care physicians and women in a health maintenance organization J Am Board Fam Pract 1993 Sep 6(5):443 51 8213234
Rimer BK, Conaway MR, Kornguth PJ, et al Effects of force, race, and coping style on pain during patient-controlled mammography J Womens Health 1993 2(3):249 55
Rimer BK, Conaway MR, Lyna PR, et al Cancer screening practices among women in a community health center population Am J Prev Med 1996 12(5):351 7 8909646
Rimer BK, Schildkraut JM, Lerman C, et al Participation in a women's breast cancer risk counseling trial. Who participates? Who declines? High Risk Breast Cancer Consortium Cancer 1996 Jun 1 77(11):2348 55
Rimer BK, Conaway M, Lyna P, et al The impact of tailored interventions on a community health center population Patient Educ Couns 1999 37(2):125 40 14528540
Rimer BK, Glassman B Is there a use for tailored print communications in cancer risk communication? J Natl Cancer Inst Monogr 1999(25):140 8
Rimer BK Cancer control research 2001 Cancer Causes and Control 2000 11(3):257 70 10782660
Risko A, Fleischmann T, Molnar Z, et al Influence of the pathological psychological state of cancer patients on their decisions Support Care Cancer 1996 Jan 4(1):51 5 8771295
Ritvo P, Irvine J, Katz J, et al The patient's motivation in seeking complementary therapies Patient Educ Couns 1999 38(2):161 5 14560712
Ritvo PG Quality of life and prostate cancer treatment: decision-making and rehabilitative support Can J Oncol 1994 Nov 4Suppl 1:43 5 8853489
Roberson NL Clinical trial participation. Viewpoints from racial/ethnic groups Cancer 1994 Nov 1 74(9 Suppl):2687 91 7954287
Roberts CS, Cox CE, Reintgen DS, et al Influence of physician communication on newly diagnosed breast patients' psychologic adjustment and decision-making Cancer 1994 Jul 1 74(1 Suppl):336 41
Roberts CS, Turney ME, Knowles AM Psychosocial issues of adolescents with cancer Soc Work Health Care 1998 27(4):3 18 9680652
Roberts JA, Brown D, Elkins T, et al Factors influencing views of patients with gynecologic cancer about end-of-life decisions Am J Obstet Gynecol 1997 Jan 176(1 Pt 1):166 72 9024108
Robinson A Kit helps physicians, women work together to weigh HRT risks, benefits Can Med Assoc J 1997 Jan 15 156(2):248 50 9012733
Robinson JK Compensation strategies in sun protection behaviors by a population with nonmelanoma skin cancer Prev Med 1992 Nov 21(6):754 65 1438120
Robinson JK, Rademaker AW Skin cancer risk and sun protection learning by helpers of patients with nonmelanoma skin cancer Prev Med 1995 Jul 24(4):333 41 7479622
Robinson MH, Pye G, Thomas WM, et al Haemoccult screening for colorectal cancer: the effect of dietary restriction on compliance Eur J Surg Oncol 1994 Oct 20(5):545 8 7926056
Rochaix L The physician as perfect agent: a comment Soc Sci Med 1998 47(3):355 6 9681905
Roche RA, Stovall CE, Suarez L, et al Language differences in interpretation of breast cancer health messages J Cancer Educ 1998 13(4):226 30 9883782
Rodenhuis S, van den Heuvel WJ, Annyas AA, et al Patient motivation and informed consent in a phase I study of an anticancer agent Eur J Clin Oncol 1984 Apr 20(4):457 62
Rodrigue JR Promoting healthier behaviors, attitudes, and beliefs toward sun exposure in parents of young children J Consult Clin Psychol 1996 64(6):1431 6 8991330
Rodriguez JG, Velez M, Serrano E, et al Adolescent student's compliance with testicular self examination Bol Asoc Med P R 1995 Mar 87(3-4):49 53 7546023
Rogers IA Patients' rights -- choices in self-care Nurs Forum 1979 18(2):206 11 257526
Rolnick SJ, Owens B, Botta R, et al Computerized information and support for patients with breast cancer or HIV infection Nurs Outlook 1999 Mar 47(2):78 83 10227034
Rolnick SJ, LaFerla JJ, Jackson J, et al Impact of a new cervical pap smear screening guideline on member perceptions and comfort levels Prev Med 1999 28(5):530 4 10329344
Romsaas EP, Juliani LM, Briggs AL A method for assessing the rehabilitation needs of oncology outpatients... a checklist was developed to allow patients' participation Oncol Nurs Forum 1983 10(3):17 21 6553901
Rose G Reflections on the changing times BMJ 1990 Oct 3 301(6754):683 7 2224237
Rose JH, O'Toole EE, Dawson NV, et al Age differences in care practices and outcomes for hospitalized patients with cancer J Am Geriatr Soc 2000 May 48(5 Suppl):S25 S32 10809453
Rosenbaum E, Rosenbaum I. Achieving open communication with cancer patients through audio and videotapes. J Psychosoc Oncol. 1986;4:91-105.
Rosenqvist S, Sandelin K, Wickman M Patients' psychological and cosmetic experience after immediate breast reconstruction Eur J Surg Oncol 1996 22(3):262 6 8654609
Ross JW Childhood cancer: the parents, the patients, the professionals Issues Comp Pediatr Nurs 1980 Feb 4(1):7 16
Roter D. The medical visit context of treatment decision-making and the therapeutic relationship. Health Expect. 2000;3:17-25. [pmid: 11281908].
Roter DL Patient participation in the patient-provider interaction: the effects of patient question asking on the quality of interaction, satisfaction and compliance Health Educ Monogr 1977 5(4):281 315 346537
Roth B Wisconsin's response to pediatric cancer pain J Pediatr Oncol Nurs 1991 Apr 8(2):
Rothenbacher D, Lutz MP, Porzsolt F Treatment decisions in palliative cancer care: patients' preferences for involvement and doctors' knowledge about it Eur J Cancer 1997 Jul 33(8):1184 9 9301440
Rothert ML, Holmes-Rovner M, Rovner D, et al An educational intervention as decision support for menopausal women Res Nurs Health 1997 Oct 20(5):377 87 9334792
Rothman AJ, Salovey P, Turvey C, et al Attributions of responsibility and persuasion: increasing mammography utilization among women over 40 with an internally oriented message Health Psychol 1993 Jan 12(1):39 47 8462498
Rozenberg S, Kroll M, Vandromme J Decision factors influencing hormone replacement therapy Br J Obstet Gynaecol 1996 May 103(Suppl 13):92 7 8624351
Rubens RD, Richards MA, Ramirez AJ, et al Large operable breast cancer: The applicability of primary chemotherapy Breast 1997 6(1):45 9,50
Ruccione K, Kramer RF, Moore IK, et al Informed consent for treatment of childhood cancer: factors affecting parents' decision making J Pediatr Oncol Nurs 1991 Jul 8(3):112 21 1930801
Ruccione K, Kramer R, Moore K, et al Informed consent for treatment of childhood cancer: factors affecting parents' decision making J Pediatr Oncol Nurs 1991 Apr 8(2):65 6 1675073
Ruckdeschel JC, Albrecht TL, Blanchard C, et al Communication, accrual to clinical trials, and the physician-patient relationship: implications for training programs... this paper received a Presidential Award at the 29th Annual Meeting of the AACE in Tampa, Florida, November 11, 1995 J Cancer Educ 1996 11(2):73 9 8793646
Ruffin JE, Creed JM, Jarvis C A retreat for families of children recently diagnosed with cancer. [Review] [19 refs] Cancer Pract 1997 Mar 5(2):99 104 9110646
Ruhnke GW, Wilson SR, Akamatsu T, et al Ethical decision making and patient autonomy: a comparison of physicians and patients in Japan and the United States Chest 2000 Oct 118(4):1172 82 11035693
Runowicz CD, Passik SD, Hann D, et al Workgroup II: Patient education -- Pre- and post-treatment Cancer 1998 83(12 Suppl. II):2880 1 9874416
Rushton CH, Glover JJ Involving parents in decisions to forego life-sustaining treatment for critically ill infants and children AACN Clin Issues Crit Care Nurs 1990 May 1(1):206 14 2357440
Rutgers EJ, Peterse JL, Bartelink H, et al Surgical treatment and deciding definitive management policy in a premenopausal patient with early breast cancer Eur J Surg Oncol 1994 Oct 20(5):607 9 7926071
Rutter DR, Iconomou G, Quine L Doctor-patient communication and outcome in cancer patients: an intervention Psychol Health 1996 12(1):57 71
Rylance G Should audio recordings of outpatient consultations be presented to patients? Arch Dis Child 1992 May 67(5):622 4 1599301
Sabbioni ME. Informing cancer patients: whose truth matters?. Ann N Y Acad Sci. 1997 Feb 20;809:508-13. [pmid: 9103601].
Sachs L Knowledge of no return -- Getting and giving information about genetic risk Acta Oncol 1999 38(6):735 40 10522763
Sacile R, Ruggiero C, Dieng R Using CommonKADS to create a conceptual model of a guideline system for breast cancer prognosis Med Inform 1996 21(1):45 59
Safran C, Tsichlis PN, Bluming AZ, et al Diagnostic planning using computer assisted decision-making for patients with Hodgkin's disease Cancer 1977 Jun 39(6):2426 34 872042
Sahay TB, Gray RE, Fitch M A qualitative study of patient perspectives on colorectal cancer Cancer Pract 2000 8(1):38 44 10732538
Sahlberg-Blom E, Ternestedt BM, Johansson JE Patient participation in decision making at the end of life as seen by a close relative Nurs Ethics 2000 7(4):296 313 11221407
Sakorafas GH, Tsiotou AG Prophylactic mastectomy: evolving perspectives Eur J Cancer 2000 36(5):567 78 10738120
Salander P, Bergenheim AT, Bergstrom P, et al How to tell cancer patients: a contribution to a theory of communicating the diagnosis J Psychosoc Oncol 1998 16(2):79 93
Salazar MK, de Moor C An evaluation of mammography beliefs using a decision model Health Educ Q 1995 Feb 22(1):110 26 7721597
Salazar MK Hispanic women's beliefs about breast cancer and mammography Cancer Nurs 1996 Dec 19(6):437 46 8972976
Salkeld G, Ryan M, Short L The veil of experience: do consumers prefer what they know best? Health Econ 2000 Apr 9(3):267 70 10790707
Sandison AJ, Gold DM, Wright P, et al Breast conservation or mastectomy: treatment choice of women aged 70 years and older Br J Surg 1996 Jul 83(7):994 6 8813798
Sandrick K Physicians study tool to help patients select treatment for breast cancer Bull Am Coll Surg 1999 84(9):24 8 10620889
Sanson-Fisher R, Girgis A, Boyes A, et al The unmet supportive care needs of patients with cancer. Supportive Care Review Group Cancer 2000 Jan 1 88(1):226 37
Sarfati D, Howden-Chapman P, Woodward A, et al Does the frame affect the picture? A study into how attitudes to screening for cancer are affected by the way benefits are expressed J Med Screen 1998 5(3):137 40 9795874
Sarna L, Ganley BJ A survey of lung cancer patient-education materials Oncol Nurs Forum 1995 Nov 22(10):1545 50 8577622
Sarna L How nurses can help with smoking cessation after the diagnosis of lung cancer Dev Supp Cancer Care 1998 2(2):45 9
Sarrel PM Hormone replacement therapy in the menopause Int J Fertil Womens Med 1997 42(2):78 84 9160217
Sasako M Getting informed consent in clinical trials on Japanese cancer patients Jpn J Cancer Chemother 1996 23(2):146 50
Sasako M Meaning for incurable patients to know the truth of their disease Jpn J Cancer Chemother 1997 24(7):771 5
Sawka CA, O'Connor AM, Llewellyn TH, et al Appropriateness of adjuvant systemic therapy for axillary node-negative breast cancer: a physician opinion survey J Clin Oncol 1995 13(6):1459 69 7751893
Sawka C, Goel V, Mahut C, et al. Development of a patient decision aid for choice of surgical treatment for breast cancer. Health Expect. 1998;1:23-36. [pmid: 11281859].
Sawyer H Meeting the information needs of cancer patients. [Review] [43 refs] Prof Nurse 2000 Jan 15(4):244 7 10983139
Scardino PT Rationale for the treatment of clinically localized prostate cancer Eur Urol 1995 27(Suppl. 2):17 20
Schain W Psychosocial issues and life-cycle concerns of women with breast cancer Cancer Prev Control 1997 Jun 1(2):122 32 9765734
Schain WS Patients' rights in decision making: the case for personalism versus paternalism in health care Cancer 1980 Aug 15 46(4 Suppl):1035 41 7397654
Schain WS, Jacobs E, Wellisch DK Psychosocial issues in breast reconstruction. Intrapsychic, interpersonal, and practical concerns Clin Plast Surg 1984 Apr 11(2):237 51 6723194
Schain WS, Fetting JH Modified radical mastectomy versus breast conservation: psychosocial considerations Semin Oncol 1992 Jun 19(3):239 43 1609292
Schain WS Barriers to clinical trials. Part II: knowledge and attitudes of potential participants Cancer 1994 Nov 1 74(9 Suppl):2666 71 7954283
Schapira DV, Kumar NB, Clark RA, et al Mammography screening credit card and compliance Cancer 1992 Jul 15 70(2):509 12
Schapira MM, Meade C, Nattinger AB Enhanced decision-making: the use of a videotape decision-aid for patients with prostate cancer Patient Educ Couns 1997 Feb 30(2):119 27 9128614
Schapira MM, VanRuiswyk J The effect of an illustrated pamphlet decision-aid on the use of prostate cancer screening tests J Fam Pract 2000 49(5):418 24 10836772
Schilling A, Conaway MR, Wingate PJ, et al Recruiting cancer patients to participate in motivating their relatives to quit smoking. A cancer control study of the Cancer and Leukemia Group B (CALGB 9072) Cancer 1997 Jan 1 79(1):152 60
Schinke SP, Singer B, Cole K, et al Reducing cancer risk among Native American adolescents Prev Med 1996 Mar 25(2):146 55 8860279
Schlomer U Clinical observations on the topic of informing cancer patients Rontgenpraxis 1990 Oct 43(10):380 4 2244249
Schmitt N, Gogate J, Rothert M, et al Capturing and clustering women's judgment policies: the case of hormonal therapy for menopause J Gerontol A Biol Sci Med Sci 1991 May 46(3):92 101
Schneider M, Namer M An example of planning: breast cancer screening in Alpes-Maritimes Bull Cancer 1991 78(Suppl 1):27s 9s 1912680
Schneiderman LJ, Kronick R, Kaplan RM, et al Attitudes of seriously ill patients toward treatment that involves high costs and burdens on others J Clin Ethics 1994 5(2):109 12 7919478
Schnurre M. Helping the patient sing his own song. WHO Regional Publ Eur Ser. 1992;44:388-95.
Schoene-Seifert B, Childress JF How much should the cancer patient know and decide? CA: Cancer J Clin 1986 Mar 36(2):85 94 3082490
Schofield MJ, Walkom S, Sanson-Fisher R Patient-provider agreement on guidelines for preparation for breast cancer treatment Behav Med 1997 23(1):36 45 9201429
Schonwetter RS, Walker RM, Kramer DR, et al Resuscitation decision making in the elderly: the value of outcome data J Gen Intern Med 1993 Jun 8(6):295 300 8320572
Schouwstra J, Van den Blink JW. Communication in cancer care. The Dutch situation. Ann N Y Acad Sci. 1997 Feb 20;809:422-39.
Schover LR Psychosocial aspects of infertility and decisions about reproduction in young cancer survivors: a review Med Pediatr Oncol 1999 Jul 33(1):53 9 10401498
Schowalter JE, Ferholt JB, Mann NM The adolescent patient's decision to die Pediatrics 1973 Jan 51(1):97 103 4567585
Schrag D, Kuntz KM, Garber JE, et al Decision analysis -- Effects of prophylactic mastectomy and oophorectomy on life expectancy among women with BRCA1 or BRCA2 mutations N Engl J Med 1997 336(20):1465 71 9148160
Schröck R, Bohm HM, Stepien J, et al Satisfaction with treatment and quality of life in breast cancer patients. Differential primary surgical procedure Gynakol 1993 33Suppl 1:95 7
Schutta KM, Burnett CB Factors that influence a patient's decision to participate in a phase I cancer clinical trial Oncol Nurs Forum 2000 Oct 27(9):1435 8 11058975
Schwartz DA, Reilly P The choice not to be resuscitated J Am Geriatr Soc 1986 Nov 34(11):807 11 3771981
Schwartz MD, Hughes C, Roth J, et al Spiritual faith and genetic testing decisions among high-risk breast cancer probands Cancer Epidemiol Biomarkers Prev 2000 9(4):381 5 10794482
Sciartelli CH Using a clinical pathway approach to document patient teaching for breast cancer surgical procedures Oncol Nurs Forum 1995 Jan 22(1):131 7 7708513
Scott JT, Entwistle VA, Watt J Recordings or summaries of consultations for people with cancer (Cochrane Review) In: The Cochrane Library 2002Issue 2.Oxford Update Software 373432
Sculier JP Cardiopulmonary resuscitation in cancer patients: indications and limits Clin Intensive Care 1995 6(2):72 5 10150802
Sebban C, Browman G, Gafni A, et al Design and validation of a bedside decision instrument to elicit a patient's preference concerning allogenic bone marrow transplantation in chronic myeloid leukemia Am J Hematol 1995 Apr 48(4):221 7 7717368
Sefton E, Glazebrook C, Garrud P, et al Educating patients about malignant melanoma: computer-assisted learning in a pigmented lesion clinic Br J Dermatol 2000 142(1):66 71 10651696
Sen M. Communication with cancer patients. The influence of age, gender, education, and health insurance status. Ann N Y Acad Sci. 1997 Feb 20;809:514-24. [pmid: 9103602].
Senn HJ Guidance and management of the cancer patient by the physician and tumor center ZFA (Stuttgart) 1979 Feb 20 55(5):284 95 17350 425639
Seo M, Tamura K, Shijo H, et al Telling the diagnosis to cancer patients in Japan: attitude and perception of patients, physicians and nurses Palliat Med 2000 Mar 14(2):105 10 10829144
Sepucha KR, Belkora JK, Tripathy D, et al Building bridges between physicians and patients: results of a pilot study examining new tools for collaborative decision making in breast cancer J Clin Oncol 2000 18(6):1230 8 10715292
Servodidio CA Teaching aids for patients diagnosed with choroidal melanoma Insight 1991 Dec 16(6):21 3 1783826
Servodidio CA, Abramson DH Genetic teaching for the retinoblastoma patient Insight 1996 Dec 21(4):120 4 9392772
Sevcik SG Commentary: inpatient nurse manager Oncol Nurs Forum 1996 23(4):599 600 8735317
Severson KT Dying cancer patients: choices at the end of life J Pain Symptom Manage 1997 Aug 14(2):94 8 9262039
Sharf BF Communicating breast cancer on-line: support and empowerment on the internet Women Health 1997 26(1):65 84 9311100
Sharp DJ, Peters TJ, Bartholomew J, et al Breast screening: a randomised controlled trial in UK general practice of three interventions designed to increase uptake J Epidemiol Community Health 1996 Feb 50(1):72 6 8762358
Sharp HM, List M, MacCracken E, et al Patients' priorities among treatment effects in head and neck cancer: evaluation of a new assessment tool Head Neck 1999 Sep 21(6):538 46 10449670
Sharp JW, Blum D, Aviv L Elderly men with cancer: social work interventions in prostate cancer Soc Work Health Care 1993 19(1):91 107 7507601
Shaw HJ Palliation in head and neck cancer: discussion paper J R Soc Med 1986 Feb 79(2):84 6 2419558 1290188
Sheehan, P.K. Body image, decision-making, and breast cancer treatment (thesis). Boston College; Boston (MA). 1994. [pmcid: 43273].
Sheldon JM, Fetting JH, Siminoff LA Offering the option of randomized clinical trials to cancer patients who overestimate their prognoses with standard therapies Cancer Nurs 1993 11(1):57 62
Sherer M, Meyers CA, Bergloff P Efficacy of postacute brain injury rehabilitation for patients with primary malignant brain tumors Cancer 1997 80(2):250 7 9217038
Shields P Communication: a supportive bridge between cancer patient, family, and health care staff Nurs Forum 1984 21(1):31 6 6562572
Shimada Y Informed consent in phase I trial Jpn J Cancer Chemother 1996 23(2):226 30
Shriner DL, Wagner RFJ, Weedn VW, et al. Informed consent and risk management in dermatology: to what extent do dermatologists disclose alternate diagnostic and treatment options to their patients?. J Contemp Health Law Policy. 1992;8:137-62. [pmid: 10118984].
Siegel K, Gorey E, Gluhoski V Pregnancy decision making among women previously treated for breast cancer J Psychosoc Oncol 1997 15(1):27 42
Silliman RA, Troyan SL, Guadagnoli E, et al The impact of age, marital status, and physician-patient interactions on the care of older women with breast carcinoma Cancer 1997 Oct 1 80(7):1326 34
Silverman DC, Edbril S, Gartrell N, et al A pilot study of women's attitudes towards breast-conserving surgery with primary radiation therapy for breast cancer Int J Psychiatry Med 1985 Aug 15(4):381 91 3830945
Silvestri G, Pritchard R, Welch HG Preferences for chemotherapy in patients with advanced non-small cell lung cancer: descriptive study based on scripted interviews BMJ 1998 Sep 317(7161):771 5 28665 9740561
Simes RJ Risk-benefit relationships in cancer clinical trials: the ECOG experience in non-small-cell lung cancer J Clin Oncol 1985 Apr 3(4):462 72 2984343
Simes RJ, Tattersall MH, Coates AS, et al Randomised comparison of procedures for obtaining informed consent in clinical trials of treatment for cancer Br Med J (Clin Res Ed) 1986 Oct 25 293(6554):1065 8
Siminoff LA, Fetting JH Effects of outcome framing on treatment decisions in the real world: impact of framing on adjuvant breast cancer decisions Med Decis Making 1989 Oct 9(4):262 71 2796634
Siminoff LA, Fetting JH, Abeloff MD Doctor-patient communication about breast cancer adjuvant therapy J Clin Oncol 1989 Sep 7(9):1192 200 2671280
Siminoff LA, Fetting JH Factors affecting treatment decisions for a life-threatening illness: the case of medical treatment of breast cancer Soc Sci Med 1991 32(7):813 8 2028276
Siminoff LA Improving communication with cancer patients. [Review] [58 refs] Oncology (Huntingt) 1992 Oct 6(10):83 7 419372 1390017
Siminoff LA, Ravdin P, Colabianchi N, et al Doctor-patient communication patterns in breast cancer adjuvant therapy discussions Health Expect 2000 3(1):26 36 11281909
Simmons MS, Nides MA, Rand CS, et al Trends in compliance with bronchodilator inhaler use between follow-up visits in a clinical trial Chest 1996 Apr 109(4):963 8 8635378
Simmons WJ, Goforth L The impact of managed care on cancer care. Review and recommendations Cancer Pract 1997 5(2):111 8 9110648
Singer ME, Cebul RD BRCA1: to test or not to test, that is the question Health Matrix (Cleveland, OH) 1997 7(1):163 85
Singer PA, Tasch ES, Stocking C, et al Sex or survival: trade-offs between quality and quantity of life J Clin Oncol 1991 Feb 9(2):328 34 1988579
Singh J, Cuttler L, Shin M, et al Medical decision-making and the patient: understanding preference patterns for growth hormone therapy using conjoint analysis Med Care 1998 36(8):AS31 AS45 9708581
Sitzia J, Wood N Patient satisfaction with cancer chemotherapy nursing: a review of the literature Int J Nurs Studies 1998 Feb 35(1/2):1 12
Skala E, Dientsbier Z Information possessed by women before and after breast surgery on account of cancer Prakt Lek 1998 78(12):674 6
Skerritt U, Pitt B 'Do not resuscitate': How? Why? And when? Int J Geriatr Psychiatry 1997 12(6):667 70 9215951
Skinner B How to participate in your own health: a cancer patient's view Lancet 1984 Oct 27 2(8409):971 2 6149354
Skinner CS, Strecher VJ, Hospers H Physicians' recommendations for mammography: do tailored messages make a difference? Am J Public Health 1994 Jan 84(1):43 9 8279610 1614921
Slavin LA, O'Malley JE, Koocher GP, et al Communication of the cancer diagnosis to pediatric patients: impact on long-term adjustment Am J Psychiatry 1982 Feb 139(2):179 83 7055287
Slevin ML, Stubbs L, Plant HJ, et al Attitudes to chemotherapy: comparing views of patients with cancer with those of doctors, nurses, and general public BMJ 1990 Jun 2 300(6737):1458 60
Slevin TJ, Donnelly N, Clarkson JP, et al Prostate cancer testing: behaviour, motivation and attitudes among Western Australian men Med J Aust 1999 Aug 16 171(4):185 8
Sloper P Needs and responses of parents following the diagnosis of childhood cancer Child Care Health Dev 1996 22(3):187 202 8735673
Small W, Morrow M Local management of primary breast cancer Cancer Control 1997 4(3):201 10 10763019
Smeltzer CH, Vrba PD Education and cancer screening Nurs Manage 1986 Jun 17(6):64 6
Smith DH, McCarty K Ethical issues in the care of cancer patients Prim Care Clin Off Pract 1992 Dec 19(4):821 33
Smith J "Internet patients" turn to support groups to guide medical decisions J Natl Cancer Inst 1998 Nov 18 90(22):1695 7 9827520
Smith MD, Mcghan WF Prostate cancer: sometimes it pays to do nothing Bus Health 1997 15(1):42 3
Smith RD Is Regret Theory an alternative basis for estimating the value of healthcare interventions? Health Policy 1996 37(2):105 15 10162642
Smith SD, Nicol KM, Devereux J, et al Encounters with doctors: quantity and quality Palliat Med 1999 May 13(3):217 23 10474708
Smith TJ, Desch CE, Hackney MH, et al How long does it take to get a "do not resuscitate" order? J Palliat Care 1997 13(1):5 8
Smitt MC, Heltzel M Women's use of resources in decision-making for early-stage breast cancer: results of a community-based survey Ann Surg Oncol 1997 Oct 4(7):564 9 9367022
Snyderman RK Prophylactic mastectomy: pros and cons Cancer 1984 Feb 1 53(3 Suppl):803 8 6692279
Sobczyk W, Hazel N, Reed CD, et al Health Promotion Schools of Excellence: a model program for Kentucky and the nation J Ky Med Assoc 1995 Apr 93(4):142 7 7751805
Solanke TF. Communication with the cancer patient in Nigeria. Information and truth. Ann N Y Acad Sci. 1997 Feb 20;809:109-18. [pmid: 9103562].
Somerville MA The ethics and law of access to new cancer treatments Curr Oncol 1999 6(3):161 74
Sortet JP, Banks SR Health beliefs of rural Appalachian women and the practice of breast self-examination Cancer Nurs 1997 20(4):231 5 9265808
Souchek J, Stacks JR, Brody B, et al A trial for comparing methods for eliciting treatment preferences from men with advanced prostate cancer: results from the initial visit Med Care 2000 38(10):1040 50 11021677
Spatz TS Improving breast self-examination training by using the 4MAT instructional model J Cancer Educ 1991 6(3):179 83 1931598
Speice J, Harkness J, Laneri H, et al Involving family members in cancer care: focus group considerations of patients and oncological providers Psychooncology 2000 9(2):101 12 10767748
Spiegel D Psychosocial aspects of breast cancer treatment Semin Oncol 1997 24(Suppl. 1):S1 S1 9045314
Sprangers MA Quality-of-life assessment in colorectal cancer patients: evaluation of cancer therapies Semin Oncol 1999 Dec 26(6):691 6 10606262
Stalmeier P, Unic I, Verhoef L, et al. Evaluation of a shared decision making program for women suspected to have a genetic predisposition to breast cancer. Med Decis Making. 1999;19:230-41. [pmid: 10424830].
Stanislaw AE, Wewers ME A smoking cessation intervention with hospitalized surgical cancer patients: a pilot study Cancer Nurs 1994 Apr 17(2):81 6 8020001
Stanton AL, Estes MA, Estes NC, et al Treatment decision making and adjustment to breast cancer: a longitudinal study J Consult Clin Psychol 1998 Apr 66(2):313 22 9583334
Steele S, Carruth AK A comprehensive interdisciplinary chemotherapy teaching documentation flowsheet Oncol Nurs Forum 1997 Jun 24(5):907 11 9201743
Stefanek M, Enger C, Benkendorf J, et al Bilateral prophylactic mastectomy decision making: a vignette study Prev Med 1999 Sep 29(3):216 21 10479610
Stefanek ME Psychosocial aspects of breast cancer Curr Opin Oncol 1993 Nov 5(6):996 1000 8305550
Stefanek ME, Helzlsouer KJ, Wilcox PM, et al Predictors of and satisfaction with bilateral prophylactic mastectomy Prev Med 1995 Jul 24(4):412 9 7479633
Stein HD Ambulatory breast biopsies: the patient's choice Am Surg 1982 May 48(5):221 4 7081837
Stein MT, Wells R, Stephenson S, et al Decision making about medical care in an adolescent with a life-threatening illness J Dev Behav Pediatr 1998 Oct 19(5):355 8 9809268
Stetz KM Survival work: the experience of the patient and the spouse involved in experimental treatment for cancer Sem Oncol Nurs 1993 May 9(2):121 6
Stevens MM, Freeman DHJ, Mott LA, et al Smokeless tobacco use among children: the New Hampshire Study Am J Prev Med 1993 May 9(3):160 7 8347367
Stewart-Brown S, Farmer A Screening could seriously damage your health BMJ 1997 Feb 22 314(7080):533 4
Stewart DE, Lickrish GM, Sierra S, et al The effect of educational brochures on knowledge and emotional distress in women with abnormal Papanicolaou smears Obstet Gynecol 1993 Feb 81(2):280 2 8423964
Stewart DE, Buchegger PM, Lickrish GM, et al The effect of educational brochures on follow-up compliance in women with abnormal Papanicolaou smears Obstet Gynecol 1994 Apr 83(4):583 5 8134070
Stewart DE, Wong F, Cheung AM, et al Information needs and decisional preferences among women with ovarian cancer Gynecol Oncol 2000 Jun 77(3):357 61 10831342
Stewart MA Effective physician-patient communication and health outcomes: a review [see comments] Can Med Assoc J 1995 May 1 152(9):1423 33 7728691
Stiggelbout AM, Kiebert GM, Kievit J, et al Utility assessment in cancer patients: adjustment of time tradeoff scores for the utility of life years and comparison with standard gamble scores Med Decis Making 1994 Jan 14(1):82 90 8152360
Stiggelbout AM, de Haes JC, Kiebert GM, et al Tradeoffs between quality and quantity of life: development of the QQ Questionnaire for Cancer Patient Attitudes Med Decis Making 1996 Apr 16(2):184 92 8778537
Stiggelbout AM, Kiebert GM A role for the sick role. Patient preferences regarding information and participation in clinical decision-making Can Med Assoc J 1997 157(4):383 9 9275945 1243812
Stockler M, Butow PN, Tattersall MH The take-home message: doctors' views on letters and tapes after a cancer consultation Ann Oncol 1993 Aug 4(7):549 52 8363987
Stopfer JE Genetic counseling and clinical cancer genetics services Semin Surg Oncol 2000 18(4):347 57 10805957
Straton JA, Sutherland GJ, Hyndman JC Cervical cancer screening for hospital inpatients: report of an intervention study Aust J Public Health 1995 Jun 19(3):288 93 7542929
Street RLJ, Voigt B, Geyer CJ, et al Increasing patient involvement in choosing treatment for early breast cancer Cancer 1995 Dec 1 76(11):2275 85
Street RLJ, Voigt B Patient participation in deciding breast cancer treatment and subsequent quality of life Med Decis Making 1997 Jul 17(3):298 306 9219190
Street RLJ, Van Order A, Bramson R, et al Preconsultation education promoting breast cancer screening: does the choice of media make a difference? J Cancer Educ 1998 13(3):152 61 10898560
Stroup DF, Berlin JA, Morton SC, et al Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group JAMA 2000 283(15):2008 12 10789670
Struewing JP, Lerman C, Kase RG, et al Anticipated uptake and impact of genetic testing in hereditary breast and ovarian cancer families Cancer Epidemiol Biomarkers Prev 1995 Mar 4(2):169 73 7742725
Strull WM, Lo B, Charles G Do patients want to participate in medical decision making? JAMA 1984 Dec 7 252(21):2990 4
Stuart-Harris R, Simes RJ, Coates AS, et al Patient treatment preference in advanced breast cancer: a randomized cross-over study of doxorubicin and mitozantrone Eur J Clin Oncol 1987 May 23(5):557 61
Stuber ML, Reed GM "Never been done before" -- consultative issues in innovative therapies Gen Hosp Psychiatry 1991 Sep 13(5):337 43 1743503
Sugarman J, Regan K, Parker B, et al Ethical ramifications of alternative means of recruiting research participants from cancer registries Cancer 1999 86(4):647 51 10440692
Suhayda L, Riley MA, Roth L, et al Cancer screening in the community. Taking the show on the road Cancer Pract 1997 Mar 5(2):105 10 9110647
Sulmasy DP, Terry PB, Weisman CS, et al The accuracy of substituted judgments in patients with terminal diagnoses Ann Intern Med 1998 128(8):621 9 9537935
Sumner W An evaluation of readable preventive health messages Fam Med 1991 Aug 23(6):463 6 1936723
Sung JC, Blumenthal DS, Coates RJ, et al Effect of a cancer screening intervention conducted by lay health workers among inner-city women Am J Prev Med 1997 13(1):51 7
Suominen T Breast cancer patients' opportunities to participate in their care Cancer Nurs 1992 Feb 15(1):68 72 1544135
Suominen T, Leino KH, Laippala P Who provides support and how? Breast cancer patients and nurses evaluate patient support Cancer Nurs 1995 18(4):278 85 7664255
Surath Y, O'Connor NP Patient education: reaching the Hispanic community Oncol Nurs Forum 1999 Jun 26(5):
Surbone A The information to the cancer patient: psychosocial and spiritual implications Support Care Cancer 1993 Mar 1(2):89 91 8143106
Surbone A, Zwitter M. Learning from the world. The editors' perspective. Ann N Y Acad Sci. 1997 Feb 20;809:1-6.
Sutherland HJ, Dunn V, Boyd NF Measurement of values for states of health with linear analog scales Med Decis Making 1983 3(4):477 87 6668992
Sutherland HJ, Llewellyn-Thomas HA, Lockwood GA, et al Cancer patients: their desire for information and participation in treatment decisions J R Soc Med 1989 May 82(5):260 3 2754680 1292127
Sutherland HJ, Lockwood GA, Till JE Are we getting informed consent from patients with cancer? J R Soc Med 1990 Jul 83(7):439 43 2395147 1292733
Sutherland HJ, Lockwood GA, Tritchler DL, et al Communicating probabilistic information to cancer patients: is there 'noise' on the line? Soc Sci Med 1991 32(6):725 31 2035049
Sutherland HJ, da Cunha R, Lockwood GA, et al What attitudes and beliefs underlie patients' decisions about participating in chemotherapy trials? Med Decis Making 1998 Jan 18(1):61 9 9456210
Sutton S, Hallett R Smoking intervention in the workplace using videotapes and nicotine chewing gum Prev Med 1988 Jan 17(1):48 59 3362801
Sutton S, Bickler G, Sancho-Aldridge J, et al Prospective study of predictors of attendance for breast screening in inner London J Epidemiol Community Health 1994 Feb 48(1):65 73 8138773
Swaddiwudhipong W, Chaovakiratipong C, Nguntra P, et al Effect of a mobile unit on changes in knowledge and use of cervical cancer screening among rural Thai women Int J Epidemiol 1995 Jun 24(3):493 8 7672887
Swanson GL Patient focus J Nurs Care 1982 Mar 15(3):10 1 6919606
Tabak N Decision making in consenting to experimental cancer therapy Cancer Nurs 1995 Apr 18(2):89 96 7720055
Tabory E, Sered S Accessibility of information and informed consent: experiences of breast cancer patients Harefuah 1998 134(2):88 92 9517288
Talcott JA Quality of life in early prostate cancer: do we know enough to treat? Hematol Oncol Clin North Am 1996 10(3):691 701 8773505
Tamburini M, Buccheri G, Brunelli C, et al The difficult choice of chemotherapy in patients with unresectable non-small-cell lung cancer Support Care Cancer 2000 8(3):223 8 10789964
Tamburni M, Gangeri L, Brunelli C, et al Assessment of hospitalised cancer patient's needs by the needs evaluation questionnaire Ann Oncol 2000 11(1):31 7 10690384
Tan CT, Dlugacz YD Expectations and reactions of parents of children on investigational chemotherapy Loss, Grief and Care 1987 1(3-4):87 92
Tangrea JA Patient participation and compliance in cancer chemoprevention trials: issues and concerns Proc Soc Exp Biol Med 1997 Nov 216(2):260 5 9349695
Tanner R, Abraham SF, Llewellyn-Jones D External breast prostheses. A survey of their use by women after mastectomy Med J Aust 1983 Mar 1(6):270 2 6828014
Taplin S, Anderman C, Grothaus L Breast cancer risk and participation in mammographic screening Am J Public Health 1989 Nov 79(11):1494 8 2817159 1349799
Tarbox BB, Rockwood JK, Abernathy CM Are modified radical mastectomies done for T1 breast cancers because of surgeon's advice or patient's choice? Am J Surg 1992 Nov 164(5):417 20 1443364
Tarzian AJ, Iwata PA, Cohen MZ Autologous bone marrow transplantation: the patient's perspective of information needs Cancer Nurs 1999 Apr 22(2):103 10 10217025
Tattersall MH, Butow PN, Griffin AM, et al The take-home message: patients prefer consultation audiotapes to summary letters J Clin Oncol 1994 Jun 12(6):1305 11 8201393
Taub M, Begas A, Love N Advanced prostate cancer: endocrine therapies and palliative measures Postgrad Med 1996 100(3):139 54
Taub S Cancer and the law of informed consent J Am Med Rec Assoc 1983 54(4):30 5 10309942
Taube AW, Bruera E Collegial disagreements over appropriate palliative care: A case study J Pain Symptom Manage 1999 18(1):67 71 10439576
Taylor JO, Gustafson DH, Hawkins R, et al The comprehensive health enhancement support system Qual Manag Health Care 1994 2(4):36 43
Taylor KM, Margolese RG, Soskolne CL Physicians' reasons for not entering eligible patients in a randomized clinical trial of surgery for breast cancer N Engl J Med 1984 May 24 310(21):1363 7
Taylor P, Fox J, Todd PA A model for integrating image processing into decision aids for diagnostic radiology Artif Intell Med 1997 9(3):205 25 9071462
Taylor V, Thompson B, Lessler D, et al A clinic-based mammography intervention targeting inner-city women J Gen Intern Med 1999 14(2):104 11 10051781
Temple W, Toews J, Fidler H, et al Concordance in communication between surgeon and patient Can J Surg 1998 Dec 41(6):439 45 9854533
Terasaki MR, Morgan CO, Elias L Medical student interactions with cancer patients: evaluation with videotaped interviews Med Pediatr Oncol 1984 12(1):38 42 6700539
Tessaro I, Borstelmann N, Regan K, et al Genetic testing for susceptibility to breast cancer: findings from women's focus groups J Womens Health 1997 Jun 6(3):317 27 9201666
Tetzlaff L Consumer informatics in chronic illness J Am Med Inform Assoc 1997 Jul 4(4):285 300 61246 9223035
The BAM, Koeter GH, Tijmstra TJ, et al Therapeutic possibilities and communication with patients suffering from lung small cell carcinoma Ned Tijdschr Geneeskd 1996 140(41):2021 3 8965936
Theml H Categories of common behaviors of physicians and patients in relation to cancer Med Klin 1986 Feb 28 81(4):148 50
Thomas, A.C. Cancer screening behaviors in older adults: grounded theory Texas Woman's University. 1994.
Thomas AJ Patient autonomy and cancer treatment decisions Int J Pall Nurs 1997 Nov 3(6):317 23
Thomas R, Thornton H, Mackay J Patient information materials in oncology: are they needed and do they work? Clin Oncol 1999 11(4):225 31
Thomas R, Deary A, Kaminski E, et al Patients' preferences for video cassette recorded information: effect of age, sex and ethnic group Eur J Cancer Care (Engl) 1999 Jun 8(2):83 6 10476110
Thomas R, Daly M, Perryman B, et al Forewarned is forearmed -- benefits of preparatory information on video cassette for patients receiving chemotherapy or radiotherapy -- a randomised controlled trial Eur J Cancer 2000 36(12):1536 43 10930801
Thomasma DC The ethics of caring for the older patient with cancer: defining the issues Oncology (Huntingt) 1992 Feb 6(2 Suppl):124 30 419372 1532726
Thompson IM Counseling patients with newly diagnosed prostate cancer Oncology (Huntingt) 2000 14(1):119 26 419372 10680153
Thompson RS, Michnich ME, Gray J, et al Maximizing compliance with hemoccult screening for colon cancer in clinical practice Med Care 1986 Oct 24(10):904 14 3762240
Thomson H Information needs in the early detection phase of colorectal cancer Can Oncol Nurs J 2000 10(1):22 5 10887861
Thorne SE, Harris SR, Hislop TG, et al The experience of waiting for diagnosis after an abnormal mammogram Breast J 1999 Jan 5(1):42 51 11348255
Thornton H Clinical trials -- a brave new partnership? J Med Ethics 1994 Mar 20(1):19 22 8035434
Thornton H Information and involvement Health Expect 2001 4(1):71 4 11286601
Thornton HM Breast cancer trials: a patient's viewpoint Lancet 1992 Jan 4 339(8784):44 5 1345963
Till JE, Sutherland HJ, Meslin EM Is there a role for preference assessments in research on quality of life in oncology? Qual Life Res 1992 Feb 1(1):31 40 1301113
Till JE Measuring quality of life: apparent benefits, potential concerns Can J Oncol 1994 Jan 4(1):243 8 8156152
Timonen L, Sihvonen M Guidance for breast cancer patients in the surgical ward and in the outpatient department Hoitotiede 1998 10(5):299 308 10437453
Tingen MS, Weinrich SP, Boyd MD, et al Search and research. Prostate cancer screening: predictors of participation J Am Acad Nurse Pract 1997 Dec 9(12):557 67 9460422
Toivianen H, Hemminki E Finnish physicians' attitudes towards preconsultation information: menopausal treatment practices as an example Patient Educ Couns 1998 Oct 35(2):101 9 10026553
Tomamichel M, Sessa C, Herzig S, et al Informed consent for phase I studies: evaluation of quantity and quality of information provided to patients Ann Oncol 1995 Apr 6(4):363 9 7619751
Tootla J, Easterling AD Current options in bladder cancer management RN 1992 Apr 55(4):42 8
Topham C, Moore J Patient preferences for chemotherapy schedules used in the treatment of advanced colorectal cancer -- a pilot study Eur J Cancer Care 1997 Dec 6(4):291 4
Tornberg SA Screening for early detection of cancer -- Ethical aspects Acta Oncol 1999 38(1):77 81 10090692
Torrecillas L. Communication of the cancer diagnosis to Mexican patients. Attitudes of physicians and patients. Ann N Y Acad Sci. 1997 Feb 20;809:188-96. [pmid: 9103570].
Tourniaire J, Mirakian P, Pugeat M Management of secreting tumors of the ovary: tumor localization Reprod Hum Horm 1996 9(4):289 93
Towler B, Irwig L, Glasziou P, et al The potential benefits and harms of screening for colorectal cancer Aust J Public Health 1995 19(1):24 8 7734588
Traugott I, Alpers A In their own hands: adolescents' refusals of medical treatment. [Review] [31 refs] Arch Pediatr Adolesc Med 1997 Sep 151(9):922 7 9308870
Trigg ME The decision in pediatrics to go ahead with bone marrow transplant for a pediatric malignancy. [Review] [0 refs] Bone Marrow Transplant 1986 Dec 1(2):111 4 3332126
Trnka YM, Henderson CA Flexible sigmoidoscopy screening: patient acceptance HMO Pract 1997 11(3):130 3 10174522
Trock B, Rimer BK, King E, et al Impact of an HMO-based intervention to increase mammography utilization Cancer Epidemiol Biomarkers Prev 1993 Mar 2(2):151 6 8467250
Truant T For enquiring minds. Complementary therapies: the decision-making process of women with breast cancer Can Oncol Nurs J 1997 May 7(2):
Truant T, Bottorff JL Decision making related to complementary therapies: a process of regaining control Patient Educ Couns 1999 38(2):131 42 14528705
Truman JT, Brant J Ethical and legal issues in the treatment of children with cancer. Our responsibilities to the parents, to the child, and to the other similarly afflicted children Am J Pediatr Hematol Oncol 1984 6(3):313 7 6517226
Trumbo CW Heuristic-systematic information processing and risk judgment Risk Anal 1999 19(3):391 400 10765412
Tubiana M Judgement and decision in oncology Bull Cancer 1980 67(4):369 73 7225594
Turk DC, Rudy TE, Salovey P Health protection: attitudes and behaviors of LPNs, teachers, and college students Health Psychol 1984 3(3):189 210 6536489
Turnbull D, Irwig L, Simpson JM, et al The psychosocial impact of implementing a mammography screening campaign in an Australian community Soc Sci Med 1994 Aug 39(4):543 51 7973854
Turner J, Blaney R, Roy D, et al Does a booklet on breast self-examination improve subsequent detection rates? Lancet 1984 Aug 11 2(8398):337 9
Turner KM, Wilson BJ, Gilbert FJ Improving breast screening uptake: persuading initial non-attenders to attend J Med Screen 1994 Jul 1(3):199 202 8790517
Turner S, Maher EJ, Young T, et al What are the information priorities for cancer patients involved in treatment decisions? An experienced surrogate study in Hodgkin's disease Br J Cancer 1996 Jan 73(2):222 7 8546910
Turrisi R, Hillhouse J, Gebert C, et al Examination of cognitive variables relevant to sunscreen use J Behav Med 1999 Oct 22(5):493 509 10586383
Tversky A, Kahneman D The framing of decisions and the psychology of choice Science 1981 Jan 30 211(4481):453 8
Tyzenhouse P Perspective of the patient advocate Obstet Gynecol Surv 1998 53(10 Suppl.):
Ubel PA, DeKay ML, Baron J, et al Cost-effectiveness analysis in a setting of budget constraints -- is it equitable? Nurs Times 1996 May 2 334(18):1174 7
Uchitomi Y, Yamawaki S. Truth-telling practice in cancer care in Japan. Ann N Y Acad Sci. 1997 Feb 20;809:290-9.
Unbehaun V Randomization and its effects on patient information Onkologie 1996 19(2):189 90
Ungerleider JT, Sarna G, Fairbanks LA, et al. THC or Compazine for the cancer chemotherapy patient -- the UCLA study. Part II: Patient drug preference. Journal title not available. 1985 Apr;8:142-7. [pmcid: 420021].
Unic I, Stalmeier PF, Verhoef LC, et al Assessment of the time-tradeoff values for prophylactic mastectomy of women with a suspected genetic predisposition to breast cancer Med Decis Making 1998 Jul 18(3):268 77 9679991
Unic I, Verhoef LC, Stalmeier PF, et al Prophylactic mastectomy or screening in women suspected to have the BRCA1/2 mutation: a prospective pilot study of women's treatment choices and medical and decision-analytic recommendations Med Decis Making 2000 20(3):251 62 10929847
Urban CE, Mutz ID Psychological management of children with malignancies and their families Padiatr Padol 1978 13(2):137 44 643290
Urban N, Taplin SH, Taylor VM, et al Community organization to promote breast cancer screening among women ages 50-75 Prev Med 1995 Sep 24(5):477 84 8524722
Ureda JR Community intervention. Creating opportunities and support for cancer control behaviors. [Review] [35 refs] Cancer 1993 Aug 1 72(3 Suppl):1125 31 8334668
Uyl-De Groot C, Touw C Economic evaluation of cancer treatments: methodological and practical issues Anticancer Drugs 1998 9(10):835 41 9890694
Vaeth A. A patient's perspective of conservation surgery and radiation therapy. Front Radiat Ther Oncol. 1983;17:16-22. [pmid: 6822351].
Vaeth PA Women's knowledge about breast cancer. Dimensions of knowledge and scale development Am J Clin Oncol 1993 Oct 16(5):446 54 8213627
Vaitones V, Rice L, Degner LF, et al Protocol "shopping" on the Internet... multiple myeloma Cancer Pract 1995 Sep 3(5):274 8 7663545
Valanis B, Rumpler C Healthy women's preferences in breast cancer treatment J Am Med Womens Assoc 1982 Dec 37(12):311 6 7188397
Valanis BG, Rumpler CH Helping women to choose breast cancer treatment alternatives Cancer Nurs 1985 Jun 8(3):167 75 3849340
Valdimarsdottir HB, Bovbjerg DH, Brown K, et al Cancer-specific distress is related to women's decisions to undergo BRCA1 testing Cancer Res Ther Control 1999 8(1-2):61 8
Valverius E, Nilstun T, Nilsson B Palliative care, assisted suicide and euthanasia: nationwide questionnaire to Swedish physicians Palliat Med 2000 14(2):141 8 10829148
van Assema P, Steenbakkers M, Kok G, et al Results of the Dutch community project "Healthy Bergeyk." Prev Med 1994 May 23(3):394 401 8078862
Van der Bruggen H Sharing: an original point of view on relationships in health care Soins 1983 Feb(399):3 8
Van der Donk J, Levendag PC, Kuijpers AJ, et al Patient participation in clinical decision-making for treatment of T3 laryngeal cancer: a comparison of state and process utilities J Clin Oncol 1995 13(9):2369 78 7666096
van der Schueren E FECS Clinical Award lecture 1989. Factors in decision making in the treatment of breast cancer. Federation of European Cancer Societies Radiother Oncol 2000 Jun 55(3):205 16 10869736
Van Dongen MJEWM, De Groot A, Hahlen K, et al Impact of childhood leukemia on family planning Pediatr Hematol Oncol 1995 12(2):117 27 7626379
Van Dongen MJEWM, van Zuuren FJ, Verhulst FC Experiences of parents of childhood cancer survivors: a qualitative analysis Patient Educ Couns 1998 34(3):185 200 9791523
van Eys J Children as decision makers J Assoc Pediatr Oncol Nurses 1986 3(3):18 22 3640816
Van Ruiswyk J, Griffin R, Schapira M Informing patients about prostate cancer screening risks Med Decis Making 1995 15(4):
van Uden MM, van Dam FS Informed consent in clinical cancer research; psychological aspects Ned Tijdschr Geneeskd 1986 Nov 15 130(46):2078 82
van Wersch A, Bonnema J, Prinsen B, et al Continuity of information for breast cancer patients: the development, use and evaluation of a multidisciplinary care-protocol Patient Educ Couns 1997 Feb 30(2):175 86 9128619
van Wersch A, De Boer MF, Van der Does E, et al Continuity of information in cancer care: evaluation of a logbook Patient Educ Couns 1997 31(3):223 36 9277245
Varekamp I, Koedoot CG, Bakker PJ, et al Joint decisions, how? Physician-patient communication about palliative chemotherapy Ned Tijdschr Geneeskd 1997 Oct 4 141(40):1897 900
Veatch RM The patient as partner: ethics in clinical oncology research Johns Hopkins Medical Journal 1982 Oct 151(4):155 61 7120718
Veit CT Motivating mammography adherence in elderly Latinas: a test of three mathematical models of decision making Med Decis Making 1999 Oct 19(4):448 65 10520683
Vennin P, Hecquet B, Marcuzzi I, et al Information and participation preferences among patients with breast cancer and their doctors Bull Cancer 1995 82(9):698 704 8535027
Veno-Sharp MB, Mrozek-Orlowski M. Breast cancer options: getting through the treatment. Am J Nurs. Suppl. 1998 Apr:12-6.
Verhoef LC, Stalpers LJ, Verbeek AL, et al Breast-conserving treatment or mastectomy in early breast cancer: a clinical decision analysis with special reference to the risk of local recurrence Eur J Cancer 1991 27(9):1132 7 1835623
Verhoef LC, de Haan AF, Van Daal WA Risk attitude in gambles with years of life: empirical support for prospect theory Med Decis Making 1994 Apr 14(2):194 200 8028473
Verhoef MJ, Hilsden RJ, O'Beirne M Complementary therapies and cancer care: an overview Patient Educ Couns 1999 38(2):93 100 14528701
Verne J, Kettner J, Mant D, et al Self-administered faecal occult blood tests do not increase compliance with screening for colorectal cancer: results of a randomized controlled trial Eur J Cancer Prev 1993 Jul 2(4):301 5 8358281
Vernon SW, Gritz ER, Peterson SK, et al Correlates of psychologic distress in colorectal cancer patients undergoing genetic testing for hereditary colon cancer Health Psychol 1997 Jan 16(1):73 86 9028817
Vernon SW, Gritz ER, Peterson SK, et al Intention to learn results of genetic testing for hereditary colon cancer Cancer Epidemiol Biomarkers Prev 1999 Apr 8(4 Pt 2):353 60 10207640
Veronesi U, von Kleist S, Redmond K, et al Caring About Women and Cancer (CAWAC): a European survey of the perspectives and experiences of women with female cancers Eur J Cancer 1999 Nov 35(12):1667 75 10674011
Vesterdal A Breast cancer. Freedom of choice in surgery for breast cancer? Sygeplejersken 1990 88(40):20 1
Vetto JT, Dubois PM, Vetto IP The impact of distribution of a patient-education pamphlet in a multidisciplinary breast clinic... presented at the twenty-eighth Annual Meeting of the American Association for Cancer Education, Louisville, Kentucky, November 17-20, 1994 J Cancer Educ 1996 11(3):148 52 8877574
Villejo L, Meyers C Brain function, learning styles, and cancer patient education. [Review] [50 refs] Sem Oncol Nurs 1991 May 7(2):97 104
Vincent C, Furnham A Why do patients turn to complementary medicine? An empirical study Br J Clin Psychol 1996 35(1):37 48 8673034
Virmani J, Schneiderman LJ, Kaplan RM Relationship of advance directives to physician-patient communication Arch Intern Med 1994 Apr 25 154(8):909 13
Visser A, Bleiker E Genetic education and counseling Patient Educ Couns 1997 32(1-2):1 7 9355567
Vlek C Risk assessment, risk perception and decision making about courses of action involving genetic risk: an overview of concepts and methods Birth Def Orig Art Ser 1987 23(2):171 207
Voelker R The last resort JAMA 2000 283(12):
Volk RJ, Cantor SB, Spann SJ, et al Preferences of husbands and wives for prostate cancer screening Arch Fam Med 1997 Jan 6(1):72 6 9003176
Volk RJ, Cass AR, Spann SJ A randomized controlled trial of shared decision making for prostate cancer screening Arch Fam Med 1999 Jul 8(4):333 40 10418541
Volk RJ, Spann SJ Decision-aids for prostate cancer screening J Fam Pract 2000 May 49(5):425 7 10836773
Volk R, Spann SJ, Cass AR A randomized, comparative trial of shared decision making for prostate cancer screening: one-year follow-up Med Decis Making 1998 Oct 18(4):
Volkenandt M About telling the truth to melanoma patients Aktuel Dermatol 1995 21(6):182 7
Volzer HJ Laetrile and the privacy right in decisional responsibility Med Trial Tech Q 1980 26(4):395 429 7402007
von Wrese D. Alternative treatments for small cancers of the breast: motives and preferences of patients having to choose. Recent Results Cancer Res. 1988;111:174-8. 174. 8. [pmid: 3175304].
Wagner EH, Barrett P, Barry MJ, et al The effect of a shared decisionmaking program on rates of surgery for benign prostatic hyperplasia. pilot results Med Care 1995 Aug 33(8):765 70 7543638
Wagner U Psychological know-how. The patient hears only 'cancer.' Arztliche Prax Urol Nephrol 1998(9-10):
Wainstock JM Making a choice: the vein access method you prefer Oncol Nurs Forum 1987 Jan 14(1):79 82 3643593
Walker B, Jr Cancer risk assessment. [Review] [20 refs] J Natl Med Assoc 1997 Jan 89(1):21 6 9002413
Walker C The Anti-Cancer Council of Victoria's Living with Cancer Education Program and the Non English Speaking Background Community in Victoria Cancer Forum 1995 19(2):143 6
Walker LG Behavioural oncology: psychosocial aspects of understanding and treating malignant disease Eur J Surg Oncol 1996 22(5):543 5 8903502
Walker LG, Kohler CD, Heys SD, et al Psychosocial aspects of cancer in the elderly Eur J Surg Oncol 1998 24(5):375 8 9800963
Walker R, Guyton R Modeling and guided practice as components within a comprehensive testicular self-examination cancer education program J Am Coll Health 1989 Mar 37(5):211 5 2703604
Wallberg B, Michelson H, Nystedt M, et al Information needs and preferences for participation in treatment decisions among Swedish breast cancer patients Acta Oncol 2000 39(4):467 76 11041108
Waller M, Batt S Advocacy groups for breast cancer patients. [Review] [20 refs] Can Med Assoc J 1995 Mar 15 152(6):829 33
Wallston KA, Smith RA, King JE, et al Desire for control and choice of antiemetic treatment for cancer chemotherapy West J Nurs Res 1991 Feb 13(1):12 23 1998252
Wamstad K Commentary on a quantitatively scored cancer-risk assessment tool: its development and use ONS Nursing Scan in Oncology 1992 1(4):2 Dec
Wan GJ, Counte MA, Cella DF The influence of personal expectations on cancer patients' reports of health-related quality of life Psychooncology 1997 Psycho-Oncology 1997 6(1):1 11 9126711
Ward B, Shah S, Kirwan P, et al Issues of consent in colonoscopy: if a patient says 'stop' should we continue? J R Soc Med 1999 92(3):132 3 10396257 1297103
Ward J Population-based mammographic screening: does 'informed choice' require any less than full disclosure to individuals of benefits, harms, limitations and consequences? Aust N Z J Public Health 1999 Jun 23(3):301 4 10388176
Ward JE, Boyle K, Redman S, et al Increasing women's compliance with opportunistic cervical cancer screening: a randomized trial Am J Prev Med 1991 Sep 7(5):285 91 1790034
Ward S, Heidrich S, Wolberg W Factors women take into account when deciding upon type of surgery for breast cancer Cancer Nurs 1989 Dec 12(6):344 51 2590902
Ward S, Griffin J Developing a test of knowledge of surgical options for breast cancer Cancer Nurs 1990 Jun 13(3):191 6 2354432
Warner E, Goel V, Ondrusek N, et al Pilot study of an information aid for women with a family history of breast cancer Health Expect 1999 May 2(2):118 28 11281885
Warren G. Discussion summary: truth telling in pediatrics. Prog Clin Biol Res. 1983;139:195-6. [pmid: 6583710].
Watson, EJG. Decision-making style, motivation, and use of Papanicolaou screening tests in women age 35-and-older (thesis). Columbia (SC): University of South Carolina. 1993. [pmcid: 372939].
Watson M, Lloyd SM, Eeles R, et al Psychosocial impact of testing (by linkage) for the BRCA1 breast cancer gene: an investigation of two families in the research setting Psychooncology 1996 Sep 5(20 ref):233 9
Watson M, Duvivier V, Wade WM, et al Family history of breast cancer: what do women understand and recall about their genetic risk? J Med Genet 1998 35(9):731 8 9733031
Watt S Clinical decision-making in the context of chronic illness Health Expect 2000 3(1):6 16 11281907
Webb C, Koch T Women's experiences of non-invasive breast cancer: literature review and study report J Adv Nurs 1997 Mar 25(3):514 25 9080278
Webb P Issues that influence information-giving in Europe Eur J Cancer Care (Engl) 1996 Mar 5(1 Suppl):1 2 8715513
Weber BL, Watson P, Stefanek ME, et al Multidisciplinary rounds... Evaluating and counseling individuals at risk for heritable cancers Cancer Pract 1994 Jul 2(4):252 5 7858651
Weeks JC, Cook EF, O'Day SJ, et al Relationship between cancer patients' predictions of prognosis and their treatment preferences JAMA 1998 Jun 3 279(21):1709 14
Wegner RE Deciding on radical prostatectomy: a patient's perspective Semin Urol Oncol 2000 Aug 18(3):192 9 10975491
Weinrich SP, Weinrich MC, Stromborg MF, et al Using elderly educators to increase colorectal cancer screening Gerontologist 1993 Aug 33(4):491 6 8375677
Weinrich SP, Weinrich MC, Boyd MD, et al Teaching older adults by adapting for aging changes Cancer Nurs 1994 Dec 17(6):494 500 7529659
Weinrich SP, Boyd MD, Weinrich M, et al Increasing prostate cancer screening in African American men with peer-educator and client-navigator interventions J Cancer Educ 1998 13(4):213 9 9883780
Weinrich SP, Reynolds-WA J, Tingen MS, et al Barriers to prostate cancer screening Cancer Nurs 2000 23(2):117 21 10763282
Weinrich SP, Greiner E, Reis-Starr C, et al Predictors of participation in prostate cancer screening at worksites J Community Health Nurs 1998 15(2):113 9 9631594
Weinstein ND, Sandman PM, Roberts NE Perceived susceptibility and self-protective behavior: a field experiment to encourage home radon testing Health Psychol 1991 10(1):25 33 2026127
Weiss BD, Coyne C Communicating with patients who cannot read Nurs Times 1997 Jul 24 337(4):272 4
Weiss SM, Wengert PAJ, Martinez EM, et al Patient satisfaction with decision-making for breast cancer therapy Ann Surg Oncol 1996 May 3(3):285 9 8726184
Weithorn LA, Campbell SB The competency of children and adolescents to make informed treatment decisions Child Dev 1982 Dec 53(6):1589 98 7172783
Welch-McCaffrey D To teach or not to teach? Overcoming barriers to patient education in geriatric oncology Oncol Nurs Forum 1986 Jul 13(4):25 31 3636910
Wenger NS, Phillips RS, Teno JM, et al Physician understanding of patient resuscitation preferences: insights and clinical implications J Am Geriatr Soc 2000 48(5 Suppl.):S44 S51 10809456
Wennberg JE Shared decision making and the future of managed care Dis Manage Clin Outcomes 1997 1(1):15 6
Westdahl PR. Selection, work-up and surgical technique of conservation surgery and axillary dissection. Front Radiat Ther Oncol. 1983;17:48-53. [pmid: 6822354].
Westman J, Hampel H, Bradley T Efficacy of a touchscreen computer based family cancer history questionnaire and subsequent cancer risk assessment J Med Genet 2000 37(5):354 60 10807694
Whamond L The importance of patient-physician communication: a patient's perspective Cancer Prev Control 1999 Feb 3(1):17 8 10474747
Whelan T, Levine M, Gafni A, et al Mastectomy or lumpectomy? Helping women make informed choices J Clin Oncol 1999 Jun 17(6):1727 35 10561209
Whelan T, Gafni A, Charles C, et al Lessons learned from the Decision Board: a unique and evolving decision aid Health Expect 2000 3(1):69 76 11281913
Whelan TJ, Levine MN, Gafni A, et al Breast irradiation postlumpectomy: development and evaluation of a decision instrument J Clin Oncol 1995 Apr 13(4):847 53 7707110
Whelan TJ, Mohide EA, Willan AR, et al The supportive care needs of newly diagnosed cancer patients attending a regional cancer center Cancer 1997 Oct 15 80(8):1518 24
White CD The gynecologist's role in the treatment of breast carcinoma J Reprod Med 1990 Mar 35(3):232 4 2325033
White DR, Muss HB, Michielutte R, et al Informed consent: patient information forms in chemotherapy trials Am J Clin Oncol 1984 Apr 7(2):183 90 6702721
White GE Older women's attitudes to cervical screening and cervical cancer: a New Zealand experience J Adv Nurs 1995 Apr 21(4):659 66 7797700
White JE, Begg L, Fishman NW, et al Increasing cervical cancer screening among minority elderly. Education and on-site services increase screening J Gerontol Nurs 1993 May 19(5):28 34
White MK, Malik T Choices: biomedical ethics and women's health. Teaching clinician-patient communication in the treatment of breast diseases J Womens Health 1999 Jan 8(1):39 44 10094079
White VM, Wearing AJ, Hill DJ Is the conflict model of decision making applicable to the decision to be screened for cervical cancer? A field study J Behav Decis Making 1994 7(1):57 72
Whitman M Breast surgery: helping patients choose Nursing 1994 Aug 24(8):
Whyte A Patient power in the net Nurs Times 1996 92(45):31 12
Wiggers JH, Donovan KO, Redman S, et al Cancer patient satisfaction with care Cancer 1990 Aug 1 66(3):610 6
Wiley FM, Ruccione K, Moore IM, et al Parents' perceptions of randomization in pediatric clinical trials Cancer Pract 1999 7(5):248 56 10687594
Wilkins E, Lowery J, Hamill J The impact of shared decision-making in prostate specific antigen (PSA) screening Med Decis Making 1999 19(4):
Wilkinson J, Broadley P, Pickering A Taking into account the views of women in the development of guidelines for the management of breast cancer J Cancer Care 1996 Jul 5(3):107 11
Willard C Informed consent in the oncology setting J Cancer Care 1995 Oct 4(4):147 51
Willems M, Dik E, Wolschrijn H, et al How can patient experiences systematically be registered Pharm Weekbl 1998 133(9):385 7
Williams CJ, Zwitter M Informed consent in European multicentre randomised clinical trials -- are patients really informed? Eur J Cancer 1994 30A(7):907 10 7946580
Williams J Treatment choices in breast cancer: a comparative analysis of mastectomy patients and radiation patients Dissertation Abstracts International 1985 46(2-A):
Williams TR, O'Sullivan M, Snodgrass SE, et al Psychosocial issues in breast cancer: helping patients get the support they need Postgrad Med 1995 98(4):97 104+107
Williams TR, Love N Treatment of localized prostate cancer: choosing the best alternative Postgrad Med 1996 100(3):105 20
Williamson GM, Jones DJ, Ingram LA. Medical and psychosocial predictors of breast cancer treatment decisions. In: Park, Denise C, ed. Mahwah NJ, USA: Lawrence Erlbaum Associates, Inc. 1999:p. 69-91.
Wilson RG, Hart A, Dawes PJ Mastectomy or conservation: the patient's choice BMJ 1988 Nov 5 297(6657):1167 9
Winters G, Glass E, Sakurai C Ethical issues in oncology nursing practice: an overview of topics and strategies Oncol Nurs Forum 1993 Nov 20(10 Suppl):21 34 8278288
Wittrock DA, Larson LS, Sandgren AK When a child is diagnosed with cancer: II. Parental coping, psychological adjustment, and relationships with medical personnel J Psychosoc Oncol 1994 12(3):17 32
Wolberg WH, Tanner MA, Romsaas EP, et al Factors influencing options in primary breast cancer treatment J Clin Oncol 1987 Jan 5(1):68 74 3806161
Wolberg WH, Romsaas EP, Tanner MA, et al Psychosexual adaptation to breast cancer surgery Cancer 1989 Apr 15 63(8):1645 55
Wolberg WH Mastectomy or breast conservation in the management of primary breast cancer: psychosocial factors Oncology (Huntingt) 1990 4(10):101 4 419372 2149819
Wolberg WH Surgical options in 424 patients with primary breast cancer without systemic metastases Arc Surg 1991 Jul 126(7):817 9
Wolf AM, Nasser JF, Schorling JB The impact of informed consent on patient interest in prostate-specific antigen screening Arch Intern Med 1996 Jun 24 156(12):1333 6
Wolf AM, Becker DM Cancer screening and informed patient discussions. Truth and consequences Arch Intern Med 1996 May 27 156(10):1069 72
Wolf AM, Philbrick JT, Schorling JB Predictors of interest in prostate-specific antigen screening and the impact of informed consent: what should we tell our patients? Am J Med 1997 Oct 103(4):308 14 9382123
Wolf AM, Schorling JB Preferences of elderly men for prostate-specific antigen screening and the impact of informed consent J Gerontol A Biol Sci Med Sci 1998 May 53(3):M195 M200
Wolf AM, Schorling JB Does informed consent alter elderly patients' preferences for colorectal cancer screening? Results of a randomized trial J Gen Intern Med 2000 Jan 15(1):24 30 10632830 1495322
Wolfe JT The role of screening in the management of skin cancer Curr Opin Oncol 1999 11(2):123 8 10188077
Wolff G Silence in children with oncologic diseases Klin Padiatr 1978 May 190(3):287 92 566351
Woloshin S, Schwartz LM, Black WC, et al Women's perceptions of breast cancer risk: how you ask matters Med Decis Making 1999 Jul 19(3):221 9 10424829
Woolf SH, Lawrence RS Preserving scientific debate and patient choice: lessons from the Consensus Panel on Mammography Screening. National Institutes of Health JAMA 1997 Dec 17 278(23):2105 8
Woolf SH, Rothemich SF. Screening for prostate cancer: the roles of science, policy, and opinion in determining what is best for patients. [Review] [61 refs]. Ann Rev Med. 1999;50:207-21. [pmid: 10073273].
Woolf SH, Dickey LL Differing perspectives on preventive care guidelines: A new look at the mammography controversy Am J Prev Med 1999 17(4):260 8 10606194
Worden JK, Solomon LJ, Flynn BS, et al A community-wide program in breast self-examination training and maintenance Prev Med 1990 May 19(3):254 69 2377588
Worthen HG Inherited cancer and the primary care physician: barriers and strategies Cancer 1999 86(11 Suppl.):2583 8 10630185
Wren B Hormonal therapy and genital tract cancer Curr Opin Obstet Gynecol 1996 8(1):38 41 8777257
Wright J, Jones G, Whelan T, et al Patient preference for high or low dose rate brachytherapy in carcinoma of the cervix Radiother Oncol 1994 Dec 33(3):187 94 7716259
Wright SV An investigation into the causes of absconding among black African breast cancer patients S Afr Med J 1997 87(11):1540 3 9472279
Wright S Patient satisfaction in the context of cancer care Ir J Psychol 1998 19(2-3):274 82
Wroblewski S Commentary on a study of breast self examination beliefs: implications for worksite education programs ONS Nursing Scan in Oncology 1993 Mar 2(2):2 3
Wroe AL, Salkovskis PM, Rimes KA The prospect of predictive testing for personal risk: attitudes and decision making Behav Res Ther 1998 Jun 36(6):599 619 9648334
Wroe AL, Salkovskis PM Factors influencing anticipated decisions about genetic testing: experimental studies Br J Health Psychol 1999 4(1):19 40
Yan Y, Carvalhal GF, Catalona WJ, et al Primary treatment choices for men with clinically localized prostate carcinoma detected by screening Cancer 2000 88(5):1122 30 10699903
Yancey AK, Tanjasiri SP, Klein M, et al Increased cancer screening behavior in women of color by culturally sensitive video exposure Prev Med 1995 Mar 24(2):142 8 7597016
Yaniv G Withholding information from cancer patients as a physician's decision under risk Med Decis Making 2000 20(2):216 27 10772359
Yeh CH, Lin CF, Tsai JL, et al Determinants of parental decisions on 'drop out' from cancer treatment for childhood cancer patients J Adv Nurs 1999 Jul 30(1):193 9 10403996
Yellen SB, Cella DF, Leslie WT Age and clinical decision making in oncology patients J Natl Cancer Inst 1994 Dec 7 86(23):1766 70
Yellen SB, Cella DF Someone to live for: social well-being, parenthood status, and decision-making in oncology J Clin Oncol 1995 May 13(5):1255 64 7738630
Yoder LH, O'Rourke TJ, Etnyre A, et al Expectations and experiences of patients with cancer participating in phase I clinical trials Oncol Nurs Forum 1997 Jun 24(5):891 6 9201741
Young PE, Beasley NP, Houghton DJ, et al A new short practical quality of life questionnaire for use in head and neck oncology outpatient clinics Clin Otolaryngol 1998 23(6):528 32 9884807
Younge D, Moreau P, Ezzat A, et al. Communicating with cancer patients in Saudi Arabia. Ann N Y Acad Sci. 1997 Feb 20;809:309-16.
Youssefzadeh S, Eibenberger A, Helbich T, et al Reduction of adverse events in MRI of the breast by personal patient care Clin Radiol 1997 52(11):862 4 9392465
Yu Y Multiobjective decision theory for computational optimization in radiation therapy Med Phys 1997 24(9):1445 54 9304573
Zakotnik B. To tell or not to tell? Communication with cancer patients. Ann N Y Acad Sci. 1997 Feb 20;809:500-7. [pmid: 9103600].
Zamudio A Finding solutions through the eyes of our patients Fam Med 2000 Jan 32(1):15 6 10645508
Zapka JG, Costanza ME, Harris DR, et al Impact of a breast cancer screening community intervention Prev Med 1993 Jan 22(1):34 53 8475011
Zapka JG, Harris DR, Hosmer D, et al Effect of a community health center intervention on breast cancer screening among Hispanic American women Health Serv Res 1993 Jun 28(2):223 35 8514501 1069931
Zappa SC Education program for hematology-oncology patients and siblings J Pediatr Oncol Nurs 1991 Apr 8(2):
Zawid C Patient information survey: meeting the psychosocial needs of the patient with cancer Oncol Nurs Forum 1991 18(8):1415 Dec 1762983
Zimet GD, Mays RM, Winston Y, et al Acceptability of human papillomavirus immunization J Womens Health Gender-based Med 2000 9(1):47 50
Zimmermann C, Baldo C, Molino A Framing of outcome and probability of recurrence: breast cancer patients' choice of adjuvant chemotherapy (ACT) in hypothetical patient scenarios Breast Cancer Res Treat 2000 Mar 60(1):9 14 10845804
Zuckerman DM The need to improve informed consent for breast cancer patients J Am Med Womens Assoc 2000 55(5):285 9 11070648
Zwitter M. Communication with the patient in clinical research. Ann N Y Acad Sci. 1997 Feb 20;809:83-96. [pmid: 9103560].