# References

1 Adolfsson J Treatment of localized prostatic cancer -- different alternatives. Patients with localized prostatic cancer must actively participate in the choice of therapy Lakartidningen 2000 Sep 6 97(36):3870 4 11036336
2 Brock DW, Wartman SA When competent patients make irrational choices N Engl J Med 1990 May 31 322(22):1595 9
3 Cassileth BR, Zupkis RV, Sutton-Smith K, et al Information and participation preferences among cancer patients Ann Intern Med 1980 Jun 92(6):832 6 7387025
4 Emanuel EJ, Emanuel LL Four models of the physician-patient relationship JAMA 1992 Apr 22 267(16):2221 6
5 Charles C, Gafni A, Whelan T Decision-making in the physician-patient encounter: revisiting the shared treatment decision-making model Soc Sci Med 1999 Sep 49(5):651 61 10452420
6 Charles C, Gafni A, Whelan T Shared decision-making in the medical encounter: what does it mean? (or it takes at least two to tango) Soc Sci Med 1997 Mar 44(5):681 92 9032835
7 Siminoff LA, Fetting JH, Abeloff MD Doctor-patient communication about breast cancer adjuvant therapy J Clin Oncol 1989 Sep 7(9):1192 200 2671280
8 Mackillop WJ, Stewart WE, Ginsburg AD, et al Cancer patients' perceptions of their disease and its treatment Br J Cancer 1988 Sep 58(3):355 8 2460120
9 Rimer B, Jones WL, Keintz MK, et al Informed consent: a crucial step in cancer patient education Health Educ Q 1984 10Suppl:30 42
10 Reynolds PM, Sanson-Fisher RW, Poole AD, et al Cancer and communication: information-giving in an oncology clinic Br Med J (Clin Res Ed) 1981 May 2 282(6274):1449 51
11 Penman DT, Holland JC, Bahna GF, et al Informed consent for investigational chemotherapy: patients' and physicians' perceptions J Clin Oncol 1984 Jul 2(7):849 55 6737023
12 Rodenhuis S, van den Heuvel WJ, Annyas AA, et al Patient motivation and informed consent in a phase I study of an anticancer agent Eur J Clin Oncol 1984 Apr 20(4):457 62
13 Degner LF, Kristjanson LJ, Bowman D, et al Information needs and decisional preferences in women with breast cancer JAMA 1997 May 14 277(18):1485 92
14 O'Connor AM, Rostom A, Fiset V, et al Decision aids for patients facing health treatment or screening decisions: systematic review BMJ 1999b Sep 18 319(7212):731 4 28223
15 O'Connor AM, Fiset V, DeGrasse C, et al Decision aids for patients considering options affecting cancer outcomes: evidence of efficacy and policy implications. [Review] [94 refs] J Natl Cancer Inst Monographs 1999a(25):67 80
16 Kassirer JP, Moskowitz AJ, Lau J, et al Decision analysis: a progress report Ann Intern Med 1987 Feb 106(2):275 91 3541727
17 Bekker H, Thornton JG, Airey CM, et al Informed decision making: an annotated bibliography and systematic review Health Technol Assess 1999 3(1):1 156
18 Estabrooks, C A, Goel, V, Thiel, E et al. Consumer Decision Aids: where do we stand? A systematic review of structured consumer decision aids. Institute for Clinical Evaluative Sciences. 00-01-TR. 2000.
19 Molenaar S, Sprangers MA, Postma-Schuit FC, et al Feasibility and effects of decision aids Med Decis Making 2000 20(1):112 27 10638544
20 Informing, communicating and sharing decisions with people who have cancer. Effective Health Care. University of York. 2000.
21 Jadad AR, Moore RA, Carroll D, et al Assessing the quality of reports of randomized clinical trials: is blinding necessary? Control Clin Trials 1996 Feb 17(1):1 12 8721797
22 Downs SH, Black N The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions J Epidemiol Community Health 1998 Jun 52(6):377 84 9764259
23 Guyatt GH, Sackett DL, Cook DJ Users' guides to the medical literature. II. How to use an article about therapy or prevention. A. Are the results of the study valid? Evidence-Based Medicine Working Group JAMA 1993 Dec 1 270(21):2598 601
24 Chapman GB, Elstein AS, Hughes KK Effects of patient education on decisions about breast cancer treatments: a preliminary report Med Decis Making 1995 Jul 15(3):231 9 7564937
25 Fiset V, O'Connor AM, Evans W, et al Development and evaluation of a decision aid for patients with stage IV non-small cell lung cancer Health Expect 2000a 3(2):125 36 11281919
26 Brundage MD, Davidson JR, Mackillop WJ Trading treatment toxicity for survival in locally advanced non-small cell lung cancer J Clin Oncol 1997 Jan 15(1):330 40 8996160
27 Levine MN, Gafni A, Markham B, et al A bedside decision instrument to elicit a patient's preference concerning adjuvant chemotherapy for breast cancer Ann Intern Med 1992a Jul 1 117(1):53 8
28 Whelan TJ, Levine MN, Gafni A, et al Breast irradiation postlumpectomy: development and evaluation of a decision instrument J Clin Oncol 1995a Apr 13(4):847 53 7707110
29 Whelan T, Levine M, Gafni A, et al Mastectomy or lumpectomy? Helping women make informed choices J Clin Oncol 1999 Jun 17(6):1727 35 10561209
30 Unic I, Stalmeier PF, Verhoef LC, et al Assessment of the time-tradeoff values for prophylactic mastectomy of women with a suspected genetic predisposition to breast cancer Med Decis Making 1998 Jul 18(3):268 77 9679991
31 Ravdin PM, Siminoff LA, Davis GJ, et al Computer program to assist in making decisions about adjuvant therapy for women with early breast cancer J Clin Oncol 2001 19(4):980 91 11181660
32 Sebban C, Browman G, Gafni A, et al Design and validation of a bedside decision instrument to elicit a patient's preference concerning allogenic bone marrow transplantation in chronic myeloid leukemia Am J Hematol 1995 Apr 48(4):221 7 7717368
33 Elit LM, Levine MN, Gafni A, et al Patients' preferences for therapy in advanced epithelial ovarian cancer: development, testing, and application of a bedside decision instrument Gynecol Oncol 1996a Sep 62(3):329 35 8812525
34 Elit LM, Levine MN, Gafni A, et al Patients' preferences for therapy in advanced epithelial ovarian cancer: development, testing, and application of a bedside decision instrument Gynecol Oncol 1996b Sep 62(3):329 35 8812525
35 Lawrence VA, Streiner D, Hazuda HP, et al A cross-cultural consumer-based decision aid for screening mammography Prev Med 2000 30(3):200 8 10684743
36 Carrère M, Moumjid-Ferdjaoui N, Charavel M, et al. Eliciting patients' preferences for adjuvant chemotherapy in breast cancer: development and validation of a bedside decision-making instrument in a French Regional Cancer Centre. Health Expect. 2000:97-113.
37 Gustafson D, Wise M, McTavish F, et al Development and pilot evaluation of a computer-based support system for women with breast cancer J Psychosoc Oncol 1993a 11(4):69 93
38 Gustafson D, Wise M, McTavish F, et al Development and pilot evaluation of a computer-based support system for women with breast cancer J Psychosoc Oncol 1993b 11(4):69 93
39 McTavish FM, Gustafson DH, Owens BH, et al CHESS (Comprehensive Health Enhancement Support System): an interactive computer system for women with breast cancer piloted with an underserved population J Ambulatory Care Manage 1995 18(3):35 41 10143478
40 Rolnick SJ, Owens B, Botta R, et al Computerized information and support for patients with breast cancer or HIV infection Nurs Outlook 1999 Mar 47(2):78 83 10227034
41 Dolan JG Are patients capable of using the analytic hierarchy process and willing to use it to help make clinical decisions? Med Decis Making 1995 Jan 15(1):76 80 7898301
42 Jenkinson J, Wilson-Pauwels L, Jewett MA, et al Development of a hypermedia program designed to assist patients with localized prostate cancer in making treatment decisions J Biocomm 1998 25(2):2 11
43 Sawka C, Goel V, Mahut C, et al. Development of a patient decision aid for choice of surgical treatment for breast cancer. Health Expect. 1998a;1:23-36. [pmid: 11281859].
44 Sawka C, Goel V, Mahut C, et al. Development of a patient decision aid for choice of surgical treatment for breast cancer. Health Expect. 1998b;1:23-36. [pmid: 11281859].
45 Rakowski W, Andersen MR, Stoddard AM, et al Confirmatory analysis of opinions regarding the pros and cons of mammography Health Psychol 1997 16(5):433 42 9302540
46 Schapira MM, Meade C, Nattinger AB Enhanced decision-making: the use of a videotape decision-aid for patients with prostate cancer Patient Educ Couns 1997 Feb 30(2):119 27 9128614
47 Whelan T, Gafni A, Charles C, et al Lessons learned from the Decision Board: A unique and evolving decision aid Health Expect 2000 3(1):69 76 11281913
48 O'Connor AM Validation of a decisional conflict scale Med Decis Making 1995 Jan 15(1):25 30 7898294
49 O'Connor AM, Tugwell P, Wells GA, et al A decision aid for women considering hormone therapy after menopause: decision support framework and evaluation Patient Educ Couns 1998 Mar 33(3):267 79 9731164
50 Lerman C, Biesecker B, Benkendorf JL, et al Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing J Natl Cancer Inst 1997 Jan 15 89(2):148 57
51 Watson M, Duvivier V, Wade WM, et al Family history of breast cancer: What do women understand and recall about their genetic risk? J Med Genet 1998 35(9):731 8 9733031
52 Volk RJ, Cass AR, Spann SJ A randomized controlled trial of shared decision making for prostate cancer screening Arch Fam Med 1999 Jul 8(4):333 40 10418541
53 Davison BJ, Kirk P, Degner LF, et al Information and patient participation in screening for prostate cancer Patient Educ Couns 1999 37(3):255 63 14528551
54 Wolf AM, Nasser JF, Schorling JB The impact of informed consent on patient interest in prostate-specific antigen screening Arch Intern Med 1996 Jun 24 156(12):1333 6
55 Schapira MM, VanRuiswyk J The effect of an illustrated pamphlet decision-aid on the use of prostate cancer screening tests J Fam Pract 2000 49(5):418 24 10836772
56 Maslin AM, Baum M, Walker JS, et al Shared decision-making using an interactive video disk system for women with early breast cancer... including commentary by Beaver K. Nt Research 1998 Nov 3(6):444 55 170365
57 Hack TF, Pickles T, Bultz BD, et al Feasibility of an audiotape intervention for patients with cancer: A multicenter, randomized, controlled pilot study J Psychosoc Oncol 1999 17(2):1 15
58 Davison BJ, Degner LF Empowerment of men newly diagnosed with prostate cancer Cancer Nurs 1997 Jun 20(3):187 96 9190093
59 Street RLJ, Voigt B, Geyer CJ, et al Increasing patient involvement in choosing treatment for early breast cancer Cancer 1995 Dec 1 76(11):2275 85
60 North N, Cornbleet MA, Knowles G, et al Information giving in oncology: a preliminary study of tape-recorder use Br J Clin Psychol 1992 Sep 31(3):357 9 1393167
61 Irwin E, Arnold A, Whelan TJ, et al Offering a choice between two adjuvant chemotherapy regimens: A pilot study to develop a decision aid for women with breast cancer Patient Educ Couns 1999 37(3):283 91 14528554
62 Iglehart JD, Miron A, Rimer BK, et al Overestimation of hereditary breast cancer risk Ann Surg 1998 228(3):375 84 9742920 1191495
63 Pignone M, Harris R, Kinsinger L. Vidoetape-Based Decision Aid for Colon Cancer Screening. Ann Intern Med. 2000;133:761-9. [pmid: 11085838].
64 Wolf AM, Schorling JB Does informed consent alter elderly patients' preferences for colorectal cancer screening? Results of a randomized trial J Gen Intern Med 2000 Jan 15(1):24 30 10632830 1495322
65 Goel V, Sawka CA, Thiel EC, et al Randomized trial of a patient decision aid for choice of surgical treatment for breast cancer Med Decis Making 2001 21(1):1 6 11206942
66 Flood AB, Wennberg JE, Nease RFJ, et al. The importance of patient preference in the decision to screen for prostate cancer. Prostate Patient Outcomes Research Team. J Gen Intern Med. 1996a Jun;11(6):342-9.
67 Flood AB, Wennberg JE, Nease RFJ, et al The importance of patient preference in the decision to screen for prostate cancer. Prostate Patient Outcomes Research Team J Gen Intern Med 1996b Jun 11(6):342 9 8803740
68 Sepucha KR, Belkora JK, Tripathy D, et al Building bridges between physicians and patients: Results of a pilot study examining new tools for collaborative decision making in breast cancer J Clin Oncol 2000 18(6):1230 8 10715292
69 Molenaar S, Sprangers MA, Rutgers EJ, et al Decision support for patients with early-stage breast cancer: effects of an interactive breast cancer CDROM on treatment decision, satisfaction, and quality of life J Clin Oncol 2001 19(6):1676 87 11250997
70 Whelan TJ, Levine MN, Gafni A, et al Breast irradiation postlumpectomy: development and evaluation of a decision instrument J Clin Oncol 1995b Apr 13(4):847 53 7707110
71 Whelan T, Levine M, Gafni A, et al Mastectomy or lumpectomy? Helping women make informed choices J Clin Oncol 1999 Jun 17(6):1727 35 10561209
72 Stalmeier P, Unic I, Verhoef L, et al. Evaluation of a shared decision making program for women suspected to have a genetic predisposition to Breast Cancer. Med Decis Making. 1999;19:230-41. [pmid: 10424830].
73 Brundage MD, Feldman SD, Dixon P, et al A treatment trade-off based decision aid for patients with locally advanced non-small cell lung cancer Health Expect 2000 3(1):55 68 11281912
74 Onel E, Hamond C, Wasson JH, et al Assessment of the feasibility and impact of shared decision making in prostate cancer Urology 1998 Jan 51(1):63 6 9457290
75 Gramlich EP, Waitzfelder BE Interactive video assists in clinical decision making Methods Inf Med 1998 Jun 37(2):201 5 9656665
76 Ashcroft JJ, Leinster SJ, Slade PD Breast cancer patient choice of treatment: preliminary communication J R Soc Med 1985 Jan 78(1):43 6
77 Fiset V, O'Connor AM, Evans W, et al Development and evaluation of a decision aid for patients with stage IV non-small cell lung cancer Health Expect 2000b 3(2):125 36 11281919
78 Levine MN, Gafni A, Markham B, et al A bedside decision instrument to elicit a patient's preference concerning adjuvant chemotherapy for breast cancer Ann Intern Med 1992b Jul 1 117(1):53-8
79 Cotton T Patient choice in breast cancer treatment Nurs Times 1995 91(17):
80 Cotton T, Locker AP, Jackson L, et al A prospective study of patient choice in treatment for primary breast cancer Eur J Surg Oncol 1991 Apr 17(2):115 7 2015917
81 Wilson RG, Hart A, Dawes PJ Mastectomy or conservation: the patient's choice BMJ 1988 Nov 5 297(6657):1167 9
82 Wolberg WH, Tanner MA, Romsaas EP, et al Factors influencing options in primary breast cancer treatment J Clin Oncol 1987 Jan 5(1):68 74 3806161
83 Sandison AJ, Gold DM, Wright P, et al Breast conservation or mastectomy: treatment choice of women aged 70 years and older Br J Surg 1996 Jul 83(7):994 6 8813798
84 Protiere C, Viens P, Genre D, et al Patient participation in medical decision-making: a French study in adjuvant radio-chemotherapy for early breast cancer Ann Oncol 2000 Jan 11(1):39 45
85 Adler K Research in brief. Chemotherapy: the patient's choice Eur J Oncol Nurs 1999 Jun 3(2):102 4
86 Cassileth BR, Soloway MS, Vogelzang NJ, et al Patients' choice of treatment in stage D prostate cancer Urology 1989 May 33(5 Suppl):57 62
87 Klass W, Varenhorst E, Hjertberg H, et al A study on prostatic cancer. The patient can decide himself: medical or surgical treatment Lakartidningen 1992 May 6 89(19):1659 61
88 Okamato M, Takahashi HO, Yao K, et al A prospective study of introducing self-determined treatment policy for the patients with hypopharyngeal cancer Nippon Jibinkoka Gakkai Kaiho 1999 Jul 102(7):918 24
89 Lerman C, Hughes C, Benkendorf JL, et al Racial differences in testing motivation and psychological distress following pretest education for BRCA1 gene testing Cancer Epidemiol Biomarkers Prev 1999 8(4 II):361 7 10207641
90 Hack TF, Degner LF Coping with breast cancer: A cluster analytic approach Breast Cancer Res Treat 1999 54(3):185 94 10445417
91 Bluman LG, Rimer BK, Berry DA, et al Attitudes, knowledge, and risk perceptions of women with breast and/or ovarian cancer considering testing for BRCA1 and BRCA2 J Clin Oncol 1999 17(3):1040 6 10071299
92 Miron A, Schildkraut JM, Rimer BK, et al Testing for hereditary breast and ovarian cancer in the southeastern United States Ann Surg 2000 231(5):624 34 10767783 1421049
93 Wolf AM, Schorling JB Preferences of elderly men for prostate-specific antigen screening and the impact of informed consent J Gerontol A Biol Sci Med Sci 1998 May 53(3):M195 M200
94 Lerman C, Rimer BK, Engstrom PF Cancer risk notification: psychosocial and ethical implications J Clin Oncol 1991 Jul 9(7):1275 82 2045867
95 Degner LF, Davison BJ, Sloan JA, et al Development of a scale to measure information needs in cancer care J Nurs Meas 1998 6(2):137 53 10028780