# Directions for Future Research

- The early stage of development of this field and the gaps in our knowledge outlined in this systematic review underline the need for further research. A number of different areas were identified. Future research efforts should consider:
- Developing a better understanding of how decisionmaking happens in the real world. Who is involved-clinician, patient, or others? To what degree are they involved? When does decisionmaking happen-at the clinical encounter, before, or afterward?
- Identifying the processes involved and when they occur. Presumably, information transfer is the first step, but what are the stages of deliberation and how do patients and clinicians interact at each stage? How do they ultimately make a decision?
- Investigators need to determine the key features of quality decisionmaking from patients and clinicians. Such information will have a number of important benefits to help investigators develop instruments to facilitate quality decisionmaking and, perhaps most importantly, to identify and prioritize outcomes of effectiveness.
- Determining patients' understanding of numerical estimates of risk. Is it meaningful for them? What is the impact of framing in real life decisions? Is there a substantial influence?
- Much more work is needed to determine if decision aids are effective for cancer-related treatment decisions. Research in other disease sites besides breast and prostate cancer and in the metastatic setting is also necessary. The latter may be particularly challenging in terms of explicit discussion of benefits and risks of proposed treatments.
- Future research should also focus on which components of a decision aid are necessary and effective. For example, besides exchanging information, is counseling helpful? How should it be instituted?
- Are different types of decision aids more effective than others?
- Is decisionmaking regarding cancer really different from decisionmaking in other chronic medical illnesses? In view of the life-threatening nature of this disease, are special approaches necessary here (e.g., psychosocial support techniques, patient support groups or teleconferences, use of repetition)?
- What patient, clinician, or decisionmaking factors affect the effectiveness of decision aids? Are decision aids more or less useful in particular situations (i.e., do decision aids facilitate communication for less interactive clinicians)? Or, visa versa, do decision aids impede communication in a more interactive clinician-patient relationship? Are there particular groups of patients who benefit from decision aids? Who are they (e.g., patients having difficulty making a decision)? Can they be identified a priori?
- Are decision aids useful for members of special populations (e.g., the elderly, ethnic groups, or people with low levels of education)? Should decision aids be modified for these populations, and how should this be done?
- In addition to focusing on these areas, our future research efforts should consider:
- Multicenter collaboration to formally set a research agenda. From our review, there appeared to be poor integration of different research efforts in the field. National or international collaboration would permit development of consensus about important basic concepts regarding decisionmaking, what a decision aid is, and important outcomes.
- Development of an accepted conceptual framework for decisionmaking, standardized definitions of a decision aid, and a core set of outcomes. These would have important benefits for patients, clinicians, and policymakers. Outcomes should be important to all parties and could include knowledge, patient and clinician satisfaction or comfort with decisionmaking, patient and clinician involvement in decisionmaking, resources utilized both for the decisionmaking and the decision, and the treatment chosen.
- With respect to evaluation, larger studies with more rigorous design, more comprehensive reports, and longer-term followup are needed to clearly establish the effectiveness and adverse effects (if any) of decision aids, especially for cancer-related treatment decisions. Ideal studies would include evaluation of decision aids developed based on sound principles compared to usual practice with random allocation of intervention. Cluster randomization may be necessary to avoid contamination. Appropriate outcomes should be assessed using sensitive instruments soon after administration of the intervention and with long followup to determine any latent effects. Studies should be powered large enough to detect important differences and to look at factors predictive of effect. Multicentered collaboration is likely to facilitate this process and may have additional benefits in terms of increasing opportunities for dissemination of research results.
- Institution of collaborative efforts, such as workshops; development of practice guidelines by policymakers, clinicians, and patients; and other methods to improve dissemination and implementation of decision aids.
- Increased involvement of consumer groups in helping to set the agenda, advocate for funding, facilitate the development of research studies, and disseminate research results.
- Procurement of funding from government and industry to support research.

In summary, the study of cancer-related decision aids will respond to the needs of clinicians and patients to improve communication and involve patients more in decisions about their care. This is a vital area of research that has important implications for the well being of patients and their families, and also for society as a whole in terms of appropriate utilization of medical therapies. This is a new and growing area of research. Some work has been done, as reported in this review, and some is ongoing. Much more is needed.