# A Review of the Questions Posed and Conclusions

Decision aids have been developed to improve communication between patients and health professionals, to help patients become involved in the decisionmaking process, and to incorporate their values in health care decisions. The area of cancer-related decisions has been found to be particularly problematic with respect to health professional/patient communication and decisionmaking for a number of reasons, including difficulties in sharing information about poor prognoses, the understandable anxiety connected with a life-threatening illness, and the modest benefits and severity of side effects associated with available treatments.

Recent reviews have suggested that decision aids may be effective in supporting general health care decisions. The objective of this systematic review was to determine the impact of decision aids for cancer prevention, screening, and treatment decisions. We identified specific criteria for study eligibility and performed an extensive search of the literature. We purposely used a broad definition of decision aids to be inclusive. While we identified 61 studies of cancer-related decision aids, our review was generally disappointing. The majority of the studies were case series. Only a minority (23) were comparative studies with a concurrent control group, including 18 RCTs. The state of research in this area is perhaps understandable given its relative newness, our still poor understanding of how patients and clinicians make decisions, the labor-intensive process of developing decision aids, and the difficulties (logistical, methodological, and ethical) in conducting research in this area. Even for the studies identified, interpretation was limited by a lack of adequate reporting, small sample sizes, and significant risk of bias and confounding. Interpretation was also hampered by the lack of any uniform widely accepted conceptual framework for decisionmaking between clinicians and patients. As a result, a number of different outcomes were evaluated inconsistently between studies.

In this summary section, we provide the best evidence available to support the questions posed. For the most part, information from the effectiveness randomized trials (n = 16) was used (Chapter Five). Where relevant, data from studies of other designs are included.

## Types of Decision Aids

- What conceptual framework for decisionmaking (e.g., informed, shared) underpin decision aids that have been used?
- What has been the mode of delivery (e.g., print, interactive video)?

Sixty-one studies reported the development (22) or evaluation of a DA (39). We identified a number of different conceptual frameworks or models for the type of interaction and process of decisionmaking. Of the 61 studies, 22 referred to "shared" decisionmaking, 5 to an "informed" model, and 1 to an "empowerment" model, although there was often insufficient description of any of these processes. Over half the studies reviewed did not report any conceptual framework or model. The type of interaction described in some instances did not seem congruent with the model of interaction reported. This was felt to relate to a number of factors, including poor reporting and disagreement in definition. The lack of a widely accepted uniform conceptual framework for clinician-patient decisionmaking is seen as a potential barrier to progress in our understanding of how decision aids work and what are the important outcomes to measure. An extensive range of decision aids have been developed and evaluated for cancer patients. We identified over 10 different types of decision aids, including brochures, audiotapes, videotapes, interactive computer programs, educational scripts or sessions, decision boards, time tradeoff visual aids, counseling, and informal decision analysis. A number of studies reported using a combination of different instruments (e.g., workbook and audiotape or educational sessions and counseling).

- What clinical contexts (e.g., prevention, screening, and treatment) have been investigated?
- What has been the clinical focus of the decision aids (e.g., type of cancer and extent of disease)?

Of the 22 studies describing the development of a decision aid, there were 3 studies of prevention or screening and 19 of treatment. There were 14 studies involving breast cancer patients; 2 each of prostate, ovarian, and lung cancer; and 1 study each of colon cancer and leukemia.

Of the 39 studies evaluating a decision aid, the topics included all areas along the cancer care continuum. Instruments were evaluated for choices regarding genetic testing (2 studies), prevention versus increased surveillance (2 studies), screening (8 studies), and treatment (27 studies). The most common areas were primary surgical treatment and adjuvant therapy. Few instruments were developed for the treatment of metastatic disease. Instruments were applied to a limited number of disease sites. The most common were breast (23 studies) and prostate (11 studies).

## Effectiveness of Decision Aids

- What is the effectiveness of decision aids?
- What is the effectiveness of decision aids in different clinical contexts?
- What is the effectiveness of different modes of delivery?

Despite the many different instruments developed, few studies have been reported that critically evaluated the effectiveness of these instruments. Despite potential logistical difficulties, randomized studies remain the best study design with the least chance of bias to evaluate effectiveness. Sixteen randomized trials assessing effectiveness were identified. In total, there were 22 comparisons (three of the trials had three arms). Unfortunately, the quality of the randomized trials was poor, primarily because of incomplete reporting and small patient numbers.

An interesting contrast was seen. The minority of decision aids developed for prevention/screening decisions were represented more frequently in randomized studies, while the majority of decision aids developed for treatment decisions were rarely evaluated in randomized studies. This probably reflects the early stage of development of this field and the difficulty in performing these types of studies for cancer patients at the treatment decision point.

We identified a total of nine randomized studies (13 comparisons) of decision aids for prevention/screening, and seven randomized studies (nine comparisons) of decision aids for treatment (see Table 33). Six studies evaluated decision aids for the prevention (two) or treatment (four) of breast cancer only. Five studies evaluated decision aids for the screening (four) or treatment (one) of prostate cancer only. Two studies evaluated decision aids for the screening of colon cancer, and two studies evaluated decision aids in patients with various cancer types making treatment decisions.

Table 33. Results of RCTs

Decision | | Comparison | Patient Number | Treatment Chosen | Anxiety | Knowledge | Role in DM ^a^ | Satisfaction | Other
Decision Aids vs. Usual Care (UC) (Screening/Prevention)
Schapira, 2000 | Prostate Screening | DA brochure vs. UC | 257 | ND ^b^ | -- | ↑ | -- | -- | --
Wolf, 1996 | Prostate Screening | Education script vs. UC | 205 | ↓ | --↓ | -- | -- | -- | --
Volk, 1999 | Prostate Screening | Videotape vs. UC | 160 | ↓ | -- | ↑ | -- | -- | --
Davison, 1999 | Prostate Screening | Counseling vs. UC | 100 | ND | ND | -- | ↑ | -- | ↓ Decisional conflict
Wolf, 2000 | Colorectal Screening | Education Script (relative risk reduction) vs. UC | 169 | ND | -- | ↑ | -- | -- | --
Wolf, 2000 | Colorectal Screening | Education Script (absolute risk reduction) vs. UC | 166 | ND | -- | ↑ | -- | -- | --
Pignone 2000 | Colorectal Screening | Videotape + DA brochure vs. UC | 249 | ↑ | -- | -- | -- | -- | --
Watson, 1998 | Breast Cancer Prevention | Audiotape vs. UC | 115 | ND | ND | ND | -- | -- | --
Lerman, 1997 | BRCA1 testing | Education session vs. Wait List Control | 278 | ND | -- | ↑ | -- | -- | --
Lerman, 1997 | BRCA1 testing | Educational session + counseling vs. Wait List Control | 286 | ND | -- | ↑ | -- | -- | --
Decision Aids vs. UC (Treatment)
North, 1992 | Not stated | Audiotape vs. UC | 34 | -- | ↓ | ↑ | -- | -- | --
Hack, 1999 | Not stated | Audiotape vs. UC | 24 | -- | NE ^c^ | NRD ^d^ | -- | NE | --
Hack, 1999 | Not stated | Audiotape by choice vs. UC | 24 | -- | NE ^c^ | NRD ^d^ | -- | NE | --
Maslin, 1998 | Breast cancer (surgery and adjuvant therapy) | Computer program vs. UC | 100 | NE | NE | NRD | -- | -- | Depression NE
Davison 1997 | Prostate cancer (primary treatment; options not reported) | Counseling + audio tape+ info pamphlet vs. UC + info pamphlet | 60 | -- | ND | -- | ↑ | -- | Depression ND
Decision Aids vs. Decision Aids
Lerman, 1997 | BRCA1 testing | Educational session + counseling vs. Educational session | 236 | ND | -- | ↑ | -- | -- | --
Street, 1995 | Breast Cancer Surgery | Computer program vs. DA brochure | 60 | ND | -- | ND | -- | -- | Optimism ND
Goel, 2000 | Breast Cancer Surgery | Audiotape workbook + values clarification vs. DA brochure | 136 | ND | ND | ND | -- | -- | Decisional Conflict ND
Wolf, 2000 | Colorectal Screening | Educational Script (relative) vs. Educational Script (absolute) | 166 | ND | -- | ND | -- | -- | --
Irwin,1999 | Breast Cancer adjuvant treatment | Decision board vs. Decision board | 46 | ND | -- | -- | -- | -- | --
Miron 2000) | Genetic Testing for women with breast or ovarian cancer | DA brochure (individualized) + vs. DA brochure + genetic counseling | 420 (at baseline)
Hack, 1999 | Not stated (treatment) | Audiotape vs. Audiotape by choice | 24 | -- | -- | NE ^e^ | -- | -- | --

a Decisionmaking

b ND= No difference

c NE= Not extractable

d NRD= No raw data

e The authors reported that "patients who received the audiotape by choice recalled more thorough consultation...," however data were provided by type of cancer group rather than intervention group.

↓↑Decrease/increase

To answer the question of effectiveness, we first examined the 12 RCTs (15 comparisons) that compared a decision aid plus usual care versus usual care. Of the 15 comparisons identified, 10 were in prevention/screening and 5 were in treatment.

Studies in prevention/screening were generally larger studies (n = 100 to 286 patients). These included four studies evaluating decision aids for prostate screening methods, two studies of colon cancer screening methods, one study of preventive practices for women at high risk of breast cancer, and one study looking at a woman's wish to have BRCA1 testing. A variety of decision aids were evaluated, including a decision aid brochure, educational scripts, audiotapes, videotapes, counseling, educational session ± counseling. The treatment chosen was reported in all 10 comparisons. Three comparisons indicated that patients who used the decision aid were less likely to opt for screening practice (two for PSA screening and one for colon cancer screening). Knowledge was increased with the use of the decision aid in six of seven comparisons. Patient role in decisionmaking was reported in only one study. In this trial, patients who used the decision aid assumed a more active role. Anxiety was evaluated in only two studies; no increase in anxiety was demonstrated in these studies. Patient satisfaction was not reported in any of these studies. One study reported a decrease in decisional conflict.

The four RCTs of treatment (five comparisons) were significantly smaller (n = 34 to 100 patients) and were at significant risk of being underpowered. Two of these studies (three comparisons) appeared to be pilot studies only. Studies of decision aids for cancer treatments also were problematic in that they were most often poorly reported with no outcomes extractable for the relevant comparison. One study investigated local treatment options for prostate cancer (the options were not clearly stated), and one study looked at treatment options for breast cancer surgery and adjuvant chemotherapy (treatment options were not clearly stated). Two other studies for cancer treatment did not describe the treatment options. The patients' treatment decision was not reported in three studies, and data could not be extracted in one study. Knowledge, reported in only one study, was increased. One study reported that patients' role in decisionmaking was increased, but groups were poorly balanced at baseline and this was not corrected for in the analysis. Patient satisfaction with decisionmaking was measured in one study, but data could not be extracted. Patient anxiety was measured in all four studies and, in one study, anxiety was decreased with the use of an audiotape (Table 33).

These results support that decision aids are effective for cancer-related screening decisions, particularly for PSA screening, colorectal screening techniques, and BRCA testing. In all studies, decision aids improved knowledge about screening and, in a number of instances, affected the intention to be screened. Data regarding decision aids for cancer-related treatment decisions are very limited, and no definitive conclusions can be made.

- What is the effectiveness of different modes of delivery?

The best way to compare different instruments is through a direct randomized comparison. However, in this review, it is difficult to compare different instruments in view of the limited number of studies. Eight studies involved a randomized comparison of different types of decision aids. In a number of the studies, there was a trend for knowledge to be improved with the more intensive decision aid, but in only one study did this reach statistical significance. Again, the majority of these studies may have been underpowered. No difference in treatment decisions were noted, but interesting trends were observed.^64^

A second less satisfactory way to compare different instruments is to compare their relative effectiveness in different studies. Again, in view of the limited number of studies and poor reporting, it was difficult to make even indirect comparisons. Our results demonstrate that a number of different instruments have been used and shown to be effective at least in terms of increased knowledge, including decision aid brochures, audiotapes, videotapes, and educational sessions ± counseling. None appear to be more effective than another.

## Populations Using Decision Aids

- On what populations has research been conducted?

We reviewed all 39 of the effectiveness studies. In seven studies, the eligibility criteria limited the sample to a certain age range. Five studies of prostate cancer screening and one of colorectal screening restricted their samples to middle or older age people (lower age limit varied from 45 to 50 years; upper limit from 70 years to no limit). One study investigated breast cancer treatment decisionmaking in women age 70 years or older. Only four studies reported information regarding income level. None of the studies targeted a particular SES class. However, in the prostate cancer screening study by Wolf and colleagues,^54^ more than 50 percent of the participants had annual incomes below $15,000 (U.S.). Of the 39 studies, 19 provided information about participants' level of education. The majority of participants in each of these 19 studies had at least a high school education, except for three studies. No study targeted a DA intervention for a specific education level. Ethnicity of participants was reported in eight studies. In all of these studies, the majority of participants were Caucasian, except for one study. This study was conducted in Hawaii, and approximately 50 percent of the participants were from an Asian ethnic group (Japanese, Chinese, Filipino, or Korean).

- Are decision aids used by members of special populations (e.g., the elderly or minorities)?
- What is the effectiveness of decision aids on special populations?

Of the 22 developmental studies, two specifically studied a DA for special populations. McTavish and colleagues^39^ assessed an interactive computer program, the CHESS, in eight African-American breast cancer patients from impoverished neighborhoods. As well, Lawrence and colleagues^35^ developed a DB to encourage the use of breast cancer screening among European-American and Mexican-American women in the United States. This was not a randomized trial, but the instrument appeared to be well accepted by the minority groups.

Few randomized studies have been performed in members of special populations. One study by Wolf and colleagues^54^ evaluated a DA for men at risk of prostate cancer by looking at options for prostate cancer screening. The investigators demonstrated that the instrument was effective for both younger and older men. Another study by the same author for the elderly deciding on colorectal cancer screening reported improvements in knowledge but no effect on the treatment chosen.

The evaluation of a number of decision aids also included patients with less than a high school education. However, we were unable to identify a decision aid targeted to patients with less than a high school education or that specifically reported results in this group of patients.

## Decision Aids and Outcomes

- What outcomes have been evaluated?

Variability was observed both in the outcomes measured and the results observed. Different outcomes were reported in different studies, reflecting the different decisionmaking frameworks or lack of identified frameworks on which the decision aids were developed. For the effectiveness of randomized studies, the most common outcomes evaluated were knowledge and the treatment chosen (16 of 22 comparisons). Patients' role in decisionmaking was reported in only 2 out of 22 comparisons, and satisfaction with decisionmaking was reported only once. Patient anxiety was reported in 8 out of 22 comparison studies. Other outcomes such as decisional conflict (two comparisons) and depression (two comparisons) were reported.

- Are there characteristics of decision aids related to key outcomes?

Characteristics and context of the decision aids varied substantially (in terms of type, qualitative versus quantitative, and amount of information presented). It is difficult to attribute impact on treatment chosen to any key characteristic. Few properly reported trials are available for decision aids related to cancer treatment decisions. Again, the framework for decisionmaking was so poorly described, it was impossible to make any comment on the impact this might have on effectiveness. Further work is necessary to determine the characteristics of decision aids related to different outcomes.

## Conclusions

In essence, our review is limited by the newness of this field and early development with respect to cancer-related decision aids. We did identify increasing data supporting that decision aids are useful and effective for prevention or screening situations. Unfortunately, we found little data to support their effectiveness in the treatment situation.

Research in this area appears to be hampered by the lack of a widely accepted or used conceptual framework for clinician-patient decisionmaking. This is understandable given our rather "black box" understanding of clinician-patient interaction and processes in decisionmaking. As a result, it is difficult to identify quality decisionmaking and, following from this, the important outcomes to determine whether a decision aid is actually helping the process. A related problem is the lack of uniform, reliable, valid, and sensitive measures of outcome to evaluate decision aids. Investigators often use instruments that have not been psychometrically evaluated. Much more work is needed in this area to identify the important outcomes, to get agreement amongst investigators to develop psychometrically appropriate instruments, and to use them consistently.

Many investigators evaluated knowledge in recognition of the previous problems identified with communication between clinicians and patients and the primary importance of information in decisionmaking. In addition, most investigators evaluated the treatment chosen. However, other outcomes regarding the processes of decisionmaking, such as patient involvement in decisionmaking or satisfaction with the process, were inconsistently assessed.

The vagueness of understanding of decisionmaking also appears to have resulted in quite a number of different decision aids. These interventions vary not only in their mode of delivery (e.g., print or videotape), but also in their application. Some interventions may be used by the patient alone, before or after meeting with the clinician; by the clinician-patient dyad; by the clinician-patient-and-significant-other triad; and for single use only or for repeated use.

We attempted to categorize studies according to type of interaction (paternalistic, shared, or informed). This was unsuccessful, owing to a limited description of this feature in the studies evaluated; again underlining the lack of attention to conceptual models for decisionmaking.

More studies that investigate the actual interaction between cancer patients and clinicians when decisions are being made and determine from both parties important attributes of quality decisionmaking will help to better elucidate how treatment decisionmaking occurs, how we can help it, and the important outcomes to judge effectiveness.

Also noticeably missing from the literature was taking the development of a decision aid to its formal evaluation. Many different aids were developed, but few were evaluated in well-designed studies. Again, this may relate to the newness of the field. Formal evaluation of decision aids should not be underestimated. Concern has been raised about the slow adoption of available instruments into practice. Lack of knowledge about instruments and concerns about effectiveness and required resources are likely to remain barriers to the use of decision aids in practice. Instruments with proven efficacy that require limited resources are certainly more likely to be accepted into clinical practice.

Another important limitation of studies reviewed was the lack of clear reporting, including a description of the decisionmaking situation studied, the aid itself, allocation of the intervention, baseline characteristics of study groups, description of outcomes measured, and breakdown of outcomes by treatment group. Such reporting severely limits interpretation of study results and suggests that more rigor needs to be applied to the design and reporting of studies.

Our results support that decision aids are helpful for a number of cancer screening decisions. In these situations, instruments can increase knowledge, do not increase a person's anxiety, and can influence a person's decision. In contrast, there is very little data available evaluating decision aids for cancer-treatment-related decisions. Unfortunately, further evidence is still needed before making specific conclusions regarding decision aids in this situation.

### Comparison With Other Reviews

In the last several years, five systematic reviews^14,15,17-19^ and one summary of decision aids, including one limited to cancer, have been performed.^20^ To date, three of the five systematic reviews have been published in peer-reviewed journals. O'Connor and colleagues^14^ comprehensively reviewed published and unpublished randomized trials of patient decision aids in various health conditions. Seventeen studies were identified. The review included six studies (five trials and one nonrandomized study) that were included in our review, including four studies in prevention/screening and two studies involving cancer treatment decisions. A meta-analysis was performed for some of the outcomes evaluated. Patient knowledge was reported in 8 out of 17 (47 percent) studies. Knowledge was statistically improved in four studies, and the meta-analysis supported that it was improved overall. Fourteen studies assessed the effect of decision aids on decisions made by the participants. Decisions were affected in only 3 out of the 14 studies. In a meta-analysis, a trend was observed that decision aids increased the likelihood for patients facing major surgery to prefer the less intensive option. Three studies reported that decision aids increased the proportion of patients assuming a more active role in decisionmaking. Four studies showed that decision aids did not affect patient anxiety, and the impact on patient satisfaction was variable. Our results complement the findings of this study and are consistent.

O'Connor and colleagues^15^ also published the results of a systematic review of decision aids that included both before/after studies and RCTs. While the focus of the review was cancer-related, the inclusion criteria did not limit to cancer-related decision aids due to the small number of studies assessing the efficacy of DA interventions. In total, 39 studies of DA interventions were identified, 19 of which were cancer-related. The results reported by O'Connor and colleagues are consistent with the findings of our review.

Molenaar and colleagues^19^ conducted a comprehensive review of decision aids that included all study designs (controlled and noncontrolled). The review included 30 studies, 18 of which were cancer-related (seven RCTs, two nonrandomized controlled trials, and nine one-group-only studies). Decision aids were found to be feasible, acceptable, and to increase patient knowledge of available options. Modest beneficial effects of DAs on decision uncertainty and satisfaction were reported. These results are consistent with the findings of our systematic review.

Our systematic review of cancer-related decision aids included 61 studies (22 development and 39 effectiveness). Of the 39 studies assessing the effectiveness of cancer-related DA interventions, there were 16 RCTs, 4 nonrandomized controlled trials, 2 nonconcurrent cohort studies, and 17 one-group-only studies.

### Limitations of the Task Order Report

Qualifications of our study should be noted. Abstracts and unpublished studies were not included in this review in view of the need to critically appraise each study. While such limitations may potentially result in some selection bias, this was not perceived to be a problem in view of the early development in this area and because a number of negative studies have been published.

In addition, the findings and conclusions of this Task Order are based on information that was available in the published reports and studies included. Additional information obtained directly from the authors could have overcome some of the reporting limitations described above. The contact with authors also could have led to a reduction in any likelihood of publication by bias through the identification of unpublished studies. The budget and timeline available, however, were insufficient to permit us to communicate with authors. The interpretability of the data included in most of the tables of the evidence report is limited because a number of different outcome measures were used, often with limited descriptions.

## Final Remarks

The strengths of our systematic review are that it was extensive and involved a critical appraisal of each included study. The review is limited to cancer-related health decisions because of the many reported problems and concerns with information exchange and decisionmaking in this stressful situation. Our results are consistent with systematic reviews performed in other health conditions; that is, at least for cancer screening decisions, these instruments can improve knowledge, do not increase anxiety, and may on occasion impact the final decision. Perhaps, like all good research, our review raises more questions than answers. Most of the initial questions we posed were not fully answered by the available literature, and further research is needed in this important area. It is hoped that this review will serve as an important background for researchers, health care providers, and consumers interested in resolving these questions and determining the appropriate role of decision aids in cancer control (see Chapter 7: Directions for Future Research).